# Abbreviations and Acronyms

ADL: Activities of daily living
AHRQ: Agency for Healthcare Research and Quality
AMI: Acute myocardial infarction
ART: Assisted reproductive therapy
CABG: Coronary artery bypass graft surgery
CAHPS: Consumer Assessment of Healthcare Providers and Systems
CDC: Centers for Disease Control
CHF: Congestive heart failure
CHOP: California’s Hospital Outcomes Project
CHQC: Cleveland Health Quality Choice
CMS: Centers for Medicare and Medicaid Services
CQG series: Closing the Quality Gap: Revisiting the State of the Science series
CSRS: Cardiac Surgery Reporting System
ED: Emergency department
EPC: Evidence-based Practice Center
HAI: Healthcare acquired infection
HAI: Hospital acquired infections
HCFA: Health Care Financing Administration
HEDIS: Healthcare Effectiveness Data and Information Set
HER: Hospital Effectiveness Report
HMO: Health Maintenance Organization
HQA: Hospital Quality Alliance
LTC: Long-term care
MCO: Managed care organization
NH: Nursing home
NHS: National Health Service
PCI: Percutaneous coronary intervention
PPO: Preferred provider organization
PTCA: Percutaneous transluminal coronary angioplasty
QI: Quality improvement
RAMR: Risk adjusted mortality rates
SFF: Special focus facility
TEP: Technical Expert Panel
TOO: Task Order Officer
VBAC: Vaginal birth after cesarean