# Results

## Introduction

This chapter presents the results of the literature searches, followed by results for each Key Question (KQ). KQ 1 presents evidence on medication adherence and other outcomes for patient, provider, and systems interventions. KQ 2 presents similar evidence for policy interventions. No overlap exists between these two bodies of evidence. KQ 3 (on intervention characteristics [KQ 3a] and direct comparisons of intervention components [KQ 3b]), KQ 4 (on vulnerable populations), and KQ 5 (on adverse effects) are cross-cutting questions that draw upon available evidence from KQ 1 and KQ 2.

## Results of Literature Searches

Figure 2 presents our literature search results. Literature searches through December 8, 2011, for the current report identified 3,855 unduplicated citations. Handsearches of systematic reviews and other sources added 124 citations. All these sources produced a total of 3,979 references. Appendix A provides a list of all search terms used and the results of each literature search.

Figure 2 Disposition of articles (PRISMA figure)

Abbreviations: NA = not applicable; PICOTS = population, intervention, comparator, outcomes, timing, setting and study duration; PRISMA = Preferred Reporting Items for Systematic Reviews and Meta-Analyses; SR = systematic reviews; US = United States.

Figure 2 is titled “Disposition of articles.” The figure is a flow chart that summarizes the search and selection of articles for the report. There were 3,855 records identified after database searching and removing duplicate citations. In addition, 124 records were identified through other sources. After removal of all duplicate citations, the titles and abstracts of 3,979 references were screened for possible inclusion. Of these, we selected 729 for full-text review to determine their eligibility. After applying our eligibility and exclusion criteria, we excluded 661 of these articles from further review: 125 applied to non-US populations; 74 used an ineligible study design or publication type; 29 used a sample size smaller than 40; 384 failed to meet at least one PICOTS element; 24 were deemed to have a high risk of bias; and 25 were ineligible systematic reviews, which were set aside for hand searching. Sixty-eight articles representing 62 studies are included in this report’s qualitative synthesis.

After applying our eligibility and exclusion criteria to titles and abstracts of all identified citations, we obtained full-text copies of 729 published articles. We reapplied our inclusion criteria and excluded 637 of these articles from further review before risk of bias assessment; an additional 24 were rated as having high risk of bias. Appendix C provides a list of excluded studies and reasons for exclusion at the full-text stage.

Of the 92 articles included after full-text review, we dropped 24 articles from further analysis because of their high risk of bias. Thus, we included a total of 68 articles for qualitative synthesis. Evidence tables for these 68 articles are in Appendix D; risk of bias assessments for all 92 articles included after full-text review can be found in Appendix E.

The 68 articles included in this review represent 62 studies. Of the 68 included articles, 64 were randomized controlled trials (RCTs), and 4 were observational studies. Among the trials, 51 used a parallel randomization scheme, 12 used cluster randomization, and 1 used stratified randomization. Among the observational studies, 2 used a before–after design, 1 used an interrupted time series design with a concurrent control group, and 1 used a retrospective quasi-experimental design. We assessed 57 included articles as medium risk of bias and 11 as low risk of bias.

## Key Question 1 Patient, Provider, and Systems Interventions

### Descriptions of Included Studies

We found 57 studies (reported in 63 articles) that addressed patient, provider, systems, or combinations of these targets for medication adherence and other outcomes. As noted earlier, this KQ is organized by the clinical condition for which we found evidence: diabetes; hyperlipidemia; cardiovascular conditions, specifically hypertension, heart failure, and myocardial infarction; reactive airway disease, specifically asthma and chronic obstructive pulmonary disease (COPD); depression; glaucoma; multiple sclerosis; musculoskeletal disorders; and multiple or unknown chronic conditions. KQ 1 presents an integrated discussion of medication adherence (KQ 1a) and other outcomes (KQ 1b) for greater ease of interpreting the effect of each intervention within a clinical area.

We elected to use descriptors of interventions based on common features and terminology specific to each clinical condition rather than impose any external taxonomy. The primary organizational principle for this KQ is clinical condition: using terminology specific to each clinical condition maintains and supports this organizational structure. We list the clinical conditions and interventions clusters in Table 4. These intervention descriptors generally reflect the target of the intervention and/or the agent of the intervention.

Table 4 Number of included studies by clinical condition, intervention, comparator, and outcome

Clinical Condition | Intervention | Comparator | Number of Studies
Diabetes | Case management/collaborative care | Usual care | 3 Bogner et al., 2010^87^ Grant et al., 2003^88^ Lin et al., 2006^89^
Diabetes | Health coaching | Usual care | 1 Wolever et al., 2010^90^
Diabetes | Education with social support | Education without social support | 1 Pearce et al., 2005^91^
Hyperlipidemia | Collaborative care | Usual care | 1 Lin et al., 2006^89^
Hyperlipidemia | Decision aids | Educational materials, no decision aid | 2 Mann et al., 2010^92^ Weymiller et al., 2007^93^ Jones et al., 2009^94^
Hyperlipidemia | Education and behavioral support (phone or mail) | Usual care or less intense intervention | 5 Guthrie et al., 2001^95^ Johnson et al., 2006^96^ Powell et al., 1995^97^ Schectman et al., 1994^98^ Stacy et al., 2009^99^
Hyperlipidemia | Multicomponent (education face-to-face with pharmacist + blister packaging) | Discontinuation of intervention | 1 Lee et al., 2006^78^
Hypertension | Blister packaging | Usual care | 1 Schneider et al., 2008^100^
Hypertension | Case management | Usual care | 3 Bogner et al., 2007^101^ Rudd et al., 2004^102^ Wakefield et al., 2011^103^
Hypertension | Collaborative care | Usual care | 3 Carter et al., 2009^104^ Hunt et al., 2008^105^ Lin et al., 2006^89^
Hypertension | Education and behavioral support (telephone, mail, and/or video) | Usual care | 5 Bosworth et al., 2008^106,107^ Bosworth et al., 2005^108^ Friedman et al., 1996^109^ Johnson et al., 2006^110^ Powell et al., 1995^97^
Hypertension | Education (face-to-face with pharmacist) | Discontinuation of or less intense intervention | 3 Lee et al., 2006^78^ Solomon et al., 1998^111,112^ Vivian et al., 2002^113^
Hypertension | Education with social support | Education without social support | 1 Pearce et al., 2005^91^
Hypertension | Risk communication | Educational materials | 1 Powers et al., 2011^114^
Heart failure | Reminder video and telephone calls | No reminder calls | 1 Fulmer et al., 1999^115^
Heart failure | Multicomponent pharmacist-led | Usual care | 1 Murray et al., 2007^116^
Heart failure | Case management | Usual care | 1 Rich et al., 1996^117^
Heart failure | Access to medical records | Usual care (no access) | 1 Ross et al., 2004^118^
Myocardial infarction | Education and behavioral support | Usual care | 1 Smith et al., 2008^119^
Reactive airway disease: Asthma | Self-management | Usual care | 5 Bender et al., 2010^120^ Berg et al., 1997^121^ Janson et al., 2003^122^ Janson et al., 2009^123^ Schaffer et al., 2004^124^
Reactive airway disease: Asthma or COPD | Pharmacist or physician access to patient adherence information | Pharmacist training or usual care | 2 Weinberger et al., 2002^125^ Williams et al., 2010^126^
Reactive airway disease: Asthma | Shared or clinical decisionmaking | Clinical decisionmaking or usual care | 1 Wilson et al., 2010^127^
Depression | Medication telemonitoring or telephone care | Usual care | 2 Rickles et al., 2005^128^ Simon et al., 2006^129^
Depression | Case management | Usual care | 3 Bogner et al., 2007^101^ Bogner et al., 2010^87^ Katon et al., 2001;^130^ Ludman et al., 2003;^131^ Von Korff et al. 2003^132^
Depression | Collaborative care | Usual care | 5 Capoccia et al., 2004^133^ Katon et al., 1995^134^ Katon et al., 1996^135^ Katon et al., 1999;^136^ Katon et al., 2002^137^ Pyne et al., 2011^138^
Depression | Reminders to nonadherent patients and lists of nonadherent patients to providers | Usual care | 1 Hoffman et al., 2003^139^
Glaucoma | Multicomponent intervention (educational video, discussion of barriers, reminder calls and dosing aid) | Usual care | 1 Okeke et al. 2009^140^
Multiple sclerosis | Counseling (software-based telephone) | Less intense intervention | 1 Berger et al., 2005^141^
Musculoskeletal diseases | Case management | Less intense intervention | 1 Rudd et al. 2009^142^
Musculoskeletal diseases | Virtual osteoporosis clinic | Usual care | 1 Waalen et al., 2009^143^
Musculoskeletal diseases | Decision aid | Usual care | 1 Montori et al., 2011^144^
Multiple or unspecified chronic conditions | Outreach, education, and problem-solving (pharmacist-led) | Usual care | 3 Nietert et al., 2009^145^ Schnipper et al., 2006^146^ Taylor et al., 2003^147^
Multiple or unspecified chronic conditions | Case management intervention | Usual care | 1 Sledge et al., 2006^148^

The remainder of this section describes the characteristics of studies, notes key points, and gives a detailed synthesis for each clinical condition in the order listed in Table 4. We support the analysis for each clinical condition with a summary table under key points showing overall findings. The detailed synthesis subsection for each clinical condition includes one table describing the characteristics of the trial and medication adherence outcomes for the clinical condition and separate strength-of-evidence tables for each intervention type. Entries in summary tables are presented by intervention type first, and then by the last name of the first author of the trial.

For each subsection on characteristics of the trial, we present an overview, followed by details on population, intervention, comparator, outcome and timing, and setting (i.e., PICOTS) and applicability. The key points distinguish “insufficient” grades for (a) bodies of evidence in which some research exists on the outcomes but is insufficient to make a call on the strength and (b) bodies of evidence in which no research exists.

As noted in the Introduction and Methods chapters, we synthesize evidence on other outcomes only for studies that had demonstrated a statistically significant difference in medication adherence outcomes or, occasionally, in outcomes related to either initiation or persistence of medication. As a result, strength-of-evidence grades of insufficient or low for any other outcomes reflect the paucity of the evidence on such outcomes, based on the subset of studies that demonstrate improvement in medication adherence. Strength-of-evidence grades for any other outcomes cannot be interpreted as evidence of effectiveness of intervention strategies that may alter health outcomes through mechanisms other than medication adherence. Appendix G includes summary tables for each health or other outcome.

### Key Question 1 Diabetes: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

We found five RCTs (five articles) that assessed the effects of five different interventions aimed at improving medication adherence among adult patients with diabetes mellitus.87–91 Four trials had a medium risk of bias88–91 and one trial87 had a low risk of bias.

##### Population

Three trials reported limiting the sample to patients with type 2 diabetes or who were on oral hypoglycemic agents.88,90,91 Two required a codiagnosis of depression87,89 and one a codiagnosis of uncontrolled hypertension.91

##### Interventions

The interventions to improve adherence differed considerably, although all were directed at patients. Three trials additionally targeted the health system,87–89 and one targeted providers.88

Two interventions used what the authors termed “integrative” approaches to disease management, each of which involved personalization of care:87,90 integrative health coaching in one and the an integrated care model delivered by a care manager in the other. The former helped individuals to integrate their values with their own health behaviors and targeted only patients,90 whereas in the latter, the care manager integrated the care the person was receiving—hence targeted both the patient and the system.87 One trial focused on cardiovascular risk reduction provided education involving a social support person.91

In a pharmacist-delivered intervention,88 pharmacists assessed patients’ adherence barriers, provided tailored verbal patient education, and communicated these to physicians and social service providers. Finally, one trial attempted to improve adherence to diabetes treatment by individualizing depression management using collaborative care,89 which required systems integration.

Taken together, these five intervention trials fell into three clusters of intervention types. One cluster involved a “case management/collaborative care” model, in the sense that, regardless of the agent delivering it, the intervention was designed to enhance health care by integrating different aspects of the care with one another. Means of integrating care included enhancing communication between different provider types (e.g., between physicians and pharmacists88 or between different subspecialists of physicians89) or using a care manager as a liaison between patient and physician.87 Authors of the case manager trial pointed out that their intervention differed from other care manager trials by focusing on the care manager’s role as a liaison between the patient and the physician87 The trials in this cluster addressed factors resulting in nonadherence and used a tailored individualized approach in which participants work with the intervention agent to develop strategies to overcome barriers to medication adherence.

In the two other trials (one cluster each), one involved a “health coaching”90 intervention and another implemented an intervention focused on education with a patient-designated “social support person.”91

##### Comparator

Most trials compared an active arm with what was termed “standard of care” or “usual care.” The content of such care was often not specified; when it was, it varied among trials. In the trial seeking to enhance diabetes adherence by improving depression management, usual care was treatment of depression by the primary care physician.89 In the trial in which intervention participants received education via a social support person, the comparator was receipt of the same educational information without the involvement of a social support person.91 Similarly, for the pharmacist-delivered intervention that was tailored to assess patient adherence barriers, those in the comparison group answered the same pharmacist-delivered barrier assessment questions but received no tailored strategies.88

##### Outcome and Timing

Adherence to diabetes medications was defined and assessed in a wide variety of ways. Two of these five trials used a nonself-reported measure. The trial that used medication event monitoring system (MEMS) defined adherence as the percentage of participants taking more than 80 percent of their prescribed doses. The trial using pharmacy refill data defined adherence as the percentage of time that prescriptions were filled on time.

Among the three trials with only self-reported adherence, two used the Morisky Adherence Scale although each defined adherence differently.90,91 One trial using a single item to ask about patients’ medication taking, with a 7-day recall period,88,90 defined adherence as the number of days that no doses were missed.88

Some trials evaluated effects on various intermediate outcomes (e.g., %HbA1C [glycosylated hemoglobin]) or ultimate health outcomes (e.g., health-related quality of life); we report on these below only when the impact on medication adherence was statistically significant.

Timing and frequency of the trials’ assessments of outcomes assessments varied widely, ranging from 6 weeks to 12 months followup and from one to four times (every 3 to 6 months) Similarly, timing of the outcome assessment relative to administration or completion of the intervention differed across the trials.

##### Setting

Three trials were conducted in primary care settings.87,89,91 One was performed in an outpatient tertiary care center clinic90 and one in an academically affiliated community health center.88

##### Applicability

The diversity of settings in which these trials were conducted contributed to the overall applicability of the results. However, no trial assessed results among subgroups of patients with poorly controlled diabetes, limiting applicability of the results to that type of patient population.

#### Key Points

##### Overview

- All five RCTs assessed intervention effects on medication adherence (e.g., percentage of participants achieving a threshold of pills taken, proportion of pills taken), albeit each used a slightly different definition of medication adherence and tested different interventions (Table 5). One of the five trials (one of three testing a case management/collaborative care model),87 demonstrated a statistically significant effect of the intervention on medication adherence and a statistically and clinically important effect on hemoglobin percent A1c.

Table 5 Diabetes: summary of the evidence

Type of intervention | Studies, N Randomized | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Collaborative care/case management | Bogner et al., 2010^87^ N=58 | + Adherence (MEMS) for taking ≥ 80% oral hypoglycemic agents over 6 weeks | + Percentage HbA1c (mean) at 6 weeks
Collaborative care/case management | Grant et al., 2003^88^ N=462 | = Number of days in last 7 no doses were missed | NA
Collaborative care/case management | Lin et al., 2006^89^ N=329 | = Percentage of days non- adherent (pharmacy refill data) | NA
Health coaching | Wolever et al., 2010^90^ | = 4-item Morisky scale score at 6 months | NA
Education with social support | Pearce et al., 2005^91^ N=199 | = Morisky, proportion with high, medium, or low adherence at 2 months | NA

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; MEMS = medication event monitoring system; N = number; NA = not applicable

##### Case Management/Collaborative Care

- Medication adherence: One approach improved medication adherence among patients with diabetes, particularly those with comorbid depression (low strength of evidence).
- Biomarkers of clinical outcomes: The intervention that improvedadherence improved percent HbA1C—a difference of 1.2 percentage points between arms (low strength of evidence).

##### Health Coaching

- Medication adherence: One trial showed no statistically significant differences in medication adherence between health coaching and usual care arms (insufficient).

##### Education With Social Support

- Medication adherence: One trial reported no significant differences between education with or without social support (insufficient).

#### Detailed Synthesis for Collaborative Care/Case Management Interventions for Diabetes

##### Medication Adherence

Of three trials testing the effects of coordinated care models on medication adherence,87–89 one, assessed as low risk of bias, found a significant effect on adherence to both oral hypoglycemic agents and antidepressants at 6 weeks followup.87 The other two trials (both medium risk of bias) found no beneficial effect at 12^89^ and 3 months,88 respectively (Table 6).

Table 6 Diabetes: detailed medication adherence outcomes

Type of Intervention | Study N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, direction) | Source | Baseline | First Followup | Additional Followups
Case management/collaborative care | Bogner et al., 2010^87^ G1: 29 G2: 29 | Adults ≥50 years with depression and diabetes Community primary care clinic | G1: Integrated care of depression and diabetes with care manager G2: Usual care | Three face-to-face + two calls over 4 weeks | Percentage of patients with ≥80% adherence to oral hypoglycemics (0 to 100%) | MEMS | n (%) G1: 10 (34.5) G2: 6 (20.7) 95% CI, NR p:0.19 | 6 weeks: G1: 18 (62.1) G2: 7 (24.1) 95% CI, NR p:0.004 | NR
Case management/collaborative care | Grant et al., 2003^88^ G1: 61 G2: 54 G3: 230 | Adults with type 2 diabetes mellitus Academically affiliated community health center | G1: Pharmacist-administered questions, physician feedback, social service referrals G2: Pharmacist-administered questionnaire only G3: Set-aside lab controls | One phone session | Number of days in the last 7 that no doses were missed | Self-report | Mean number of days±SD G1: 6.7 ± 0.9 6.9 ± 0.4 P=0.3 | 3 months Mean change in number of days±SD G1: 0.1 (1) G2: 0.1 (0.4) 95% CI, NR p=0.8 | NR
Case management/collaborative care | Lin et al., 2006^89^ G1: 164 G2: 165 | Adults with diabetes mellitus and persistent depression Nine primary care clinics Washington State | G1: Collaborative care for depression with medications or problem-solving G2: Advised to consult PCP for depression treatment | 16 phone or face-to-face visits over 12 months | Percentage of days nonadherent to oral hypoglycemic (0–100%) | Pharmacy refill data | Mean % (SD) G1: 19.8 (21.3) G2: 22.9 (24.0) 95% CI, NR p: NS | 12 months: Mean % (SD) G1: 28.2 (28.9) G2: 24.0 (24.7) | NR
Case management/collaborative care | Lin et al., 2006^89^ G1: 164 G2: 165 | Adults with diabetes mellitus and persistent depression Nine primary care clinics Washington State | G1: Collaborative care for depression with medications or problem-solving G2: Advised to consult PCP for depression treatment | 16 phone or face-to-face visits over 12 months | Adjusted mean difference in percentage of days nonadherent (baseline minus endpoint) | Pharmacy refill data | NR | 12 months: −6.3 (−11.91 to −0.71) p=0.03 | NR
Education with social support | Pearce et al., G1: 50 G2: 58 G3: 91 | Adults >21 years with type 2 diabetes mellitus and HTN 18 primary care practices Kentucky | G1: Nurse-delivered cardiovascular risk education with patient's social support person, quarterly educational newsletters G2: Same as G1 intervention G3: Same as G1 without social support person | One face-to-face session plus four quarterly news-letters | 4-item Morisky Adherence Scale | Self-report | High (%): G1: 50.0 G2: 29.8 G3: 41.8 Medium (%): G1: 42.0 G2: 63.2 G3: 49.5 Low (%): G1: 8.0 G2: 7.0 G3: 8.8 95% CI, NR p (G1 vs. G2 vs. G3): 0.1584 | 9 to 12 months Details NR, P NS | NR
Health coaching | Wolever et al., 2010^90^ G1: 27 G2: 22 | Adults with type 2 diabetes mellitus on oral hypoglycemics Outpatient clinic at tertiary care center | G1: 6 months integrative health coaching G2: Usual care | 14 phone sessions (either weekly, four biweekly; one monthly) | 4-item Morisky Adherence Scale | Self-report | (Mean, SD) G1:6.7 (0.96) G2: 6.7 (1.25) | (Mean, SD): G1:7.2 (0.97) Within group change over time p=0.004 G2: 6.9 (1.25) Within group change over time p=NS 95% CI, NR p-value for between group differences in change: NS | NR
Health coaching | Wolever et al., 2010^90^ G1: 27 G2: 22 | Adults with type 2 diabetes mellitus on oral hypoglycemics Outpatient clinic at tertiary care center | G1: 6 months integrative health coaching G2: Usual care | 14 phone sessions (either weekly, four biweekly; one monthly) | One-item dichotomous question assessing whether patients missed dose in last 7 days | Self-report | G1:51.9 G2: NR | G1: 7.4 Within group change over time: p<0.001 G2: NR Within group change over time: NS 95% CI, NR p:for between group differences NR | NR

Abbreviations: CI = confidence interval; G = group; HbA1c = hemoglobin A1C; MEMS = medication event monitoring system; N = number; NR = not reported; NS = not significant; PCP = primary care physician; OR = odds ratio; SD = standard deviation.

The first of these three trials87 assessed the effect of a case manager intervention delivered to type 2 diabetic patients with depression over 4 weeks (three 30-minute in-person and two 15-minute telephone contacts in 4 weeks) on adherence to diabetes and antidepressant medications at 6 weeks followup, using MEMS. Data from this trial showed large and statistically significant differences in adherence between intervention and control groups for both medications.

In the second such trial,89 which tested a 1-year intervention of collaborative depression treatment, adherence to diabetes, blood pressure, and lipid-lowering medications (defined as the percentage of days of nonadherence based on 12-month pharmacy refill data) was not improved among intervention compared with control participants. Similarly, the intervention using a one-time pharmacist-administered phone session that included a questionnaire assessing barriers to adherence with tailored verbal education, physician feedback, and social service referrals found no differences from baseline to 3-month followup in self-reported adherence.88

Taken together, these trials provide low strength of evidence that coordinated care interventions improve medication adherence (Table 7).

Table 7 Case management/collaborative care for diabetes: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Study Design/ Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Collaborative care/case management vs. usual care | 3; 507 (507) | Medication adherence | RCT Medium | Consistent | Direct | Precise | Varied measures and magnitude Low
Collaborative care/case management vs. usual care | 1; 58 (58) | Biomarker: HbA1c | RCT Low | Not applicable | Direct | Precise | Difference between groups: 1.2 percentage points Low

Abbreviations: HbA1C = hemoglobin A1C; RCT = randomized controlled trial.

##### Other Outcomes

HbA1C is sometimes considered a surrogate marker for adherence; however, because effects on HbA1c are considered to depend partly on adherence, we present this outcome only for the trial87 that demonstrated a significant effect on adherence. It showed a statistically significant improvement in HbA1c among intervention group members at followup compared with controls (6.7% vs. 7.9%, p=0.019). This trial provides a low level of evidence that coordinated care interventions improve percent HgbA1c (Table 7).

#### Detailed Synthesis for Health Coaching Intervention for Diabetes

##### Medication Adherence

One small trial, conducted at one site, assessed a program that included 14 telephone calls as a 6-month health coaching program. Health coaching was found to have no statistically significant effect at 12-month followup (Table 6).90 Evidence is insufficient to determine whether health coaching interventions can improve medication adherence among patients with diabetes (Table 8).

Table 8 Health coaching for diabetes: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Study Design/ Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Health coaching vs. usual care | 1; 56 (49) | Adherence | RCT Medium | Unknown | Direct | Imprecise | Difference between groups on 4-point scale: 0.3 Insufficient

Abbreviation: RCT = randomized controlled trial.

#### Detailed Synthesis for Social Support Intervention for Diabetes

##### Medication Adherence

One trial of education with social support among approximately 200 patients from 18 primary care practices in a statewide ambulatory practice-based research network showed no statistically significant difference between the social support intervention and educational controls (Table 6).91 Evidence is insufficient to determine whether including a social support person in a diabetes education effort improves medication adherence (Table 9).

Table 9 Social support for diabetes: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Study Design/ Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Patient education with social support vs. patient education without social support | 1; 199 (189) | Medication adherence | RCT Medium | Unknown | Direct | Imprecise | No significant difference between groups for Morisky scale scores at 12 months Insufficient

Abbreviation: RCT= randomized controlled trial.

### Key Question 1 Hyperlipidemia: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

Nine trials (10 articles) evaluated interventions to improve medication adherence among patients with hyperlipidemia.78,89,92–99 We rated all nine trials as medium risk of bias.

##### Population

Three trials were conducted primarily among patients with elevated cholesterol,96,98,99 one was among patients with both elevated risk of a first myocardial infarction and elevated cholesterol,95 and two were among patients with diabetes;92–94 three trials evaluated subgroups with hyperlipidemia.78,89,97 All trials were conducted in adults 21 years and older96,99 to 65 years or older.78 In the seven trials that reported mean participant ages,78,89,92–95,97,98 the range was from 54 to 55 years of age97 to 78 years.78 In the trials reporting proportion of female participants,78,89,92–97,99 women made up between 22.9 percent78 and 65 percent to 68 percent97 of the trial populations. African-American participants were between 5.8 percent96 and 32.3 percent78 of the trial populations in the three trials that reported this information.78,95,96

##### Intervention

The nine trials evaluated diverse interventions, but all targeted patients; one trial additionally targeted systems of care.98

One trial evaluated the effect of collaborative care individualized to include either antidepressant medication or problem-solving treatment to promote adherence to medications, including angiotensin converting enzyme (ACE) inhibitors in a subgroup with hypertension.89 Two trials tested a decision aid aimed at cardiovascular risk reduction choices to promote statin use.92–94

Five trials evaluated the effect of education and behavioral support on medication adherence.95–99 In one trial the intervention included face-to-face education with a physician, 2 weeks of free pravastatin, telephone calls that served primarily as reminders, and educational mailings.95 Another trial mailed an individualized, stage-matched intervention and manual for adherence to lipid-lowering medication based on the transtheoretical model for change.96 A third trial mailed one of four educational videotape programs to participants; these provided educational information on the patients’ disease/condition process, medication(s), and the importance of adherence.97 Another trial delivered an intervention through an initial face-to-face visit followed by telephone calls that addressed problems and adverse events associated with medications.98 The final trial in this group delivered tailored behavioral support interventions via an interactive voice recognition (IVR) system supplemented by mailed printed materials.99

The final intervention for hyperlipidemia was a continuation of a multicomponent pharmacy-based intervention; it included visits with a clinical pharmacist to deliver individualized medication education and blister packaging of medications.78

##### Comparator

Active arms were compared with usual care in four of the nine trials.89,96–98 Comparator arm activities varied among the intervention clusters. In the one trial of collaborative care, usual care consisted of advising participants to consult their primary care physician for treatment.89 In the two trials evaluating statin decision aids, usual care patients received control educational printed materials.92–94

Among the five education and behavioral support interventions, the control group in one trial received a free 2-week supply of medication and recommendations from physicians (also received by the intervention group) and two reminder postcards to reinforce recommendations (compared with four postcards in the intervention group) but no telephone calls (two calls were made to the intervention group).95 In two trials in this cluster, usual care consisted of not receiving mailed intervention materials.96,97 In the fourth trial of education and behavioral support, usual care consisted of receiving no phone calls following an initial clinic visit.98 In the fifth trial in this cluster, the control group received nontailored behavioral advice from a single interactive voice recognition call at baseline, coupled with a nontailored, generic, self-help cholesterol management guide received through the mail that did not address medication persistence or adherence.99

In the multicomponent trial, after a 6-month phase in which both intervention and control groups received the intervention, the intervention was discontinued for the control group, which then received medications in pill bottles with a 90-day supply.78

##### Outcome and Timing

No trials reported on initiation of medication. Three trials reported on persistence of medication use; two trials used persistence measures from pharmacy refill or claims data98,99 and the other used self-reported persistence measures at 3 months following the intervention.93,94 Of the trials using pharmacy refill data to report persistence, one trial reported persistence in two ways: (1) being in possession of a statin prescription at the end of a 180-day observation period and (2) having no gaps of more than 30 days in statin refills over 6 months;99 the other trial reported persistence as the proportion of participants refilling prescriptions for either niacin or a bile acid sequestrant (BAS) at 2 months.98

All nine trials reported medication adherence outcomes. Measures of adherence included pharmacy refill data in three trials,89,97,99 pill counts in one trial,78 and self-reported measures in five trials.92–96,98 One trial used multiple measures: pharmacy refill data to report persistence and a self-reported measure to report adherence.98 Three of four trials with nonself-reported adherence measures described proportions with 80 percent or greater adherence as determined by medication possession ratios (MPR) from pharmacy refill data in two trials97,99 and by pill count in one trial.78 Self-reported adherence measures were ascertained through adherence-related questions in three trials93–95,98 and a Morisky scale in one trial.92 In addition, one trial ascertained self-reported adherence measures from both a stage of change algorithm and medication adherence scale scores.96

Of the four trials with either improved medication adherence or persistence outcomes,78,93,94,96,99 three reported other outcomes. These additional outcomes included low-density-lipoprotein cholesterol (LDL-C) levels and changes in LDL-C levels from baseline to followup in one trial78 and patient satisfaction in the two other trials.92–94 The shortest trial lasted 3 months;93,94 the longest lasted 18 months.96 One trial reported adherence and persistence outcomes at 2 months, although the intervention was 6 months.98 Two trials reported adherence at points during and at the conclusion of the intervention.92,96 One trial reported adherence measured 3 months following the conclusion of the intervention.93,94 The other five trials either reported adherence measured at the conclusion of the intervention95 or reported average adherence or persistence measured throughout the intervention.78,89,97,99 In the trial that reported LDL-C measures, outcomes were measured at the conclusion of the intervention (14 months); changes in LDL-C levels from 2 to 14 months were reported. This trial lasted a total of 14 months with an initial 2-month run-in period followed by a 6-month cohort intervention in which both groups received the intervention followed by a final 6-month RCT in which one group continued the intervention and one group discontinued the intervention.78 Two trials that reported patient satisfaction measures obtained outcomes immediately following the intervention.92–94

##### Setting

Three trials were based in primary care clinics,89,92,95 one of which involved participants enrolled in a pharmaceutical registry through their primary care clinic.95 One trial was based in a metabolic specialty clinic.93,94 Two trials were based in either a military medical center78 or a Department of Veterans Affairs medical center (VAMC).98 Two trials were conducted among either health maintenance organization (HMO) or preferred provider organization (PPO) members.97,99 Finally, one trial recruited participants from multiple sources: random-digit dialing, a pre-existing database of potential participants from prior studies, a large Massachusetts health plan, and health screenings or health fairs.96

##### Applicability

Notable limitations to applicability included trials that were conducted only among select populations such as participants in a registry program who received a free 2-week supply of pravastatin,95 HMO or PPO members in two trials,97,99 patients cared for at a military medical center in one trial78 and patients cared for at a VAMC in one trial.98 After randomization, one trial additionally eliminated participants who expressed “no intention of picking up their prescription” for a statin within 7 days, were not aware of the prescription, or failed to answer at least 50 percent of the baseline assessment, which may have introduced selection bias.99^p.243^

#### Key Points

##### Overview

- Medication adherence: Across nine trials, we found variable evidence for medication adherence or persistence. Four of nine trials found significant improvements in outcomes of either medication adherence or persistence (Table 10).
- Other outcomes: Two of the four trials with either improved medication adherence or better persistence outcomes reported additional outcomes. One reported LDL-C, which was not different between groups; the other reported patient satisfaction outcomes for which some, but not all, outcomes were improved in the intervention group.

Table 10 Hyperlipidemia: summary of findings

Type of Intervention | Studies, N Randomized | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Collaborative care | Lin et al., 2006^89^ N=329 | = Percentage of days nonadherent to lipid-lowering medication over 12 months; = Adjusted difference in percentage of days nonadherent comparing G1 and G2 over 12 months | NA
Decision aids | Mann et al., 2010^92^ N=150 | = Percentage with high adherence on Morisky scale at 3 and 6 months | NA
Decision aids | Weymiller et al., 2007^93^ Jones et al., 2009^94^ N=98 | + Number missing no medication doses in prior week at 3 months; = Percentage using statins at 3-month followup | Patient satisfaction items; + Amount of information; = Clarity of information; + Helpfulness of information; = Would recommend to others deciding on statins; = Would prefer similar approach for other treatment choices; + Overall acceptability
Education and behavioral support (phone or mail) | Guthrie et al., 2001^95^ N=13,100 | = Currently taking pravastatin as prescribed at 6 months; = Proportion missing no doses of pravastatin in past 7 days at 6 months | NA
Education and behavioral support (phone or mail) | Johnson et al., 2006^96^ N=404 | Among pre-action sample:; + Stage of change algorithm: percentage reaching action or maintenance stage for adherence at 6 and 18 months; + Medication adherence scale score at 6, 12, and 18 months; = Adherence score on additional 5-item survey at 6 months; + Adherence score on additional 5-item survey at 12 and 18 months; Among post-action sample:; = Percentage maintaining stage for adherence on 5-item survey at 6 and 12 months; + Percentage maintaining stage for adherence on 5-item survey at 18 months | NR
Education and behavioral support (phone or mail) | Powell et al., 1995^97^ N=4246 | = Medication possession ratio over 9 months, overall and for antihypertensive medications, over 9 months; = Percentage of participants with ≥80% medication possession ratio, over 9 months, overall and for antihypertensive medications | NA
Education and behavioral support (phone or mail) | Schectman et al., 1994^98^ N=102 (Niacin) N=62 (Bile acid sequestrant) | = Number of medication doses missed in past week, at 2 months in both niacin and BAS groups; = Proportion refilling prescription at 2 months in both niacin and BAS groups | NA
Education and behavioral support (phone or mail) | Stacy et al., 2009^99^ N=578 | + Medication possession ratio; + ≥ 80% over 6 months; + In possession of statin at the end of 6 months; + Refilling statin within 30 days of the refill date over 6 months; + Both MPR ≥ 80% and refilling statin within 30 days of refill date over 6 months | NR
Multicomponent (education face-to-face with pharmacist + blister packaging) | Lee et al., 2006^78^ N=159 | + Proportion of pills taken over 6-month RCT; + Percentage of participants with ≥ 80% adherence to medications over 6-month RCT | Among patients with hyperlipidemia: Biomarkers; = LDL-C at 14 months (2-month run-in + 6-month cohort + 6-month RCT); = LDL-C difference between 2 months and 14 months (2-month run-in + 6-month cohort + 6-month RCT)

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; BAS = bile acid sequestrant; LDL-C = low density lipoprotein cholesterol; MPR = medication possession ratio; N = number; NA = not applicable; NR = not reported; RCT = randomized controlled trial.

##### Collaborative Care Interventions for Hyperlipidemia

- Medication adherence: The trial that evaluated collaborative depression care had imprecise outcomes with small sample sizes (insufficient evidence).

##### Decision Aids for Hyperlipidemia

- Medication adherence: One of two trials with improved medication adherence, overall small sample sizes and imprecise outcomes (insufficient evidence); persistence measured in one trial, no significant improvement (insufficient evidence).
- Patient satisfaction: Decision aid interventions improved patient satisfaction with some but not all aspects care (low strength of evidence of benefit).

##### Educational and Behavioral Support Interventions for Hyperlipidemia

- Medication adherence: Five trials with heterogeneous, and sometimes imprecise, outcomes reported some measures of improved medication adherence or persistence (low strength of evidence of benefit).

##### Multicomponent Intervention for Hyperlipidemia

- Medication adherence: One small trial reported improved medication adherence, but timing of measurement of the adherence outcome differed between groups (low strength of evidence of benefit).
- Biomarkers: Groups did not differ in LDL-C outcomes (insufficient evidence).

#### Detailed Synthesis for Collaborative Care for Hyperlipidemia

##### Medication Adherence

The trial of a collaborative care model resulting in individualized management of depression care did not identify a difference between groups for lipid-lowering agent adherence in subgroup analyses (Table 11).89 Given the imprecise adherence outcomes and small sample size, the evidence was insufficient to draw any conclusions (Table 12).

Table 11 Hyperlipidemia: detailed medication adherence outcomes

Type of Intervention | Trial N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, direction) | Source | Baseline | First Followup | Additional Followups
Collaborative care | Lin et al., 2006^89^ Baseline: G1: 50 G2: 52 12 mos: G1: 54 G2: 63 | Adults with diabetes mellitus and depression Primary care clinics | G1: Collaborative care for depression using either medications or problem-solving treatment G2: Advised to consult PCP for depression treatment | 16 phone or face-to-face visits over 12 months | Percentage of days nonadherent to lipid-lowering agent (0–100%) | Pharmacy refill data | Baseline Mean (SD) G1: 29.3% (26.7%) G2: 24.5% (23.0%) 95% CI, NR p: NS | 12 months: G1: 28.8% (27.1%) G2: 27.7% (24.0%) 95% CI, NR p: NS | NR
Collaborative care | Lin et al., 2006^89^ Baseline: G1: 50 G2: 52 12 mos: G1: 54 G2: 63 | Adults with diabetes mellitus and depression Primary care clinics | G1: Collaborative care for depression using either medications or problem-solving treatment G2: Advised to consult PCP for depression treatment | 16 phone or face-to-face visits over 12 months | Adjusted difference in percentage of days non-adherent to lipid-lowering agent comparing G1 and G2 | Pharmacy refill data | NA | 12 months: (%) = −0.2 95% CI: −7.23 to 6.76 p: NS | NR
Decision aids | Mann et al., 2010^92^ G1: NR G2: NR | Adult patients with diabetes mellitus Urban primary care clinic | G1: Statin choice decision aid G2: ADA print material | One face-to-face session + printed material | Percentage with “good adherence” on 8-item Morisky Adherence Scale (0–100%) | Self-report | Baseline NR | 3 months: Overall: 70% G1: NR G2: NR 95% CI, NR p: No significant difference between groups | 6 months: Overall: 80% G1: NR G2: NR 95% CI, NR p: No significant difference between groups
Decision aids | Weymiller et al., 2007^93^ Jones et al., 2009^94^ G1: 33 G2: 29 G1a: NR G1b: NR G2a: NR G2b: NR G1: 52 G2: 46 | Adults with Type 2 diabetes mellitus Metabolic specialty clinic | G1: Statin choice decision aid G1a: Research staff before visit G1b: Clinician during visit G2: Standard of care educational pamphlet control G2a: Research staff before visit G2b: Delivered by clinician during visit | One face-to-face session + printed material | Number missing no medication doses in the last week | Self-report | NR | 3 months: G1: 31 G2: 23 OR: 3.4 95% CI: 1.5 to 7.5 p: NR | NR
Decision aids | Weymiller et al., 2007^93^ Jones et al., 2009^94^ G1: 33 G2: 29 G1a: NR G1b: NR G2a: NR G2b: NR G1: 52 G2: 46 | Adults with Type 2 diabetes mellitus Metabolic specialty clinic | | One face-to-face session + printed material | Number missing no medication doses in the last week, by mode of delivery | Self-report | NR | 3 months: G1a: NR G1b: NR G2a: NR G2b: NR OR for delivery mode: 0.8 95% CI: 0.3, 2.6 p: NS | NR
Decision aids | Weymiller et al., 2007^93^ Jones et al., 2009^94^ G1: 33 G2: 29 G1a: NR G1b: NR G2a: NR G2b: NR G1: 52 G2: 46 | Adults with Type 2 diabetes mellitus Metabolic specialty clinic | | One face-to-face session + printed material | Percentage using statins at followup | Self-report | NR | 3 months: N (%) G1: 33 (63%) G2: 29 (63%) 95% CI, NR p: NR OR: 1.4 95% CI: 0.8 to 2.4 p: NR | NR
Education and behavioral support | Guthrie et al., 2001^95^ G1: 3635 G2: 913 | Adults with elevated MI risk and elevated cholesterol Primary care clinics | G1: Education from physicians, 2 weeks of free statin, two phone reminders, and four reminder postcards G2: Education from physicians, 2 weeks of free statin, no telephone calls, and two reminder postcards | Face-to-face + two phone calls + four mailings | Percentage reporting currently taking pravastatin as prescribed | Self-report | NR | 6 months: G1: 79.7% G2: 77.4% 95% CI, NR p: NR | NR
Education and behavioral support | Guthrie et al., 2001^95^ G1: 3635 G2: 913 | Adults with elevated MI risk and elevated cholesterol Primary care clinics | | Face-to-face + two phone calls + four mailings | Percentage indicating that no doses missed in the past 7 days | Self-report | NR | 6 months: G1: 64.3% G2: 61.8% 95% CI, NR p: NR | NR
Education and behavioral support | Johnson et al., 2006^96^ G1: NR G2: NR | Adults 21 to 85 on cholesterol medication Multiple sources | G1: Mailed individualized computer-generated intervention and manual for lipid-lowering medication adherence. G2: Did not receive intervention materials | Three mailings over 6 months | Pre-action sample: percentage reaching action or maintenance stage for medication adherence; stage of change algorithm (0 to 100%) | Self-report | Baseline: G1: NR G2: NR 95% CI, NR p >0.05 | 6 months: G1: 55.3% G2: 40.0% OR: 1.80 95% CI, NR p<0.05 | 12 months: G1: NR G2: NR 95% CI, NR p=0.057 18 months: G1: 56.0% G2: 37.8% OR: NR 95% CI, NR p<0.01
Education and behavioral support | Johnson et al., 2006^96^ G1: NR G2: NR | Adults 21 to 85 on cholesterol medication Multiple sources | G1: Mailed individualized computer-generated intervention and manual for lipid-lowering medication adherence. G2: Did not receive intervention materials | Three mailings over 6 months | Pre-action sample: 4-item Medication Adherence Scale Score (better adherence with higher scores) | Self-report | Baseline: G1: NR G2: NR 95% CI, NR p >0.05 | 6 months: G1: NR G2: NR OR: 1.49 95% CI, NR p<0.01 | 12 months: G1: NR G2: NR OR: 1.62 95% CI, NR p<0.001 18 months: G1: NR G2: NR OR: 1.62 95% CI, NR p<0.01
Education and behavioral support | Johnson et al., 2006^96^ G1: NR G2: NR | Adults 21 to 85 on cholesterol medication Multiple sources | G1: Mailed individualized computer-generated intervention and manual for lipid-lowering medication adherence. G2: Did not receive intervention materials | Three mailings over 6 months | Pre-action sample: Mean adherence score on 5-item survey (better adherence with lower scores) | Self-report | Baseline: G1: NR G2: NR 95% CI, NR p >0.05 | 6 months: G1: NR G2: NR OR: 2.03 95% CI, NR p>0.05 | 12 months: G1: NR G2: NR OR: 3.67 95% CI, NR p<0.01 18 months: G1: NR G2: NR OR: 2.86 95% CI, NR p<0.05
Education and behavioral support | Johnson et al., 2006^96^ G1: NR G2: NR | Adults 21 to 85 on cholesterol medication Multiple sources | G1: Mailed individualized computer-generated intervention and manual for lipid-lowering medication adherence. G2: Did not receive intervention materials | Three mailings over 6 months | Post-action sample: percentage maintaining action or maintenance stage for medication adherence; stage of change algorithm (0 to 100%) | Self-report | Baseline: G1: NR G2: NR 95% CI, NR p NR | 6 months: G1: NR G2: NR OR: 2.12 95% CI, NR p>0.05 | 12 months: G1: NR G2: NR OR: NR 95% CI, NR p>0.05 18 months: G1: 85.0% G2: 55.6% OR: NR 95% CI, NR p<0.01
Education and behavioral support | Powell et al., 1995^97^ Overall G1: 1,993 G2: 2,253 Simvastatin G1: 271 G2: 297 | Adults on benazepril, metoprolol, simvastatin or transdermal estrogen HMO members | G1: Mailed educational videotapes to improve adherence G2: Did not receive mailed videotapes | One mailed video | MPR (0 to 1) | Pharmacy refill data | NR | 9 months: Overall Mean (SD) G1:0.70(0.23) G2:0.70(0.28) 95% CI, NR p: NR Simvastatin Mean (SD) G1:0.73(0.26) G2:0.70(0.28) 95% CI, NR p: NR | NR
Education and behavioral support | Powell et al., 1995^97^ Overall G1: 1,993 G2: 2,253 Simvastatin G1: 271 G2: 297 | Adults on benazepril, metoprolol, simvastatin or transdermal estrogen HMO members | G1: Mailed educational videotapes to improve adherence G2: Did not receive mailed videotapes | One mailed video | ≥80% adherence by MPR ≥80% adherence by MPR | Pharmacy refill data | NR | 9 months: Overall: N (%) G1:917 (46%) G2:998 (44%) 95% CI, NR p: NR Simvastatin G1:135 (50%) G2:138 (46%) 95% CI, NR p: NR | NR
Education and behavioral support | Schectman et al., 1994^98^ Niacin: G1: 40 G2: 40 BAS: G1: 18 G2: 22 | Adults with hyperlipidemia on treatment with either niacin or bile acid sequestrant VA medical center | G1: Initial clinic visit + five calls for education and support G2: No telephone contact following initial clinic visit | One face-to-face + five calls over 28 days | “During the past week, how many doses of your medication have you missed?” (Proportion measured not described) | Self-report | NR | 2 months: Niacin: G1: 76 (SD 5) G2: 77 (SD 6) 95% CI, NR p: 0.85 BAS: G1: 76 (SD 7) G2: 60 (SD 9) 95% CI, NR p: 0.14 | NR
Education and behavioral support | Schectman et al., 1994^98^ Niacin: G1: 40 G2: 40 BAS: G1: 18 G2: 22 | Adults with hyperlipidemia on treatment with either niacin or bile acid sequestrant VA medical center | G1: Initial clinic visit + five calls for education and support G2: No telephone contact following initial clinic visit | One face-to-face + five calls over 28 days | Percentage refilling prescription | Pharmacy refill data | NR | 2 months: Niacin (Mean (SD)): G1: 90% (2) G2: 84% (3) 95% CI, NR p: 0.07 BAS (Mean (SD)): G1: 88% (4) G2: 82% (4) 95% CI, NR p: 0.32 | NR
Education and behavioral support | Stacy et al., 2009^99^ G1: 253 G2: 244 | Adults ≥21 years old with a new statin prescription HMO or PPO members | G1: Tailored behavioral support delivered via an IVR system + tailored printed mailed materials G2: Nontailored behavioral advice from a single IVR call + nontailored, printed materials | One to three IVR calls over 6 months | Percentage with MPR ≥80% | Pharmacy refill data | NR | 6 months: G1: 47.0% G2: 38.9% Unadjusted OR: 1.39 90% CI: 1.03 to 1.88 Adjusted OR: 1.43 90% CI, 1.05 to 1.96 p: <0.10 | NR
Education and behavioral support | Stacy et al., 2009^99^ G1: 253 G2: 244 | Adults ≥21 years old with a new statin prescription HMO or PPO members | G1: Tailored behavioral support delivered via an IVR system + tailored printed mailed materials G2: Nontailored behavioral advice from a single IVR call + nontailored, printed materials | One to three IVR calls over 6 months | Persistence: Percentage in possession of a statin at the end of 6 months | Pharmacy refill data | NR | 6 months: G1: 70.4% G2: 60.7% Unadjusted OR, 1.54 90% CI: 1.13, 2.10 Adjusted OR: 1.64 90%CI: 1.19, 2.26 p: <0.05 | NR
Education and behavioral support | Stacy et al., 2009^99^ G1: 253 G2: 244 | Adults ≥21 years old with a new statin prescription HMO or PPO members | G1: Tailored behavioral support delivered via an IVR system + tailored printed mailed materials G2: Nontailored behavioral advice from a single IVR call + nontailored, printed materials | One to three IVR calls over 6 months | Continuous Persistence: statin prescription dispensed at least every 30 days after the refill date (no gaps >30 days) | Pharmacy refill data | NR | 6 months: G1: 52.2% G2: 44.3% Unadjusted OR: 1.37 90% CI: 1.02–1.85 Adjusted OR: 1.41 90%CI: 1.05–1.94 p: <0.10 | NR
Education and behavioral support | Stacy et al., 2009^99^ G1: 253 G2: 244 | Adults ≥21 years old with a new statin prescription HMO or PPO members | G1: Tailored behavioral support delivered via an IVR system + tailored printed mailed materials G2: Nontailored behavioral advice from a single IVR call + nontailored, printed materials | One to three IVR calls over 6 months | Both Continuous persistence (as defined above) and medication possession ratio ≥80% | Pharmacy refill data | NR | 6 months: G1: 45.1% G2: 37.3% Unadjusted OR: 1.38 90% CI: 1.03 to 1.86 Adjusted OR: 1.41 90% CI: 1.03 to 1.92 p: <0.10 | NR
Multicomponent (education face-to-face, pharmacist + blister packaging) | Lee et al., 2006^78^ G1: 83 G2: 76 G1: 83 G2: 76 | Adults ≥65 taking ≥four daily medications Pharmacy at U.S. military medical center | G1: Continuation of intervention: Face-to-face educational pharmacist visits and blister packing of medications G2: Discontinuation of intervention, medications provided in bottles | Seven face-to-face visits over 12 months | Percentage of pills taken vs. prescribed | Pill count | NR | 6 months: Mean (SD) G1: 95.5% (7.7) G2: 69.1% (16.4) 95% CI, NR p<0.001 | NR
Multicomponent (education face-to-face, pharmacist + blister packaging) | Lee et al., 2006^78^ G1: 83 G2: 76 G1: 83 G2: 76 | Adults ≥65 taking ≥four daily medications Pharmacy at U.S. military medical center | G1: Continuation of intervention: Face-to-face educational pharmacist visits and blister packing of medications G2: Discontinuation of intervention, medications provided in bottles | Seven face-to-face visits over 12 months | Percentage with ≥80% adherence | Pill count | NR | 6 months: G1: 97.4% G2: 21.7% 95% CI, NR p<0.001 | NR

Abbreviations: ADA = American Diabetes Association; BAS = bile acid sequestrant; CI = confidence interval; G = group; HMO = health maintenance organization; IVR = interactive voice recognition; MI = myocardial infarction; mos = months; MPR = medication possession ratio; N = number; NA = not applicable; NR = not reported; NS = not significant; OR = odds ratio; PCP = primary care provider; PPO = preferred provider organization; SD = standard deviation; U.S. = United States; VA = Department of Veterans Affairs

Table 12 Hyperlipidemia: strength of evidence for collaborative care intervention

Intervention | Number of Trials; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hyperlipidemia: Collaborative care vs. usual care | 1; 329 (117 on lipid- lowering meds) | Medication adherence | RCT Medium | Unknown | Direct | Imprecise | No sig diff between groups for percentage of days nonadherent (28.8% vs. 27.7%) or difference in change in adherence (−0.2%) over 12 months, pharmacy refill Insufficient

Abbreviations: diff = difference; RCT = randomized controlled trials; sig = significant; vs. = versus.

#### Detailed Synthesis for Statin Decision Aids for Hyperlipidemia

##### Medication Adherence

Of the two trials of statin decision-aid interventions,92–94 one found improved self-reported medication persistence in the intervention group compared with the control group, but only among participants on statins at 3 months following the intervention (Table 11).93,94 The other trial of statin decision aids did not find improved adherence in the intervention group.92 Because of small sample sizes and imprecise outcomes in medication adherence and persistence, we graded the evidence as insufficient (Table 13).

Table 13 Hyperlipidemia: strength of evidence for decision aid interventions

Intervention | Number of Trials; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hyperlipidemia: Decision aids vs. educational materials with no decision aid | 2; 248 (98 + NR in 1 trial) | Medication initiation, adherence, persistence | RCT Medium | Consistent | Direct | Imprecise | Variable self-report measures with variable outcomes Insufficient
Hyperlipidemia: Decision aids vs. educational materials with no decision aid | 1; 98 (98) | Patient satisfaction | RCT Medium | Unknown | Direct | Imprecise | Variable self-report measures, some improvements for intervention group in specific areas Low

Abbreviations: NR = not reported; RCT = randomized controlled trial.

##### Other Outcomes

The one trial with improved adherence outcomes reported patient satisfaction outcomes (Appendix G).93,94 This trial found higher odds of patient satisfaction for some but not all questions in the intervention group than in the control group. Scales ranged from 0 to 7 for all items with higher scores indicating better satisfaction; the odds of responding 6 or 7 out of 7 were calculated as an odds ratio comparing intervention to control group participants. Significant results were found for receiving an acceptable amount of information (OR, 3.4; 95% CI, 1.7 to 6.7), acceptable helpfulness of information (OR, 2.3; 95% CI, 1.4 to 3.8), and overall acceptability (OR, 2.8; 95% CI, 1.2 to 6.9). However, groups did not differ on items pertaining to clarity of information (OR, 1.6; 95% CI, 0.8 to 3.2), indicating that participants would recommend approach to others deciding on statins (OR, 2.6; 95% CI, 0.8 to 8.0), and indicating a preference for a similar approach for other treatment choices (OR, 1.5; 95% CI, 0.6 to 3.8). Because the evidence came from a small sample and some satisfaction outcomes were imprecise, we graded strength of evidence as low for benefit (Table 13).

#### Detailed Synthesis for Education and Behavioral Support Interventions for Hyperlipidemia

##### Medication Adherence

Among the five trials that evaluated an intervention of education and behavioral support,95–99 two trials reported improved adherence and/or persistence (Table 8).96,99 To measure medication adherence or persistence, two trials used only self-reported survey items,95,96 two trials used only pharmacy refill data,97,99 and one used a combination of self-reported and pharmacy refill measures.98

In the two trials that found improved adherence or persistence measures, one found a higher percentage of participants in the intervention group with an MPR of 80 percent or more over 6 months than in the control group; however, this trial used a cutoff of p<0.10 (90% CI) for statistical significance.99 This trial found better persistence as measured by the proportion in possession of a statin at the end of the 180-day intervention in the intervention group.99 Other measures of persistence that were improved in the intervention group compared with the control group in this trial included the proportion of each group without a gap of more than 30 days in statin prescription refills and the proportion both without a gap of more than 30 days in statin prescription refills and MPR of 80 percent or more over months.99 In other trial with adherence improvements, adherence was evaluated among participants who received a mail-based intervention as reaching or maintaining an “Action” stage (having improved adherence for less than 6 months) or “Maintenance” stage (having improved adherence for more than 6 months) by self-report in a stage of change algorithm.96 Among a “pre-action” portion of the trial sample, the proportion reaching Action or Maintenance was higher at 6 and 18 months, but not at 12 months, in the intervention group than in the control group. Among a “post-action” sample, the proportion maintaining Action or Maintenance was higher in the intervention group only at 18 months. Other statistically significant differences between intervention and control groups were identified among the pre-action portion of the sample in (1) a self-reported 4-item Medication Adherence Scale scores at 6, 12, and 18 months and (2) in a 5-item mean level of adherence score at 12 and 18 months.96

Among the three trials that did not find improved medication adherence or persistence outcomes, one found no difference between groups either for the number of patients who reported taking pravastatin as prescribed or for the percentage that reported missing no doses of pravastatin in the past 7 days at 6 months.95 The second trial did not find improved adherence in MPR or proportion with an MPR of 80 percent or more between intervention and control groups over 9 months.97 The third trial found no difference between groups either in self-report of missing medication doses in the past week or in the percentage refilling prescriptions. Given that only two of the five trials found improved persistence or adherence, the variability of measures, and imprecision in outcomes, evidence of improved adherence was graded as low for benefit (Table 14).

Table 14 Hyperlipidemia: strength of evidence for education and behavioral support interventions

Intervention | Number of Trials; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hyperlipidemia: Education + behavioral support vs. usual care or less intense intervention | 5; 18,492 (9,411 + NR in 1 trial) | Medication Adherence, persistence | RCT medium | Consistent | Direct | Imprecise | Variable measures (self-report, pharmacy refill) with variable outcomes Low

Abbreviations: NR = not reported; RCT = randomized controlled trial.

#### Detailed Synthesis for Multicomponent Intervention for Hyperlipidemia

##### Medication Adherence

The one pharmacist intervention found improved medication adherence outcomes in the intervention group compared with the control group (Table 8).78 This trial evaluated adherence from pill counts both as the percentage of medication adherence in the intervention arm (95.5 percent) versus the control arm (69.1 percent) at 6 months and as the proportion of participants with 80 percent or greater adherence in the intervention arm (97.4 percent) compared with the control arm (21.7 percent) over 6 months (Table 15).78 However, pill counts were performed less frequently in the control arm (once over 6 months) than the intervention arm (three times over 6 months). Because adherence outcomes were at risk of bias in this relatively small trial, we graded strength of evidence as insufficient (Table 15).

Table 15 Hyperlipidemia: strength of evidence for multicomponent intervention

Intervention | Number of Trials; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hyperlipidemia: Multicomponent (face-to-face education with a pharmacist and blister packaging) vs. discontinuation of intervention | 1; 159 (159) | Medication adherence | RCT Medium | Unknown | Indirect | Precise | Improved in intervention group over 6 months, outcome at risk of bias due to differing measurement frequency:; 1. Percentage adherence (95.5% vs. 69.1%); 2. Percentage with ≥80% adherence (97.4 vs. 21.7); Insufficient
Hyperlipidemia: Multicomponent (face-to-face education with a pharmacist and blister packaging) vs. discontinuation of intervention | 1; 159 (135) | Biomarkers LDL-C | RCT Medium | Unknown | Indirect | Imprecise | No difference between groups Insufficient

Abbreviations: LDL-C = low density lipoprotein cholesterol; RCT = randomized controlled trial.

##### Other Outcomes

This small trial reported LDL-C outcomes and found no statistically significant differences either in LDL-C between intervention (87.5) and control groups (88.4) at 14 months or in changes in LDL-C from 2 months to 14 months between intervention (−2.8) or control groups (−5.8). We graded the strength of evidence for no differences in this biomarker as insufficient. (Table 15).

### Key Question 1 Hypertension: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

Seventeen RCTs (19 articles) evaluated interventions to improve medication adherence in patients taking medications for hypertension.78,89,91,97,100–114 Ten trials primarily evaluated patients with a hypertension diagnosis,100,102,104–110,113,114 one evaluated patients with hypertension and depression,101 two evaluated patients with diabetes mellitus and hypertension,91,103 and four evaluated subgroups with hypertension.78,89,97,111,112 We rated 16 trials as having medium risk of bias78,89,91,97,101–114 and one trial as having low risk of bias.100

##### Population

All trials were conducted in adults ranging from 18 years or older110 to 65 years or older;78,100 mean ages ranged from 54 to 55 years97 to 78 years.78 Women made up between 0 percent113 and 75 percent101 of the trial populations. Among the two trials that reported race and ethnicity, the proportion of Black participants ranged from between 8 percent to 11 percent102 up to 70 percent to nearly 85 percent.113

##### Intervention

All 17 trials evaluated interventions that were targeted at patients. Five trials additionally targeted systems of care,101,102,104,105,113 and one trial additionally targeted providers.104

One trial evaluated the effect of blister packaging medications.100

Three trials evaluated the effect of case management (two involving nurses).101–103 In one trial an integrated care manager delivered the intervention both in person and by telephone for patients with depression and hypertension.101 In another, a nurse managed hypertension medications by telephone as guided by home blood pressure readings.102 In the third trial, a nurse managed blood pressure and glucose data that was collected by a home telehealth device and determined whether further education or other management changes were needed.103

Three trials evaluated collaborative care models.89,104,105 Two collaborative care trials evaluated a primary care physician/pharmacist collaboration for hypertension care.104,105 The third evaluated the effect of collaborative care for depression with individualized management using either antidepressant medication or problem-solving treatment to promote adherence to medications, including angiotensin-converting enzyme (ACE) inhibitors in a subgroup with hypertension.89

Five trials examined interventions that provided education and behavioral support by either telephone or mail.97,106–110 In two trials, a nurse delivered education and support by telephone.106–108

In a third, an interactive computer-based telecommunications system delivered the education and support by telephone.109 The remaining two trials delivered interventions by mail;97,110 one evaluated the effect of mailing an individualized intervention and manual for antihypertensive adherence based on the transtheoretical model for change110 and the other evaluated the effect of mailing educational videotape programs about the participants’ medications and inferred diseases.97

Of the remaining trials, three evaluated interventions that involved between five111,112 and seven78 face-to-face educational visits with a pharmacist.78,111–113 In two of these interventions pharmacists delivered education and counseling about adherence;78,111,112 in the third trial, pharmacists additionally managed participants’ hypertension medications.113

Finally, one trial evaluated the effect of education and social support by involving a patient’s social support person in an educational session delivered face-to-face by a nurse.91 Another trial evaluated the effect of personalized risk communication for coronary heart disease and stroke.114

##### Comparator

Twelve trials compared active arms to usual care;89,97,100–103,105–110,113 the remaining trials involved more than simple usual practices.78,91,104,111,112,114 In the blister packaging intervention, the control group received medications in pill bottles instead of the blister packs provided to the intervention group.100 In the trials of case management, usual care included typical clinical care in one trial101,103 and was minimally described in the other trial.102

Among the three trials of collaborative care, usual care involved the typical clinical care offered to patients in two trials;89,105 in the third trial, control participants did not have contact with pharmacists but did have contact with trial nurses, who measured blood pressures and provided education.104

Among the education and behavioral support interventions, usual care consisted of no telephone contact with the control group in two trials,106–108 no mailings to the control group in one trial,97 and was minimally described in two trials.109,110 In one of the three trials of face-to-face education with a pharmacist, the investigators discontinued the intervention after a 6-month phase in which both intervention and control groups received pharmacist visits and blister packages of medications.78 In another trial of face-to-face education, the control group had two visits with a pharmacist, one at baseline and one between 4 and 6 months, with no supplemental services or visits.111,112 In the third trial of face-to-face education, the control group received typical clinical care with no pharmacist visits.113

In the trial evaluating education and social support, a social support person was not included in the nurse-delivered educational session for the control group.91 In the risk communication trial, the control group received nonpersonalized educational information about heart attack and stroke risk.114

##### Outcomes and Timing

Medication adherence measures varied widely. None of the trials evaluated initiation of medication therapy; two evaluated persistence of medication therapy.100,113 Self-reported adherence measures included nonvalidated survey measures in two trials,110,113 a stage-of-change algorithm in one trial,110 and Morisky scales in eight trials.91,103–108,111,112,114 Additional adherence measures included pill counts in two trials,78,109 pharmacy refill data in four trials,89,97,100,113 and the MEMS in two trials.101,102 One trial used both self-reported (survey questions) and nonself-reported (pharmacy refill data) measures of adherence.113

Of the five trials for which we discuss blood pressure outcomes, three reported systolic and diastolic blood pressure measurements (mm Hg) at followup;78,101,111,112 two reported mean changes (mm Hg) in systolic and diastolic blood pressure between baseline and followup,102,109 and one reported the proportion of patients with reductions in systolic and diastolic blood pressure between baseline and followup.100

Other outcomes included the occurrence of angina, myocardial infarction, and stroke (one trial).100 Two trials reported on health care utilization, including emergency department (ED) visits and hospitalizations;100,111,112 one additionally reported number of contacts with health care providers other than pharmacists.111,112 Patient satisfaction and quality-of-life outcomes were reported in one trial from an unvalidated survey question.111,112

The length of these trials varied considerably; the shortest lasted 6 weeks101 and the longest were planned to last 24 months,106–108 although the publications we identified for both 24-month trials reported only 6-month outcomes.

In most trials, adherence outcomes were collected at the conclusion of the intervention. Exceptions include the 24-month trials reporting only 6-month outcomes,106–108 one trial of an 18-month intervention that reported 6-, 12-, and 18-month outcomes,110 and a 12-month trial that reported 6- and 12-month outcomes.100 One trial lasted 14 months; it had an initial 2-month run-in period followed by a 6-month cohort intervention followed by a final 6-month RCT in which one group continued the prior cohort intervention and one group did not.78

##### Setting

Eleven trials focused on primary care populations,89,91,100–108,114 three on pharmacy populations,78,111–113 two on HMO populations,97,110 and one recruited participants from community sites including senior centers.109 Of the 17 trials, 5 were conducted within a population at least partly composed of patients from Veterans Administration medical centers (VAMCs),103,108,111–114 and one was in a U.S. military medical center.78

##### Applicability

Overall, the six trials that were based within VAMCs and the military hospital were considered to have relatively limited applicability (except perhaps to those relevant populations).78,103,107,108,111–114 Compared with the trials in other settings, the VA and military populations studied included a lower proportion of women (ranging from 0 to 22 percent) and, with the exception of one trial conducted in an Iowa VA primary care clinic,103 a higher proportion of Black participants (ranging from 32.3 percent to 80 percent to nearly 85 percent). In addition, one trial performed at a VAMC was considered to have limited generalizability because a large component of the intervention involved having a pharmacist prescribe medications,113 which is a role available to pharmacists only within the VA system and a small number of states.

The two trials that were based in HMO populations tended to have a younger mean age (54 to 55.7 years old) than trials conducted in other populations.97,110

#### Key Points

##### Overview

- Medication adherence: Across 17 trials, evidence for medication adherence varied substantially (Table 16). Seven of the 17 trials reported significant improvements in at least one measure of medication adherence. The other 10 trials demonstrated no difference between groups for adherence to antihypertensive medications.
- Morbidity: Six of the seven trials with improved medication adherence reported blood pressure outcomes. Four of the six trials reported improvements in systolic blood pressure; four of the six reported improvements in diastolic blood pressure.
- We graded strength of evidence formally for five intervention clusters: (1) blister packaging of medications, (2) case management, (3) collaborative care, (4) education and behavioral support (telephone, mailing, or videotape), and (5) education (face-to-face with pharmacist). We graded the body of evidence for education with social support and for risk communication as insufficient.

Table 16 Hypertension: summary of findings

Type of Intervention | Studies, N Randomized | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Blister packaging | Schneider et al., 2008^100^ N=93 | + Percentage of patients refilling medications on time over 12 months; + Medication possession ratio over 12 months | Morbidity; = Systolic blood pressure change at 6 months and 12 months; = Diastolic blood pressure change at 6 and 12 months; = Proportion of patients with reduced systolic blood pressure at 6 and 12 months; = Proportion of patients with reduced diastolic blood pressure at 6 months; + Proportion of patients with reduced diastolic blood pressure at 12 months; = Occurrence of angina at 6 and 12 months; = Occurrence of MI at 6 and 12 months; = Occurrence of stroke at 6 and 12 months; Health care utilization; = ED visits and hospitalizations at 6 and 12 months
Case management | Bogner et al., 2007^101^ N=64 | + Adherence for taking ≥80% hypertensive medications over 6 weeks | Morbidity; + Systolic blood pressure (mean) at 6 weeks; + Diastolic blood pressure (mean) at 6 weeks
Case management | Rudd et al., 2004^102^ N=150 | + Adherence for number of days medications taken correctly over 6 months | Morbidity; + Systolic blood pressure (change), from baseline to 6 months; + Diastolic blood pressure (change), from baseline to 6 months
Case management | Wakefield et al., 2011^103^ N=302 | = Morisky scale scores at 6 months | NA
Collaborative care | Carter et al., 2009^104^ N=402 | = Morisky scale, percentage of patients reporting low medication adherence at 6 months; = Morisky scale, within-group change in percentage of patients reporting low adherence from baseline to 6 months | NA
Collaborative care | Hunt et al., 2008^105^ N=463 | = Morisky scale, percentage of patients reporting high medication adherence at 12 months; = Morisky scale, change in report of high medication adherence, from baseline to 12 months | NA
Collaborative care | Lin et al., 2006^89^ N=329 | = Percentage of days nonadherent to hypertension medication over 12 months; = Adjusted difference in percentage of days nonadherent comparing G1 and G2 over 12 months | NA
Education and behavioral support (telephone, mail, and/or video) | Bosworth et al., 2008^106,107^ N=636 | = Morisky scale, percentage reporting high adherence at 6 months; = Morisky scale, change in percentage reporting adherence from baseline to 6 months | NA
Education and behavioral support (telephone, mail, and/or video) | Bosworth et al., 2005^108^ N=588 | = Morisky scale, change in proportion reporting adherence from baseline to 6 months | NA
Education and behavioral support (telephone, mail, and/or video) | Friedman et al., 1996^109^ N=299 | = Unadjusted adherence to hypertensive medication by pill count, change from baseline to 6 months; + Adjusted adherence to hypertensive medication by pill count, change from baseline to 6 months | Morbidity; = Systolic blood pressure change from baseline to 6 months; = Diastolic blood pressure change from baseline to 6 months
Education and behavioral support (telephone, mail, and/or video) | Johnson et al., 2006^110^ N=1227 | = Behavioral measure of nonadherence at 6 months; + Behavioral measure of nonadherence at 12 months and 18 months | NR
Education and behavioral support (telephone, mail, and/or video) | Powell et al., 1995^97^ N=4246 | = Medication possession ratio over 9 months, overall and for antihypertensive medications, over 9 months; = Percentage of participants with ≥80% medication possession ratio, over 9 months, overall and for antihypertensive medications | NA
Education (face-to-face with pharmacist) | Lee et al., 2006^78^ N=159 | + Proportion of pills taken over 6-month RCT; + Percentage of participants with ≥80% adherence to medications over 6-month RCT | Among patients with hypertension: Morbidity; + Systolic blood pressure (mean) at 14 months (2-month run-in + 6-month cohort + 6-month RCT); + Systolic blood pressure difference between 2 months and 14 months (2-month run-in + 6-month cohort + 6-month RCT outcome); = Diastolic blood pressure at 14 months (6-month cohort + 6-month RCT outcome); = Diastolic blood pressure difference between 2 months and 14 months (2-month run-in + 6-month cohort + 6-month RCT outcome)
Education (face-to-face with pharmacist) | Solomon et al., 1998^111,112^ N=133 (Hypertension) | Among patients with hypertension:; + Morisky scale score, reporting compliance at 4- to 6-month visit; + Morisky scale score, difference in proportion reporting compliance between baseline and 4- to 6- month visit; improved in G1 not G2 | Among patients with hypertension: Morbidity; + Systolic blood pressure (mean) at 4- to 6-month visit; + Systolic blood pressure difference from baseline to 4- to 6-month visit within intervention group; = Diastolic blood pressure (mean) at 4 to 6 months; = Diastolic blood pressure difference from baseline to 4- to 6-month visit within intervention group; Quality of life; = Sexual dysfunction, dizziness and headaches at 4 to 6 months; Patient satisfaction; + Four medication-related questions at 4 to 6 months; = One medication-related question at 4 to 6 months; Health care utilization; = Emergency department visits over 4 weeks prior, at 4 to 6 months; + Hospitalizations over 4 weeks prior, at 4 to 6 months (one-tailed p<0.05); + Contacts with other health care providers (MD, NP, PA or RN) over 4 weeks prior, at 4 to 6 months (one-tailed p<0.05)
Education (face-to-face with pharmacist) | Vivian et al., 2002^113^ N=56 | = Compliance survey questions at 6 months; = Proportion of patients that received refills within 2 weeks of next scheduled refill date over 6 months | NA
Education with social support | Pearce et al., 2005^91^ N=199 | = Morisky, proportion with high, medium, or low adherence at 12 months | NA
Risk communication | Powers et al., 2011^114^ N=89 | = Morisky, proportion with high adherence at 3 months | NA

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; ED = emergency department; G = group; MD = physician; MI = myocardial infarction; N = number; NA = not applicable; NP = nurse practitioner; NR = not reported; PA = physician assistant; RCT = randomized controlled trial; RN = registered nurse.

#### Key Points by Intervention Type

##### Blister Packaging of Medications

- Medication adherence: The trial that evaluated blister packaging of medication without additional intervention components reported significantly improved medication adherence and persistence (low strength of evidence of benefit).
- Morbidity: The blister packaging trial did not show a difference between groups for change in systolic or diastolic blood pressure at either 6 or 12 months. It did not show a significant difference between groups in the proportion of patients with reduced systolic blood pressure at 6 or 12 months or in the proportion with reduced diastolic blood pressure at 6 months. However, significantly more patients in the intervention than in the control group had reduced diastolic blood pressure at 12 months. These outcomes are all graded insufficient evidence for either no difference or benefit. This trial found no difference between groups for occurrence of angina, myocardial infarction, or stroke (insufficient evidence).
- Health care use: This trial demonstrated no significant difference between groups for ED visits and hospitalizations (insufficient evidence).

##### Case Management

- Medication adherence: Two of three trials that involved case management reported significantly improved medication adherence (low strength of evidence of benefit).
- Morbidity: These two trials reported blood pressure outcomes. One trial found significantly reduced mean systolic and diastolic blood pressures in the intervention group compared with the control group at 6 weeks; the other trial found systolic and diastolic blood pressure at 6 months were decreased more in the intervention than in the control group (low strength of evidence of benefit).

##### Collaborative Care

- Medication adherence: Among three trials evaluating collaborative care, none found improved medication adherence (low strength of evidence of no benefit).

##### Education and Behavioral Support

- Medication adherence: Among the five trials that evaluated education and behavioral support, two found significantly improved medication adherence; however, the trials used variable measures to assess medication adherence and some outcomes were imprecise (low strength of evidence of benefit).
- Morbidity: In one of the two trials with improved medication adherence, systolic and diastolic blood pressures did not differ between groups at 6 months (insufficient evidence).

##### Education (Face-to-Face With Pharmacist)

- Medication adherence: Among the three trials that evaluated education delivered face-to-face by a pharmacist, two found improved medication adherence; however, the trials used variable measures to assess medication adherence and had some imprecise outcomes (low strength of evidence of benefit). One trial evaluated medication persistence and found no difference between groups (insufficient evidence).
- Morbidity: Both trials with improved medication adherence found improvements in mean systolic blood pressure in the intervention arm compared with the control arm (moderate strength of evidence of benefit). No significant differences in mean diastolic blood pressure were identified between groups in either trial (insufficient).
- Quality of life: One trial reported quality-of-life outcomes, which did not differ between groups for sexual dysfunction, dizziness, or headaches (insufficient evidence).
- Patient satisfaction: One trial reported patient satisfaction outcomes from survey questions related to medications. The intervention group had better satisfaction scores than the control group for four of five questions (low strength of evidence of benefit).
- Health care utilization: One trial found no difference between groups for ED visits (insufficient evidence). Hospitalizations and contacts with various health care providers (physicians, nurses and nurse practitioners, physician assistants) were significantly lower in the intervention group than the control group (low strength of evidence of benefit).

##### Education With Social Support

- Medication adherence: The one trial that evaluated education with social support reported no difference in medication adherence between groups (insufficient evidence).

##### Risk Communication

- Medication adherence: The one trial that evaluated risk communication reported no difference in medication adherence between groups (insufficient evidence).

#### Detailed Synthesis for Blister Packaging of Medications for Hypertension

##### Medication Adherence

The intervention of blister packaging of medications improved both adherence and persistence in the intervention compared with the control group (using pharmacy refill data) (Table 17).100 This trial found both a significantly higher percentage of patients who had prescriptions refilled on time and a higher MPR (medications received: medications prescribed) over 12 months in the intervention arm (Table 18). We graded the strength of evidence of benefit for persistence and adherence as low.

Table 17 Hypertension: detailed medication adherence outcomes

Study | N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, Direction) | Source | Baseline | First Followup | Additional Followups
Blister packaging | Schneider et al., 2008^100^ G1: 47 G2: 38 | Adults >65 with HTN Primary care clinic | G1: Blister packaging of lisinopril G2: No blister packaging of lisinopril | Monthly blister packs for 12 months | Percentage refilling medications on time (+/− 5 days of refill date) (0 to 100%) | Pharmacy refill data | NR | 12 months: Mean (SD) G1: 80.4% (21.2) G2: 66.1% (28.0) 95% CI, NR p: 0.012 | NR
Blister packaging | Schneider et al., 2008^100^ G1: 47 G2: 38 | Adults >65 with HTN Primary care clinic | G1: Blister packaging of lisinopril G2: No blister packaging of lisinopril | Monthly blister packs for 12 months
Blister packaging | Schneider et al., 2008^100^ G1: 47 G2: 38 | Adults >65 with HTN Primary care clinic | G1: Blister packaging of lisinopril G2: No blister packaging of lisinopril | Monthly blister packs for 12 months | Medication possession ratio (0 to 100%) | Pharmacy refill data | NR | 12 months: Mean (SD) G1: 0.93 (11.4) G2: 0.87 (14.2) 95% CI, p: 0.039 | NR
Case management | Bogner et al. 2007^101^ G1: 32 G2: 32 | Adults ≥50 with depression and HTN Primary care clinic | G1: Integrated care of depression and hypertension with care manager G2: Usual care | Three face-to-face + two calls over 4 weeks | Number of patients with ≥80% adherence to hypertension medications (0 to 100%) | MEMS | NR | 6 weeks: G1: 25 (78.1%) G2: 10 (31.3%) p<0.001 95% CI, NR | NR
Case management
Case management | Rudd et al., 2004^102^ G1: NR G2: NR | Adults with HTN Primary care clinic | G1: Nurse management by phone, HTN medication adjustment guided by home BPs G2: Not described | Five calls over 4 months | Adherence to daily medications (0 to 100%) | MEMS | NR | 6 months: Mean (SD) G1: 80.5% (23.0) G2: 69.2% (31.1) 95% CI, NR p=0.03 | NR
Case management
Case management | Wakefield et al., 2011^103^ G1: NR G2: NR G3: NR | Adults with diabetes mellitus and HTN Primary care clinic at VA medical center | G1: High-intensity: use of home telehealth device for blood pressure and glucose as well as education with nurse case management. G2: Low –intensity: Similar to G1 intervention with lower intensity of educational content. G3: Usual care | 6 months, daily entries for BP and glucose | Morisky scale | Self-report | NR | 6 months: G1: NR G2: NR G3: NR p: Per text no significant difference between groups; all groups improved from baseline; NR if statistically significant | NR
Collaborative care | Carter et al., 2009^104^ G1: 192 G2: 210 | Adults >21 with HTN Family medicine residency programs | G1: Collaborative model between pharmacists and physicians G2: No collaboration with pharmacists | Baseline visit+ telephone calls over 6 months | Percentage with low adherence on Morisky scale (0 to 100%) | Self-report | Baseline Mean (SD) G1:17.3% (27.5) G2: 18.7% (22.0) 95% CI, NR | 6 months: Mean (SD) G1: 14.6% (25.4) G2: 14.7% (20.9) 95% CI, NR Within-group change from baseline to 6 months: G1: −2.7% p=0.979 G2: −4% p=0.602 | NR
Collaborative care
Collaborative care | Hunt et al., 2008^105^ G1: 142 G2: 130 | Adults with HTN Primary care clinics | G1: Collaborative primary care-pharmacist HTN management. G2: Usual care | Between one to four face-to-face visits over 12 months | Percentage with high adherence on Morisky scale (0 to 100%) | Self-report | Baseline G1: 61% G2: NR | 12 months: G1: 67% G2: 69% 95% CI, NR p: 0.771 Within-group change from baseline to 12 months: G1: +6% p=0.08 G2: NR p NR | NR
Collaborative care
Collaborative care | Lin et al., 2006^89^ Baseline: G1: 54 G2: 65 12 mos: G1: 59 G2: 52 Baseline: G1: 54 G2: 65 12 mos: G1: 59 G2: 52 | Adults with diabetes mellitus and depression Primary care clinics | G1: Collaborative care for depression using either medications or problem-solving treatment G2: Advised to consult PCP for depression treatment | 16 phone or face-to-face visits over 12 months | Percentage of days nonadherent to ACE inhibitor (0 to 100%) | Pharmacy refill data | Baseline Mean (SD) G1: 27.4% (27.1) G2: 29.7% (29.3) 95% CI, NR p: NS | 12 months: Mean (SD) G1: 24.2% (22.7%) G2: 18.9% (17.4%) 95% CI, NR p: NS | NR
Collaborative care | Lin et al., 2006^89^ Baseline: G1: 54 G2: 65 12 mos: G1: 59 G2: 52 Baseline: G1: 54 G2: 65 12 mos: G1: 59 G2: 52 | Adults with diabetes mellitus and depression Primary care clinics | G1: Collaborative care for depression using either medications or problem-solving treatment G2: Advised to consult PCP for depression treatment | 16 phone or face-to-face visits over 12 months | Adjusted difference in percentage of days nonadherent to ACE inhibitor comparing G1 and G2 | Pharmacy refill data | Baseline Mean (SD) G1: 27.4% (27.1) G2: 29.7% (29.3) 95% CI, NR p: NS | 12 months: (%)=−2.5% 95% CI, −8.69 to 3.70 p: NS | NR
Education and behavioral support | Bosworth et al., 2008^106,107^ G1: 319 G2: 317 | Adults with HTN Primary care clinics | G1: Nurse delivered behavioral and educational intervention by phone G2: No telephone contact, usual care | 12 calls every 2 months over 24 months planned | Percentage with high adherence on Morisky scale (0 to 100%) | Self-report | Baseline G1: 63% G2: 67% 95% CI, NR p: NR | 6 months: G1: 72% G2: 68% 95% CI, NR p: NR Within-group change from baseline to 6 months: G1: + 9% G2: + 1% 95% CI, NR p: NR | NR
Education and behavioral support
Education and behavioral support | Bosworth et al., 2005^108^ G1: NR G2: NR | Adults with HTN Primary care clinics at VA medical center | G1: Nurse delivered behavioral and educational intervention by phone G2: No nurse telephone contact, usual care | 12 calls every 2 months over 24 months planned | Difference in change of percentage with high adherence on Morisky scale (0 to 100%) | Self-report | NR | Change from baseline to 6 months: 0.74% 95% CI: −6.2 to 7.6 p: NR | NR
Education and behavioral support
Education and behavioral support | Friedman et al., 1996^109^ G1: 133 G2: 134 | Adults ≥ 60 on medication for HTN Community-based | G1: An interactive computer-based telecommunications system (TLC) that conversed with patients in homes G2: Regular medical care (not described) | 24 TLC calls over 6 months | Change in percentage of pills taken vs. prescribed | Pill count | NR | Change from baseline to 6 months: Unadjusted: G1: +2.4% G2: +0.4% p=0.29 Adjusted: G1: +17.7% G2: +11.7% p=0.03 | NR
Education and behavioral support
Education and behavioral support | Johnson et al., 2006^110^ G1: NR G2: NR | Adults 18–80 on medication for HTN HMO members | G1: Mailed individualized computer-generated intervention and manual for HTN medication adherence. G2: Not described | Three mailings over 6 months | 5-item adherence behavioral survey (0–5, lower score indicates better adherence) | Self-report | Baseline: G1: NR G2: NR 95% CI, NR p>0.05 | 6 months: G1: NR G2: NR 95% CI, NR p>0.05 | 12 months: G1: NR G2: NR 95% CI, NR p<0.01 18 months: G1: NR G2: NR 95% CI, NR p<0.001
Education and behavioral support
Education and behavioral support | Powell et al., 1995^97^ Overall G1: 1,993 G2: 2,253 Benazepril G1: 175 G2: 243 Metoprolol G1: 830 G2: 898 | Adults on benazepril, metoprolol, simvastatin or transdermal estrogen HMO members | G1: Mailed educational videotapes to improve adherence G2: Did not receive mailed videotapes | One mailed video | Medication possession ratio | Pharmacy refill data | NR | 9 months: Overall Mean (SD) G1:0.70(0.23) G2:0.70(0.28) 95% CI, NR p: NR On benazepril Mean (SD) G1:0.71(0.25) G2:0.72(0.26) 95% CI, NR p: NR On metoprolol Mean (SD) G1:0.74(0.27) G2:0.73(0.28) 95% CI, NR p: NR | NR
Education and behavioral support | Powell et al., 1995^97^ Overall G1: 1,993 G2: 2,253 Benazepril G1: 175 G2: 243 Metoprolol G1: 830 G2: 898 | Adults on benazepril, metoprolol, simvastatin or transdermal estrogen HMO members | G1: Mailed educational videotapes to improve adherence G2: Did not receive mailed videotapes | One mailed video
Education and behavioral support | Powell et al., 1995^97^ Overall G1: 1,993 G2: 2,253 Benazepril G1: 175 G2: 243 Metoprolol G1: 830 G2: 898 | Adults on benazepril, metoprolol, simvastatin or transdermal estrogen HMO members | G1: Mailed educational videotapes to improve adherence G2: Did not receive mailed videotapes | One mailed video | Percentage with ≥80% adherence by MPR | Pharmacy refill data | NR | 9 months: Overall: N (%) G1:917 (46%) G2:998 (44%) 95% CI, NR p: NR On benazepril N (%) G1: 78 (45%) G2: 104 (44%) 95% CI, NR p: NR On metoprolol N (%) G1:438 (53%) G2:466 (52%) 95% CI, NR p: NR | NR
Education (face-to-face, pharmacist) | Lee et al., 2006^78^ G1: 83 G2: 76 | Adults ≥65 taking ≥4 daily medications Pharmacy at U.S. military medical center | G1: Continuation of intervention: face-to-face educational pharmacist visits and blister packaging of medications G2: Discontinuation of intervention, medications provided in bottles | Seven face-to-face visits over 12 months | Percentage of pills taken vs. prescribed | Pill count | NR | 6 months: Mean (SD) G1: 95.5% (7.7) G2: 69.1% (16.4) 95% CI, NR p<0.00 | NR
Education (face-to-face, pharmacist) | Lee et al., 2006^78^ G1: 83 G2: 76 | Adults ≥65 taking ≥4 daily medications Pharmacy at U.S. military medical center | G1: Continuation of intervention: face-to-face educational pharmacist visits and blister packaging of medications G2: Discontinuation of intervention, medications provided in bottles | Seven face-to-face visits over 12 months
Education (face-to-face, pharmacist) | Lee et al., 2006^78^ G1: 83 G2: 76 | Adults ≥65 taking ≥4 daily medications Pharmacy at U.S. military medical center | G1: Continuation of intervention: face-to-face educational pharmacist visits and blister packaging of medications G2: Discontinuation of intervention, medications provided in bottles | Seven face-to-face visits over 12 months | Percentage with ≥80% adherence | Pill count | NR | 6 months: G1: 97.4% G2: 21.7% 95% CI, NR p<0.001 | NR
Education (face-to-face, pharmacist)
Education (face-to-face, pharmacist) | Solomon et al., 1998^111,112^ G1: 62 G2: 70 | Adults with HTN (on dihydropyridine or dihydropyridine + diuretic therapy) Pharmacy at VA medical centers, university hospital | G1: Five face-to-face educational pharmacist visits G2: Two pharmacist visits with only usual care provided | Five face-to-face visits over 6 months | Adherence on Morisky scale (0 to 4, lower score indicates better adherence) | Self-report | Baseline: Mean (SD) G1: 0.63 (0.111) G2: 0.60 (0.087) 95% CI, NR p: 0.75 | 4 to 6 months: Mean (SD) G1: 0.23 (0.054) G2: 0.61 (0.094) 95% CI, NR p: 0.007 Within-group change from baseline to 4 to 6 months: G1: −0.4 95% CI, NR p<0.05 G2: +0.01 95% CI, NR p: NR | NR
Education (face-to-face, pharmacist)
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months | Percentage that forget to take medications ≥1 time/week, survey (0 to 100%) | Self-report | NR | 6 months: G1: 68% G2: 48% 95% CI, NR p: 0.252 | NR
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months | Percentage that stop medications when feeling better ≥1 time/week, survey (0 to 100%) | Self-report | NR | 6 months: G1: 32% G2: 20% 95% CI, NR p: 0.520 | NR
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months | Percentage that stop medications when they think it is making them feel worse, ≥1 time/week survey (0 to 100%) | Self-report | NR | 6 months: G1: 40% G2: 20% 95% CI, NR p: 0.217 | NR
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months | Percentage that take more medication than prescribed when it does not seem to be working ≥1 time/week survey (0 to 100%) | Self-report | NR | 6 months: G1: 8% G2: 8% 95% CI, NR p: 1.00 | NR
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months | Percentage that forgot to take medications when away from home overnight, ≥2 time/week survey (0 to 100%) | Self-report | NR | 6 months: G1: 15% G2: 10% 95% CI, NR p: 1.00 | NR
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months
Education (face-to-face, pharmacist) | Vivian et al., 2002^113^ G1: 26 G2: 27 | Adults >18 on medication for HTN Pharmacy at VA medical center | G1: Face-to-face pharmacist visits for management of HTN medication, education and counseling G2: Usual care, no face-to-face pharmacist visits | Six face-to-face visits over 6 months | Percentage that received refills for HTN meds within 2 weeks of scheduled refill date | Pharmacy refill data | NR | 6 months: G1: 85% G2: 93% 95% CI, NR p>0.42 | NR
| | Adults >21 with diabetes mellitus and HTN Primary care clinics | G1: Nurse-delivered face-to-face educational session in presence of patient’s social support person; educational mailings G2: Same as G1 intervention G3: Same as G1 with exception of not involving patient’s social support person for face-to-face education | One face-to-face visit | Adherence level, Morisky scale (low, medium, high) | Self-report | Baseline: High (%): G1: 50.0 G2: 29.8 G3: 41.8 Medium (%): G1: 42.0 G2: 63.2 G3: 49.5 Low (%): G1: 8.0 G2: 7.0 G3: 8.8 95% CI, NR p (G1 vs. G2 vs. G3): 0.1584 p (G1+G2 vs. G3): 0.4358 | 12 months: High (%): G1: NR G2: NR G3: NR Medium (%): G1: NR G2: NR G3: NR Low (%): G1: NR G2: NR G3: NR 95% CI, NR p: NS | NR
| | Adults ≥ 55 with HTN Primary care clinic at VA medical center | G1: Personalized risk communication about CHD and stroke. G2: Nonpersonalized educational materials about CHD and stroke | One face-to-face visit | High adherence on Morisky scale | Self-report | Baseline: G1: 50% G2: 51% 95% CI, NR p: NR | 3 months: G1: 46% G2: 49% 95% CI, NR p=0.55 | NR

Abbreviations: ACE = angiotensin-converting enzyme; BP =blood pressure; CI = confidence interval; CHD = coronary heart disease; G = group; HMO = health maintenance organization; HTN = hypertension; MEMS = medication event monitoring system; MPR = medication possession ratio; N = number; NR = not reported; NS = not significant; PCP = primary care practitioner; rxs = prescriptions; SD = standard deviation; TLC = telephone-linked computer; VA = Department of Veterans Affairs.

Table 18 Hypertension: strength of evidence for blister packaging of medication intervention

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hypertension blister packaging vs. usual care | 1; 93 (85) | Medication adherence | RCT Low | Unknown | Direct | Precise | MPR: Stat sig 6 percentage points difference between groups, Low
Hypertension blister packaging vs. usual care | 1; 93 (85) | Medication persistence | RCT Low | Unknown | Direct | Precise | Percentage of patients who had prescriptions refilled on time: stat sig 14.3 percentage points difference between groups, Low
Hypertension blister packaging vs. usual care | 1; 93 (85) | Morbidity: SBP + DBP | RCT Low | Unknown | Direct | Imprecise | No stat sig difference in change in SBP or DBP or in percentage of patients with reduced SBP 29.8 percentage points difference in patients with reduced DBP at 12 months in G1 than G2, stat sig Insufficient
Hypertension blister packaging vs. usual care | 1; 93 (85) | Morbidity: Angina, MI, or stroke | RCT Low | Unknown | Direct | Imprecise | No stat sig difference between groups for angina, MI, or stroke Insufficient
Hypertension blister packaging vs. usual care | 1; 93 (85) | Health care utilization: ED visits + hospitalizations | RCT Low | Unknown | Direct | Imprecise | No stat sig difference between groups for either outcome Insufficient

Abbreviations: DBP = diastolic blood pressure; ED = emergency department; G = group; MI = myocardial infarction; MPR = medication possession ratio; RCT = randomized controlled trial; SBP = systolic blood pressure; stat sig = statistically significant

##### Other Outcomes

This trial reported one significant finding:100 the proportion of patients with reduced diastolic blood pressure at 12 months was higher in the intervention than the control group (48.0% vs. 18.2%, p=0.031 (insufficient evidence of benefit) (Table 18). It found no significant differences for absolute systolic or diastolic blood pressures at 6 or 12 months, proportion of patients with reduced systolic blood pressure at 6 or 12 months, or proportion with reduced diastolic blood pressure at 6 months (all insufficient evidence). It reported the occurrence of angina, myocardial infarction, and stroke, none of which differed between the groups (insufficient evidence); it found no difference in ED visits and hospitalizations between at 6 and 12 months (insufficient evidence).

#### Detailed Synthesis for Case Management for Hypertension

##### Medication Adherence

Among the three trials with interventions involving case management, two found evidence for improved medication adherence (Table 17).101–103 Both trials with adherence improvements used MEMS caps to measure adherence. In one in patients with depression and hypertension, the number of with ≥80% adherence to hypertension medications was higher in the intervention than control group at 6 weeks.101 In the other trial involving nurse case management for hypertension, the mean adherence to taking daily medications was higher in the intervention than the control group at 6 months.102 In the trial that did not find improved adherence, Morisky scale scores did not differ between groups at 6 months, although improved Morisky scores were noted in all groups.103 We graded strength of evidence as low for adherence benefit (Table 19).

Table 19 Hypertension: strength of evidence for case management interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hypertension case management vs. usual care | 3; 516 (64 + NR in 2 trials) | Medication adherence | RCT Medium | Consistent | Direct | Precise | Two of three RCTs with stat sig difference in adherence:; 1. MEMS ≥80% adherence: 46.8 percentage points more in G1 than G2; 2. MEMS adherence, mean: 11.3 percentage points higher in G1 than G2; Low
Hypertension case management vs. usual care | 2; 214 (64 + NR in 1 trial) | Morbidity: SBP + DBP | RCT Medium | Consistent | Direct | Precise | Two RCTs with stat sig difference in SBP between G1 and G2:; 1. −14 mm Hg difference; 2. −8.5 mm Hg difference; Low; Two RCTs with stat sig difference in DBP between G1 and G2:; 1. −9.2 mm Hg difference; 2. −3.1 mm Hg difference; Low

Abbreviations: DBP = diastolic blood pressure; G = group; MEMS = medication event monitoring system; NR = not reported; pts = patients; RCT = randomized controlled trial; SBP = systolic blood pressure; stat sig = statistically significant.

##### Other Outcomes

Both trials found improvements in systolic and diastolic blood pressure outcomes in the intervention group compared with the control group. In one trial, the mean systolic blood pressure was approximately 14 mm Hg lower in the intervention arm than the control arm at 6 weeks (127.3 mm Hg vs. 141.3 mm Hg, p=0.003); in addition, the mean diastolic blood pressure was approximately 9.2 mm Hg lower in the intervention arm than in the control arm at 6 weeks (75.8 mm Hg vs. 85.0 mm Hg, p=0.002).101 In the other trial, systolic blood pressure decreased from baseline to 6 months by approximately 8.5 mm Hg more in the intervention arm than in the control arm (−14.2 mm Hg vs. −5.7 mm Hg, p<0.01); diastolic blood pressure decreased from baseline to 6 months by approximately 3.1 mm Hg more in the intervention arm than in the control arm (−6.5 mm Hg vs. −3.4 mm Hg, p<0.05).102 We graded the strength of evidence as low for blood pressure benefit (Table 19).

#### Detailed Synthesis for Collaborative Care for Hypertension

##### Medication Adherence

Of the three trials that evaluated collaborative care interventions, none found improvements in medication adherence for hypertension medications (Table 17).89,104,105 One trial found no difference in Morisky scores between groups at 6 months;104 another found no difference in Morisky scores at 12 months;105 and a third found no difference between groups either in the percentage of days nonadherent to ACE inhibitors or in the adjusted difference in percentage of nonadherent days to ACE inhibitors between groups at 12 months.89 We graded strength of evidence as low for no benefit from collaborative care (Table 20).

Table 20 Hypertension: strength of evidence for collaborative care interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hypertension collaborative care vs. usual care | 3; 1194 (785) | Medication adherence | RCT Medium | Consistent | Direct | Imprecise | No stat sig differences between groups Low

Abbreviations: RCT = randomized controlled trial; stat sig = statistically significant.

#### Detailed Synthesis for Education and Behavioral Support for Hypertension

##### Medication Adherence

Of the five trials that evaluated education and behavioral support delivered by telephone, mail, and/or video,97,106–110 two trials used self-reported Morisky scales,106–108 one used pill counts109, one used both a self-reported behavioral measure of nonadherence and a stage-of-change assessment for medication adherence,110 and one used MPRs from pharmacy refill data.97 Two trials found improved adherence outcomes in the intervention arm compared with the control arm (Table 17).109,110 In one trial, groups did not differ in an unadjusted model evaluating the change in proportion of medications (pill counts) taken from baseline to 6 months but did differ significantly after adjustments for age, sex, baseline medication adherence, and baseline adherence by treatment group.109 In the other trial, adherence improved significantly as assessed by both a behavioral measure of nonadherence and a stage-of-change assessment for medication adherence at 12 and 18 months (but not at 6 months) in the intervention arm compared with the control arm.110 Among the three trials that did not find improved adherence outcomes, two found no difference between groups for the proportion reporting high adherence on Morisky scales at 6 months.106–108 The third trial did not find improved MPRs in the intervention group compared with the control group either among the overall trial population or among those with a prescription for benazepril or metoprolol.97

Given the variable findings for medication adherence, measure variability, and outcome imprecision, we graded the strength of evidence as low for benefit of these types of interventions (Table 21).

Table 21 Hypertension: strength of evidence for education and behavioral support (phone, mail, and/or video) interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hypertension education and behavioral support vs. usual care | 5; 6996 (5149 + NR in 2 trials) | Medication adherence, overall (all measures) | RCT Medium | Consistent | Direct | Imprecise | Multiple variable outcomes Two RCTs with stat sig difference in adherence:; 1. 6 percentage points more change in % pills taken in G1 than G2 from baseline to 6 months; 2. More in G1 than G2 reporting adherence at 12 and 18 months, no numbers reported; Low
Hypertension education and behavioral support vs. usual care | 1; 299 (267) | SBP | RCT Medium | Unknown | Direct | Imprecise | No stat sig difference between groups in change from baseline to 6 months Insufficient
Hypertension education and behavioral support vs. usual care | 1; 299 (267) | DBP | RCT Medium | Unknown | Direct | Imprecise | No stat sig difference between groups in change from baseline to 6 months Insufficient

Abbreviations: DBP = diastolic blood pressure; G = group; NR = not reported; RCT = randomized controlled trial; SBP = systolic blood pressure; stat sig = statistically significant.

##### Other Outcomes

Of the two trials that identified improved medication adherence, one reported additional blood pressure measures but did not find any significant differences between intervention and control groups for change in systolic blood pressure (11 mm Hg vs. 10.6 mm Hg, p=0.85) or diastolic blood pressure (5.4 mm Hg vs. 3.3 mm Hg, p=0.09) from baseline to 6 months (insufficient evidence) (Table 21).109

#### Detailed Synthesis for Education for Hypertension

##### Medication Adherence

In the three trials of educational interventions that included face-to-face pharmacist visits,78,111–113 two found significantly improved medication adherence (Table 17).78,111,112 One trial (using pill counts) found that the percentage of pills taken versus prescribed and the proportion of participants with ≥80% adherence were both higher in the intervention than the control arm over 6 months.78 The other trial (Morisky scores) found significantly higher scores in the intervention arm than the control arm at the followup visit between 4 and 6 months;111,112 within-group Morisky score improvements were noted in the intervention arm from baseline to followup.111,112 The trial that used self-reported survey questions to assess medication adherence and pharmacy refill data to assess medication persistence did not find improved medication adherence over 6 months.113 Given the variable findings for improved adherence, measure variability, and outcome imprecision, we graded the strength of evidence as low for benefit (Table 22).

Table 22 Hypertension: strength of evidence for education (face-to-face with pharmacist) interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 3; 348 (344) | Medication adherence | RCT Medium | Consistent | Direct | Imprecise | Variable outcomes, some stat sig differences favoring intervention Low
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 1; 56 (53) | Medication persistence | RCT Medium | Unknown | Direct | Imprecise | No difference between groups refilling meds on time Insufficient
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 2; 292 (268) | SBP | RCT Medium | Consistent | Direct | Precise | −6.4 or −8.9 mm Hg mean SBP difference (stat sig G1 vs. G2) in two studies Moderate
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 2; 292 (268) | DBP | RCT Medium | Consistent | Direct | Imprecise | −1.1 or −4.4 mm Hg mean DBP difference (G1 vs. G2) in two trials Insufficient
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 1, 133 (NR) | Quality of life | RCT Medium | Unknown | Indirect | Imprecise | No statistically significant differences for sexual dysfunction, dizziness and headaches Insufficient
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 1; 133 (130) | Patient satisfaction | RCT Medium | Unknown | Indirect | Precise | Stat sig improvement in four of five questions Low
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 1; 133 (124) | Health care utilization: hospital visits | RCT Medium | Unknown | Direct | Precise | 0.08 fewer hospital visits in intervention group Low
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 1; 133 (124) | Health care utilization: contacts with other health care providers | RCT Medium | Unknown | Direct | Precise | 0.41 fewer visits in intervention group Low
Hypertension education (face-to-face with pharmacist) discontinuation of or less intense intervention | 1; 133 (124) | Health care utilization: ER visits | RCT Medium | Unknown | Direct | Imprecise | Insufficient

Abbreviations: DBP = diastolic blood pressure; ER = emergency room; G = group; Hosp = hospital; mm Hg = millimeter mercury; RCT = randomized controlled trial; SBP = systolic blood pressure; stat sig = statistically significant; vs. = versus.

##### Other Outcomes

Both trials that reported improved medication adherence reported various blood pressure measures.78,111,112 Both found improvements in mean systolic blood pressure. In one trial, the mean systolic blood pressure at 14-month followup was 124.4 mm Hg in the intervention group and 133.3 mm Hg in the control group (p=0.005), with an approximate difference between groups of 8.9 mm Hg.78 The difference in systolic blood pressure between baseline (i.e., after 2-month run-in) and at 14-month followup in this trial was −6.9 mm Hg in the intervention group and −1.0 mm Hg in the control group (p=0.04). In the second trial, the mean systolic blood pressure measured at between 4 and 6 months was 138.5 mm Hg in the intervention group and 144.9 mm Hg in the control group (p=0.044), with an approximate difference between groups of 6.4 mm Hg.111,112 Mean systolic blood pressure declined significantly in the intervention group between baseline and 4- to 6-month followup by approximately 8.2 mm Hg (146.7 mm Hg to 138.5 mm Hg, p<0.01). The decline in mean systolic blood pressure from baseline to the same followup points was not significant in the control group (146.2 mm Hg to 144.9, p not reported). The magnitude of effect was consistent for systolic blood pressure between the two trials and outcomes were precise, so we graded the strength of evidence as moderate for benefit on this outcome (Table 22).

By contrast, in these two trials, diastolic blood pressures did not drop significantly for either group and were not significantly different between groups at followup, although this measure would be anticipated to change less than systolic blood pressure in response to treatment. Because the magnitude of effect was not significant and outcomes were imprecise, we graded the strength of evidence as insufficient for this outcome.

Quality of life was evaluated in one pharmacist intervention trial.111,112 Quality-of-life items included problems with sexual functioning, feeling dizzy upon standing up, and having headaches more than usual, none of which differed significantly between groups at followup (between 4 and 6 months).111,112 Of note, the proportion of intervention patients reporting problems with sexual functioning during the prior 4 weeks changed significantly from baseline to followup at between 4 and 6 months (34.0% at baseline and 2.5% at followup, p=0.003).

Patient satisfaction reported in one trial111,112 consisted of answers to individual questions from a pharmaceutical care questionnaire.15,17 We abstracted data for only five items that directly applied to a patient’s experience with medications for the disease for which medications had been prescribed. Questions were rated on a Likert scale (1 strongly agree; 5 strongly disagree). The intervention group scored significantly favorably compared with the control group in four questions in which they were asked about feeling secure about taking medications (1.39 vs. 1.69, p=0.004), understanding their illness (1.45 vs. 1.84, p=0.002), feeling that the pharmacist gave complete explanations about their medication (1.48 vs. 1.82, p=0.006), and feeling that the pharmacist should give more complete explanations about medications (4.16 vs. 3.81, p=0.042).15,17 We graded strength of evidence as low for evidence of benefit (Table 22).

Health care utilization measures were self-reported in one pharmacist education trial.111,112 Significantly fewer hospitalizations and fewer contacts with health care providers other than pharmacists occurred over 4 weeks in the intervention arm than the control arm; the groups did not differ in mean number of emergency room visits over 4 weeks. Of note, a one-tailed p value of <0.05 was considered a significant result in this trial. We graded the strength of evidence related to hospitalizations and contacts with health care providers other than pharmacists as low for evidence of benefit and evidence related to emergency room visits as insufficient because of imprecision (Table 22).

#### Education With Social Support for Hypertension

##### Medication Adherence

The trial evaluating the effect of involving a patient’s support person in an educational session did not find improved adherence in the intervention groups as measured with the Morisky scale at 12 months (insufficient evidence) (Table 23).91

Table 23 Hypertension: strength of evidence for education with social support interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hypertension education with social support vs. education without social support | 1; 199 (199) | Medication adherence | RCT Medium | Unknown | Direct | Imprecise | No stat sig differences between groups at 12 months Insufficient

Abbreviations: RCT = randomized controlled trial; stat sig = statistically significant.

#### Detailed Synthesis for Risk Communication for Hypertension

##### Medication Adherence

The trial evaluating the effect of risk communication about coronary heart disease and stroke to participants did not find improved adherence in the intervention groups as measured with the Morisky scale at 3 months (insufficient evidence) (Table 24).114

Table 24 Hypertension: strength of evidence for risk communication

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hypertension risk communication vs. educational materials | 1; 89 (89) | Medication adherence | RCT Medium | Unknown | Direct | Imprecise | No stat sig difference between groups at 3 months Insufficient

Abbreviations: RCT = randomized controlled trial; stat sig = statistically significant.

### Key Question 1 Heart Failure: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

We identified four trials that evaluated interventions to improve medication adherence among patients with heart failure.115–118 We rated three as medium risk of bias115,117,118 and one as low risk of bias.116

##### Population

All trials were conducted in adults ranging from ages 18 and older118 to ages 70 and older;117 participant ages ranged from a mean of 55 to 57 years of age118 to a median age of 80 years.117 Between 20 percent to 26 percent118 and 66 percent to 68 percent116,117 of the trial populations were women. Black participants made up from 23 percent to 33 percent115 and 45 percent to 52 percent116 of the trial populations in the two trials that reported this information.

##### Intervention

The four trials tested diverse interventions all targeted at patients; three additionally targeted systems of care.116–118 One trial had two intervention arms and one control arm.115 In this trial, a research assistant made video calls via provided equipment to persons in one intervention arm and telephone calls to individuals in the other arm; all calls reminded participants to take their medications daily.115 Another trial evaluated a multicomponent pharmacist-led intervention that provided participants with face-to-face education, literacy-sensitive written materials, and labeling of medications with icons to promote adherence.116 The third trial examined a case management intervention with the following components: as inpatients, patients received nurse-delivered education that focused on adherence, visits from a dietitian and social worker, and medication review by a geriatric cardiologist; following discharge, personnel from home care services visited patients at home and the trial nurse telephoned patients.117 The final trial evaluated an intervention in which patients were given access to their online medical record, an online educational guide for heart failure, and a messaging system to communicate with nursing staff.118

##### Comparator

Active arms were compared with usual care in all four trials. In the trial of video and telephone call reminders, the control group did not receive any calls.115 In the multicomponent pharmacist-led intervention, the control group had no contact with the intervention pharmacist beyond an initial visit to obtain medication history.116 In the case management trial, control participants received conventional care from their regular physician and standard hospital and discharge services.117 In the trial of access to online medical records, the control group had no access to online records; they received the same educational guide for heart failure as the intervention arm, but as a printed packet instead of an online document.118

##### Outcomes

None of the trials reported on persistence or initiation of medication. Measures of adherence included MEMS caps in two trials,115,116 self-reported measures in two trials (Morisky scale and adherence questionnaire),116,118 and pharmacy refill data116 or pill counts117 in one trial each. One trial used multiple measures of adherence (MEMS caps, pharmacy refill data, and self-reported adherence).116

Three trials reported additional outcomes. Two trials reported quality-of-life measures: the Minnesota Living with Heart Failure (MLHF) and the SF-36 questionnaires in one trial,115 and the Chronic Heart Failure questionnaire in the other trial.116 One trial reported patient satisfaction outcomes using a self-reported validated questionnaire.116 All-cause emergency department (ED) visits were reported in one trial116,118 and all-cause hospitalizations in two.116–118 Among the two trials reporting all-cause hospitalizations, one reported both the number of patients hospitalized and total number of hospitalizations,117,118 and one additionally reported total hospitalization days.117 One trial reported multiple composite measures, including combined all-cause ED visits and hospitalizations, combined cardiovascular-related ED visits and hospitalizations, and combined heart-failure-related ED visits and hospitalizations.116 One trial evaluated costs (inpatient, outpatient, and combined).116

##### Timing

The shortest trial lasted 1 month117 and the longest 12 months.118 One trial reported adherence outcomes both during and at the conclusion of the intervention.118 The other three trials reported adherence outcomes at the conclusion of the intervention.115–117 Two trials additionally reported adherence outcomes after interventions had concluded: one at 2 weeks following an intervention,115 and one in 3 months following completion of an intervention.116

ED visits and hospitalizations were reported for a 12-month period in the trial with a 9-month intervention followed by a 3-month postintervention evaluation period.116 In a trial with a 30-day intervention, ED visits and hospitalizations were reported for 90 days.117 The period of evaluation was unclear in the remaining trial that reported ED visits and hospitalizations.118

The trial with costs and patient satisfaction outcomes reported these measures for 12 months; it reported quality of life at 6 and 12 months.116

##### Setting

One trial focused on a population recruited from an urban home health agency and ambulatory care clinic.115 Three trials focused on populations cared for in a university-affiliated system: one recruited patients from an academic primary care practice and an urban hospital;116 one recruited patients admitted to a university teaching hospital with a heart failure exacerbation;117 and one recruited patients from a heart failure specialty clinic.118

Interventions took place in diverse settings: patient homes,115 a pharmacy,116 both inpatient and outpatient settings,117 and within a heart failure specialty clinic.118

##### Applicability

Notable limitations to applicability included the following: a low participation rate (10 percent) among those eligible in one trial;115 significant differences between participants versus those who declined to participate (lower income, less education, less access to home computers, and other differences among decliners) in another trial;118 and the high complexity of one intervention that involved at least four disciplines of health professionals and both inpatient and outpatient components.117 Each trial targeted different age groups. Participants were the youngest (mean age approximately 56 years) in the trial of Web-based access to medical records;118 participants in the multicomponent pharmacist-led trial were somewhat older (mean age approximately 62 years);116 the other two trials were conducted in older age groups with a mean age of approximately 75 years in the trial of reminder video and telephone calls115 and a median age of 80 years in the case management trial.117 Thus, the final two trials would be more generalizable to elderly patients with heart failure. All trials were based primarily in nonrural settings, so would have limited generalizability for rural settings.

#### Key Points

- Three of four trials found evidence suggestive of improved medication adherence (Table 25).
- No trials produced evidence of sustained adherence improvements following the end of the interventions; no trial evaluated outcomes beyond 3 months after the intervention ended.
- Because the components of the four interventions were so heterogeneous, we evaluated each separately for strength of evidence.
- Health care utilization results were inconsistent across the trials.

Table 25 Heart failure: summary of findings

Type of Intervention | Study | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Reminder video and telephone calls | Fulmer et al., 1999^115^ N=60 | + Adherence rate, 8 weeks | = Quality of life at 10 weeks
Multicomponent pharmacist-led | Murray et al., 2007^116^ | + Adherence for taking and scheduling medications, during 9-month intervention; = Adherence for taking and scheduling medications, during 3 months following intervention; + Medication possession ratio over 1 year; = Self-report at 9 months | = Quality of life at 6 months; = Quality of life at 12 months; = Patient satisfaction at 12 months; + Combined all-cause ED visits; hospitalizations over 12 months; = All-cause hospitalization, combined cardiovascular ED visits and hospitalization; combined heart failure ED visits and hospitalizations over 12 months; = Outpatient health care costs; inpatient health care costs; combined outpatient and inpatient costs over 12 months
Case management | Rich et al., 1996^117^ N=156 | + Percentage of pills taken correctly, proportion with ≥80% medication compliance, and proportion with ≥90% medication compliance over 30 days | = Health care utilization (over 90 days): number of patients with all-cause readmissions; number of all-cause readmissions; days hospitalization from all-cause readmissions
Access to medical records | Ross et al., 2004^118^ N=107 | = Morisky scores at 6 and 12 months | NA

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference, (−) = statistically significant difference favoring comparison arm; ED = emergency department; N = number.

##### Reminder Intervention (Video and Telephone Calls)

- Medication adherence: One trial with limited followup reported improved medication adherence (low strength of evidence for benefit).
- Quality of life: This trial found no evidence of significant differences between trial arms at followup on two measures of quality of life (insufficient evidence).

##### Multicomponent, Pharmacist-Led Intervention

- Medication adherence: Medication adherence was better in the intervention group than control group on objective measures (MEMS caps, pharmacy refill data), but not on a self-reported measure during the 9-month intervention (low strength of evidence of benefit at 9 months). This trial did not show evidence that the intervention effect was sustained in the 3 months after the intervention (at 12-month followup, loss of all significant differences between groups (insufficient evidence of longer benefit).
- Quality of life: Disease-specific quality of life did not differ significantly between intervention and control groups at two time points (insufficient evidence).
- Patient satisfaction: The intervention group had better patient satisfaction outcomes than the control group (low strength of evidence of benefit).
- Health care utilization: The trial demonstrated evidence of benefit for all-cause ED visits and combined all-cause ED and hospitalization (low strength of evidence); however, it provided no evidence of benefit for all other health care utilization measures, including all-cause hospitalizations, combined cardiovascular ED visits and hospitalizations, and combined heart failure-related ED visits and hospitalizations (insufficient evidence).
- The trial demonstrated no benefit for inpatient costs, outpatient costs, and combined inpatient and outpatient costs (insufficient evidence).

##### Case Management (Multisetting, Multidisciplinary Intervention)

- Medication adherence: This relatively small trial demonstrated evidence of short-term (30-day) benefit (low strength of evidence).
- Health care utilization: Groups did not differ on several measures of all-cause readmissions (number of patients with readmissions, number of readmissions, and days of hospitalization from readmissions) (insufficient evidence).

##### Access to Medical Records

- Medication adherence: This trial showed no differences between groups on Morisky scales at 6 and 12 months (insufficient evidence of benefit).
- Other outcomes: Mortality, quality of life, patient satisfaction, all-cause hospitalizations, ED visits, and heart failure-related visits did not differ between groups (insufficient evidence).

#### Detailed Synthesis for Video and Telephone Reminder Intervention for Heart Failure

##### Medication Adherence

The two intervention groups showed higher rates of medication adherence (84 percent and 74 percent, MEMS caps measures) than the control group (57 percent) 2 weeks following an intervention (Table 26 and Table 27) (low strength of evidence of benefit).115 The control group decline in adherence from baseline (81 percent) to followup (57 percent) made up much of the difference between intervention and control groups (Table 26).

Table 26 Heart failure: detailed medication outcomes

Type of Intervention | Study N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, Direction) | Source | Baseline | First Followup | Additional Followups
Reminder calls | Fulmer et al., 1999^115^ G1: 17 G2: 15 G3: 18 | Adults >65 with HF Urban Ambulatory | G1: Daily video reminder G2: Daily phone reminder G3: No reminder calls | Daily calls (Mon–Fri), 6-week duration | Compliance rates (0 to 100%, % of total pills taken) | MEMS | G1: 82% G2: 76% G3: 81% | 8 weeks: G1: 84% G2: 74% G3: 57% (p<0.04) 95% CI, NR G1 + G2 vs. G3: F=4.08, p<0.05 G1 vs. G2:p>0.05 | NR
Multicomponent pharmacist-led | Murray et al., 2007^116^ G1: 122 G2: 192 Morisky and MPR outcomes G1: NR G2: NR | Adults ≥50 with HF Pharmacy | G1: Pharmacist-delivered verbal and written instructions, medication labeling with icons G2: No contact with intervention pharmacist after initial medication history | Number of face-to-face visits not totaled, 9-month duration | Taking adherence: Percentage of prescribed doses taken (0 to 100%, total percentage of pills taken) | MEMS | NR | 9 months during intervention: Proportion (95% CI) G1: 78.8% (74.9 to 82.7) G2: 67.9% (63.8 to 72.1) Difference: 10.9% (5.0 to 16.7) p: NR | 3 months following intervention: Proportion (95% CI) G1: 70.6% (64.9 to 76.2) G2: 66.7% (62.3 to 70.9) Difference: 3.9% (−2.8 to 10.7) p: NR
Multicomponent pharmacist-led | Murray et al., 2007^116^ G1: 122 G2: 192 Morisky and MPR outcomes G1: NR G2: NR | Adults ≥50 with HF Pharmacy | G1: Pharmacist-delivered verbal and written instructions, medication labeling with icons G2: No contact with intervention pharmacist after initial medication history | Number of face-to-face visits not totaled, 9-month duration | Scheduling adherence: Adherence to medication dose timing (0 to 100%, total percentage of pills taken within a similar time frame) | MEMS | NR | 9 months during intervention: Proportion (95% CI) G1: 53.1% (49.1 to 57.1) G2: 47.2% (43.4 to 0.9) Difference: 5.9% (0.4 to 11.5) p: NR | 3 months following intervention: Proportion (95% CI) G1: 48.9% (43.7 to 54.1) G2: 48.6% (44.7 to 52.6) Difference: 0.3 (−5.9 to 6.5) p: NR
Multicomponent pharmacist-led | Murray et al., 2007^116^ G1: 122 G2: 192 Morisky and MPR outcomes G1: NR G2: NR | Adults ≥50 with HF Pharmacy | G1: Pharmacist-delivered verbal and written instructions, medication labeling with icons G2: No contact with intervention pharmacist after initial medication history | Number of face-to-face visits not totaled, 9-month duration | MPR (0 to 100%, prescriptions prescribed to prescriptions received) | Pharmacy refill records | NR | 1 year: G1: 109.4% G2: 105.2% Difference: 4.2% 95% CI, NR p=0.007 | NR
Multicomponent pharmacist-led | Murray et al., 2007^116^ G1: 122 G2: 192 Morisky and MPR outcomes G1: NR G2: NR | Adults ≥50 with HF Pharmacy | G1: Pharmacist-delivered verbal and written instructions, medication labeling with icons G2: No contact with intervention pharmacist after initial medication history | Number of face-to-face visits not totaled, 9-month duration | Change in median of composite scores from Morisky and other validated questionnaire (range NR) | Self-report | NR | Change in median score from baseline to 9 months: G1: 1.0 G2: 0.8 95% CI, NR p=0.48 | NA
Case management | Rich et al., 1996^117^ G1: 80 G2: 76 | Adults ≥70 admitted with HF University teaching hospital | G1: Multidisciplinary intervention (inpatient and outpatient): HF teaching, med review, home care visits and phone contact by nurse G2: Standard hospital services (teaching and med instructions) | Visits not totaled, 30-day duration | Percentage of pills taken correctly for each current medication averaged (method #1) | Pill count | NR | 30 days after discharge: G1: 87.9% (SD 12.0) G2: 81.1% (SD 17.2) 95% CI, NR p=0.003 | NR
Case management | Rich et al., 1996^117^ G1: 80 G2: 76 | Adults ≥70 admitted with HF University teaching hospital | G1: Multidisciplinary intervention (inpatient and outpatient): HF teaching, med review, home care visits and phone contact by nurse G2: Standard hospital services (teaching and med instructions) | Visits not totaled, 30-day duration | Proportion with ≥80% medication compliance by method #1 | Pill count | NR | 30 days after discharge: G1: 85.0% G2: 69.7% 95% CI, NR p=0.036 | NR
Case management | Rich et al., 1996^117^ G1: 80 G2: 76 | Adults ≥70 admitted with HF University teaching hospital | G1: Multidisciplinary intervention (inpatient and outpatient): HF teaching, med review, home care visits and phone contact by nurse G2: Standard hospital services (teaching and med instructions) | Visits not totaled, 30-day duration | Percentage of pills taken correctly for all current medications, pooled (method #2) | Pill count | NR | 30 days after discharge: G1: 87.5% (SD 12.6) G2: 80.9% (SD 16.7) 95% CI, NR p=0.003 | NR
Case management | Rich et al., 1996^117^ G1: 80 G2: 76 | Adults ≥70 admitted with HF University teaching hospital | G1: Multidisciplinary intervention (inpatient and outpatient): HF teaching, med review, home care visits and phone contact by nurse G2: Standard hospital services (teaching and med instructions) | Visits not totaled, 30-day duration | Proportion with ≥80% medication compliance by method #2 | Pill count | NR | 30 days after discharge: G1: 82.5% G2: 66.2% 95% CI, NR p=0.033 | NR
Case management | Rich et al., 1996^117^ G1: 80 G2: 76 | Adults ≥70 admitted with HF University teaching hospital | G1: Multidisciplinary intervention (inpatient and outpatient): HF teaching, med review, home care visits and phone contact by nurse G2: Standard hospital services (teaching and med instructions) | Visits not totaled, 30-day duration | Proportion with ≥90% medication compliance, unclear if method #1 or #2 used | Pill count | NR | 30 days after discharge: G1: 56.3% G2: 34.2% 95% CI, NR p=0.032 | NR
Access to medical records | Ross et al., 2004^118^ G1: NR G2: NR | Adults ≥18 with HF HF clinic | G1: Access to online medical record, educational guide for HF, and messaging system with nursing staff. G2: No access to online medical record or messaging system; printed HF educational guide | Visits not totaled, 12 months | Morisky score (0 to 4 points, higher score indicates better adherence) | Self-report | NR | 6 months: G1: 3.5 mean G2: 3.4 mean Difference: 0.1 95% CI, −0.2 to 0.4 p: NR | 12 months: G1: 3.6 mean G2: 3.4 mean Difference: 0.2 95% CI, −0.1 to 0.6 p=0.15

Abbreviations: CI = confidence interval; F = F-statistic; G = group; HF = heart failure; MEMS = medication event monitoring system; MPR = medication possession ratio; NR = not reported; SD = standard deviation.

Table 27 Heart failure: strength of evidence for reminders delivered by video and telephone

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Heart failure: Video and telephone reminders vs. no reminder calls | 1; 60 (50) | Medication adherence | RCT Medium | Unknown | Indirect | Precise | Difference of 17 to 27 percent comparing video and phone to control in MEMS adherence over 8 weeks Low
Heart failure: Video and telephone reminders vs. no reminder calls | 1; 60 (42) | Quality of life | RCT Medium | Unknown | Direct | Imprecise | No statistically significant difference Insufficient

Abbreviations: MEMS = medication event monitoring system; RCT = randomized controlled trial

##### Other Outcomes

The Minnesota Living with Heart Failure (MLHF) questionnaire is a 21-item scale with each item scored 0 to 5 (a lower score indicates lower impact of heart failure treatment on quality of life). MLHF scores did not differ for intervention and control groups at 10 weeks but they improved significantly in all groups from baseline to 10 weeks (G1, video: 43.1 to 36.7 (−6.4); G2, phone: 54.4 to 32.9 (−21.5), G3 control: 46.4 to 32.9 (−13.5); p<0.001 for all within-group improvements (insufficient evidence, Table 27).115 Scores from the SF-36 questionnaire did not differ between groups at 10 weeks and did not change significantly in any group from baseline to followup (insufficient evidence, Table 27).115

#### Detailed Synthesis for Multicomponent Pharmacist-Led Intervention for Heart Failure

##### Medication Adherence

In a multicomponent pharmacist-led intervention, MEMS caps adherence measures of “taking adherence” (percentage of prescribed medication doses taken based on physician’s prescription) and “scheduling adherence” (taking medications within a similar time frame each day) were significantly better in the intervention group (78.8 percent taking and 53.1 percent scheduling adherence) than in the control group (67.9 percent taking and 47.2 percent scheduling adherence) at the end of a 9-month intervention (Table 26 and Table 28, low strength of evidence for benefit at 9 months).116 However, when the same outcomes were measured 3 months following completion of the intervention, differences between the intervention and control groups were no longer significant. The MPR (pharmacy refill data) was significantly higher in the intervention group (109.4 percent) than in the control group (105.2 percent) over 1 year (insufficient evidence).116 Self-reported adherence did not differ between intervention and control groups at 9 months (insufficient evidence, Table 28).116

Table 28 Heart failure: strength of evidence for pharmacist-led multicomponent intervention

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Heart failure pharmacist-led intervention vs. usual care | 1; 314 (314 for MEMS caps, NR for MPR or self-report) | Medication Adherence | RCT Medium | Unknown | Direct | Precise | Stat sig difference in percentage points for taking medication (MEMS) at 9 months: 10.9 Stat sig difference in percentage points for adherence to timing (MEMS) at 9 months: 5.9 Stat sig difference in percentage points for MPR over 12 months: 4.2 No significant difference for self-report Low
Heart failure pharmacist-led intervention vs. usual care | 1; 314 (NR) | Quality of life | RCT Medium | Unknown | Direct | Imprecise | No stat sig difference Insufficient
Heart failure pharmacist-led intervention vs. usual care | 1; 314 (NR) | Patient satisfaction | RCT Medium | Unknown | Direct | Precise | Stat sig difference between groups of 0.3 on 12-point validated questionnaire Low
Heart failure pharmacist-led intervention vs. usual care | 1; 314 (314) | Health care utilization: All-cause ED visits, hosp, and Combined ED visits and hosp | RCT Medium | Unknown | Direct | Precise for all-cause ED visits and all-cause ED+hosp; Imprecise for all-cause hosp | Stat sig difference of 0.52 mean all-cause ED visits and 0.69 mean all-cause ED+hosp between groups Low All-cause hosp: no stat sig difference Insufficient
Heart failure pharmacist-led intervention vs. usual care | 1; 314 (314) | Health care utilization: CV-related and HF-related events | RCT Medium | Unknown | Direct | Imprecise | No stat sig difference Insufficient
Heart failure pharmacist-led intervention vs. usual care | 1; 314 (314) | Costs | RCT Medium | Unknown | Direct | Imprecise | No stat sig difference Insufficient

Abbreviations: CV = cardiovascular; ED = emergency department; HF = heart failure; hosp = hospitalization; MEMS = medication event monitoring system; MPR = medication possession ratio; NR = not reported; RCT = randomized controlled trial; stat sig = statistically significant.

##### Other Outcomes

Questionnaire-based Heart Failure quality-of-life data did not differ significantly between groups for changes from baseline to 6 or 12 months (insufficient evidence, Table 28).116 This trial reported patient satisfaction with pharmacy services with a 12-item validated instrument; improvement from baseline to 12 months was significant in the intervention group compared with the control group (score improvements of 1 vs. 0.7, p=0.02) (low strength of evidence for benefit).116 This trial found significantly fewer all-cause ED visits (incidence rate ratio [IRR] 0.82, 95% CI, 0.70, 0.95) and combined all-cause ED visits and hospitalizations (IRR, 0.82, 95% CI, 0.72 to 0.93) over 12 months in the intervention group than in the control group (low strength of evidence for benefit on these measures).116 Intervention and control groups did not differ significantly for all-cause hospitalizations, combined cardiovascular-related ED visits and hospitalizations, or combined heart failure-related ED visits and hospitalizations over 12 months (insufficient evidence).116 Finally, outpatient health care costs, inpatient costs, and the sum of inpatient and outpatient costs did not differ significantly between intervention and control groups for the year (insufficient evidence).116

#### Detailed Synthesis for Case Management for Heart Failure

##### Medication Adherence

In the trial of a multidisciplinary, multisetting intervention, pill count measures were used to derive multiple measures of adherence, including the percentage of medications taken correctly (averaged by medication and pooled overall) and the proportion of participants with ≥80 percent adherence and ≥90 percent adherence (Table 26).117 All measures improved significantly in the intervention group compared with the control group at 30-day followup (low strength of evidence of benefit) (Table 29).117

Table 29 Heart failure: strength of evidence for case management

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Heart failure case management: multidisciplinary, multisetting intervention vs. usual care | 1; 156; (156) | Medication adherence | RCT Medium | Unknown | Direct | Precise | Stat sig difference in percentage points for med adherence between groups: 6.6 to 6.8 (range), pill count over 30 days Stat sig difference in percentage points for proportion with ≥80% adherence between groups: 15.7 to 16.3, pill count over 30 days Low
Heart failure case management: multidisciplinary, multisetting intervention vs. usual care | 1; 156 (156) | Health care utilization: All-cause hospital readmission | RCT Medium | Unknown | Direct | Imprecise | No significant difference in multiple measures of all-cause readmission Insufficient

Abbreviations: med = medication; RCT = randomized controlled trial; stat sig = statistically significant.

##### Other Outcomes

This trial did not find significant differences between groups in the number of patients with all-cause hospital admissions, total all-cause hospital admissions, or days of all-cause hospital admissions (insufficient evidence) (Table 29).117

#### Detailed Synthesis for Access to Medical Records for Heart Failure

##### Medication Adherence

In the trial in which access to an online medical record was provided to the intervention group, self-reported Morisky scores were collected at 6 and 12 months (Table 26).118 The groups did not differ on the Morisky scores at 6 or 12 months (insufficient evidence) (Table 30).

Table 30 Heart failure: strength of evidence for access to computer records

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Heart failure access to computer records vs. usual care | 1; 107; (NR) | Medication adherence | RCT Medium | Unknown | Direct | Imprecise | Morisky scores: No significant difference at 6 or 12 months Insufficient

Abbreviations: NR = not reported; RCT = randomized controlled trial.

### Key Question 1 Myocardial Infarction: Medication Adherence Interventions

#### Description of Included Study

##### Overview

One trial (medium risk of bias) tested an intervention to improve medication adherence among patients with a recent myocardial infarction.119

##### Population

This trial was conducted in adults ages 18 and older with a mean participant age of approximately 65 years. Women made up approximately 32 percent of the trial population.

##### Intervention and Comparator

The intervention in this trial was targeted at both patients and providers. The intervention provided education and behavioral support; two mailed communications approximately 2 months apart primarily stressed the importance of using beta blockers following myocardial infarctions. Primary care clinicians caring for patients in the intervention arm received a letter that encouraged their support of the initiative.

In the control arm, neither patients nor their primary care clinicians received these communications.

##### Outcome and Timing

Medication adherence outcomes (pharmacy refill data) included the absolute increase in proportion of days covered per month from baseline to followup and the likelihood of having ≥80 percent of medications across the entire 9-month period. Medication persistence outcomes (pharmacy refill data) included the proportion of patients with gaps of 1, 2, 3, and 4 months in length between filling beta-blocker prescriptions. The intervention lasted approximately 1 month, which spanned the time between two mailings to patients, and the trial measured adherence and persistence across 9 months.

##### Setting

This trial was based in primary care clinics.

##### Applicability

This trial is generally applicable to ambulatory care patients who have suffered a myocardial infarction (more so for men than women) and provides more than just short-term data.

#### Key Points

- Medication adherence and persistence: In the trial providing education and behavioral support following a myocardial infarction, medication adherence was significantly better in the intervention than the control group at 9 months (Table 31, low strength of evidence for benefit). Intervention and control groups did not differ significantly in persistence (insufficient evidence).

Table 31 Myocardial infarction: summary of findings

Type of Intervention | Studies, N Randomized | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Education and behavioral support | Smith et al., 2008^119^ N=907 | + Absolute increase in proportion of days covered over 9 months; + Likelihood of having ≥ 80% of days covered over 9 months; = Proportion of groups with gaps of 1, 2, 3, or 4 months in refilling beta-blocker | NR

Abbreviation: NR = not reported.

#### Detailed Synthesis for Interventions Directed at Patients and Providers Through Mailed Communications for Myocardial Infarction

The trial involving patients with recent myocardial infarction showed statistically significant improvement in medication adherence outcomes but not in persistence outcomes in the intervention group compared with the control group (Table 32).119 Compared with the controls, patients in the intervention group had a 4.3 percent mean absolute increase in proportion of days covered per month from baseline to 9 months; they had a higher likelihood of having ≥80 percent or more of medications across the entire 9-month period (low strength of evidence for benefit) (Table 33). The groups did not differ in the proportion of patients with gaps of 1, 2, 3, or 4 months between beta-blocker prescriptions (insufficient evidence).

Table 32 Myocardial infarction: detailed medication adherence outcomes

Type of Intervention | Study N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, direction) | Source | Baseline | Followup
Education and behavioral support | Smith et al., 2008^119^ G1: 426 G2: 410 Gap in refilling prescription G1: NR G2: NR | Adults ≥18 years with a myocardial infarction Primary care clinics | G1: Two mailings to patients encouraging beta-blocker adherence; mailing to primary care providers G2: Usual care (no mailings) | Two mailings | Absolute increase in proportion of days covered per month | Pharmacy refill data | NR | 9 months: G1: 4.3% mean absolute increase in days covered per month compared with G2 95% CI, NR p=0.04
Education and behavioral support | Smith et al., 2008^119^ G1: 426 G2: 410 Gap in refilling prescription G1: NR G2: NR | Adults ≥18 years with a myocardial infarction Primary care clinics | G1: Two mailings to patients encouraging beta-blocker adherence; mailing to primary care providers G2: Usual care (no mailings) | Two mailings | Likelihood of having at least 80% proportion of days covered | Pharmacy refill data | NR | 9 months: G1: 64.8% G2: 58.5% Relative risk: 1.17 95% CI, 1.02 to 1.29
Education and behavioral support | Smith et al., 2008^119^ G1: 426 G2: 410 Gap in refilling prescription G1: NR G2: NR | Adults ≥18 years with a myocardial infarction Primary care clinics | G1: Two mailings to patients encouraging beta-blocker adherence; mailing to primary care providers G2: Usual care (no mailings) | Two mailings | Among patients with a beta-blocker prescription at start of intervention: Proportion of group with a gap in refilling beta-blocker | Pharmacy refill data | NR | 1-month gap: G1:104 (23%) G2: 110 (25%) HR, 0.85 (0.65 to 1.12) Adjusted HR, 0.89 (0.67 to 1.19) 2-month gap: G1:63 (14%) G2: 67 (15%) HR, 0.86 (0.61 to 1.22) Adjusted HR, 0.95 (0.67 to 1.33) 3-month gap: G1: 43 (9%) G2: 51 (12%) HR, 0.77 (0.51 to 1.16) Adjusted HR 0.87 (0.60 to 1.26) 4-month gap: G1: 30 (7%) G2: 37 (9%) HR, 0.74 (0.46 to 1.20) Adjusted HR, 0.85 (0.54 to 1.35)

Abbreviations: CI=confidence interval; G=group; HR=hazard ratio; NR=not reported

Table 33 Medication adherence interventions for myocardial infarction: strength of evidence for education and behavioral support

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Myocardial infarction: Education and behavioral support | 1; 907(836) | Medication adherence | RCT Medium | Unknown | Direct | Precise | Stat sig difference in percentage points mean increase in adherence over 9 months: 4.3% Stat sig difference in percentage points with ≥80% adherence: 6% Low
Myocardial infarction: Education and behavioral support | 1; 907(NR) | Medication persistence | RCT Medium | Unknown | Direct | Imprecise | No difference Insufficient

Abbreviations: RCT = randomized controlled trial; stat sig = statistically significant.

### Key Question 1 Reactive Airway Diseases: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

Eight trials implemented interventions to improve medication adherence among patients with asthma120–127 or for asthma or COPD.125 We rated three as having low risk of bias123,125,126 and five as having medium risk of bias.120–122,124,127

##### Population

Of the eight trials, four did not appear to select for asthma severity or control;120,124–126 populations for the remaining four were restricted to moderate-to-severe asthma (two trials),121,123 low-to-moderate severity (one),122 and poorly controlled asthma (one).127 One trial presented results separately for asthma and COPD.125

##### Interventions

Five trials focused on patients as the target of the intervention examined the effectiveness of self-management programs that provide education or other strategies for self-management.120–124 Three used traditional care settings with nurses and other professionals;121–123 one employed an interactive voice response system;120 and one tested combinations of audiotapes and booklets.124

The remaining three trials focused on providers and systems in addition to patients.125–127 Of these three, one trial evaluated shared and clinical decisionmaking between patients and clinicians,127 and two evaluated changes in patient adherence when information delivery systems were altered to provide pharmacists125 or physicians126 with patient adherence information. The pharmacist trial provided patients in the two arms with peak flow monitors and pharmacists in all three arms with disease-specific training.125

##### Comparator

Six trials compared active arms to a control arm characterized as “usual care.”120–124,126 In two trials, usual care was minimally described;120,121 in the remaining four trials, usual care could be inferred from the description to be a care environment that was unaltered by the intervention with the exception of data collection.122–124,126 Data collection for control arms varied: e.g., minimal effort in one that relied on pharmacy refill data for outcomes126 to fairly intense efforts in two that used daily monitoring of symptoms, medication use, and peak flow data during the intervention period.122,123 Usual care varied in setting and intensity across the six trials.

Another trial described the control arm as usual care but provided physicians in the control arm with audio, video, and written materials and tools to discuss adherence.127 The only trial without a usual-care arm involved a pharmacist intervention in which pharmacists in all arms received training.125 This trial included escalating levels of intervention components: the patients in both active arms received peak flow meters, but patient-specific information about peak flow use was available to pharmacists only in one of two active arms.

##### Outcome and Timing

All trials reported on adherence. Seven of eight trials included percentage adherence as a measure, that is, number of doses taken relative to number prescribed. These trials used metered dose inhaler data, pharmacy refill data, or a combination of self-reported adherence and electronic monitoring data to construct the measure, generally using objective measures for the numerator. A single trial relied on self-reported measures of adherence alone.125

Among the trials that we evaluated for health and other outcomes, the primary morbidity measure was symptom severity or control, using self-reported measures. Trials used a wide range of measures and instruments; two trials used the same instrument (the Asthma Therapy Assessment Questionnaire).124,127 One trial evaluated refills of short-acting beta-agonists (SABA) using refill data.127

The self-management interventions were generally short, ranging from 4 to 7 weeks. Outcomes were measured at various time points: during the intervention, at the last visit or contact, or shortly after the intervention ended. The shared decisionmaking trial recorded 2- year adherence information for an intervention with an active component that lasted 9 months.127 The two trials of system change recorded medication adherence at 1 year.125,126

##### Setting

Of the five self-management trials, four were conducted in one or more clinics120,122–124 and another recruited directly from the community.121 Interventions that focused on providers or the health system recruited local pharmacies in one case125 and worked within health systems in the other two.126,127

##### Applicability

Two trials reported eligibility criteria in poor detail, making judgments about applicability challenging.120,124 The remaining trials represent a broad range of severity overall, but the paucity of evidence for some types of interventions limits statements about applicability of findings to subpopulations along the spectrum of severity. The most significant limitation to applicability, particularly for patient-directed self-management interventions, is the lack of long-term outcome data.

#### Key Points

- Eight trials provided evidence on medication adherence and other outcomes from interventions focusing on self-management, pharmacist or physician access to patient adherence information, and shared decisionmaking (Table 34).

Table 34 Reactive airway diseases: summary of findings

Type of Intervention | Study | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Self-management vs. usual care | Bender et al., 2010^120^ N=50 | + Adherence rate, 10 weeks | = Symptoms, 10 weeks; = Quality of life, 10 weeks
Self-management vs. usual care | Berg et al., 1997^121^ N=55 | + Adherence rate, 7 weeks | = Symptoms, 7 weeks
Self-management vs. usual care | Janson et al., 2003^122^ N=65 | + Adherence rate, 7 weeks | = Forced expiratory volume, 7 weeks; = Symptom severity, 7 weeks; + Perceived asthma control, 7 weeks; = Quality of life, 7 weeks
Self-management vs. usual care | Janson et al., 2009^123^ N=84 | = Percentage adherence, 4 weeks and 14 weeks; + Odds of maintaining >60% adherence, 4 weeks; + Odds of maintaining >60% adherence, 14 weeks | = Forced expiratory volume, 4 weeks; = Forced expiratory volume, 14 weeks; = Frequency of nighttime awakenings, 4 weeks; + Frequency of nighttime awakening, 14 weeks; = Symptom-free days and symptom severity, 4 weeks and 14 weeks; + Beta-agonist use, 4 weeks; = Beta-agonist use, 14 weeks; = Quality of life, 4 weeks and 14 weeks
Self-management vs. usual care | Schaffer et al., 2004^124^ N=46 | = Percentage adherence for all except one arm compared with control in a four-arm trial, 3 months; + Percentage adherence for two of three arms compared with control in a four-arm trial, 6 months; = Number of doses of preventive medication missed in previous 2 weeks, 3 and 6 months | = Asthma control, 3 months and 6 months; = Quality of life, 3 months and 6 months
Pharmacist or physician access to patient adherence information vs. usual care or pharmacist training | Weinberger et al., 2002^125^ N= 36 Pharmacies; 1,113 Patients | = Proportion of noncompliance; = Self-reported compliance | NA
Pharmacist or physician access to patient adherence information vs. usual care or pharmacist training | Williams et al., 2010^126^ N=207 Providers; 2,698 Patients | = Percentage adherence, 1 year | NA
Shared decision-making vs. usual care | Wilson et al., 2010^127^ N=612 | + Medication acquisition ratio for all drugs, 1 year and 2 years; + Acquisition of inhaled corticosteroids, 1 year; + Acquisition of beclomethasone, 1 year and 2 years; + Acquisition of long-acting beta-agonists, 1 and 2 years | + Forced expiratory volume, 1 year; + Symptom improved: acquisition of short acting beta-agonists, 1 and 2 years; + Asthma control, 1 year; + Quality of life, 1 year; + Health care utilization: asthma-related visits

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; N = number, NA = not applicable.

##### Self-Management

- Medication adherence: Adherence improved significantly during or immediately after the intervention was completed (five trials) (moderate strength of evidence for benefit); no information was available on longer-term effects (insufficient evidence).
- Biomarkers: Groups did not differ in pulmonary function and inflammation markers (insufficient evidence).
- Symptom improvement: Groups did not differ (insufficient evidence).
- Quality of life: Groups did not differ (four trials) (low strength of evidence of no benefit).

##### Pharmacist or Physician Access to Patient Adherence Information

- Medication adherence: Adherence did not improve significantly within the first year of initiating treatment (two trials) (low strength of evidence of no benefit).

##### Shared Decisionmaking

- Medication adherence: Adherence improved significantly within the first year of initiating treatment (one trial) (low strength of evidence of benefit).
- Biomarkers: Pulmonary function improved significantly within the first year of initiating treatment (low strength of evidence of benefit).
- Symptom improvement: Rescue medication use decreased significantly within 2 years of initiating treatment (low strength of evidence of benefit).
- Quality of life: Quality of life improved at 1-year assessment (low strength of evidence of benefit).
- Health care utilization: Asthma-related visits decreased within the first year of initiating treatment (low strength of evidence).

#### Detailed Synthesis: Interventions Directed at Patients Through Self-Management of Asthma

##### Medication Adherence

Of the five self-management interventions for asthma that were directed at patients, four showed statistically significant improvement in percentage adherence in the intervention arm compared with the control arm (Table 35).120–122,124 In the remaining trial, percentage adherence did not differ significantly; however, the odds of adhering to a 60-percent threshold were higher for the intervention group than the control group at 4 weeks (during the intervention) but not at 14 weeks (after the end of the intervention).123 Four of five trials limited measurement of outcomes to the end of the intervention period or a month thereafter.120–123 The remaining trial found that the group receiving a combination of audiotape and booklet had significantly greater adherence than usual care at both 3 and 6 months124; the booklet group also had significantly higher adherence than usual care at 6 months. Other measures for this trial, such as the number of preventive medication doses missed in the previous 2 weeks, were not significant at 3 or 6 months for any group compared with usual care.

Table 35 Asthma: medication adherence

Study | N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, direction) | Source | Baseline | First Followup | Additional Followups
Self-management | Bender et al., 2010^120^ G1: 25 G2: 25 | Adults ages 18 to 65 years Tertiary care center | G1: Interactive-voice-response phone calls to monitor symptoms and encourage adherence G2: Usual care (not described) | Two to three calls for 10 to 15 minutes, 10-week duration | Mean change in percentage adherence | Electronic metered devices | NR | 4 weeks: G1: −0.18 G2: −1.40 95% CI, NR p=0.72 | 14 weeks: G1: −4.28 G2: −4.14 95% CI, NR p=0.97
Self-management | Berg et al., 1997^121^ G1: 31 G2: 24 | Adults >18 years Setting not specified, held in the community | G1: Sessions on asthma education, self-management behaviors, relaxation techniques, problem-solving skills G2: Usual care with physician | Six face-to-face visits, 7-week duration | Percentage adherence, 0 to 100% (SD) | Monitored inhaler and self-reported prescription information | G1: 43 (29) G2: 40 (26) 95% CI, NR p<0.05 | 7 weeks G1: 49 (31) G2: 32 (28) 95% CI, NR p<0.05 | NR
Self-management | Janson et al., 2003^122^ G1: 33 G2: 32 | Adults ages 18 to 55 years Clinic laboratory | G1: Asthma education, skills for correct medication inhalation and peak-flow meter use; peak-flow data reported to patients; written asthma action plan; patients maintained daily diary of symptoms, peak flow, and medication use G2: Usual care: All questions referred to regular physician; no explicit education or instruction about asthma; no feedback on peak-flow data patients maintained daily diary of symptoms, peak flow, and medication use | Five face-to-face visits, 7-week duration | Percentage adherence, 0 to 100% (SD) | Self-report, supplemented by medication monitors | G1: 70 (30) G2: 65 (34) p=NR | 7 weeks: G1: 91 (32) G2: 62 (38) 95% CI, NR Between-group difference from baseline to 7 weeks, Mean (95% CI): 24 (5 to 43) p=0.01 | NR
Self-management | Janson et al., 2009 123 G1: 45 G2:39 | Adults ages 18 to 55 years Community clinics | 4-week run-on inhaled corticosteroid therapy for all patients G1: Individualized self-management education; patients maintained daily diary of symptoms, peak flow, and medication use G2: Usual care with self-monitoring alone; patients maintained daily diary of symptoms, peak flow, and medication use | Five face-to-face visits, 14-week duration | Percentage adherence, 0 to 100% (SD), Change in percentage adherence | Electronic metered devices | Percentage adherent G1: 82 (18) G2: 81 (18) p=0.71 | Mean change in percentage at 4 weeks: G1: −0.18 G2: −1.40 95% CI, NR p=0.72 | Mean change in percentage at 14 weeks: G1: −4.28 G2: −4.14 95% CI, NR p=0.97
Self-management | Janson et al., 2009 123 G1: 45 G2:39 | Adults ages 18 to 55 years Community clinics | | Five face-to-face visits, 14-week duration | Odds of maintaining greater than 60% adherence | Electronic metered devices | NA | Odds at 4 weeks, compared with baseline: G1: 9.2 G2: 0.4 95% CI, NR p=0.02 | Odds at 14 weeks, compared with 4 weeks: G1: 0.3 G2: 1.1 95% CI, NR p=0.31
Self-management | Schaffer et al., 2004^124^ G1: 11 G2: 10 G3: 12 G4: 13 | Population, setting NR | G1: 30-minute audiotape story following a protagonist through asthma diagnosis and care; educational booklet G2: Audiotape alone G3: Educational booklet alone G4: Usual care: Patient receives standard education from provider | One contact, audio or book, duration NR | Proportion adherent (days of medication dispensed/ number of days between refill and date of study visit), (higher is better, 0 to 1) | Pharmacy refill data | Mean (SD): G1: 0.41 (0.42) G2: 0.32 (0.39) G3: 0.62 (0.34) G4: 0.62 (0.40) | Mean (SD) p-value compared with G4 at 3 months: G1: 0.53 (0.41) p=0.07 G2: 0.40 (0.32) p=0.4 G3: 0.73 (0.23) p=0.02 G4: 0.42 (0.39) 95% CI, NR | Mean (SD) p-value compared to G4 at 6 months: G1: 0.77 (0.24) p=0.04 G2: 0.48 (0.38) p=0.17 G3: 0.77 (0.24) p=0.02 G4: 0.40 (0.44) 95% CI, NR
Self-management | Schaffer et al., 2004^124^ G1: 11 G2: 10 G3: 12 G4: 13 | Population, setting NR | | One contact, audio or book, duration NR | Number of doses of preventive medication missed in previous 2 weeks | Self-report | Mean (SD): G1: 1.72 (2.15) G2: 8.10 (12.63) G3: 6.58 (9.52) G4: 3.61 (7.65) | NS for any group, 3 months | NS for any group, 6 months
Physician or pharmacist access to patient data | Weinberger et al., 2002^125^ G1: 356 G2: 296 G3: 246 | Adults > 18 Pharmacy | G1: Pharmaceutical care program: Pharmacists given access to patient-specific data symptom, adherence, and health care utilization data; trained to access and interpret patient-specific information and educated about reactive airway disease; given incentives for high utilization of patient-specific data. Patients given peak-flow monitors, instructions about its use, and monthly calls to obtain PEFR results. G2: Peak-flow monitoring: pharmacists educated and patients given peak-flow monitors and monthly reminders to use peak-flow monitors. G3: Usual care: Pharmacists educated | >One face-to- face, print, duration NR | Proportion of noncompliance (higher is worse, 0 to 1) | Self-report | Percentage not compliant G1: 34.9 G2: 32.7 G3: 33.6 | Adjusted OR (95% CI) at 1 year G1–G2: aOR: 0.81 (0.58 to 1.12) G1–G3: aOR: 1.09 (0.80 to 1.49) | NR
Physician or pharmacist access to patient data | Weinberger et al., 2002^125^ G1: 356 G2: 296 G3: 246 | Adults > 18 Pharmacy | | >One face-to- face, print, duration NR | Morisky scale, 0 (low) to 4 (high) | Self-report | Mean (SD) G1: 1.3 (1.2) G2: 1.2 (1.1) G3: 1.2 (1.2) | Mean scores (SD) at 1 year: G1: 0.87 (0.05) G2: 0.85 (0.05) G3: 0.92 (0.06) 95% CI, NR p=0.57 | NR
Physician or pharmacist access to patient data | Williams et al., 2010^126^ G1: 1335 G2: 1363 | Primary care providers; Patients ages 5 to 56 years Primary care clinics | G1: Physicians receive electronic adherence data for their patients every 2 weeks G2: Usual care with educational tools for providers to discuss nonadherence with their patients | >one computer, duration NR | Percentage adherence as a continuous measure of medication availability | Electronic prescription information and pharmacy claims data | Mean (SD) G1: 25.6 (37.3) G2: 27.7 (38.5) 95% CI, NR p=0.210 | Mean at 12 months (SE): G1: 21.3 (2.5) G2: 23.3 (2.2) 95% CI, NR p=0.553 | NR
Shared decision-making or clinical decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 years Kaiser Permanente medical centers | G1: Shared decisionmaking model G2: Clinical decisionmaking model G3: Usual care: Stepped approach to medications | Five face-to-face, phone, 9 months | Medication acquisition ratio for all asthma medications (total days supply acquired in a year/365 days) | Pharmacy refill data | NR | Means at 1 year: G1: 0.67 G2: 0.59 G3: 0.46 (95% CIs): G1–G3: (0.13 to 0.280), p=0.0001 G1–G2: (0.01 to 0.15), p=0.0029 G2–G3: (0.05 to 0.20), p=0.0008 | Mean differences at 2 years: G1–G3: 0.03 G1–G2: 0.04 G2–G3: −0.01 (95% CIs): G1–G3: (−0.05 to 0.11) G1–G2: (−0.04 to 0.12) G2–G3: (−0.09 to 0.07)
Shared decision-making or clinical decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 years Kaiser Permanente medical centers | G1: Shared decisionmaking model G2: Clinical decisionmaking model G3: Usual care: Stepped approach to medications | Five face-to-face, phone, 9 months | Medication acquisition ratio for inhaled corticosteroids (total days’ supply acquired in a year/365 days) | Pharmacy refill data | NR | Means at 1 year: G1: 0.59 G2: 0.52 G3: 0.37 (95% CIs): NR p: G1–G3: 0.0001 G1–G2: 0.017 G2–G3: 0.0001 | NR
Shared decision-making or clinical decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 years Kaiser Permanente medical centers | G1: Shared decisionmaking model G2: Clinical decisionmaking model G3: Usual care: Stepped approach to medications | Five face-to-face, phone, 9 months | Acquisition of beclomethasone canister equivalents | Pharmacy refill data | NR | Means at 1 year: G1: 10.9 G2: 9.1 G3: 5.2; (95% CIs): G1–G3: (4.5 to 7.0), p=0.0001 G1–G2: (0.57 to 0.31), p=0.005 G2–G3: (2.6 to 5.2), p=0.0001 | Means at 2 years: G1: 7.1 G2: 5.8 G3: 4.6 (95% CIs): G1–G3: (1.2 to 3.8), p=0.0002 G1–G2: (0.04 to 2.7), p=0.04 G2–G3 (−0.18 to 2.4), p>0.05
Shared decision-making or clinical decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 years Kaiser Permanente medical centers | G1: Shared decisionmaking model G2: Clinical decisionmaking model G3: Usual care: Stepped approach to medications | Five face-to-face, phone, 9 months | Medication acquisition for long-acting beta-agonists | Pharmacy refill data | NR | Mean difference at 1 year: G1–G3: 0.11 G1–G2: 0.09 G2–G3: 0.01 (95% CIs): G1–G3: (0.02 to 0.20) G1–G2: (0.02 to 0.17) G2–G3: (−0.08 to 0.11) | Mean difference at 2 years: G1–G3: 0.11 G1:G2: 0.09 G2–G3: 0.01 (95% CIs): G1–G3: (0.01 to 0.20) G1–G2: (0.01 to 0.18) G2–G3: (−0.08 to 0.11)

Abbreviations: aOR = adjusted odds ratio; CI = confidence interval; G = group; NA = not applicable; NR = not reported; OR = odds ratio; PEFR = peak expiratory flow rate; SD, standard deviation; SE, standard error.

The results for this body of evidence suggest improvement in adherence to various types of medications for this chronic disease during the intervention period (moderate strength of evidence for benefit). They offer only limited insight on whether improvements in adherence can be sustained over the long term (insufficient evidence) (Table 36).

Table 36 Asthma: strength of evidence for education and self-management interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Study Design/ Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Asthma education and self-management vs. usual care | 5; 303 (300) | Medication adherence | RCT Medium | Consistent | Direct | Precise | Difference in percentage points for adherence: 14 to 31 (range) Moderate for benefit for duration of intervention Insufficient for longer-term effects
Asthma education and self-management vs. usual care | 2; 152 (149) | Pulmonary function | RCT Medium | Consistent | Indirect | Imprecise | Insufficient
Asthma education and self-management vs. usual care | 2; 152 (149) | Inflammation markers | RCT Medium | Inconsistent | Indirect | Imprecise | Insufficient
Asthma education and self-management vs. usual care | 5; 303 (300) | Symptom improvement | RCT Medium | Inconsistent (trend to improvement sometimes favors intervention arm and sometimes control arm) | Direct | Imprecise | Varied measures and magnitude Insufficient
Asthma education and self-management vs. usual care | 4; 248 (245) | Quality of life | RCT Medium | Consistent | Direct | Imprecise | Varied measures and magnitude Low for no benefit

Abbreviation: RCT = randomized controlled trial.

##### Other Outcomes

We evaluated other outcomes for all five trials because all five reported at least one significant outcome relating to improved medication adherence (Table 36). Two asthma trials evaluated pulmonary function and some measures of inflammation through a variety of sputum markers (Appendix G).122,123 Neither found differences between trial arms in pulmonary function (insufficient evidence); both reported significant improvement in one sputum marker each but acknowledged that the clinical role of these markers was unclear (insufficient evidence).

The five trials reported a wide variety of symptom improvement measures; two found no statistically significant improvements in the intervention arm compared with the control arm,120,124 and one found a trend toward a higher percentage with symptom-free days in the control arm (insufficient evidence).121 In the two trials that reported some statistically significant improvement in the intervention arm compared with the control arm for one measure or time period, no statistically significant differences were found in other measures or at other time points (insufficient evidence).122,123

Four trials evaluated quality of life and found no differences between trial arms (insufficient evidence) (Appendix G).120,122–124

#### Detailed Synthesis: Interventions Providing Pharmacists or Physicians Access to Patient Adherence Data

##### Medication Adherence

Of three interventions aimed at providers and/or systems,125–127 two focused on patient adherence when providers (pharmacists or physicians) were provided with patient adherence data (Table 35).125,126 The pharmacist intervention, which provided additional elements of pharmacist care, examined the effects of this intervention separately for patients with asthma or COPD.125 Neither trial found statistically significant differences between groups at 1 year following the start of the trial (low strength of evidence of no benefit) (Table 37).

Table 37 Asthma: strength of evidence for interventions providing physicians or pharmacists access to patient adherence data

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Study Design/ Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Pharmacist or physician access to patient adherence data vs. usual care | 2; 3,811 (3,596) | Medication adherence | RCT Low | Consistent | Direct | Precise | Difference of 2 percentage points in percent adherence; 0.5 to 0.7 difference in Morisky scale Low for no benefit

Abbreviation: RCT = randomized controlled trial.

#### Detailed Synthesis: Shared or Clinical Decisionmaking for Asthma

##### Medication Adherence

One trial compared either shared decisionmaking or clinical decisionmaking with usual care (Table 38). At 1 year, clinical decisionmaking was more effective than usual care and shared decisionmaking was more effective than either clinical decisionmaking or usual care (low strength of evidence for benefit).127 At 2 years, clinical decisionmaking was no longer significantly different than usual care but shared decisionmaking continued to produce statistically significant improvements in medication adherence compared with clinical decisionmaking or usual care (low strength of evidence for benefit of shared decisionmaking).

Table 38 Asthma: strength of evidence for shared decisionmaking interventions

Intervention | Number of Studies; Subjects (Analyzed)* | Outcome | Study Design/Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Shared or clinical decision-making vs. usual care | 1; 612 (612) | Medication adherence | RCT Medium | Unknown | Direct | Precise | Difference in medication acquisition ratio for all asthma medications: 0.13 to 0.21 (range) Low for benefit
Shared or clinical decision-making vs. usual care | 1; 612 (551) | Pulmonary function | RCT Medium | Unknown | Direct | Precise | Difference in FEV1 percentage points: 2.7 to 3.4 Low for benefit
Shared or clinical decision-making vs. usual care | 1; 612 (612) | Symptom improvement | RCT Medium | Unknown | Direct | Precise | Difference in mean equivalents of SABA canister equivalents acquired at 2 years between shared decisionmaking and usual care: 1.6 Low for benefit
Shared or clinical decision-making vs. usual care | 1; 612 (551) | Quality of life | RCT Medium | Unknown | Direct | Precise | Difference in subscale scores on 5-item Mini Asthma Quality of Life Questionnaire: 0.3–0.4 Low for benefit
Shared or clinical decision-making vs. usual care | 1; 612 (612) | Health care utilization | RCT Medium | Unknown | Direct | Precise | Difference of 0.3 to 0.4 fewer asthma-related visits per year Low for benefit

Abbreviations: FEV1 = forced expiratory volume at 1 minute; NA = not applicable; RCT = randomized controlled trial; SABA = short-acting beta agonists.

##### Other Outcomes

This trial reported significantly improved pulmonary function for the shared decisionmaking group alone compared with usual care (Appendix G), suggesting evidence of benefit (Table 38).127 At 1 year, both intervention groups had higher odds of reporting no asthma control problems than did the group receiving usual care, and both reported significantly lower acquisition of SABA compared with usual care (6.5 and 7.1 vs. 8.1 canister equivalents, p>0.05 [Appendix G]) (low strength of evidence for benefit). At 2 years, only the shared decisionmaking arm reported lower SABA use than usual care (4.7 vs. 6.3 canister equivalents, p>0.05). Both clinical and shared decisionmaking arms produced significantly higher quality of life and fewer asthma-related visits than usual care (Table 38).

### Key Question 1 Depression: Medication Adherence Interventions

#### Description of Included Trials

##### Overview

We found 11 RCTs (reported in 14 articles) on depression87,101,128–139 (Table 39). These trials varied along numerous dimensions including the presence of other chronic conditions, type of depression (e.g., new episode, ongoing episode [with unspecified recency or all depression], recurrent depression), primary target of the intervention (patient, provider, systems, or combinations), and the type of intervention. We used the type of intervention as the primary means of clustering trials for the detailed synthesis and then incorporated other dimensions of trial characteristics within these intervention clusters. We rated one trial as having low risk of bias139 and all others as having medium risk of bias.

Table 39 Depression: summary of findings

Type of Intervention | Study | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Medication telemonitoring or telephone care | Rickles et al., 2005^128^ N=63 | = Antidepressant doses omitted over previous 3 months | NA
Medication telemonitoring or telephone care | Simon et al., 2006^129^ N=207 | = Filled prescriptions for at least 90 days over 6 months of continuous antidepressant treatment | NA
Case management | Bogner et al., 2007^101^ N=64 | + Adherence for taking ≥80% antidepressant medications over 6 weeks | + Depression severity, 6 weeks
Case management | Bogner et al., 2010^87^ N=58 | + Adherence for taking ≥80% antidepressant medications over 6 weeks | + Depression severity, 6 weeks
Case management | Katon et al., 2001;^130^ Ludman et al., 2003;^131^ Von Korff et al. 2003^132^ N=386 | + Percentage who filled antidepressant prescriptions over 12 months; + Percentage adherence over 12 months | + Depression severity for patients with severe depression across 12 months; = Self-reported functional impairment, 3, 6, 9, and 12 months
Collaborative care | Capoccia et al., 2004^133^ N= 74 | = Percentage adherent, 3, 6, 9, and 12 months | NA
Collaborative care | Katon et al., 1995^134^ N=217 | + Adequate dosage of antidepressants for ≥30 days for patients with major or minor depression; + Adequate dosage of antidepressants for ≥90 days for patients with major or minor depression | + Depression severity for patients with major depression at 4 months; = Depression severity for patients with minor depression at 4 months; + Response to treatment for patients with major depression at 4 months; = Response to treatment for patients with minor depression at 4 months; + Patient satisfaction for patients with major or minor depression; = Health care utilization; + Patient satisfaction with quality of care
Collaborative care | Katon et al., 1996^135^ N=153 | + Adequate dosage of antidepressants for ≥30 days for patients with minor depression; = Adequate dosage of antidepressants for ≥30 days for patients with major depression; = Adequate dosage of antidepressants for ≥90 days for patients with major or minor depression; + Percentage adherence for ≥25 of 30 days for major depression and minor depression for major and minor depression at 4 and 7 months | + Response to treatment for patients with major depression at 4 months; = Response to treatment for patients with minor depression at 4 months; + Patient satisfaction for patients with major depression; = Patient satisfaction for patients with minor depression; = Health care utilization; + Patient satisfaction with quality of care
Collaborative care | Katon et al., 1999;^136^ Katon et al., 2002^137^ N=228 | = Adequate dosage of antidepressants for ≥90 days in the past 6 months at 6 months for patients with moderate depression; = Adequate dosage of antidepressants for ≥90 days in the past 6 months at 12, 18, 24, and 30 months for patients with severe depression; + Adequate dosage of antidepressants for ≥90 days in the past 6 months at 6 and 12 months for patients with severe depression; = Adequate dosage of antidepressants for ≥90 days in the past 6 months at 18, 24, and 30 months for patients with severe depression | + Remission at 3 and 6 months; + Depression severity for all patients at 3 and 6 months; + Depression severity for patients with moderate severity over 28 months; = Depression severity for patients with severe depression over 28 months; = Functional impairment for patients with moderate and severe depression; = Health care utilization; = Costs; + Patient satisfaction with quality of care
Collaborative care | Pyne et al., 2011^138^ N=276 | = Number with ≥ 80% adherence to antidepressants at 6 and 12 months | NA
Reminders to nonadherent patients and lists of nonadherent patients to providers | Hoffman et al., 2003^139^ N=9,564 patients; 7,021 providers | + Percentage adherent (<10 gap days in a 30-day period), 3 and 6 months; + Percentage adherence using HEDIS guidelines at 3 and 6 months; = Persistence at 3 and 6 months | NR

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; HEDIS = Healthcare Effectiveness Data and Information Set; N = number; NA = not applicable; NR = not reported.

##### Population

One trial focused on patients with both depression and diabetes,87 one on patients with depression and hypertension,101 and one on patients with depression and HIV.138 Eight trials did not specify that subjects had any chronic conditions other than depression.128–137,139

The 11 trials covered a range of clinical presentations, although none was entirely among new patients, that is, patients with a first-ever diagnosis of depression. Six trials focused on patients with a new episode (defined as no use of antidepressants for a specified length of time ranging from 3 to 6 months before the index episode), but these either included some patients with recurrent depression or did not specify recurrence status.128–133,136,137,139 Of these, one trial (reported in multiple articles) specifically limited the population further to patients who had recurrent depression, dysthymia, and a high risk of relapse but who had largely recovered after 8 weeks of antidepressant treatment.130–132 Five trials did not require a new episode of depression as a condition of inclusion.87,101,134,135,138 Two provided data separately for major and minor depression.134,135 Another trial distinguished between moderate-severity and high-severity depression.136,137

##### Intervention

Of the 11 trials, two used interventions that appeared to be directed primarily at patients and providers. These two trials did not appear to require systems changes to be implemented in other settings;128,129 they involved telephone monitoring but differed in the extent to which the effort involved feedback loops to other providers. The less intense intervention, characterized as telemonitoring, involved pharmacists monitoring adherence and providing education in three telephone calls; pharmacists contacted providers only as needed.128 In the more intense intervention, characterized as telephone case management, care managers relied on three telephone calls to patients to monitor adherence; in addition, care managers routinely communicated findings to the treating psychiatrist and coordinated care for patients.129 This intervention was directed to patients with new episodes of depression, that is, no regular antidepressant use in the past 4 months.128,129 The authors did not clarify whether patients had recurrent depression.

Three case management interventions were primarily directed at patients and providers. Because they were conducted in populations with multiple chronic conditions or in depressed patients in a primary care setting, they required some degree of systems integration in team care. Two interventions, conducted by the same team, were identical in process exception for coexisting chronic disorder (diabetes in one case87 and hypertension in the other101). These two trials did not specify the nature of the depressive episode: they required only a diagnosis of depression in the past year. In addition to telephone calls and care coordination activities, all case management interventions included multiple regular in-person visits.87,101 A third trial, focusing on relapse prevention, was limited to patients with recurrent depression.130–132

Five trials focused on collaborative care models that required system-level changes.133–138 These interventions were all multifaceted and involved close collaboration among various health care providers and a team care approach. Patients received education, monitoring, and counseling. Four interventions included either specific courses of therapy134,135 or stepped approaches to care and included in-person visits in the intervention arm.136–138 The remaining trial in this category did not include therapy specifically, but the pharmacists providing followup over numerous telephone calls facilitated appointments with mental health providers.133

The final systems-level intervention examined the effect of the use of information systems in a health maintenance organization to trigger monthly lists of nonadherent patients to providers and monthly letters to nonadherent patients.139 This trial limited patients to those on newly prescribed therapy, that is, patients with no history of previous antidepressant use for 6 months before the index episode. The proportion with recurrent depression was not specified.

##### Comparator

Comparators for all interventions included usual care; as with the intervention, the intensity of usual care varied. The telemonitoring, case management, and information systems interventions generally reported usual care as routine care offered in that setting.87,101,128,129 The collaborative care interventions used usual care as the comparator,133–138 but usual care was specified as involving depression care by primary care physicians, including antidepressants and referrals to specialty mental health services when needed.134–138

##### Outcomes and Timing

Medication adherence outcomes differed markedly across these trials. Very few reported the same outcome; several reported multiple outcomes. No trial reported on initiation of therapy. One trial reported on persistence.139 Medication adherence outcomes examined in the other trials included the following: whether the prescription was filled at successive time points;130–132 dichotomous measures of adherence (taken vs. prescribed), using thresholds of 80 percent or higher87,101,138 and 95 percent or higher;138 dichotomous measures of adequate doses (based on strength and number of doses according to guidelines) taken for a minimum number of days over a given period (e.g., 90 days of adequate dose over 6 months);136,137 dichotomous measures of gap days (e.g., less than 10 days over 30 days);139 and continuous measures of doses omitted128 over a given period of time. Two trials relied solely on self-reported measures of adherence;133,138 all others used pharmacy refill or pharmacy claims data128–132,134–137,139 or MEMS.87,101 For length of followup, medication adherence outcomes were reported at times ranging from 6 weeks to 28 months after randomization of patients in the trials.

Of the trials for which we report health and other outcomes, two with very similar designs reported on symptom improvement using the same scale: the Center for Epidemiologic Studies-Depression scale (CES-D).87,101 Three others used symptom improvement on the Hopkins Symptom Checklist (SCL-20);130–132,134,136,137 these three trials used other measures of symptom improvement as well. Two trials evaluated similar measures along a scale for patient satisfaction, that is, rating care as good to excellent.134,136,137 One trial reported on health care utilization and costs.134,136,137

Most trials reported on outcomes during, immediately following, or within 3 months of the end of the intervention; intervention length ranged from 4 weeks87,101 to 12 months.130–133,138 Some 12-month interventions included an acute phase for the first 3 months or so, followed by a continuation phase that lasted up to 12 months.133 Only one trial reported on long-term outcomes (up to 28 months after randomization); the active phase of this intervention lasted for a maximum of 3 months.136,137 For measures that were constructed based on gap days or days adherent divided by the total number of days prescribed, the look-back period for the denominator varied from 4 days to 1 year, with 3 months or 6 months being the two most commonly used reference time periods.

##### Setting

Eight trials were set in primary care clinics: of these, two were in community-based primary care,87,101 one was in university-based primary care clinics,133 and five were in primary care clinics in one health care system (Group Health Cooperative).129–132,134–137 Of the remaining trials, one was set in community pharmacies affiliated with a managed care organization;128 one was in a Department of HIV clinic of the Department of Veterans Affairs (VA);138 and one employed systems records within a large health maintenance organization.139

##### Applicability

The body of evidence for depression, despite the replication of collaborative care interventions in multiple trials, is somewhat limited in applicability for collaborative care and case management interventions in particular. In both instances, the same team produced multiple studies, leaving uncertain the degree to which other teams can replicate their successes.

#### Key Points

##### Overview

- Eleven trials produced inconsistent evidence on medication adherence (Table 39).
- Five of 11 trials reported improvement in health and other outcomes.

##### Medication Telemonitoring or Telephone Care

- Medication adherence: Telephone-only interventions with low intensity and short duration showed no statistically significant benefit (insufficient evidence).

##### Case Management

- Medication adherence: Case management improved medication adherence for antidepressants (moderate strength of evidence for benefit).
- Morbidity:
  – Case management improved symptoms of depression (moderate strength of evidence for benefit).
  – Case management had no statistically significant effect on self-reported disability (insufficient evidence).

##### Collaborative Care

- Collaborative care interventions varied by intensity and population; the strength-of -evidence grades reflect these underlying sources of heterogeneity.
- Medication adherence:
  – Intensive collaborative care with multifaceted telephone and in-person components improved medication adherence (moderate strength of evidence for benefit).
  – Telephone-only collaborative care showed no statistically significant improvement in medication adherence (insufficient evidence).
  – No statistically significant difference in medication adherence was found for patients with depression and HIV (insufficient evidence).
- Morbidity:
  – Collaborative care reduced depressive symptoms in patients with major depression (low strength of evidence for benefit).
  – Collaborative care did not result in statistically significant improvement in depressive symptoms for patients with minor depression (insufficient evidence).
  – Collaborative care reduced depressive symptoms for patients with moderately severe depression (low strength of evidence for benefit).
- Patient satisfaction:
  – Collaborative care resulted in improved patient satisfaction with antidepressants (low strength of evidence for benefit).
- Health care utilization:
  – Evidence was insufficient for primary care or mental health visits.
  – Evidence was insufficient for total, ambulatory, depression, and nondepression costs.
- Quality of care: Collaborative care resulted in improved patient satisfaction with quality of care (moderate strength of evidence for benefit)

##### Reminders to Nonadherent Patients and Lists of Nonadherent Patients to Providers

- Medication adherence: Reminder letters sent to nonadherent patients and monthly lists of nonadherent patients sent to provider improved patients’ medication adherence (low strength of evidence for benefit).

#### Detailed Synthesis: Telemonitoring or Telephone Case Management Interventions for Depression

##### Medication Adherence

Neither of the two trials relying solely on telephone-based care found statistically significant differences between intervention and usual care arms on patient adherence (Table 40).128,129 The evidence is insufficient for the effects of telephone-only interventions with low intensity and short duration for medication adherence (Table 41).

Table 40 Depression: medication adherence

Type of Intervention | Study N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, Direction) | Source | Baseline | First Followup | Additional Followups
Medication telemonitoring or telephone care | Rickles et al., 2005^128^ G1: 28 G2: 32 | Patients ≥18 years Pharmacies | G1: Pharmacists called patients to discuss adherence, treatment goals, education, symptoms, adverse effects, and other concerns; recommendations made as needed G2: Usual care: Education and monitoring typical of pharmacies | Three phone contact over 3 months | Antidepressant doses omitted over previous 3 months | Pharmacy refill | NR | Number (Mean ± SD) at 3 months: G1:28 (18.1±23.5) G2: 32 (18.7±22.1) 95% CI, NR p=NS | Number (Mean ± SD) at 6 months: Without ITT: G1:28 (30.3±36.4) G2: 32 (48.6±39.2) 95% CI, NR p<0.05 (one-tailed) With ITT: (data NR) p=NS
Medication telemonitoring or telephone care | Simon et al., 2006^129^ G1: 98 G2: 97 | Patients ≥18 years Phone contacts | G1: Contacts to assess symptoms, adherence, side-effects, review algorithm for change in treatment, provide motivational enhancement; crisis intervention and care coordination as needed G2: Usual care | Three phone contact over 3 months | Filled prescriptions for at least 90 days over 6 months of continuous antidepressant treatment | Pharmacy refill | NR | At 6 months: G1: 63 (64%) G2: 53 (55%) 95% CI, NR Chi-square (1 df): 1.88 p=0.17 | NR
Case management | Bogner et al., 2008^101^ G1: 32 G2: 32 | Adults ≥50 years with depression and HTN Primary care clinic | G1: Integrated care of depression and hypertension with care manager G2: Usual care | Three face-to-face + two calls over 4 weeks | Number of patients with ≥80% adherence to depression medications (0 to 100%) | MEMS | G1: 16 (50.0%) G2: 14 (43.0%) 95% CI: NR p: 0.81 | 6 weeks: G1: 23 (71.9%) G2: 10 (31.3%) 95% CI, NR p=0.001 | NR
Case management | Bogner et al., 2010^87^ G1: 29 G2: 29 | Adults ≥50 years with diabetes mellitus and depression Community-based primary care clinic | G1: Integrated care of depression and diabetes; care managers provided education, self-management instruction, symptom and side-effects monitoring, referral assistance G2: Usual care | Three face-to-face + two calls over 4 weeks | Number of patients with ≥80% adherence to depression medications (0 to 100%) | MEMS | G1: 8 (27.6%) G2: 4 (13.8%) 95% CI: NR p: 0.17 | 6 weeks: G1: 18 (62.1%) G2: 3 (10.3%) 95% CI, NR p<0.001 | NR
Case management | Katon et al., 2001;^130^ Ludman et al., 2003;^131^ Von Korff et al. 2003^132^ G1: 170 G2: 145 | Patients 18 to 80 years Primary care clinics | G1: Depression relapse prevention program including education, symptom monitoring, motivational enhancement, self-management and self-care instruction, and referral facilitation G2: Usual care: two to four visits in first 6 months following antidepressant prescription; referral to mental health services as needed. | Nine face-to-face, phone, print, DVD contact over 12 months | Percentage who filled antidepressant prescriptions | Pharmacy refill data | NR | 0 to 3 months (95 % CI): G1: 80.7 % (75.1 to 86.3) G2: 65.6 % (58.8 to 72.4) | 3 to 6 months (95 % CI): G1: 71.9 % (65.5 to 78.2) G2: 58.2% (51.2 to 65.2) 6 to 9 months (95 % CI): G1: 68.4% (61.8 to 75.0) G2: 55.6% (48.5 to 62.7) 9 to 12 months (95 % CI): G1: 63.2% (53.3 to 70.0) G2: 49.7% (42.6 to 56.9) Adjusted odds ratio (95%CI) across 12 months: 1.91 (1.37 to 2.65) p<0.001
Case management | Katon et al., 2001;^130^ Ludman et al., 2003;^131^ Von Korff et al. 2003^132^ G1: 170 G2: 145 | Patients 18 to 80 years Primary care clinics | | Nine face-to-face, phone, print, DVD contact over 12 months | Adequate dose of antidepressant medication | Pharmacy refill data | NR | NR | Adjusted odds ratio (95% CI) across 12 months: 2.08 (1.41 to 3.06) p<0.001
Collaborative care | Capoccia et al., 2004^133^ G1: 41 G2: 33 | Patients ≥18 years Primary care clinics | G1: Pharmacist or pharmacy residents collaborated with primary care providers and psychiatrists; telephoned patients to address symptom and medication concerns, authorized medication refills, managed patient assistance programs, facilitated referrals, provided additional pharmacotherapy as needed G2: Usual care: patients encouraged to use available resources (clinical pharmacist, nurses, mental health professionals, primary care provider) as suggested by their primary care provider | 18 phone contact over 12 months | Adherent to antidepressants (taken ≥25 days of previous 30 days) | Questionnaire | NR | Percentage adherent at 3 months: G1: 85% G2: 81% 95% CI, NR p=NS | Percentage adherent at 6 months: G1: 78% G2: 73% 95% CI, NR p=NS Percentage adherent at 9 months: G1: 48% G2: 67% 95% CI, NR p=NS Percentage adherent at 12 months: G1: 59% G2: 57% 95% CI, NR p=NS
Collaborative care | Katon et al., 1995^134^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Patients 18 to 80 years Primary care clinics | G1: Patients received education on depression, antidepressants, and CBT management techniques; completed a doctor-patient questionnaire to give PCP and had two psychiatric visits; psychiatrists collaborated with PCP about regimens and adherence; PCPs received education on depression; case consultations, and case conferences G2: Usual care: patients received treatment for depression from PCP; could refer to mental health specialist | Four face-to-face, print, video contact over 6 weeks | Patients receiving adequate dosage of antidepressants in continuation phase (3 to 7 months) for ≥30 days | Pharmacy refill data | NR | Percentage from 3 to 7 months: Major depression group G1: 87.8% G2: 57.1% 95% CI, NR p<0.001 Minor depression group G1: 88.1% G2: 47.8% 95% CI, NR p<0.001 | NR
Collaborative care | Katon et al., 1995^134^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Patients 18 to 80 years Primary care clinics | | Four face-to-face, print, video contact over 6 weeks | Patients receiving adequate dosage of antidepressants in continuation phase (3 to 7 months) for ≥90 days | Pharmacy refill data | NR | Percentage from 3 to 7 months: Major depression group G1: 75.5% G2: 50.0% 95% CI, NR p<0.01 Minor depression group G1: 79.7% G2: 40.3% 95% CI, NR p<0.001 | NR
Collaborative care | Katon et al., 1996^135^ Overall G1: 77 G2: 76 Major depression: 65 G1: 31 G2: 34 Minor depression: 88 G1: 46 G2: 42 | Patients 18 to 80 years Primary care clinic | G1: Multifaceted collaborative care intervention targeting the patient, PCP, and process of care. Included behavioral treatment to manage depression and counseling to improve adherence. Patients received education on depression, antidepressants, and depression management techniques G2: Usual care: two to three visits to PCP in first 6 months following antidepressant prescription; referral to mental health services as needed. | Eight face-to-face, print, phone, video, over 24 weeks | Patients receiving adequate dosage of antidepressant medication for ≥30 days (AHCPR guidelines) | Pharmacy refill data | NR | Timeframe unspecified Major depression: G1: 66.7% G2: 57.6% 95% CI, NR p<0.46 Minor depression: G1: 84.8% G2: 53.9% 95% CI, NR p<0.002 | NR
Collaborative care | Katon et al., 1996^135^ Overall G1: 77 G2: 76 Major depression: 65 G1: 31 G2: 34 Minor depression: 88 G1: 46 G2: 42 | Patients 18 to 80 years Primary care clinic | | Eight face-to-face, print, phone, video, over 24 weeks | Patients receiving adequate dosage of antidepressant medication for ≥90 days (AHCPR guidelines) | Pharmacy refill data | NR | Timeframe unspecified Major depression: G1: 62.1% G2: 54.6% 95% CI, NR p=0.55 Minor depression: G1: 69.6% G2: 39.5% p=0.08 | NR
Collaborative care | Katon et al., 1996^135^ Overall G1: 77 G2: 76 Major depression: 65 G1: 31 G2: 34 Minor depression: 88 G1: 46 G2: 42 | Patients 18 to 80 years Primary care clinic | | Eight face-to-face, print, phone, video, over 24 weeks | Percentage adherent to antidepressants (taken ≥25 days of previous 30 days) | Questionnaire | NR | 1 month: Major depression: G1: 85% G2: 63% 95% CI, NR p=0.06 Minor depression: G1: 81% G2: 67% 95% CI, NR p=0.13 | 4 months: Major depression: G1: 89% G2: 62% 95% CI, NR p=0.02 Minor depression: G1: 74% G2: 44% 95% CI, NR p=0.01 7 months: Major depression: G1: 79% G2: 54% 95% CI, NR p=0.07 Minor depression: G1: 64% G2: 41% 95% CI, NR p=0.04
Collaborative care | Katon et al., 1999;^136^ Katon et al., 2002^137^ G1: 114 G2: 114 | Patients ≥18 years Primary care providers Primary care clinics | G1: Multifaceted stepped intervention for depression persistence; patients received education, two scheduled visits with psychiatrist, additional visits as needed, brief telephone calls; psychiatrists helped PCPs adjust dosages and medication; PCPs received immediate updates about patient progress G2: Usual care: two to four visits in first 6 months following antidepressant prescription; referral to mental health services as needed. | >Two face-to-face, phone, print, DVD over NS period | Percentage of patients receiving adequate dosage of antidepressants for ≥ 90 days in previous 6 months ( per AHCPR guideline) | Pharmacy refill data | NR | Percentage: G1: 68.8% G2: 43.8% 95% CI, NR Chi-square (1 df): 12.60 p=0.0001 | NR
Collaborative care | Katon et al., 1999;^136^ Katon et al., 2002^137^ G1: 114 G2: 114 | Patients ≥18 years Primary care providers Primary care clinics | | >Two face-to-face, phone, print, DVD over NS period | Patients receiving twice the dosage of the lower range (per AHCPR guideline) | Pharmacy refill data | NR | Timeframe NR Percentage: G1: 46.8% G2: 25.7% 95% CI, NR Chi-square (1 df): 9.36 p=0.002 | NR
Collaborative care | Katon et al., 1999;^136^ Katon et al., 2002^137^ G1: 114 G2: 114 | Patients ≥18 years Primary care providers Primary care clinics | | >Two face-to-face, phone, print, DVD over NS period | Adherent to antidepressants (taken ≥25 days of previous 30 days) | Questionnaire | NR | Percentage adherent at 1 month: G1: 77.4% G2: 69.2% 95% CI, NR Chi-square (1 df): 1.38 p=0.24 | Percentage adherent at 3 months: G1: 78.6% G2: 62.1% 95% CI, NR Chi-square (1 df): 5.52 p=0.02 Percentage adherent at 6 months: G1: 73.2% G2: 50.5% 95% CI, NR Chi-square: 9.53 p=0.002
Collaborative care | Katon et al., 1999;^136^ Katon et al., 2002^137^ G1: 114 G2: 114 | Patients ≥18 years Primary care providers Primary care clinics | Among patients with moderate depression (defined as SCL-20 score ≤2.0 at baseline) N=149 | | Patients receiving adequate dosage of antidepressants for at least 90 days out of previous 6 months | Pharmacy refill data | NR | Number (percentage) at 6 months: G1: 76% G2: 46% Chi-square (1 df)= 6.10 95% CI, NR p<0.05 | At 12, 18, 24, 30 months: No significant differences across groups
Collaborative care | Katon et al., 1999;^136^ Katon et al., 2002^137^ G1: 114 G2: 114 | Patients ≥18 years Primary care providers Primary care clinics | Among patients with severe depression (defined as SCL-20 score >2.0 at baseline) N=79 | | Adherent to adequate dosage of antidepressants for at least 90 days out of previous 6 months | Pharmacy refill data | NR | Number (percentage) at 6 months: G1: 24 (72%) G2: 14 (40%) Chi-square (1 df)=8.23 95% CI, NR p<0.01 | Number (percentage) at 12 months: G1: 23 (70%) G2: 13 (37%) Chi-square (1 df)=5.98 95% CI, NR p<0.05 At 18, 24, and 30 months: No significant difference across groups
Collaborative care | Pyne et al., 2011^138^ G1: 123 G2: 126 | Patients with HIV infection and depression; HIV providers VA HIV clinics | G1: Collaborative stepped care with HIV and mental health providers; included education, self-management instruction, and monitoring of depression and substance abuse symptoms; referral assistance G2: Usual care: HIV providers received 1 hour of HIV and depression training; patients screened for depression at baseline and delivered results to HIV providers at most clinic visits | >1 phone contact for patients, NR for provider | Number of patients with ≥80% adherence to depression medications (0 to 100%) | Questionnaire | Mean percentage (SD) G1: 85.4 (30.5) G2: 86.4 (31.1) | At 6 months: G1: 52/66 (78.8%) G2: 50/72 (69.4%) Odds ratio (95%CI): Unadjusted: 1.60 (0.74 to 3.45) Adjusted: 1.65 (0.75 to 3.62) Adjusted p=0.22 | At 12 months: G1: 45/59 (76.3%) G2: 51/60 (85.0%) Odds ratio (95%CI): Unadjusted: 0.55 (0.21 to 1.44) Adjusted: 0.56 (0.20 to 1.57) Adjusted p=0.27
Reminders to nonadherent patients and lists of nonadherent patients to providers | Hoffman et al., 2003^139^ G1: 4899 Pts. G2: 4665 Pts. | Patients ≥18 years and their providers Pharmacies | G1: Monthly mail-based letters sent to providers listing patients who were prescribed antidepressants and found nonadherent through pharmacy claims; letters sent to nonadherent patients with general information about medication adherence G2: Usual care | Six print and mail contact over 6 months | Percentage adherent to antidepressants (<10 gap days in a 30-day period) | Pharmacy claims records | NR | Percentage adherent at 1 month: G1: 58.9% G2: 57.4% 95% CI, NR p=0.136 | Percentage adherent at 3 months: G1: 66.9% G2: 66.5% 95% CI, NR p<0.01 Percentage adherent at 6 months: G1: 52.3 % G2: 50.2 % 95% CI, NR p<0.001
Reminders to nonadherent patients and lists of nonadherent patients to providers | Hoffman et al., 2003^139^ G1: 4899 Pts. G2: 4665 Pts. | Patients ≥18 years and their providers Pharmacies | | Six print and mail contact over 6 months | Percentage adherence using HEDIS guidelines | Pharmacy claims records | NR | Percentage adherent at 3 months (a total of 30 gap days in days 1 to 84 of treatment): G1: 59.6% G2: 56.6% 95% CI, NR p<0.01 | Percentage adherent at 6 months (a total of 51 gap days in days 1 to 180 of treatment): G1: 31.5% G2: 29.4% 95% CI, NR p<0.05
Reminders to nonadherent patients and lists of nonadherent patients to providers | Hoffman et al., 2003^139^ G1: 4899 Pts. G2: 4665 Pts. | Patients ≥18 years and their providers Pharmacies | | Six print and mail contact over 6 months | Persistency (patient considered persistent if date of the last prescription filled plus the days’ supply was ≤10 days from the end of the trial) | Pharmacy claims records | NR | Mean percentage at 2 months: G1: 45.9% G2: 44.3% | Mean percentage (SD) from 1 to 90 days: G1: 36.8%(24.3) G2: 35.3%(12.4) Chi-square (1 df): 0.127 95% CI, NR p:NR Mean percentage (SD) from 1 to 180 days: G1: 24.9%(51.9) G2: 23.3%(51.9) Chi-square (1 df): 0.067 95% CI, NR p:NR

Abbreviations: ACE = angiotensin-converting enzyme; AHCPR = Agency for Health Care Policy and Research; CBT = cognitive behavioral therapy; CI = confidence interval; df = degrees of freedom; DVD = digital video disk; G = group; HEDIS = Healthcare Effectiveness Data and Information Set; ITT = intention to treat; MEMS = medication event monitoring systems; N = number; NR = not reported; NS = not statistically significant; PCP = primary care provider; RCT = randomized controlled trial; SCL-20 = Hopkins Symptom Checklist-20; SD = standard deviation; VA = Department of Veterans Affairs.

Table 41 Depression: strength of evidence for telemonitoring or telephone care interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Telemonitoring or telephone care vs. usual care | 2; 270 (255) | Medication Adherence | RCT Medium | Inconsistent | Direct | Imprecise | No statistically significant difference Insufficient

Abbreviation: RCT = randomized controlled trial.

#### Detailed Synthesis: Case Management Interventions for Depression

##### Medication Adherence

All three interventions using case management demonstrated statistically significant differences between intervention arms and usual care in medication adherence outcomes (Table 40).87,101,130–132 The results for this body of evidence suggest that case management yields improvements in medication adherence during or shortly after the intervention ends (moderate strength of evidence; Table 42). No evidence is available to evaluate the utility of this intervention for improving medication adherence over the longer term (after completion of the intervention).

Table 42 Depression: strength of evidence for case management interventions

Intervention | Number of Trials; Subjects (Analyzed) | Outcome | Study Design/Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Case management vs. usual care | 3; 508 (437) | Medication adherence | RCT Medium | Consistent | Direct | Precise | Difference in percentage points for adherence or filling prescriptions over time: 9 to 15 (range across studies) Moderate
Case management vs. usual care | 3; 508 (437) | Symptom improvement | RCT Medium | Consistent | Direct | Precise | Difference in CES-D scale: 7.0 to 9.4 (range across studies) Mean difference in SCL-20 (0 to 4 range) scores between groups across 12 months: 0.08 Moderate
Case management vs. usual care | 1; 386 (315) | Self-reported disability | RCT Medium | Unknown | Indirect | Imprecise | Varied measures, outcomes, time periods Insufficient

Abbreviations: CES-D scale = Center for Epidemiologic Studies-Depression scale; RCT = randomized controlled trials; SCL-20 = Hopkins Symptom Checklist-20; vs. = versus.

##### Other Outcomes

All three trials reporting improvement in medication adherence also reported health and other outcome data. The two 4-week interventions reported outcomes at 6 weeks,87,101 and the 12-month intervention reported outcomes at 3, 6, 9, and 12 months.51–53 All three trials demonstrated significant differences at followup favoring the intervention arm over the control arm for symptoms of depression (moderate strength of evidence of benefit) (Table 42).87,101,130–132 One trial, on relapse prevention, evaluated three disability measures, using the Medical Outcomes Study Short Form-36 (SF-36) Social Function scale, the SF-36 Emotional Function Scale, and the Sheehan Disability Scale.130–132 Only the SF-36 Social Functioning scale measure demonstrated a significant difference between intervention and control arm.130–132 This evidence is insufficient to draw conclusions about the effectiveness of case management to improve self-reported disability outcomes (Table 42). The trials did not report mortality, patient satisfaction, health care utilization, or costs.

#### Detailed Synthesis: Collaborative Care Interventions for Depression

##### Medication Adherence

The five collaborative care interventions varied by population and components.

Three other collaborative care interventions were developed and implemented by investigators common to all three trials and carried out in similar settings. They differed in structure (stepped care with the number of contacts and course of treatment tailored to the patient136,137 vs. a common protocol for all patients134,135) and in process (alternate visits to psychiatrists and primary care134 vs.psychiatrists136,137 or psychologists135 serving as central agent of delivery of the intervention). Two of these trials were stratified by major and minor depression;134,135 a third selected patients for persistence (based on SCL-20 scores) and then stratified by severity of depression;136,137 in addition, one trial presented results for the overall group.136

Of the two trials that stratified subjects by major and minor depression, one demonstrated statistically significant improvement in medication adherence measured by adequacy of dosage or percentage adherence for the intervention arm compared with usual care for both subgroups of major and minor depression at 7 months after randomization.134 The other trial found improved medication adherence (percentage adherent) in the intervention arm compared with the control arm at 4 and 7 months after randomization for both major and minor depression patients; with the exception of the 7-month followup for major depression, these differences were statistically significant at p<0.05.^135^ The trial did not demonstrate significant difference for measures of adequacy of prescription for either major or minor depressive groups.

One trial continued to record medication adherence outcomes for 6-month intervals through 30 months after randomization;136,137 it reported overall differences by intervention arms at 3 and 6 months after randomization.136,137 Among patients severely depressed at baseline, the intervention arm continued to show benefits of the intervention on medication adherence at 12 months.136,137 This effect did not extend to patients with moderate depression at 12 months, and neither group (moderate or severe depression) showed statistically significant differences between arms from 18 months onward.

These three trials suggest that collaborative care interventions produced improvements in medication adherence overall (moderate strength of evidence of benefit) (Table 43).

Table 43 Depression: strength of evidence for collaborative care interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Study Design/Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Collaborative care vs. usual care | 3 (telephone and in-person); 598 (598) | Medication adherence | RCT Medium | Consistent | Direct | Precise | Difference in percentage points for adherence: 16.5 to 40.3 (range across studies) Moderate
Collaborative care vs. usual care | 1; 249 (249) Depression and HIV | Medication adherence | RCT Medium | Unknown | Direct | Imprecise | Difference in percentage points for adherence: −8.7 to 9.4 (range) Insufficient for patients with depression and HIV
Collaborative care vs. usual care | 1 (telephone only); 74 (74) | Medication adherence | RCT Medium | Unknown | Direct | Imprecise | Difference in percentage points for adherence: −19 to 2 (range across study) Insufficient
Collaborative care vs. usual care | 2; 156 (156) Major depression | Symptom improvement | RCT Medium | Consistent | Direct | Precise | Varied magnitude based on outcome and time periods Low
Collaborative care vs. usual care | 2; 214 (214) Minor depression | Symptom improvement | RCT Medium | Inconsistent | Direct | Imprecise | Varied magnitude based on outcome and time periods Insufficient
Collaborative care vs. usual care | 1; 149 (149) Moderate depression | Symptom improvement | RCT Medium | Unknown | Direct | Precise | Varied magnitude based on outcome and time periods Low
Collaborative care vs. usual care | 1; 79 (79) Severe depression | Symptom improvement | RCT Medium | Unknown | Direct | Imprecise | Varied magnitude based on outcome and time periods Insufficient
Collaborative care vs. usual care | 2; 370 (370) | Patient satisfaction with utility of antidepressants | RCT Medium | Consistent | Direct | Imprecise | Difference in percentage points in those rating antidepressants as helping somewhat to a great deal: 6.0 to 24.8 (range across studies) at 4 months Low
Collaborative care vs. usual care | 3; 598 (598) | Health care utilization | RCT Medium | Inconsistent | Direct | Imprecise | Varied outcomes, time periods, and consistency Insufficient
Collaborative care vs. usual care | 1; 228 (228) | Costs | RCT Medium | Unknown | Direct | Imprecise | Direction and magnitude of difference varies by type of cost Insufficient
Collaborative care vs. usual care | 3; 598 (598) | Patient satisfaction with quality of care | RCT Medium | Consistent | Direct | Precise | Difference in percentage points in those rating quality of care as good to excellent: 5.1 to 32.5 (range across studies) at 3 to 4 months; 16 at 6 months Moderate SOE

Abbreviations: NA = not applicable; RCT = randomized controlled trials; SOE = strength of evidence.

Of the two other trials, one focused on providing populations with interventions for depression and HIV infection.138 It reported on adherence to both HIV medications and antidepressants; the look-back period of the patient-reported adherence measure was very short at 4 days.138 This trial showed no statistically significant effect of the intervention arm on medication adherence.

A second trial relied on pharmacists as the central agents in a collaborative care intervention; they communicated with a care team and had responsibility for numerous activities including prescriptive authority “for the initiation, adjustment, management, and monitoring of pharmacotherapy; triage and care of acute patient problems over the phone; and smoking cessation, blood pressure monitoring, and disease management.”133 Their interaction with patients was limited to (a) weekly telephone calls in the first 4 weeks, (b) biweekly calls through week 12, and (c) bimonthly calls from months 4 to 12. This intervention showed no difference between intervention and usual care arms in medication adherence at 3, 6, 9, or 12 months. The evidence for these two interventions is insufficient to judge their effectiveness (Table 43).

##### Other Outcomes

All three collaborative care interventions that showed a difference between arms for medication adherence reported on changes in depression symptoms (Appendix G). Two demonstrated statistically significant improvements in response (difference in response to treatment varied from 28.1 to 30.6 percentage points, p<0.05) and in symptoms using the SCL-20 scale in the group with major depression but not in the group with minor depression (difference in response to treatment varied from 7.9 to 13.9 percentage points, p>0.2).134,135 A third trial, with stratified results for patients with moderate or severe depression, found statistically significant differences in depression severity at 28 months following randomization in the intervention arm compared with usual care for patients with moderate depression (0.88 vs. 10.23 on a 0–4 SCL-20 depression score, p=0.004) but not for those with severe depression (1.16 vs. 1.19, p=0.88).136,137 Table 43 provides strength-of-evidence grades for this limited body of trials that suggest benefit from collaborative care (low strength of evidence).

Two trials reported improvement in patients’ viewing antidepressant therapy as helping somewhat to a great deal (21.7 to 24.8 percentage points difference for major depression, 6.0 to 20.4 percentage points difference for minor depression) (low strength of evidence).134,135 Three trials reported on health care utilization and found conflicting but nonsignificant differences between arms (insufficient evidence).134–137 One trial examined costs and found no difference between trial arms (insufficient evidence).136,137 All three trials found greater patient satisfaction with quality of care in the intervention arm than in usual care (moderate strength of evidence).134–137 This difference was not statistically significant for the patient group with minor depression in one trial;134 for the remaining trials and groups, the difference in percentage points for patients rating the quality of care received for depression as good to excellent ranged from 16 to 32.5.

#### Detailed Synthesis of Reminders to Nonadherent Patients and Lists of Nonadherent Patients to Providers

##### Medication Adherence

A single large trial, with a 6-month intervention, provided evidence on the utility of employing information systems as a trigger to send letters to nonadherent patients and their providers about the importance of medication adherence.139 Patients in the intervention arm had significantly higher medication adherence at 3 and 6 months than those in the control arm of usual care (Table 40). Depending on the measure used (10 gap days or MPR) and the time span for the outcome (1 month, 90 days, 180 days), the difference between the arms ranged from 1 to 3 percentage points (low strength of evidence) (Table 44).

Table 44 Depression: strength of evidence for reminders to providers and nonadherent patients interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Study Design/Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Reminders vs. usual care | 1; 9,564 (9,564) | Medication adherence | RCT Medium | Consistent | Direct | Precise | Difference in percentage points for adherence; 1 to 3 (range across study) Low

Abbreviation: RCT = randomized controlled trials.

##### Other Outcomes

The authors of this trial noted the unknown clinical significance of such a difference in adherence rates but they offered no additional data to evaluate the effect of the intervention on health outcomes.

### Key Question 1 Glaucoma: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

One trial, rated medium for risk of bias, examined an intervention that attempted to improve medication adherence among patients with glaucoma.140

##### Population

The trial population included patients ages 18 years or older with diagnosis of open-angle glaucoma, angle-closure glaucoma, glaucoma suspect, or ocular hypertension who had been prescribed eye drops for their condition.

##### Intervention

This trial was directed at patients. It tested a multicomponent intervention consisting of an education video, discussion of barriers and strategies, reminder telephone calls, and a dosing aid.

##### Control

The control group received no additional intervention except for an instruction to take their eye drops as indicated.

##### Outcome and Timing

The trial did not report on the initiation of therapy; it reported proportion of prescribed doses taken as well as changes in adherence rates. Medication adherence was measured as proportion of prescribed doses taken and changes in adherence rates (from the end of an initial 3-month observational cohort period and the end of the RCT period in the trial, 6 months into the overall trial period). These measurements were taken using a dosing aid that was downloaded at the appropriate times for measurement. This trial reported a significantly higher medication adherence in the intervention arm than in the control arm. The trial reported a health outcome of intraocular pressure for glaucoma patients measured in millimeters of mercury (mm Hg).

##### Setting

The trial was conducted at two eye clinics.

##### Applicability

The applicability of this trial is limited by the availability of dosing aids such as those tested in this intervention.

#### Key Points

##### Overview

- A single trial provided evidence on improving medication adherence and other outcomes for glaucoma (Table 45).

Table 45 Glaucoma: summary of findings

Type of Intervention | Study | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Multicomponent intervention including an educational video, discussion of barriers, reminder calls, and dosing aid | Okeke et al., 2009^140^ N=127 | Adherence rate, 3 months after intervention Change in adherence rate (unadjusted), change between 3 and 6 months Change in adherence rate (adjusted), change between 3 and 6 months | Intraocular pressure, change between 3 and 6 months

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; N = number

##### Multicomponent Intervention for Glaucoma

- Medication adherence: One trial provided evidence of improved medication adherence (low strength of evidence).
- Morbidity (intraocular pressure): Because of lack of precision, we were unable to judge the true effect of the intervention on intraocular pressure (insufficient).

#### Detailed Synthesis of Results

This multicomponent intervention significantly improved medication adherence, as measured with dosing aids (proportion of pills taken and change in adherence rate) (low strength of evidence for benefit) (Table 46).

Table 46 Glaucoma: detailed medication outcomes

Type of Intervention | Study N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, Direction) | Source | Baseline | First Followup | Additional Followups
Multicomponent | Okeke et al., 2009^140^ G1: 35 G2: 31 | Adults with glaucoma, glaucoma suspect, open-angle glaucoma, angle-closure glaucoma, or ocular hypertension Two eye clinics | G1: Educational video, discussion of barriers and strategies with study coordinator, reminder phone calls,, use of a dosing aid G2: Controls were told that it is important to take their eye drops as prescribed, but had no other intervention | 10-minute educational video; reminder call once a week for first followup month and every other week for the next 2 months | Adherence rate | Dosing aids | 3 months before intervention Adherence rate: G1: 0.54 (0.17) G2: 0.46% (0.23) P = 0.10 | 3 months after intervention: G1: 0.73 (0.22) G2: 0.51 (0.30) 95% CI, NR P= 0.001 | Change between 3 and 6 months (unadjusted): G1: 0.19 (0.20) G2: 0.06 (0.23) 95% CI, NR P = 0.01 Change between 3 and 6 months (adjusted): G1: 0.21 (0.05) G2: −0.002 (0.04) 95% CI, NR P= 0.0001

This trial presented specific morbidity outcomes. Intraocular pressure did not significantly improve in the between baseline to 3 months, or up to 6 months after the end of the intervention (Table 47).

Table 47 Multicomponent intervention for glaucoma: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Multicomponent vs. usual care | 1; 66 (66) | Proportion of prescribed doses taken | RCT Medium | Unknown | Direct | Precise | Difference in adherence rate: 0.22 Low
Multicomponent vs. usual care | 1; 66 (66) | Morbidity: Intraocular pressure | RCT Medium | Unknown | Direct | Imprecise | Insufficient

Abbreviations: N=number; RCT=randomized controlled trial.

### Key Question 1 Multiple Sclerosis: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

One trial, with medium risk of bias, provided evidence on a software-based telephone counseling intervention to improve medication persistence among patients with multiple sclerosis (MS).141

##### Population

The trial population consisted of adult patients who were on Avonex® (interferon beta-1a) treatment for their MS (Biogen Idec manufactures Avonex, the MS treatment examined in this trial).

##### Software-Based Telephone Counseling Intervention

The intervention was directed at patients and systems. In this trial, call center staff at the Biogen call center used a software-based counseling intervention. This software, which was based on the transtheoretical model of change and motivational interviewing, focused on increasing persistence in therapy-taking for MS patients. The software program guided call center staff members with appropriate messages to convey to patients during telephone calls about Avonex therapy continuation. Patients in the control group did not receive telephone calls from Biogen call center staff, but they were provided with a toll-free hotline number with which they could reach the call center if needed.

##### Outcome and Timing

The trial did not report on the initiation of therapy or on medication adherence per se. It presented persistence outcomes, looking specifically at discontinuation of Avonex therapy for MS. The trial reported improvement in medication persistence in the intervention arm, but it did not present data on other health outcomes.

##### Setting

The trial was conducted with a group of MS patients who were contacted by a pharmaceutical company (Biogen Idec).

##### Applicability

Although the intervention itself was broadly applicable among MS patients, recruitment of patients was stratified by stage of readiness to discontinue Avonex treatment. The recruitment process involved contacting sufficient participants to get adequate representation across all three stages, which likely makes the study population not representative of the overall MS patient population and hence limits applicability of findings.

#### Key Points

##### Overview

- A single trial intervention, which used software to guide telephone counselors through their conversations with MS patients, significantly improved medication persistence for patients with MS (Table 48).

Table 48 Multiple sclerosis: summary of findings

Type of Intervention | Study | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Counseling (software-based telephone) vs. usual care | Berger et al., 2005 141 N=435 | + Percentage of patients who discontinued use of Avonex therapy for multiple sclerosis | NR

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; N = number; NR = not reported.

##### Software-Based Telephone Counseling Intervention for MS

- Medication persistence: The software-based telephone intervention reduced the percentage of patients who discontinued use of the MS medication (low strength of evidence for benefit).

#### Detailed Synthesis of Results

The intervention, based on the transtheoretical model of change, significantly improved medication persistence for individuals with MS (Table 49, as measured by proportion of patients who discontinued MS treatment) when compared with those who did not receive this intervention (low strength of evidence for benefit) (Table 50).

Table 49 Multiple sclerosis: detailed medication outcomes

Type of Intervention | Study N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, direction) | Source | Baseline | First Followup | Additional Followups
Counseling (software-based telephone) | Berger et al., 2005 141 G1: 172 G2: 195 | Adults currently on MS therapy with Avonex Network of patients with MS contacted by Biogen (manufacturer of this drug) | G1: Software-based counseling intervention to contact patients (depending on stage of readiness and importance of continuing the medicine); call center staff used Web-based software to guide them through motivational interviewing based counseling sessions. G2: Patients did not receive calls, but had access to call center staff via standard toll-free hotline mechanisms. | Every 2 or 4 weeks | Percentage of patients who discontinued use of Avonex therapy for MS | Self-report | NR | G1: 2 (1.2%) discontinued G2: 17 (8.7%) discontinued 95% CI, NR P= 0.001 | NR

Abbreviations: CI = confidence interval; G = group; MS = multiple sclerosis; NR = not reported.

Table 50 Software-based telephone counseling interventions for multiple sclerosis: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Counseling (software-based telephone) vs. less intense intervention | 1; 435(367) | Percentage of patients who discontinued therapy | RCT Medium | Unknown | Direct | Precise | Difference in percentage points of patients who discontinued use of MS therapy: 7.5 Low

Abbreviations: MS = multiple sclerosis; N = number; RCT = randomized controlled trial.

### Key Question 1 Musculoskeletal Diseases: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

Three trials examined interventions designed to improve medication adherence in populations that had musculoskeletal diseases.142,143 We rated two trials as having low risk of bias142,144 and the other as having medium risk of bias.143

##### Population

One trial focused on populations with rheumatoid arthritis, psoriatic arthritis, and inflammatory arthritis.142 The other two trials focused on populations with osteoporosis or osteopenia.143,144

##### Intervention

Two trials were directed at patients and systems-level change.142,143 In one, the intervention consisted of case management, which included appointments with a health educator in addition to standard rheumatology care, a notebook containing Arthritis Foundation pamphlets, medicine calendars, and a map of the hospital.142 In the other trial, the intervention group received care from a physician assistant and monthly telephone conversations with staff in a virtual osteoporosis clinic. One trial, directed only at patients, involved use of a decision aid (a tailored pictographic 10-year fracture risk estimate, absolute risk reduction with bisphosphonates, side-effects, and out-of-pocket cost).144

##### Comparator

In one trial, patients in the control group received standard care, defined as care from their rheumatologist;142 In addition, they received pamphlets from the Arthritis Foundation, examples of medicine calendars, and a map of the hospital (but not educational visits).142 In another trial, the control group received usual care, defined as referral to and evaluation and treatment from, a primary care physician.143 Finally, in a third, the control group received usual care, defined as review of bone mineral density results without calculations of fracture risk in addition to a standard brochure.144

##### Outcome and Timing

One trial examined adherence.142 Adherence was measured using a self-report from patients and creating a mean score of adherence at various time points (baseline, 6 months, and 12 months).142 The change in adherence from baseline to various time points was measured.142 Another trial examined initiation of treatment measured by examining the percentage of study subjects who filled osteoporosis medication within 130 days of enrolling in the trial.143 In addition, for those trials in which medication adherence improved significantly, we included relevant health outcomes when reported. Such information, specifically patient satisfaction outcomes, which was an overall self-reported level of satisfaction regarding osteoporosis treatment, was relevant and reported for one trial.143 The third trial, which focused only on patients, assessed adherence, persistence, and initiation of therapy.144 Adherence and persistence were measured at 6 months using pharmacy refill data;144 adherence was measured at 6 months by self-report.144 Initiation of bisphosphonates therapy was measured at baseline using pharmacy refill data.144

##### Setting

One trial was conducted in an arthritis center of an urban teaching hospital.142 Another focused on patients with osteoporosis, was conducted at the Kaiser Permanente San Diego Department of Preventive Medicine.143 The third trial, focused on patients with osteoporosis or osteopenia, was conducted in 10 general medicine and primary care practices that were affiliated with the Mayo Clinic in Minnesota.144

##### Applicability

We found all three trials to be broadly applicable to patients with these conditions because of the potential ease with which the interventions described could be more broadly applied and the types of primary care settings in which they were conducted.142–144

#### Key Points

- Three trials evaluated medication adherence. Two reported significant improvement in medication adherence but, in one, improvement in medication adherence was seen only in one of the adherence outcomes reported (Table 51).
- Two trials were directed at patients and systems-level change; one was directed only at patients.
- We evaluated other outcomes (patient satisfaction) for the two trials that showed improvement in medication adherence (insufficient evidence).
- We graded strength of evidence formally for the three trials separately, which equated to grading the following three kinds of interventions: (1) case management, (2) virtual clinic, and (3) a decision aid. We judged the body of evidence as low for the virtual clinic and insufficient evidence for case management and decision aid interventions due to lack of precision.

Table 51 Musculoskeletal diseases: summary of findings

Type of Intervention | Study | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Case management | Rudd et al., 2009^142^ | = Mean score on adherence to treatments scale (0=best, 3=worst); = Percentage change at 6 months in medication adherence outcome; = Percentage change at 12 months in medication adherence outcome | NA
Virtual osteoporosis clinic | Waalen et al., 2009^143^ | + Percentage of women using osteoporosis medication, at 13 months from entry into study | = Patient satisfaction with care, at 1 year and 30 days from entry into study
Decision aid | Montori et al., 2011^144^ | + Proportion with > 80% adherence, 6 months; = Proportion of days covered, 6 months; = Persistence, 6 months; = Proportion that did not miss a dose, 6 months; = Started therapy, baseline | = Mean satisfaction with knowledge transfer

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; N = number.

#### Detailed Synthesis for Interventions for Musculoskeletal Diseases

##### Medication Adherence

One trial examined initiation of treatment and showed that a telephone-based virtual clinic intervention can increase the use of osteoporosis medication among newly diagnosed women (Table 52 and Table 53, low strength of evidence of benefit).143 In this trial, initiation of treatment was measured by examining the percentage of women who were using osteoporosis medication (at 1 year and 30 days from entry into the study) using a pharmacy database.

Table 52 Musculoskeletal conditions: detailed medication outcomes

Type of Intervention | Study N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, Direction) | Source | Baseline | First Followup | Additional Followups
Case management | Rudd et al., 2009^142^ Adherence baseline G1: 51 G2: 63 Adherence 6 months G1: 49 G2: 57 Adherence 12 months G1: 48 G2: 57 Percentage change 6 months G1: 49 G2: 57 Percentage change 12 months G1: 48 G2: 57 | Adults with arthritis; who had ≥one visit with rheumatologist Arthritis center in urban teaching hospital | G1: Case management that included standard rheumatology care; a notebook containing Arthritis Foundation pamphlets written in plain language, examples of medicine calendars, and hospital map; two appointments with health educator. G2: Standard rheumatology care and a notebook containing Arthritis Foundation pamphlets, examples of medicine calendars, and hospital map. | Individualized care involved two appointments, 1 hour each, with an educator | Mean score on adherence to treatments scale (0=best, 3=worst) | Self-report | G1: 0.40 (0.40) G2: 0.30 (0.37) | 6 months: 6-month mean (SD) G1: 0.23 (0.28) G2: 0.24 (0.32) | 12 months: 12-month mean (SD) G1: 0.17 (0.25) G2: 0.18 (0.30)
Case management | | Adults with arthritis; who had ≥one visit with rheumatologist Arthritis center in urban teaching hospital | | Individualized care involved two appointments, 1 hour each, with an educator | Percentage change medication adherence outcome | Self-report | | 6 months G1: −4.76 G2: 0.25 95% CI, NR p= 0.33 | 12 months G1: −12.21 G2: −3.12 95% CI, NR p= 0.10
Virtual osteoporosis clinic | Waalen et al., 2009 143 G1: 109 G2: 102 | Women ≥60 years, who had uncomplicated osteoporosis and who had not previously identified as having osteoporosis Kaiser Permanente San Diego Department of Preventive Medicine | G1: Patients received care from a PA under the supervision of a physician. G2: Patients received a referral to their usual primary care physician and were told they would be contacted by the PCP for followup. No further contact with the patient was initiated by the osteoporosis clinic until the end of the study. | One-time mailing; open-ended telephone conversation | Percentage of women using osteoporosis medication Measured at 1 year and 30 days from entry into study | Pharmacy database | NR | G1: 68.8% G2: 45.1% 95% CI, NR p: <0.001 | NR
Decision aid | Montori et al., 2011^144^ Initiation: Started therapy G1 52 G2: 48 Adherence: > 80% days covered: G1: 23 G2: 19 Adherence: Median (range) proportion of days covered: G1: 23 G2: 19 Persistence: Median (range) number of days covered G1: 23 G2: 19 Adherence: Did not miss a dose G1: 17 G2: 19 | Postmenopausal women, ≥50 years, bone mineral density levels consistent with osteopenia or osteoporosis, not already under osteoporosis medication, found eligible for bisphosphonate therapy, had a followup appointment with clinician and were available for phone followup 6 months from initial appointment 10 general medicine and primary care practice in MN, affiliated with the Mayo Clinic | G1: Intervention patients received a decision aid in addition to usual care. G2: Control patients received a standard brochure in addition to usual care. | Patients in intervention group had access to the decision aid during their consultation with a physician, discussed the decision aid during the consultation, and then took the decision aid home. | Initiation: Started therapy | Pharmacy refill data | Total G1: 44% G2: 40% 95% CI: NR p= NR <10% Risk Category G1: 50% G2: 25% 95% CI: NR p= NR 10 to 30% Risk Category G1: 45% G2: 45% 95% CI: NR p= NR >30% Risk Category G1: 40% G2: 33% 95% CI: NR p=NR | NA | NA
Decision aid | | | G1: Intervention patients received a decision aid in addition to usual care. G2: Control patients received a standard brochure in addition to usual care. | Patients in intervention group had access to the decision aid during their consultation with a physician, discussed the decision aid during the consultation, and then took the decision aid home. | Adherence: > 80% days covered | Pharmacy refill data | NR | 6 months G1: 100% G2: 74% 95% CI: NR p=0.009 | NR
Decision aid | | | G1: Intervention patients received a decision aid in addition to usual care. G2: Control patients received a standard brochure in addition to usual care. | Patients in intervention group had access to the decision aid during their consultation with a physician, discussed the decision aid during the consultation, and then took the decision aid home. | Adherence: Median (range) proportion of days covered | Pharmacy refill data | NR | 6 months G1: 100 (86.1 to 100) G2: 98.2 (0 to 100) 95% CI: NR p= 0.09 | NR
Decision aid | | | G1: Intervention patients received a decision aid in addition to usual care. G2: Control patients received a standard brochure in addition to usual care. | Patients in intervention group had access to the decision aid during their consultation with a physician, discussed the decision aid during the consultation, and then took the decision aid home. | Persistence: Median (range) number of days covered | Pharmacy refill data | NR | 6 months G1: 170 (30 to 180) G2: 180 (28 to 180) 95% CI: NR p= 0.38 | NR
Decision aid | | | G1: Intervention patients received a decision aid in addition to usual care. G2: Control patients received a standard brochure in addition to usual care. | Patients in intervention group had access to the decision aid during their consultation with a physician, discussed the decision aid during the consultation, and then took the decision aid home. | Adherence: did not miss a dose | Self-report | NR | 6 months G1: 65% G2: 63% 95% CI: NR p=0.92 | NR

Abbreviations: CI = confidence interval; G = group; NR = not reported; PA = Physician Assistant.

Table 53 Virtual clinic interventions for musculoskeletal diseases: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Virtual clinic vs. usual care | 1; 235 (211) | Initiation of treatment | RCT Medium | Unknown | Indirect | Precise | Difference in percentage of women using osteoporosis medication at (G1 vs. G2) at 13 months: 23.7 Low
Virtual clinic vs. usual care | 1; 235 (211) | Patient satisfaction | RCT Medium | Unknown | Direct | Imprecise | No statistically significant difference Insufficient

Abbreviations: G = group; RCT = randomized controlled trial; vs. = versus.

Another trial, using a decision aid as the intervention, measured initiation of therapy at baseline using pharmacy refill data (Table 52).144

One trial, using a case management intervention, examined adherence but did not show a significant effect of the intervention on adherence (Table 52).142

The trial using the decision aid examined adherence and showed a significant difference in the proportion of patients with more than 80 percent adherence at 6 months among those in the intervention group, as compared with the control group. Other medication adherence outcomes in the same trial showed no significant differences between the intervention and the control. The same trial measured initiation of therapy at baseline.144 This trial also examined persistence in adherence and did not show significant difference of the intervention.144

We judged the body of evidence as insufficient to rate strength of evidence for the case management and decision aid interventions (Table 54 and Table 55).

Table 54 Case management interventions for musculoskeletal diseases: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Case management vs. usual care | 1; 127 (127) | Medication adherence | RCT Low | Unknown | Direct | Imprecise | Difference in mean adherence score (G1 vs. G2) at 6 months: −0.01 Insufficient

Abbreviations: G = group; RCT = randomized controlled trial; vs. = versus.

Table 55 Decision aid interventions for musculoskeletal diseases: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Decision aid vs. usual care | 1; 100 (100) | Medication adherence | RCT Low | Unknown | Indirect | Imprecise | Various outcomes with varied measures Insufficient
Decision aid vs. usual care | 1; 100 (100) | Persistence | RCT Low | Unknown | Indirect | Imprecise | No statistically significant difference Insufficient
Decision aid vs. usual care | 1; 100 (100) | Initiation of therapy | RCT Low | Unknown | Indirect | NR | Insufficient
Decision aid vs. usual care | 1; 100 (NR) | Patient satisfaction | RCT Low | Unknown | Indirect | Imprecise | No statistically significant difference Insufficient

Abbreviations: NR = not reported; RCT = randomized controlled trial; vs. = versus.

##### Other Outcomes

In one trial where medication adherence outcomes were improved for those in the intervention group,143 patient satisfaction outcomes were collected using a poststudy questionnaire completed by approximately 65 percent of women in both the intervention and the control groups (Appendix G). However, no significant differences were seen between groups when women were asked whether their treatment experiences for osteoporosis were good (Table 55). In the other trial where significant differences were seen in the intervention group, when examining the proportion of patients with more than 80 percent adherence, patient satisfaction with knowledge transfer was measured by self-report. The trial found no significant differences, suggesting insufficient strength of evidence (Table 55).144

### Key Question 1 Unspecified or Multiple Chronic Conditions: Medication Adherence Interventions

#### Description of Included Studies

##### Overview

Four trials examined interventions designed to improve medication adherence in populations that had unspecified or multiple chronic conditions.145–148 We rated one trial as having a low risk of bias146 and the other three as having medium risk of bias.145,147,148

This section includes trials that are not featured in other sections of this KQ. Specifically, this section includes trials with populations that had unspecified chronic conditions or multiple chronic conditions. Multiple chronic conditions does not refer to coexisting conditions, unless the conditions are unspecified, in which case multiple unspecified conditions may be present simultaneously. Explicitly mentioned coexisting conditions (such as, for example, studies of patients with diabetes and hypertension as comorbidities) are included in KQ 4, which deals with vulnerable populations.

##### Population

We included here trials that populations with various multiple or unspecified chronic conditions. In trials that specified multiple conditions, the disorders included diabetes, hypertension, hyperlipidemia, and depression.

##### Intervention

In three of these four trials, the interventions included interaction with a pharmacist, a pharmacy outreach program, medication-related education (conducted by a pharmacist via telephone conversations with the patient), and a problem-solving intervention.145–147 In the fourth, an interdisciplinary case management intervention formed the basis for what the authors termed as a “primary intensive care” intervention.148

##### Comparator

The comparator in each case was a usual-care control group (essentially a care environment that followed a typical standard of care for that group of patients). The specific components of usual care varied considerably because each trial had a different combination of chronic diseases and different intervention components. In the trial involving an interdisciplinary care environment, usual care was care directed by the primary care provider and the same psychiatrist who provided consultation services for the intervention group provided consultation for control group patients, but only if the provider specifically requested it.148 Usual care in one trial was described as regular filling of prescriptions as requested by patients, without the pharmacist contact that the intervention included.145 In another trial with pharmacist contact, usual care included routine review of medication and counseling by a nurse before discharge.146 In the fourth trial, usual care included pharmacist evaluation of prescribed medications and clinical outcomes, but the pharmacist did not provide any form of counseling or advice to the patient.147

##### Outcome and Timing

None of the four trials reported on the initiation of therapy. All trials examined and reported adherence-related outcomes,145–148 measured in different ways. Three trials relied on self–report.146–148 A fourth assessed medication adherence using pharmacy refill data.145 In one trial, exactly when outcomes were measured was unclear, although the references to “during the intervention year” indicated that various measurements were taken during the intervention or immediately after it.148 In another, outcomes were measured at the completion of intervention (which was at the 12-month mark).147 In one, medication adherence outcomes focused on whether the patient had taken each medication as prescribed on the previous day.146 Finally, one trial measured outcomes during the interventions, when pharmacists contacted the patients, but the exact timing was unclear.145

##### Setting

One trial was done in nine pharmacies where pharmacists either called patients or faxed physicians.145 One trial was conducted among patients who were discharged from one of four teams on the general medicine service of a hospital and were under the care by a hospital physician or resident.146 A third trial was conducted within the primary care center of a hospital148 The fourth trial was conducted in community-based physician offices.147

##### Applicability

Applicability of interventions examined is limited in several ways. First, the level of involvement of pharmacists in the intervention arm was appreciably greater than the currently accepted level of pharmacist involvement.145 Second, the intensity (duration and frequency of contact) of the multidisciplinary intervention may be high for routine or common use.148

#### Key Points

##### Overview

- Of the four trials, none significantly improved medication adherence (low strength of evidence of no benefit) (Table 56). The evidence suggests that pharmacy outreach, education, and problem-solving interventions (all pharmacist-led) have no benefit (low strength of evidence of no benefit). The case management intervention, called the “primary intensive care” intervention, did not improve adherence (insufficient evidence).

Table 56 Unspecified or multiple chronic conditions: summary of findings

Type of Intervention | Study | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Pharmacy outreach | Nietert et al., 2009^145^ N=3048 | = Time-to-refill (days); = Filled prescription for any qualified medication in the same chronic disease classification as the index medication, within 30 days of index date; = Filled prescription for any qualified medication in the same chronic disease classification as the index medication, within 60 days of index date; = Filled prescription for any medication, within 30 days of index date | NA
Education | Schnipper et al., 2006^146^ N=178 | = Medication adherence score on previous day; = Number of patients nonadherent with at least one medication | NA
Problem-solving intervention | Taylor et al., 2003^147^ N=81 | = Medication adherence | NA
Case management intervention | Sledge et al., 2006^148^ N=96 | = Medication adherence score | NA

Abbreviations: (+) = statistically significant difference favoring intervention arm(s); (=) = no statistically significant difference; (−) = statistically significant difference favoring comparison arm; N = number; NA = not applicable.

##### Pharmacist-Led Outreach, Education, and Problem-Solving Interventions

- Medication adherence: Three trials (dominated by one with a large sample size [more than 3,000 patients analyzed] did not significantly improve medication adherence (low strength of evidence for no benefit). The large trial, in a post hoc analysis, reported that its physician-directed intervention arm may be inferior to usual care in improving time to refill for medications (insufficient evidence).

##### Case Management Intervention

- Medication adherence: The “primary intensive care” trial did not improve medication adherence (insufficient strength of evidence).

#### Detailed Synthesis of Interventions for Unspecified or Multiple Chronic Conditions

Four trials, each dealing with populations with unspecified or multiple chronic conditions, met the inclusion criteria for our review (Table 57).145–148 One trial was directed at patients,147 one at patients and providers,145 one at patients and systems, 146 and one (with a multidisciplinary approach), was directed at systems-level change.148 No trial found statistically significant differences in adherence between the intervention and control groups (Table 58 and Table 59).145–148

Table 57 Unspecified or multiple chronic conditions: detailed medication outcomes

Type of Intervention | Study N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, Direction) | Source | Baseline | First Followup | Additional Followups
Pharmacy outreach | Nietert et al., 2009^145^ G1: 1,018 G2: 1,016 G3: 1,014 | Patients with prescription for one of multiple chronic conditions, with least two refills remaining Nine pharmacies within a medium-sized grocery store chain | G1: Phone patient intervention G2: Fax physician intervention G3: Usual care | | Time-to-refill (days from index date^a^ to date of refill or end of study) | Pharmacy refill data | NA | Adjusted G1: HR 97.5% CI, 0.93 (0.82 to 1.06) G2: HR, 98.3% CI, 0.87 (0.76 to 1.00) G3: HR, 95% CI, 0.93 (0.83 to 1.05) 95% CI = NR p= NR | NR
Pharmacy outreach | Nietert et al., 2009^145^ G1: 1,018 G2: 1,016 G3: 1,014 | Patients with prescription for one of multiple chronic conditions, with least two refills remaining Nine pharmacies within a medium-sized grocery store chain | G1: Phone patient intervention G2: Fax physician intervention G3: Usual care | | Filled prescription for any qualified medication in the same chronic disease classification as the index disease,^b^ within 30 days of index date^a^ | Pharmacy refill data | NA | Adjusted G1: Hazard ratio (HR, 98.3% CI), 0.79 (0.61 to 1.03) G2: HR, 97.5% CI, 0.83 (0.65 to 1.06) G3: HR, 95.0% CI, 0.96 (0.77 to 1.20) 95% CI = NR p= NR | NA
Pharmacy outreach | Nietert et al., 2009^145^ G1: 1,018 G2: 1,016 G3: 1,014 | Patients with prescription for one of multiple chronic conditions, with least two refills remaining Nine pharmacies within a medium-sized grocery store chain | G1: Phone patient intervention G2: Fax physician intervention G3: Usual care | | Filled prescription for any qualified medication in the same chronic disease classification as the index disease,^b^ within 60 days of index date^a^ | Pharmacy refill data | NA | Adjusted G1: Hazard ratio (HR, 97.5% CI), 0.86 (0.68 to 1.08) G2: HR, 97.5% CI, 0.83 (0.65 to 1.07) G3: HR, 95.0% CI, 1.03 (0.84 to 1.26) 95% CI =NR p= NR | NA
Pharmacy outreach | Nietert et al., 2009^145^ G1: 1,018 G2: 1,016 G3: 1,014 | Patients with prescription for one of multiple chronic conditions, with least two refills remaining Nine pharmacies within a medium-sized grocery store chain | G1: Phone patient intervention G2: Fax physician intervention G3: Usual care | | Filled prescription for any medication, within 30 days of index date^a^ | Pharmacy refill data | NA | Adjusted G1: Hazard ratio (HR, 98.3% CI), 0.86 (0.68 to 1.08) G2: HR, 95.0% CI, 0.99 (0.81 to 1.19) G3: HR, 97.5% CI, 0.87 (0.70 to 1.08) 95% CI = NR p= NR | NA
Education (pharmacist-led) | Schnipper et al., 2006^146^ Medication adherence score on previous day: G1: 92 G2: 84 Number of patients nonadherent: G1: 67 G2: 62 | Discharged patients from general medicine service of hospital Hospital setting | G1: Pharmacist intervention involved review of medication regimen and followup call with patient G2: Routine review of medication orders by a ward-based pharmacist and medication counseling by a nurse at the time of discharge | Pharmacist counseling at the time of discharge with followup call 3 to 5 days after discharge | Medication adherence score on previous day (0 to 100; 100 indicates complete adherence with all medications) | Self-report | NR | G1: 88.9 (0.71 to 1.00) G2: 87.5 (0.73 to 1.00) 95% CI, NR p= 0.91 | NR
Education (pharmacist-led) | Schnipper et al., 2006^146^ Medication adherence score on previous day: G1: 92 G2: 84 Number of patients nonadherent: G1: 67 G2: 62 | Discharged patients from general medicine service of hospital Hospital setting | | Pharmacist counseling at the time of discharge with followup call 3 to 5 days after discharge | Number of patients nonadherent | Self-report | NR | G1: 36 (54%) G2: 33 (53%) 95 % CI, NR p>0.99 | NR
Problem-solving (pharmacist-led) | Taylor et al., 2003^147^ G1: 33 G2: 36 | Adults at participating clinics at high risk for medication-related adverse events Community-based physician offices | G1: Usual medical care, and pharmacotherapeutic interventions by a pharmacist during regularly scheduled office visits G2: Standard medical care without pharmaceutical care | Patient met with pharmacist for 20 minutes prior to seeing physician | Medication adherence: (Took ≥80% of all medications in past month) | Self-report | G1: 84.9 (6.7) G2: 88.9 (5.8) | 12 months: Mean (SD) compliant patients G1: 100 G2: 88.9 (6.3) 95% CI, NR p= 0.115
Case Management | Sledge et al., 2006^148^ G1: NR G2: NR | Adults with ≥two medical or surgical hospital admissions Primary care center of an urban, academically affiliated hospital | G1: Comprehensive interdisciplinary medical and psychosocial assessment (and ambulatory case management for 1 year in addition to usual care G2: Usual care directed by their PCP, including psychiatric consultation which was available on-site if requested by the PCP | 2- to 3-hour visit that include comprehensive interdisciplinary assessment Case management for 1 year in addition to usual care | Medication adherence score | Self-report | G1: 1.4 G2: 1.3 p = nonsignficant | G1: NR G2: NR p = nonsignificant | NR

a Index date: the first date during the study period when the patient was seven days overdue

b Index disease: the chronic disease associated with the prescription on the index date

Abbreviations: CI = confidence interval; G = group; N = number; NA = not applicable; NR = not reported; PCP = primary care physician.

Table 58 Pharmacist-led outreach, education, and problem-solving interventions for unspecified or multiple chronic conditions: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Pharmacist-based interventions (pharmacy outreach, education and problem solving) vs. usual care | 3; 3307 (3269) | Persistence of prescription refills (number of days from recommended refill date) | RCT Medium | Unknown | Indirect | Imprecise | No significant difference in time to refill across arms. Low

Abbreviations: N = number; NR = not reported; RCT = randomized controlled trial.

Table 59 Case management interventions for unspecified or multiple chronic conditions: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Case management vs. usual care | 1; 96(75) | Medication Adherence | RCT Medium | Unknown | Indirect | Imprecise | No significant difference in medication adherence score across arms Insufficient

Abbreviations: N = number; NR = not reported; RCT = randomized controlled trial.

## Key Question 2 Summary of Policy-Level Interventions: Medication Adherence and Other Outcomes

This KQ evaluates the effect of policy-level interventions on medication adherence. We describe included studies, present key points for the body of evidence, and give a detailed synthesis of included studies. Appendix G presents information concerning clinical and economic outcomes, respectively.

### Description of Included Studies

#### Overview

Five studies evaluated the effects of policy interventions on medication adherence.149–153 Four of these studies were nonexperimental studies that used cohort designs and had a medium risk of bias. One study used an RCT design with low risk of bias.153

#### Population, Intervention, and Comparator

Four studies examined the effect of reduced medication copays on medication adherence. The remaining policy study investigated the impact of Medicare Part D on medication adherence among adults ages 65 or older with hyperlipidemia, hypertension, and/or diabetes.

Of the four copay studies, one RCT tested the effect of eliminating copays for brand-name and generic medications in four classes—angiotensin-converting-enzyme (ACE) inhibitors, angiotensin receptor blockers (ARBs), beta-blockers, and 3-hydroxy-3-methyl-glutaryl-CoA reductase inhibitors (statins) for patients after their discharge from a hospital for a myocardial infarction.153 The study excluded individuals if they were enrolled in a health savings account or were 65 years of age or older. All participants received medical and prescription drug coverage through Aetna, and randomization was performed at the plan level. In addition to assessing the impact of reduced medication copays on adherence, this trial examined the effect of the policy change on clinical outcomes, including major vascular events and revascularization, and on patient and insurer prescription drug and nondrug spending.

Three other cohort studies examined the effect of reduced medication copays. One study evaluated the effects of reduced copays for medications in five classes—ACE inhibitors, ARBs, beta-blockers, diabetes medications, statins, and inhaled corticosteroids—for employees and covered dependents of a large company that used a specific disease management program.149 This study was limited to adults ages 18 to 64 years. It compared the outcomes of the policy change with outcomes for employees and covered dependents of another large employer that used the same disease management program but kept medication copays stable during the study.

Another study examined the effects of reduced copays for statins and clopidogrel (an antiplatelet medication) for beneficiaries of Pitney Bowes, a large company located in New Jersey.150 Although this study did not impose age restrictions, the mean age ranged from 53.8 to 67.5 years across groups. This study compared outcomes of the policy change with outcomes for beneficiaries of Horizon Blue Cross Blue Shield of New Jersey, which uses the same pharmacy benefit manager as Pitney Bowes but maintained stable medication copays during the study

The third study examined the effect of a value-based insurance design program implemented by Blue Cross Blue Shield of North Carolina.152 This program reduced copays for brand-name medications used to treat diabetes, hypertension, hyperlipidemia, and heart failure for all of the insurer’s enrollees; it eliminated copays for generic medications for enrollees whose employer opted into the program. The study compared outcomes of individuals whose employer opted into the program with those of individuals whose employer did not join the program. Because copays in the two groups differed only for generic medications, the investigators hypothesized that changes in adherence to brand-name drugs would be similar across the two groups but that individuals who participated in the program would exhibit greater changes in adherence to generic medications.

The remaining study investigating a policy-level intervention examined the impact of Medicare Part D on medication adherence among adults ages 65 or older with hyperlipidemia, hypertension, and/or diabetes.151 The study restricted participants to those who were continuously enrolled in a large Pennsylvania insurer’s Medicare Advantage products between 2003 and 2007.^151^ The study had three groups that varied in their level of coverage for prescription medications before the introduction of Medicare Part D; the prior coverage ranged from no coverage to a $350 quarterly cap on costs that were covered by the insurer. Thus, individuals in these three groups experienced an improvement in coverage when Medicare Part D was introduced. The study had a comparison group of individuals with retiree health insurance that almost always provided more generous coverage for prescription medications than that offered by Medicare Part D plans. Thus, individuals in the comparison group did not experience improved prescription drug coverage following implementation of Medicare Part D.

#### Outcome and Timing

In three of the cohort studies, the investigators tracked medication adherence for 1 year before and 1 year after the change in copay using either the MPR or proportion of days covered (PDC); both measures reflect the days of medication supply obtained during a specified period of time divided by the number of days in the period.149,150,152 The other cohort study tracked the MPR for 4 years, 2 years before and 2 years after the introduction of Medicare Part D.151 The trial tracked participants for up to 3 years following randomization; the median duration of followup was 394 days.153

#### Applicability

We regarded all five studies as broadly applicable to these types of policy changes and outcomes. We assessed four of the studies as broadly applicable to the remaining criteria considered (i.e., population, comparator). However, we considered the remaining (nonexperimental) study as potentially less applicable to population and comparator because it was limited to individuals who had been continuously enrolled in a Medicare Advantage plan from 2004 through 2007.^151^ In 2004, only 13 percent of Medicare beneficiaries were enrolled in such plans.154

### Key Points

- All five studies found statistically significant differences in adherence between the intervention and comparison groups following implementation of policies decreasing copays or improving prescription drug coverage for all medications except inhaled corticosteroids (moderate strength of evidence for benefit).
- In two studies,149,150 medication adherence decreased over time in both intervention and comparisons groups. Thus, the between-group differences observed were caused by a difference in the extent to which adherence declined. In another study, medication adherence decreased over time in the comparison group and remained stable in the intervention group, accounting for the between-group difference observed.152
- Among patients with cardiovascular disease, consistent results from four observational studies and one RCT suggest that policy interventions can improve medication adherence (moderate strength of evidence of benefit).
- Among patients with diabetes, consistent results from three observational studies suggest that policy interventions can improve medication adherence (moderate strength of evidence for benefit).
- Among patients taking inhaled corticosteroids, results from one study did not show a benefit of reduced copays (insufficient evidence).
- Results from one RCT (low risk of bias) suggest that eliminating copays for preventive medications following a myocardial infarction can decrease the risk of fatal and nonfatal vascular events (insufficient strength of evidence for benefit).

### Detailed Synthesis

Four policy-level studies examined effects of reduced medication copays on adherence to medications used to treat cardiovascular diseases (Table 60).149,150,152,153 All four studies (three cohort; one RCT) performed analyses using MPR or PDC as a continuous measure and found statistically significant between-group differences, favoring the intervention group, that ranged from 1.31 to 6.2 percentage points.

Table 60 Policy interventions: medication adherence

Author, Year | N per Group | Sample; Setting | Intervention Groups | Intervention Dose | Measure (Range, Direction) | Source | Baseline | Followup
Chernew et al., 2008^149^ | For diabetes drugs: 2004 (pre) G1: range 919 to 1,245 G2: range 3,596 to 4,185 2005 (post) G1: range 1,056 to 1,306 G2: range 3,535 to 4,072 For all other drugs: N: NR | Adults, ages 18 to 64 years; employee health plan | G1: Employer-based health insurance plan implemented policy to reduce copays for five chronic medication classes as part of a disease management program. G2: No reduction in copays | Copays for generics were reduced to zero, copays for brand-name medications were reduced by half of previous value | Change in MPR (0 to 100%) | Prescription claims data | 69.5 | Diabetes drugs: 4.02, p<0.001
Chernew et al., 2008^149^ | For diabetes drugs: 2004 (pre) G1: range 919 to 1,245 G2: range 3,596 to 4,185 2005 (post) G1: range 1,056 to 1,306 G2: range 3,535 to 4,072 For all other drugs: N: NR | Adults, ages 18 to 64 years; employee health plan | G1: Employer-based health insurance plan implemented policy to reduce copays for five chronic medication classes as part of a disease management program. G2: No reduction in copays | Copays for generics were reduced to zero, copays for brand-name medications were reduced by half of previous value | Change in MPR (0 to 100%) | Prescription claims data | 68.4 | ACE inhibitors or ARBs: 2.59, p<0.001
Chernew et al., 2008^149^ | For diabetes drugs: 2004 (pre) G1: range 919 to 1,245 G2: range 3,596 to 4,185 2005 (post) G1: range 1,056 to 1,306 G2: range 3,535 to 4,072 For all other drugs: N: NR | Adults, ages 18 to 64 years; employee health plan | G1: Employer-based health insurance plan implemented policy to reduce copays for five chronic medication classes as part of a disease management program. G2: No reduction in copays | Copays for generics were reduced to zero, copays for brand-name medications were reduced by half of previous value | Change in MPR (0 to 100%) | Prescription claims data | 68.3 | Beta blockers: 3.02, p<0.001
Chernew et al., 2008^149^ | For diabetes drugs: 2004 (pre) G1: range 919 to 1,245 G2: range 3,596 to 4,185 2005 (post) G1: range 1,056 to 1,306 G2: range 3,535 to 4,072 For all other drugs: N: NR | Adults, ages 18 to 64 years; employee health plan | G1: Employer-based health insurance plan implemented policy to reduce copays for five chronic medication classes as part of a disease management program. G2: No reduction in copays | Copays for generics were reduced to zero, copays for brand-name medications were reduced by half of previous value | Change in MPR (0 to 100%) | Prescription claims data | 53.0 | Statins: 3.39, p<0.001
Chernew et al., 2008^149^ | For diabetes drugs: 2004 (pre) G1: range 919 to 1,245 G2: range 3,596 to 4,185 2005 (post) G1: range 1,056 to 1,306 G2: range 3,535 to 4,072 For all other drugs: N: NR | Adults, ages 18 to 64 years; employee health plan | G1: Employer-based health insurance plan implemented policy to reduce copays for five chronic medication classes as part of a disease management program. G2: No reduction in copays | Copays for generics were reduced to zero, copays for brand-name medications were reduced by half of previous value | Change in MPR (0 to 100%) | Prescription claims data | 31.6 | Inhaled corticosteroids: 1.86, p<0.134
Choudhry et al., 2010^150^ | G1: 2,051 G2: 779 G3: 38,174 G4: 11,627 | Patients with prescription claims for a statin or clopidogrel; pharmacy benefits management organization | G1: Pitney Bowes employees and beneficiaries with diabetes or vascular disease G2: Pitney Bowes employees and beneficiaries prescribed clopidogrel G3: Beneficiaries of BCBS of NJ G4: Beneficiaries of BCBS of NJ | G1: Elimination of copayments for statins G2: Lowered copayments for clopidogrel G3: No change in copayments for statins G4: No change in copayments for clopidogrel | Change in PDC (0 to 100%) | Prescription claims data | NR | Statin users G1: Immediate 3.1% higher PDC relative to G3 following copay reduction, with no subsequent change in slope over 12 months of followup; 95% CI, NR; p<0.05
Choudhry et al., 2010^150^ | G1: 2,051 G2: 779 G3: 38,174 G4: 11,627 | Patients with prescription claims for a statin or clopidogrel; pharmacy benefits management organization | | G1: Elimination of copayments for statins G2: Lowered copayments for clopidogrel G3: No change in copayments for statins G4: No change in copayments for clopidogrel | Change in PDC (0 to 100%) | Prescription claims data | NR | Clopidogrel users G2: Immediate 4.2% higher PDC relative to G4 following copay reduction, with no subsequent change in slope over 12 months of followup; 95% CI, NR; p <0.05
Choudhry et al., 2010^150^ | G1: 2,051 G2: 779 G3: 38,174 G4: 11,627 | Patients with prescription claims for a statin or clopidogrel; pharmacy benefits management organization | | G1: Elimination of copayments for statins G2: Lowered copayments for clopidogrel G3: No change in copayments for statins G4: No change in copayments for clopidogrel | Odds of PDC ≥ 0.80 | Prescription claims data | | Statin users G1: Immediate 17.0% change in odds of adherence relative to G3 following copay reduction, with no subsequent change in slope over 12 months of followup; 95% CI, NR; p <0.05
Choudhry et al., 2010^150^ | G1: 2,051 G2: 779 G3: 38,174 G4: 11,627 | Patients with prescription claims for a statin or clopidogrel; pharmacy benefits management organization | | G1: Elimination of copayments for statins G2: Lowered copayments for clopidogrel G3: No change in copayments for statins G4: No change in copayments for clopidogrel | Odds of PDC ≥ 0.80 | Prescription claims data | | Clopidogrel users G2: Immediate 19.9% change in odds of adherence relative to G4, with no subsequent change in slope over 12 months of followup; 95% CI, NR; p<0.05
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | G1: No drug coverage prior to Medicare Part D G2: Some drug coverage before Medicare Part D with a $150 quarterly cap on plan payment G3: Some drug coverage before Medicare Part D with a $350 quarterly cap on plan payment G4: Comparison group, covered by retiree health benefits had no deductible, paid copayments of $10 to $20 per monthly prescription. No change in benefits during study | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | | Estimate (95% CI)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | | Diabetes drugs
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 57.0 | G1: 17.9 (13.7 to 22.1)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 77.3 | G2: 4.5 (1.0 to 7.9)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 75.4 | G3: 3.6 (1.8 to 5.3)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 81.8 | G4: 0 (Ref)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | | Hyperlipidemia drugs
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 47.3 | G1: 13.4 (10.1 to 16.8)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 57.6 | G2: 7.3 (4.8 to 9.8)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 62.3 | G3: 4.4 (3.3 to 5.6)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 74.4 | G4: 0 (Ref)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | | Hypertension drugs
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 62.4 | G1: 13.5 (11.5 to 15.5)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 81.6 | G2: 2.6 (1.2 to 4.1)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 82.7 | G3: 2.5 (1.7 to 3.2)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in MPR (0 to 100%): | Prescription claims data | 85.1 | G4: 0 (Ref)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | | Adjusted odds ratio (95% CI)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | | Diabetes drugs
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 39.7 | G1: 2.36 (1.81 to 3.08)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 68.0 | G2: 1.17 (0.9 to 1.51)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 62.0 | G3: 1.21 (1.06 to 1.39)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 70.6 | G4: 1.00 (Ref)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | | Hyperlipidemia drugs
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 27.5 | G1: 1.67 (1.35 to 2.07)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 39.2 | G2: 1.22 (1.04 to 1.43)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 42.1 | G3: 1.14 (1.06 to 1.24)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 57.4 | G4: 1.00 (Ref)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | | Hypertension drugs
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 47.0 | G1: 2.09 (1.82 to 2.40)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 73.3 | G2: 1.13 (0.99 to 1.29)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 74.9 | G3: 1.14 (1.05 to 1.23)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Odds of MPR ≥ 0.80 | Prescription claims data | 78.4 | G4: 1.00 (Ref)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | | Estimate (95% CI)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | | Diabetes drugs
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | 0.98 | G1: 0.184 (0.1 to 0.27)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | 1.12 | G2: 0.095 (0.03 to 0.16)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | 1.11 | G3: 0.02 (−0.01 to 0.05)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | 1.29 | G4: 0 (Ref)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | | Hypertension drugs
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | 1.26 | G1: 0.221 (0.16 to 0.28)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | 1.48 | G2: 0.054 (0.02 to 0.09)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | 1.52 | G3: 0.028 (0.01 to 0.05)
Zhang et al., 2010^151^ | Diabetes G1: 247 G2: 304 G3: 2,214 G4: 1,253 Hyperlipidemia G1: 418 G2: 647 G3: 5,093 G4: 3,027 Hypertension: G1: 980 G2: 1,234 G3: 8,380 G4: 4141 | Older adults enrolled in Medicare Part D Advantage products; Medicare enrollees | | Implementation of Medicare Part D | Change in average number of pills for condition taken per day | Prescription claims data | 1.65 | G4: 0 (Ref)
Maciejewski et al., 2010^152^ | Metformin G1: 5,077 G2: 2,826 Diuretics G1: 15,605 G2: 9,137 ACE inhibitors G1: 14,250 G2: 7,668 Beta blockers G1: 11,137 G2: 6,343 Statins G1: 18,346 G2: 10,162 Calcium channel blockers G1: 7,191 G2: 4,099 ARBs G1: 7,445 G2: 4,514 Cholesterol absorption inhibitors G1: 4,019 G2: 2,291 | Individuals continuously enrolled in a BCBS of North Carolina health insurance plan between January 2007 and December 2008 | G1: Eliminated copays for generic medications used to treat diabetes, hypertension, hyperlipidemia, and congestive heart and reduced copays for brand-name medications used to treat these conditions G2: Reduced copays for brand-name medications used to treat the conditions listed above. No change in copays for generics | Elimination of copays for generic medications used to treat the conditions specified | Adjusted change in MPR (0 to 100%) | Prescription claims records | NR | Estimate, p-value Metformin: 3.80, p < 0.001 Diuretics: 3.26, p < 0.001 ACE inhibitors: 2.87, p < 0.001 Beta blockers: 2.48, p < 0.001 Statins: 1.81, p < 0.001 Calcium channel blockers: 1.46, p < 0.01 Angiotensin-receptor blockers: −0.10, NS Cholesterol absorption inhibitors: −1.04, NS
Choudhry et al., 2011^153^ | G1: 2,845 G2: 3,010 | Individuals with recent myocardial infarction who had health insurance through Aetna | G1: Eliminated copays for brand-name and generic statins, beta blockers, ACE inhibitors, and ARBs G2: No change in copays | Elimination of copays for generic and brand-name medications in classes specified | MPR (0 to 100%) | Prescription claims records | NR | Mean (SD) ACE inhibitor or ARB: G1:41.1 (39.8) G2:35.9 (38.1) Absolute Difference as reported in article (95% CI): 5.6 (3.4 to 7.7) Mean (SD) Beta-blocker: G1: 49.3 (37.5) G2: 45.0 (36.6) Absolute Difference as reported in article (95% CI): 4.4 (2.3 to 6.5) Mean (SD) Statin: G1: 55.1 (37.7) G2: 49.0 (37.3) Absolute Difference (95% CI): 6.2 (3.9 to 8.5) Mean (SD) All classes combined: G1: 43.9 (33.7) G2: 38.9 (32.7) Absolute Difference (95% CI): 5.4 (3.6 to 7.2)
Choudhry et al., 2011^153^ | G1: 2,845 G2: 3,010 | Individuals with recent myocardial infarction who had health insurance through Aetna | G1: Eliminated copays for brand-name and generic statins, beta blockers, ACE inhibitors, and ARBs G2: No change in copays | Elimination of copays for generic and brand-name medications in classes specified | Odds of MPR ≥ 0.80 | Prescription claims records | NR | ACE inhibitor or ARB: G1: 27.7 G2: 22.9 OR (95% CI): 1.31 (1.14 to 1.49) Beta blockers: G1: 30.7 G2: 25.2 OR (95% CI): 1.32 (1.16 to 1.49) Statins: G1: 38.6 G2: 31.6 OR (95% CI): 1.37 (1.20 to 1.56) All classes combined: G1: 12.1 G2: 8.9 OR (95% CI): 1.41 (1.18 to 1.67)

Abbreviations: ACE = angiotensin-converting-enzyme; ARBs = angiotensin-receptor blockers; BCBS = Blue Cross/Blue Shield; CI = confidence interval; G = group; MPR = medication possession ratio; N = number; NJ = New Jersey; NR = not reported; NS = not significant; OR = odds ratio; PDC = proportion of days covered; Ref = reference; SD = standard deviation.

In two of these studies, medication adherence decreased over time in both intervention and comparison groups.149,150 One study reported MPR scores for statins and clopidrogel ranging across study groups from about 80 percent to 87 percent at baseline and from about 63 percent to 67 percent at followup.150 In another study, adherence decreased among individuals in the comparison group and remained stable among those in the intervention group.152 Finally, the RCT gave no information about baseline adherence.153 Thus, we cannot determine whether the between-group differences observed were caused by improvements in adherence in the intervention group or declines in adherence in the control group.

Two studies dichotomized the medication adherence measure at (a) below 0.8 or (b) at or above 0.8.^150,153^ In the cohort study, individuals in the intervention group had 17 percent to 20 percent greater odds of high adherence than individuals in the comparison group immediately following the copay reduction.150 Thereafter, the magnitude of the between-group difference remained stable over time. In the RCT, the odds of high adherence were between 31 percent and 41 percent higher in the intervention group relative to the control group across the medication classes examined.153 This RCT found a 14 percent reduction in the risk of first fatal or nonfatal vascular events among individuals in the reduced copay group (Appendix G). In addition, patients in the reduced copay group spent less than those in the control group for prescription drugs and nondrug medical services. However, overall spending by the insurance provider was similar for the two groups (Appendix G).

Two cohort studies examined effects of reduced medication copays on adherence to medications for diabetes and reported findings similar to those for cardiovascular diseases (Table 60).149,152 For example, in one of these studies, adherence to diabetes medications decreased from approximately 67 percent at baseline to 60 percent at final followup among individuals in the reduced copay group; by contrast, among individuals in the comparison group, medication adherence decreased from approximately 79 percent at baseline to 68 percent at final followup. Thus, the between-group difference observed at followup could be attributed to the slower rate of decline in MPR in the intervention group relative to the comparison group. In addition, at the last assessment the comparison group had a higher mean MPR than the intervention group. In the other study, individuals in the comparison group had a decline in adherence of about 4 percentage points, whereas individuals in the intervention group had stable adherence over time.152

One study examined the effect of reduced copays on adherence to inhaled corticosteroids.149 Lower copays had no effect on adherence to medications in this class (Table 60).

In three of the observational studies, comparison groups differed on numerous characteristics from the intervention group.149,150,152 In addition, one of the studies lacked sufficient detail to permit us to evaluate fully the analytic methods used.149 In another study, medication copays increased for clopidogrel in the comparison group.150 Therefore, we cannot determine whether the effects observed could be attributed to the decrease in copay in the intervention group, the increase in copay in the comparison group, or a combination of the two changes. These factors weaken the evidence that decreasing medication copays has a beneficial effect on medication adherence. However, the RCT evaluating the effect of reduced medication copays on adherence reported findings very consistent with those reported in the observational studies.153 Therefore, we rated the strength of evidence supporting a beneficial effect of reduced medication copays on medication adherence as moderate (Table 61).

Table 61 Policy interventions: strength of evidence by condition

Condition and Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect/Strength of Evidence
Diabetes
Improved prescription drug coverage vs. Unchanged prescription drug coverage | 3; ~20,000 (~20,000) | Medication adherence | Medium | Consistent | Direct | Precise | Gaining coverage for diabetes medications 17.9 MPR points Reduced copay or improvement of previous coverage About 4 MPR points Moderate
Cardiovascular Disease
Improved prescription drug coverage vs. unchanged prescription drug coverage | 5; >70,000 (>70,000) | Medication adherence | Medium | Consistent | Direct | Precise | Magnitude of effect varies depending on the degree to which coverage is improved Moderate
Improved prescription drug coverage vs. unchanged prescription drug coverage | 1 5,855 (5,855) | Death from cardiovascular causes | Low | Unknown | Direct | Precise | Nonstatistically significant reduction in risk Insufficient
Improved prescription drug coverage vs. unchanged prescription drug coverage | 1 5,855 (5,855) | Rate of first vascular event or revascularization | Low | Unknown | Direct | Precise | Nonstatistically significant decrease in rate Insufficient
Improved prescription drug coverage vs. unchanged prescription drug coverage | 1 5,855 (5,855) | Rate of first vascular event | Low | Unknown | Direct | Precise | 14% decrease in rate Insufficient
Improved prescription drug coverage vs. unchanged prescription drug coverage | 1 5,855 (5,855) | Patient total spending | Low | Unknown | Direct | Precise | 26% decrease in relative spending Low
Improved prescription drug coverage vs. unchanged prescription drug coverage | 1 5,855 (5,855) | Insurer total spending | Low | Unknown | Direct | Precise | Nonstatistically significant decrease in relative spending Low
Inhaled corticosteroids reduced medication copay vs. unchanged medication copay | 1; NR (NR) | Medication adherence | High | Unknown | Direct | Imprecise | Insufficient

Abbreviations: MPR = Medication possession ratio; NR = not reported.

The final policy-level study examined the impact of Medicare Part D on adherence to medications used to treat patients with diabetes, hyperlipidemia, and hypertension (Table 60).151 In contrast to the findings from the studies already discussed, this study found consistent improvements in medication adherence following intervention implementation, particularly among people who had not previously had any type of prescription drug coverage. For example, in analyses focusing on medications used to treat hyperlipidemia, MPR increased 13.4 more points among individuals who did not have prescription drug coverage before Medicare Part D than among individuals in the comparison group. However, among patients with some coverage for prescription medications before implementation of Medicare Part D, the estimated differences in MPR scores ranged from 2.5 to 7.3. The study found similar differences for medications used to treat hypertension and diabetes. This dose-response relationship (i.e., adherence increased most among individuals with the greatest improvement in benefits) supports the conclusion that improved prescription drug coverage has a beneficial effect on medication adherence (moderate strength of evidence of benefit) (Table 61).

## Key Question 3 Intervention Characteristics and Outcomes for Direct Comparisons of Intervention Characteristics

KQ 3a, which addresses intervention characteristics as noted earlier, includes all studies relevant for KQ 1 and KQ 2. These studies are described in detail in earlier sections of the report. We present our results for intervention characteristics first for all included studies for this report, followed by results for the small subset of studies that directly compared intervention elements (KQ 3b).

### Key Question 3a Intervention Characteristics

#### Description of Included Studies

Earlier sections of the report provide a detailed description of all 62 studies (68 articles) included in KQ 1 and KQ 2. We present key points below, followed by a detailed synthesis for KQ 3.

#### Key Points

- The studies of adherence interventions that we included varied by six key characteristics: (1) intervention target; (2) intervention agent; (3) intervention mode; (4) intensity (total time and frequency); (5) duration of intervention delivery; and (6) intervention components.
- We included studies that did not use consistent language or taxonomy to describe the interventions that they were testing.
- About half of the adherence interventions were delivered by a pharmacist, physician, or nurse.
- About half of the adherence interventions involved face-to-face contact.
- The majority of interventions incorporated more than one component.
- Nurses, multidisciplinary teams (often including nurses), automated systems, and other nonphysician/nonpharmacist health professionals tended to combine delivery of knowledge-based components with components that raised clients’ self-awareness more than did physician or pharmacist-delivered interventions.

#### Detailed Synthesis of Intervention Characteristics

##### Overview of Characterization of Interventions

In these sections we characterize the interventions tested in the studies reviewed based on several features to answer the question, “How do medication-adherence intervention characteristics vary?” Based on a review of 62 studies that tested interventions to improve medication adherence, we identified six key characteristics by which interventions typically varied: (1) intervention target; (2) agent delivering the intervention; (3) mode of delivery; (4) intensity of the intervention; (5) duration of the intervention; and (6) intervention components. In the following sections we define each characteristic and describe the interventions identified in the literature based on these characteristics. In Figure 3, we depict the distribution of intervention characteristics in relation to one another, including intervention target, agent, and mode of delivery. We then describe the components of the interventions based on a taxonomy developed by deBruin and colleagues.74

Figure 3 Summary of medication adherence intervention characteristics (targets, agents, and modes of delivery)

Abbreviation: F2F = face-to-face; assist = assistant; NA = not applicable; NR = not reported

Figure 3 is titled “Summary of medication adherence intervention features (targets, agents, and modes of delivery).” The figure is a flow chart showing how many interventions are included in the review and their targets, agents of delivery, and modes of delivery. A total of 62 interventions were identified and evaluated. Of these, 25 targeted patients only; 14 targeted a combination of patients, providers, and systems; 12 targeted a combination of patients and systems; four targeted a combination of patients and providers; one targeted providers only; one targeted systems only; and three targeted policies. Two of the 25 interventions targeting patients only were delivered by physicians; three by pharmacists; seven by nurses; one by coaches; five by automated technology; and seven by other agents. Among the physician-delivered interventions, one intervention involved face-to-face communication only, while the other involved face-to-face contact and the use of printed materials. Two of the pharmacist-delivered interventions involved face-to-face encounters only, while the third involved the use of face-to-face and telephone contact. Three of the nurse-delivered interventions involved face-to-face contact only, while the other three involved only telephone contact. The single coach-delivered intervention involved telephone communication only. Two of the interventions delivered by automated technology involved computer or mail components, while the other three involved telephone contact. One of the interventions delivered by other agents involved contact with research staff; another one involved contact with a multidisciplinary group of providers; two involved audio/video components; and for one study, the mode of delivery was not applicable. Of the 12 interventions targeting a combination of patients and systems, one was delivered by physicians; four by pharmacists; two by nurses; one by care managers; and four by other agents of delivery. The only physician-delivered intervention involved a combination of face-to-face contact, telephone contact, and printed materials. One of the pharmacist-delivered interventions involved face-to-face contact only, one used face-to-face contact and printed materials; one used face-to-face and telephone contact; and one used telephone and fax communication. One of the nurse-delivered interventions involved telephone communication only, and the other involved face-to-face and telephone contact. The only intervention delivered by care managers involved face-to-face and telephone contact. Among the four interventions using other modes of delivery, one involved counselors; one involved health educators; one involved multidisciplinary providers; and for one study, the mode of delivery was not applicable. Of the 14 interventions targeting a combination of patients, providers, and systems, two were delivered by physicians; three by pharmacists; one by medical assistants; one by care managers; one by automated technology; and six by other agents of delivery. Of these, the two physician-delivered interventions involved a combination of face-to-face contact, telephone contact, and print or video materials. One of the pharmacist-delivered interventions involved telephone contact only, one involved face-to-face and telephone contact, and the third involved telephone and computer contact. The single intervention delivered by medical assistants involved telephone contact only. The single care manager-delivered intervention involved a combination of face-to-face and telephone contact. The only intervention delivered by automated technology was computer-based. Of the six interventions using other modes of delivery, one involved a psychologist; three involved multidisciplinary providers; one involved research assistants; and for one study, the mode of delivery was not applicable. Of the four interventions targeting a combination of patients and providers, one was delivered by physician administrators; two by pharmacists; and one by nurses. The only intervention delivered by physician administrators involved a print-by-mail component. One of the two pharmacist-delivered interventions involved face-to-face contact and printed materials, while the other involved telephone contact only. The only nurse-delivered intervention involved telephone contact only. The single intervention targeting systems only was delivered by physicians. The mode of delivery was a combination of face-to-face and telephone contact, and printed materials. A single intervention addressed providers only and five addressed policy changes.

##### Intervention Target

Intervention target refers to the person, people, health system, or policy to which intervention activities are directed. Although the ultimate goal of adherence interventions is to improve patient behavior (i.e., taking medications), the interventions may do this by directly targeting providers, patients, health systems, health policies, or some combination of these four. In the 62 studies we reviewed, we identified seven individual or combinations of intervention targets to which at least one intervention was directed. These were (in order of frequency): (1) patients only (40.3 percent of interventions); (2) combination of patients, providers, and systems (22.5 percent); (3) combination of patients and systems (19 percent); (4) combination of patients and providers (6 percent); (5) providers only (1.6 percent); (6) systems only (1.6 percent); and (7) health policy changes (8 percent). In sum, over one third of medication adherence interventions tested in trials targeted only patient factors and, hence, not the full spectrum of many factors that are known to interfere with adherence, which include provider, system and policy barriers.

##### Intervention Agent

Intervention agent refers to the person, people, or technology used to deliver the intervention. Like intervention targets, the agents that delivered the interventions varied widely and did not appear to be highly correlated with the type of target to which the intervention was directed. In total, of the 62 interventions reviewed (in order of frequency), 12 (19 percent) were delivered by pharmacists, 10 (16 percent) were delivered by nurses, 7 (11 percent) were delivered by physicians (including one physician administrator), 6 (10 percent) by an automated system, 5 (8 percent) by a multidisciplinary team, 2 (3 percent) by care managers, 1 (1.6 percent) by a medical assistant, and 1 (1.6 percent) by a health coach. Other agents included a health educator, a psychologist, a counselor, research staff members, and some audio-video materials, including decision aids. For 9 interventions (15 percent), including 4 of the 5 directed at policy changes, a specific agent of delivery was not applicable or identifiable. For one policy change intervention, the health insurer was the agent of delivery.

Interventions that targeted “patients only” tended to use automated (21 percent) and nurse (29 percent) agents more than did interventions that targeted combinations of factors. In contrast, few interventions with a combination of targets used automated systems (4 percent) or nurses (8 percent) as agents. Physicians or pharmacists delivered interventions that targeted “patients only” (22 percent) less often than did interventions that targeted combinations of factors (38 percent). Despite these few specific observations, both targets and agents of delivery were varied overall.

##### Mode of Delivery

Mode of delivery refers to the manner by which the agent delivers the intervention, such as face-to-face, over the phone, using print materials, by computer, on a DVD, video, or CD/audio or a combination of these modes. Of the 62 interventions, 26 (42 percent) of the interventions involved only 1 delivery mode and 22 (35 percent) utilized 2. Five (8 percent) used 3 delivery modes and four (6 percent) used 4 modes to deliver the intervention.

Twenty-nine of the interventions (47 percent) involved at least some face-to-face contact although, of these 29, 21 (72 percent) combined face-to-face with additional modes of delivery, such as phone contact, print materials, computer, video, or other materials. Similarly, 30 interventions (48 percent) delivered at least some of the intervention by phone; however, only 13 (43 percent) of these involved “phone-only” delivery modes. Twenty or about one third (32 percent) of the interventions used print material, although only 6 (30 percent) of these 20 utilized print materials alone, all of which were mailed to their targets. Six of the 62 interventions (10 percent) were at least partially delivered by computer, with only 2 being entirely computer delivered. Seven interventions (12 percent) involved audio or video/DVDs with only 2 (3.5 percent) delivered solely by audio or video/DVD. One intervention (1.6 percent) used a medication dosing aid device to deliver part of the intervention and another used a telehealth delivery device. Another intervention that simply involved a novel blister packaging mechanism did not have clear agent or mode of delivery.

##### Intensity of the Intervention

The intensity of an intervention refers to the frequency and total amount of time an intervention takes. It is determined by summing the duration of each individual session for the total number of sessions. Hence, as shown in Table 62, the interventions’ intensities can vary in: (1) the total number of contacts; (2) the frequency with which contacts were delivered; (3) the total number of minutes of contact time; and (4) the duration of calendar time over which the intervention was delivered.

Table 62 Delivery mode, number of contacts, frequency, total time, and calendar duration of interventions reviewed by chronic medical condition

Citation | Condition | Mode | N | Frequency | Total Minutes | Duration
Janson et al., 2003^122^ | Asthma | F2F | 5 | NS | 150 minutes | 7 weeks
Berg et al., 1997^121^ | Asthma | F2F | 6 | NS | 720 minutes | 7 weeks
Janson et al., 2009^123^ | Asthma | F2F | 5 | q 2 to 4 weeks | 150 minutes | 14 weeks
Wilson et al., 2010^127^ | Asthma | F2F, phone | 5 | NS | 210 minutes | 9 months
Weinberger et al., 2002^125^ | Asthma | F2F, print | .> 1 NS | q month | NS | NS
Weinberger et al., 2002^125^ | Asthma | F2F, print | > 1 NS | q month | NS | NS
Bender et al., 2010^120^ | Asthma | Phone | 2–3 | NS | ~10 to 15 minutes | 10 weeks
Bender et al., 2010^120^ | Asthma | Phone | 2–3 | NS | ~10 to 15 minutes | 10 weeks
Schaffer & Tian, 2004^124^ | Asthma | Audio or book | 1 | NA | 30 to 60 minutes | NS
Williams et al., 2010^126^ | Asthma | Computer | > 1 NS | q 2 weeks | NS | NS
Murray et al., 2007^116^ | Heart failure | F2F, print | NS | NS | NS | 9 months
Rich et al., 1996^117^ | Heart failure | F2F, print | NS | NS | NS | NS
Fulmer et al., 1999^115^ | Heart failure | Phone, videophone | 30 | q day | ~120 minutes | 6 weeks
Ross et al., 2004^118^ | Heart failure | Computer | NS | NS | NS | 12 months
Bogner & de Vries, 2010^87^ | Depression, Diabetes | F2F, phone | 5 | NS | 120 minutes | 4 weeks
Bogner & de Vries, 2008^101^ | Depression | F2F, phone | 5 | NS | 120 minutes | 4 weeks
Katon et al., 2001^130^ Ludman et al., 2003^131^ Von Korff et al., 2003^132^ | Depression | F2F, phone, print, DVD | 9 | NS | 150+ minutes | 12 months
Katon et al., 1999^136^ Katon et al., 2002^137^ | Depression | F2F, phone, print, DVD | 2+ | NS | 75 minutes | NS
Katon et al., 1996^135^ | Depression | F2F, phone, print, videos | 8 | q 2 to 12 weeks | 360+ minutes | 24 weeks
Katon et al., 1995^134^ | Depression | F2F, print, video | 4 | q 8 to 10 days | 105 minutes | 6 weeks
Simon et al., 2006^129^ | Depression | Phone | 3 | q 1 to 2 months | 60 minutes | 3 months
Capoccia et al., 2004^133^ | Depression | Phone | 18 | q 1 to 2 weeks | 270 minutes | 12 months
Pyne et al., 2011^138^ | Depression | Phone [for Pat] EMR [for Prov] | > 1 NS | q 2 to 4 weeks | NS | NS
Rickles et al., 2005^128^ | Depression | Phone | 3 | NS | 45 minutes | 3 months
Hoffman et al., 2003^139^ | Depression | Print, mail | 6 | q month | NS | 6 months
Weymiller et al., 2007^93^ Jones et al., 2009^94^ | Diabetes | F2F | 1 | NA | NS | NA
Pearce et al., 2008^91^ | Diabetes | F2F | 1 | NA | 30 minutes | NA
Lin et al., 2006^89^ | Diabetes | F2F, phone | 16 | NS | 240+minutes | 12 months
Mann et al., 2010^92^ Choice | Diabetes | F2F, print | 1 | NA | 6 minutes | NA
Mann et al., 2010^92^ Choice | Diabetes | F2F, print | 1 | NA | 6 minutes | NA
Grant et al., 2003^88^ | Diabetes | Phone, computer | 6 | Q 2 weeks | 111 minutes | 3 months
Okeke et al., 2009^140^ | Glaucoma | F2F, phone, video, dosing aid device | 10 | NS | NS | 3 months
Schectman et al., 1994^98^ | Hypercholesterolemia | Phone | 5 | NS | NS | 28 days
Stacy et al., 2009^99^ | Hypercholesterolemia | Phone, mail, print | 3 | NS | NS | 6 months
Guthrie, 2001^95^ | Hypercholesterolemia | Phone, mail | 5 | Per schedule | NS | 6 months
Johnson et al., 2006^96^ | Hypercholesterolemia | Computer; mail | 3 | NS | NS | 6 months
Hunt et al., 2008^105^ | Hypertension | F2F | 1–4 | NS | NS | NS
Lee et al., 2006^78^ | Hypertension, Hyperlipidemia | F2F | 7 | q 2 months | 240 minutes | 12 months
Vivian, 2002^113^ | Hypertension | F2F | 6 | NS | NS | 6 months
Carter et al., 2009^104^ | Hypertension | F2F, phone | 1.6 | q 3 months | NS | 6 months
Solomon et al., 1998^111^ Gourley et al., 1998^112^ | Hypertension, COPD | F2F, phone | 5 | NS | NS | 6 months
Rudd et al., 2004^102^ | Hypertension | Phone | 5 | Per schedule | NS | 4 months
Bosworth et al., 2008^106^ Bosworth et al., 2007^107^ | Hypertension | Phone | 12 | Q 2 months | NS | 24 months
Bosworth et al., 2005^108^ | Hypertension | Phone | 12 | Q 2 month | NS | 24 months
Friedman et al., 1996^109^ | Hypertension | Phone | 24 | Weekly | 96 minutes | 6 months
Johnson et al., 2006^110^ | Hypertension | Computer; mail | 3 | q 3 months | NA | 6 months
Schneider et al., 2008^100^ | Hypertension | Packaging | NA | NA | NA | NA
Rudd et al., 2009^142^ | Inflammatory arthritis | F2F, phone, print | 2 | q months | 40 minutes | NS
Powell et al., 1995^97^ | Multiple chronic conditions | Mail | 1 | NA | 30 minute | NA
Zhang et al., 2010^151^ | Multiple chronic conditions | NA | NA | NA | NA | NA
Chernew et al., 2008^149^ | Multiple chronic conditions | NA | NA | NA | NA | NA
Nietert et al., 2009^145^ | Multiple chronic conditions | Telephone, fax | NS | NS | NS | NS
Wakefield, et al, 2011^103^ | Multiple Unspecified Chronic Conditions | Telehealth | 157 | Daily | NS | 6 months
Choudhry et al., 2010^150^ | Multiple conditions | NA | NA | NS | NA | NA
Berger et al., 2005^141^ | Multiple sclerosis | Phone | 6 to 12 | q 2 to 4 weeks | NS | 3 months
Waalen et al., 2009^143^ | Osteoporosis | F2F, phones, print | varied | q month | 5-minute/call | NS
Taylor et al., 2003^147^ | Other | F2F, print | >1 NS | NS | 20-minute/visit | 12 months
Sledge et al., 2006^148^ | Other | F2F, phone, print | > 13 | Monthly phone | 180+ minutes | 1 year
Schnipper et al., 2006^146^ | Other | F2F, phone | 2 | NS | NS | NS

Abbreviations: COPD = chronic obstruction pulmonary disease; DVD= optical disc storage media format; EMR = electronic medical record; F2F = face-to-face; N = number; NA = not applicable; NS = not specified; Q/q = every.

###### Number and Frequency of Contacts

As seen in Table 62, in six studies, the intervention did not involve specific contact points (such as with a systems or policy change) and in four other studies, information about the number of contacts was not specified. Among those that provided such information, the number of contacts ranged from 1 to 30. As might be expected, interventions with higher numbers of contacts often were solely or at least partially delivered by phone. Many face-to-face interventions, however, included as many as five to six contacts. Interventions that involved more than one contact varied not only by number of contacts but also by the frequency of delivery. Frequencies ranged from as often as daily to as infrequently as every 3 months, although most were delivered weekly to monthly.

###### Total Amount of Contact Time

Thirty-three studies (53 percent) did not specify the total dose intensity of the interventions; another 7 (11 percent) gave only the minimum amount of the intervention (e.g., 120+ minutes, at least 2.5 hours, etc.) or specified only the amount per contact but did not give the number of contacts or the number of contacts but not the amount of time per contact (Table 62). Among the studies that provided this information, the amount of time varied widely among interventions, ranging from 6 minutes to 12 hours. Of 26 trials that provided information regarding at least the minimum amount of total contact time, 15 (58 percent) were less than 120 minutes in total time; 6 (23 percent) were more than 180 minutes in total time.

While only a limited number of conclusions can be drawn due to the large number of studies not reporting total contact time, the overall duration of the program does not appear to be strongly associated with the total intensity of time. For example, in comparing three asthma studies, one study lasting 10 weeks had a total intensity of only 15 minutes while another lasting 7 weeks had a total intensity of 150 minutes, and yet a third lasting 9 months had a just slightly greater intensity at 210 minutes.

##### Intervention Duration

As with frequency, reporting of calendar time was not relevant for the interventions that were delivered during a single contact episode. Several others did not specify the duration of the program in calendar time. Of the 38 interventions (61 percent) that did, the duration ranged widely from 4 weeks to 2 years, with 6 months’ duration as the mode: 11 (29 percent) of the 38 studies lasted 6 months. Another 7 (18 percent) of programs with known duration lasted 12 months, 5 (about 13 percent) lasted 3 months, and only 2 (5 percent) lasted 2 years. Duration of the remaining 13 interventions (34 percent) fell between 4 weeks and 12 months. In general, asthma and heart failure medication adherence interventions appeared to be of slightly shorter duration compared with those for diabetes, depression, hypertension, and hypercholesterolemia.

##### Taxonomy of Adherence Intervention Components

A taxonomy of 16 mutually exclusive, distinguishable intervention components have been described previously (deBruin et al., 2010) that may be present in a medication adherence intervention.74 An intervention may be found to include one, several, or all of these components. Examples of these components include features such as knowledge-based activities, awareness-based pursuits, self-efficacy enhancement, and contingent rewards. Our assessment of intervention components was based on whether the studies provided an explicit description of intervention components. Hence, we noted a particular component for a particular intervention only if that component was identifiable from the report. In addition, some studies tested interventions that included components not identified in deBruin’s 16-component taxonomy. We included these as “novel components” in our count of the components each study reported and have listed and described them below.

Although the range of the total number of components included in each intervention was somewhat broad (1 to 9), few interventions involved only one component. Most interventions with only a single component were not delivered by a specified agent but involved a policy or institutional change (such as a reduction in medication copay, novel packaging of pills, or a mailed informational sheet).

The median and modal number of components delivered were both 3: 16 interventions (27 percent) had 3 components, 21 (35 percent) had fewer than 3, and only 3 interventions (5 percent) had more than 6 components. Table 63 shows the reported number of interventions that had each number of components (1 through 9) by agent of delivery. The number of components delivered did not appear to vary greatly based on the agent delivering the interventions. One exception was noted in the case of interventions that were delivered by a multidisciplinary team, which usually had a greater number of components.

Table 63 Reported number of interventions with each number of components (1–9) by delivery agent

Number of Components | Auto | Multidisciplinary | Nurse | Pharmacist | Physician | Other | Nonspecified Agent | Total
1 | 0 | 0 | 0 | 0 | 0 | 3 | 6 | 9
2 | 2 | 0 | 1 | 5 | 2 | 1 | 1 | 12
3 | 2 | 1 | 1 | 4 | 1 | 5 | 2 | 16
4 | 0 | 0 | 3 | 2 | 2 | 0 | 0 | 7
5 | 2 | 2 | 0 | 1 | 0 | 1 | 0 | 6
6 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 6
7 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 2
8 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
9 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 1

The vast majority of the medication adherence interventions reviewed included a knowledge-based component (77 percent). About 44 percent of all interventions included an awareness-based component in addition to the knowledge component. The awareness components involved activities to enhance a person’s self-awareness, such as awareness of their own health risks, their current health state, or their values and preferences. Examples of activities to raise awareness included risk communication, self-monitoring, reflective listening, and behavioral feedback. Of note, only one intervention involved an awareness-based element without a knowledge-based component.

About half of the interventions used facilitation techniques, including supportive activities such as continuous professional support, helping clients deal with adverse effects, individualizing or simplifying regimens, or reducing environmental barriers to taking medication to improve adherence. Components designed to enhance self-efficacy were included in 13 (20 percent) of the interventions. Activities such as modeling, practicing task-specific skills, verbal persuasion, making plans for coping responses, setting graded tasks, and reattributing success and failure were coded as self-efficacy enhancements.

Other components that were present in some of the interventions reviewed included intention formation activities (18 percent), action control (17 percent), addressing attitudes (12 percent), motivational interviewing (10 percent), stress management (3 percent), and social influence (3 percent). Sixteen percent of interventions included a component that addressed maintenance. We identified no interventions that utilized contingent rewards to improve medication adherence in the studies that met our inclusion criteria.

No pattern of the distribution of components was evident among interventions sorted by target. However, as shown in Table 64, a few generalizations about intervention components based on the agent of intervention delivery can be made.

Table 64 Number of interventions with each of nine key components most commonly observed in adherence interventions reviewed by agent of delivery

Nine Key Intervention Components
Agent of Delivery | Knowledge, Without Awareness | Knowledge, With Awareness | No Knowledge | Self-Efficacy | Facilitation | Maintenance | Intentions, Action Control | Intentions, Action Control | No Intentions, Action Control | No Intentions, No Action Control | Motivational Interviewing | Attitude Changes
Pharmacists (N=12) | 8 (67%) | 4 (33%) | 0 | 1 (8%) | 11 (92%) | 2 (17%) | 3 (25%) | 0 | 0 | 9 (75%) | 0 | 0
Physicians (N=6) | 4 (67%) | 2 (33%) | 0 | 1 (16%) | 4 (67%) | 0 | 0 | 0 | 0 | 0 | 0 | 0
Nurses (N=10) | 1 (10%) | 7 (70%) | 2 (20%) | 5 (50%) | 6 (60%) | 4 (40%) | 2 (20%) | 2 (20%) | 1 (10%) | 4 (40%) | 2 (20%) | 1 (10%)
Multidisciplinary (N=5) | 1 (20%) | 4 (80%) | 0 | 2 (40%) | 3 (60%) | 1 (20%) | 1 (20%) | 2 (40%) | 2 (40%) | 0 | 2 (40%) | 0
Automated (N=6) | 1 (17%) | 5 (83%) | 0 | 3 (50%) | 0 | 1 (17%) | 0 | 0 | 0 | 6 (100%) | 1 (17%) | 2 (34%)
Other health professionals (N=9) | 4 (44%) | 1 (11%) | 4 (44%) | 4 (44%) | 6 (67%) | 0 | 2 (22%) | 0 | 0 | 7 (78%) | 1 (11%) | 2 (22%)

Abbreviation: N = number.

First, all interventions involved knowledge-based components, with the exception of two of nine delivered by nurses and four of nine delivered by other health professionals (such as counselors, health coaches, etc.). However, the pattern of knowledge-based delivery differed for physicians and pharmacists as compared with other agents. When knowledge-based components were delivered by nurses, multidisciplinary teams (those often included nurses), automated systems, and other nonphysician/nonpharmacist health professionals, most (66 percent to 83 percent) were coupled with an awareness-based component that served to raise clients’ self-awareness. In contrast, physician and pharmacist-delivered interventions all involved knowledge delivery but were less often coupled with awareness-based elements.

Second, physician- and pharmacist-delivered interventions rarely used self-efficacy enhancement components, whereas about half of those delivered by other agent groups used them. No physician interventions addressed maintenance, while nearly half of nurse-delivered interventions (44 percent) did. Finally, none of the automated interventions used facilitation, while nearly all (92 percent) of the pharmacist-delivered interventions did, and about two thirds of each of the other intervention delivery agent groups did.

Similarly, physician and pharmacist-delivered interventions seemed less likely to use the components of either intention formation or action control than nurses and multidisciplinary teams. Only 3 of 18 interventions delivered by physicians or pharmacists included at least one of these two components compared with 10 of 14 interventions delivered by nurses or multidisciplinary teams. No automated interventions involved intention formation or action control.

Motivational-interviewing and attitude-changing components were used less often in general, and neither was ever used by physician or pharmacist-delivered interventions.

##### Components of Interventions Not Encompassed by deBruin Taxonomy

Some interventions included components that did not appear to fit within deBruin’s taxonomy. Because deBruin’s taxonomy focuses primarily on individual patient-level components, it is not surprising that many of the novel components we identified targeted systems-level factors. However, we did note two patient-level components that were not included in deBruin’s taxonomy: shared decision-making/decision-aid approaches and approaches that specifically tested the effects of “gain-framing” messages. Both components are of interest because they may have an influence on medication adherence and have not received as much focus heretofore. Each of the novel components we identified are listed in Table 65. Shared decisionmaking is distinct from interventions that address self-efficacy. Self-efficacy is a key construct in Social Cognitive Theory that has been used to encourage adoption of health behavior change when there is a clear healthier choice indicated. Self-efficacy is task-specific, and achieved via specified approaches which involves gradual steps. Shared decisionmaking, in contrast, is not based in psychological theory nor aimed at changing behavior but rather in helping patients decide which health option to choose by providing information and values clarification.

Table 65 Components of interventions not encompassed by deBruin taxonomy

New Components | Level | Target | Agent
Provision of patient adherence data to clinician | Systems | Combination: Patient, provider, system | Automated
Shared decisionmaking | Patient | Combination: Patient, provider, system | Multidisciplinary
Change on medication cost sharing with company | Policy | Combination: Patient, policy | Company
Reduction of copay/out-of-pocket expenses | Policy | Policy | NA
Specific packaging design | Systems | Patient | NA or Pharmacist
Gain-framing messages | Patient | Patient | Nurse
Pharmacist-physician collaboration | System | Patient, provider, system | Pharmacist
Monitoring of medication regimen to identify system errors | System | Patient, system | Pharmacist
Appointment making for patients | System | Combination: Patient, system | Pharmacist
Collaborative care between physicians | System | Combination: Patient, Provider, system | Physician

Abbreviation: NA = not applicable.

### Key Question 3b Direct Comparisons of Intervention Characteristics and Medication Adherence Outcomes

#### Description of Studies

##### Overview

We found five articles comprising only four randomized trials (~5 percent) that assessed the effects of four different interventions aimed at improving medication adherence among adult patients; one involved patients with heart failure, two involved patients with asthma, one involved patients with diabetes mellitus, and one involved patients with hypertension.93,94,103,115,127 KQ 1 presents complete results for outcomes for all comparators, including controls; the tables in this section focus on direct comparisons only. We rated all of these studies as having medium risk of bias.93,103,115,127

##### Population

All four studies were conducted among adults. The study of diabetes patients reported limiting the sample to patients with type 2 diabetes or who were on oral hypoglycemic agents.93,94 One study was restricted to poorly controlled asthma.127 In the study of heart failure, all participants were restricted to those older than 65 years, with African-American participants comprising between 23 to 33 percent.115 The study of hypertension included adult Veterans Administration (VA) patients with hypertension and type 2 diabetes.103

##### Interventions

Interventions varied widely in their approaches to improving adherence; all were directed at patients.

The asthma studies focused on providers and systems in addition to patients.127 They evaluated shared decisionmaking between patients and clinicians.127

The diabetes, heart failure, and hypertension studies were directed solely at patients.93,94,103,115 The heart failure study included two intervention arms and one control arm.115 The diabetes study evaluated the effects of a lipid-lowering decision aid while directly comparing the effect of the agent of delivery (clinician or researcher).93,94 In the heart failure study, adherence reminder calls were delivered via video using provided equipment to the first intervention arm and via telephone calls to the second intervention arm; a research assistant reminded participants to take their medications daily.115 The hypertension study tested a nurse case manager home telehealth intervention 103 at two different doses of the same intervention (high and low intensity levels of monitoring and education).

##### Comparator

For KQ 3b, the relevant comparator was a modification of the intervention. In the asthma study127 for example, shared decisionmaking (in which the patients’ preferences and values were assessed and taken into account in selecting recommended treatment) was compared with traditional physician-driven clinical decisionmaking (and both were compared with a control condition). In the study of statin decision aids among patients with diabetes, patients were compared regarding whether the intervention was delivered by a physician or research staff member.93,94 In the study of video and phone call reminders, these two approaches were compared with each other (as well as a control group) among patients with heart failure and no calls were made to the control group.115 The hypertension study compared the two intensity levels of the nurse-case management home telehealth intervention103 and to each other (high and low intensity levels of monitoring and education) in addition to a usual-care control arm.

##### Outcome and Timing

The asthma study defined percentage adherence as the number of doses taken divided by the number prescribed and used metered dose inhaler data, pharmacy refill data, or a combination of self-reported adherence and electronic monitoring data to construct the measure, depending on what was available but generally using objective measures for the numerator. The investigators also evaluated refills of SABA using refill data.127

The study of diabetes patients used a single self-report item to ask about medication taking using a 7-day recall period93 to count the number of people who missed no doses.93 The heart failure studies measured adherence via MEMS caps.115

The study of a lipid-lowering decision aid for diabetic patients did not evaluate the effect of the intervention on biomarkers, but the asthma study assessed the effects of a shared decisionmaking intervention effects on forced expiratory volume (FEV-1).127 Other outcomes of interest included the Asthma Therapy Assessment Questionnaire (ATAQ) and health-related quality of life.127

The hypertension study103 assessed adherence to antihypertensives using the 4-item Morisky scale.

Timing and frequency of the study outcomes assessments varied, ranging from 6 weeks to 2-year followup, as did the timing of the outcome assessment relative to administration or completion of the intervention. For example, the shared decisionmaking study recorded 2-year adherence information for an intervention with an active component that lasted 9 months.127 The diabetes intervention was administered in one contact at baseline, and followup occurred 6 weeks later. The heart failure study assessed adherence outcomes at the conclusion of the intervention,115 which lasted 6 weeks. The hypertension trial of telemonitoring case management assessed adherence at 6-month followup103.

##### Setting

The asthma study worked within health systems.127 The diabetes study recruited from a metabolic specialty clinic where the intervention was delivered.93,94 The heart failure study focused on a population recruited from an urban home health agency and ambulatory care clinic115 but delivered the intervention in patients’ homes.115 The hypertension study recruited patients from one large VAMC although the intervention itself was administered remotely. 103

##### Applicability

For each intervention type, the scarcity of evidence limits the statements we can make about the applicability of the findings to subpopulations along the spectrum of severity and in different settings. The most significant limitation to applicability in the diabetes study is the lack of long-term outcome data. Notable limitations to applicability in the heart failure study included the low participation rate (10 percent) among those eligible.115 The hypertension study applicability is limited because it was conducted in one unique health care system, the VA.103

#### Key Points

##### Overview

- All four studies assessed intervention effects on medication adherence (e.g., percentage of patients achieving a threshold of pills taken, proportion of pills taken, etc.) albeit each used a slightly different definition of medication adherence and tested different interventions (Table 66).
- Only one of four studies demonstrated a statistically significantly effect for direct comparisons of specific intervention components on improving medication adherence.

Table 66 Medication adherence interventions with direct comparisons: summary of findings

Type of Intervention | Studies, N Randomized | Adherence: Measure, Followup Period Overall Result (+/=/−) and Timing | Additional Outcomes: Outcome Overall Result (+/=/−) and Timing
Case management | Wakefield et al., 2011^103^ N=302 | Morisky scale scores at 6 months | NA
Shared decision-making vs. usual care | Wilson et al., 2010^127^ N=612 | + Medication acquisition ratio for all drugs, 1 and 2 years; + Acquisition of inhaled corticosteroids, 1 year; + Acquisition of beclomethasone, 1 year and 2 years; Acquisition of long-acting beta-agonists, 1 and 2 years | + Forced expiratory volume, 1 year; + Symptom improved: acquisition of short acting beta-agonists, 1 and 2 years; + Asthma control, 1 year; + Quality of life, 1 year; Health care utilization: asthma-related visits
Decision aids | Mann et al., 2010^92^ N=150 | = Percentage with high adherence on Morisky scale at 3 and 6 months; + Number missing no medication doses in prior week at 3 months | NA Patient satisfaction items; + Amount of information; = Clarity of information; + Helpfulness of information
Decision aids | Weymiller et al., 2007^93^ Jones et al., 2009^94^ N=98 | = Percentage using statins at 3-month followup | = Would recommend to others deciding on statins; = Would prefer similar approach for other treatment choices; + Overall acceptability
Reminder calls | Fulmer et al., 1999^115^ N=60 | + Adherence rate, 8 weeks | = Quality of life at 10 weeks

Abbreviations: ACE = angiotensin-converting enzyme; G = group; N = number.

##### Shared Decisionmaking Compared With Clinical Decisionmaking

- Shared decisionmaking resulted in improved medication adherence within the first year of initiating treatment when compared with clinical decisionmaking (low strength of evidence).
- Biomarkers for shared decision-making interventions: Shared decisionmaking resulted in improved pulmonary function within the first year of initiating treatment when compared with clinical decisionmaking (low strength of evidence).
- Morbidity: We found no statistically significant differences in symptom improvement for shared decision-making interventions when compared with clinical decisionmaking (insufficient evidence).
- Health care utilization and quality of life for shared decision-making interventions: We found no difference between two intervention groups in reduced asthma-related visits or mini-asthma quality-of-life scores within the first year of initiating treatment (low strength of evidence).

##### Decision Aid Delivered by Clinician Compared With Research Staff

- Medication adherence: There is no evidence that improved medication adherence among patients with diabetes and comorbid depression was influenced by agent of delivery (insufficient).

##### Adherence Reminders Delivered by Video Compared With Telephone

- Medication adherence: Evidence from a single, small study with limited followup suggests no evidence of difference exists between mode of delivery (insufficient).

##### High Versus Low Intensity Case Management by Telemonitoring With Education

- Medication adherence: Evidence from a single study suggests no evidence of difference exists between the high and low dose of a telemonitoring and educational intervention (insufficient).

##### Other Outcomes

- All other outcomes for the interventions listed above: Insufficient due to lack of evidence.

#### Detailed Synthesis for Shared Decisionmaking

##### Medication Adherence

The asthma trial that evaluated shared decisionmaking and clinical decisionmaking compared with usual care found statistically significant differences in medication adherence at 1-year followup (Table 67); clinical decisionmaking was more effective than usual care, and shared decisionmaking was more effective than either clinical decisionmaking or usual care, suggesting evidence of benefit for shared decisionmaking (Table 68).127 At 2 years, clinical decisionmaking was no longer significantly different than usual care, but shared decisionmaking continued to produce statistically significant improvements in medication adherence compared with clinical decisionmaking or usual care.

Table 67 Medication adherence interventions with direct comparisons: medication adherence

Study | N per Group | Sample and Setting | Intervention Groups | Intervention Dose | Measure (Range, Direction) | Source | Baseline | First Followup | Additional Followups
Shared decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 Kaiser Permanente medical centers | G1: Shared decisionmaking model for two face-to-face visits and three phone calls G2: Clinical decisionmaking model for two face-to-face visits and three phone calls G3: Usual care: stepped approach to medications | Five face-to-face, phone, 9 months | Medication acquisition ratio for all asthma medications (total days supply acquired in a year/365 days) | Pharmacy refill data | NR | Means at 1 year: G1: 0.67 G2: 0.59 G3: 0.46 (95% CIs): G1 to G3: (0.13 to 0.280), p=0.0001 G1 to G2: (0.01 to 0.15), p=0.0029 G2 to G3: (0.05 to 0.20), p=0.0008 | Mean differences at 2 years: G1 to G3: 0.03 G1 to G2: 0.04 G2 to G3: −0.01 (95% CIs): G1 to G3: (−0.05 to 0.11) G1 to G2: (−0.04 to 0.12) G2 to G3: (−0.09 to 0.07)
Shared decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 Kaiser Permanente medical centers | | Five face-to-face, phone, 9 months
Shared decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 Kaiser Permanente medical centers | | Five face-to-face, phone, 9 months | Medication acquisition ratio for inhaled corticosteroids (total days’ supply acquired in a year/365 days) | Pharmacy refill data | NR | Means at 1 year G1: 0.59 G2: 0.52 G3: 0.37 (95% CIs):NR p: G1 to G3: 0.0001 G1 to G2: 0.017 G2 to G3: 0.0001 | NR
Shared decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 Kaiser Permanente medical centers | | Five face-to-face, phone, 9 months
Shared decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 Kaiser Permanente medical centers | | Five face-to-face, phone, 9 months | Acquisition of beclomethasone canister equivalents | Pharmacy refill data | NR | Means at year 1: G1: 10.9 G2: 9.1 G3: 5.2; (95% CIs): G1 to G3: (4.5 to 7.0), p=0.0001 G1 to G2: (0.57 to 0.31), p=0.005 G2 to G3: (2.6 to 5.2), p=0.0001 | Means at year 2: G1: 7.1 G2: 5.8 G3: 4.6 (95% CIs): G1 to G3: (1.2 to 3.8), p=0.0002 G1 to G2: (0.04 to 2.7), p=0.04 G2 to G3 (−0.18 to 2.4), p>0.05
Shared decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 Kaiser Permanente medical centers | | Five face-to-face, phone, 9 months
Shared decision-making | Wilson et al., 2010^127^ G1: 204 G2: 204 G3: 204 | Adults ages 18 to 70 Kaiser Permanente medical centers | | Five face-to-face, phone, 9 months | Medication acquisition for long-acting beta-agonists | Pharmacy refill data | NR | Mean difference at 1 year: G1 to G3: 0.11 G1 to G2: 0.09 G2 to G3: 0.01 (95% CIs): G1 to G3: (0.02 to 0.20) G1–G2: (0.02 to 0.17) G2–G3: (−0.08 to 0.11) | Mean difference at 2 years: G1 to G3: 0.11 G1:G2: 0.09 G2 to G3: 0.01 (95% CIs): G1 to G3: (0.01 to 0.20) G1 to G2: (0.01 to 0.18) G2 to G3: (−0.08 to 0.11)
Decision aids
Mann et al., 2010^92^ | G1: NR G2: NR | Adult patients with diabetes mellitus Urban primary care clinic | G1: Statin choice decision aid G2: ADA print material | One face-to-face session + printed material | Percentage with “good adherence” on 8-item Morisky Adherence Scale (0 to 100%) | Self-report | Baseline NR | 3 months: Overall: 70% G1: NR G2: NR 95% CI, NR p: No significant difference between groups | 6 months: Overall: 80% G1: NR G2: NR 95% CI, NR p: No significant difference between groups
Mann et al., 2010^92^
Mann et al., 2010^92^ | G1: NR G2: NR | | | | Percentage prescribed statin during baseline visit (0 to 100%) | Self-report | Baseline G1: 9% G2: 0% 95% CI, NR p=0.01
Weymiller et al., 2007^93^ Jones et al., 2009^94^ | G1: 33 G2: 29 | Adults with Type 2 diabetes mellitus Metabolic specialty clinic | G1: Statin choice decision aid G1a: Research staff before visit G1b: Clinician during visit G2: Standard of care educational pamphlet control G2a: Research staff before visit G2b: Delivered by clinician during visit | One face-to-face session + printed material | Number missing no medication doses in the last week | Self-report | NR | 3 months: G1: 31 G2: 23 Odds ratio (OR): 3.4 95% CI: 1.5, 7.5 p: NR
Weymiller et al., 2007^93^ Jones et al., 2009^94^ | G1a: NR G1b: NR G2a: NR G2b: NR | Adults with Type 2 diabetes mellitus Metabolic specialty clinic | | One face-to-face session + printed material | Number missing no medication doses in the last week, by mode of delivery | Self-report | NR | 3 months: G1a: NR G1b: NR G2a: NR G2b: NR OR for delivery mode: 0.8 95% CI: 0.3, 2.6 p: NS
Weymiller et al., 2007^93^ Jones et al., 2009^94^
Weymiller et al., 2007^93^ Jones et al., 2009^94^ | G1: 52 G2: 46 | | | | Percentage using statins at followup | Self-report | NR | 3 months: N (%) G1: 33 (63%) G2: 29 (63%) 95% CI, NR p: NR OR: 1.4 95% CI: 0.8 to 2.4 p: NR
Fulmer et al., 1999^115^ | G1: 17 G2: 15 G3: 18 | Adults >65 years with HF Urban Ambulatory | G1: Daily video reminder G2: Daily phone reminder G3: No reminder calls | Daily calls (Mon through Fri), 6-week duration | Compliance rates (0 to 100%, % of total pills taken) | MEMS | G1: 82% G2: 76% G3: 81% | 8 weeks: G1: 84% G2: 74% G3: 57% (p<0.04) 95% CI: NR G1 + G2 vs. G3: F=4.08, p <0.05 G1 vs. G2:p>0.05
Case management | Wakefield et al., 2011^103^ G1: NR G2: NR G3: NR | Adults with diabetes mellitus and HTN | G1: High-intensity: use of home telehealth device for blood pressure and glucose as well as education with nurse case management G2: Low–intensity: Similar to G1 intervention with lower intensity of educational content G3: Usual care | 6 months, daily entries for BP and glucose | Morisky scale | Self-report | NR | 6 months: G1: NR G2: NR G3: NR p: Per text no significant difference between groups; all groups improved from baseline; NR if statistically significant | NR

Abbreviations: aOR = adjusted odds ratio; BP = blood pressure; CI = confidence interval; G = group; HF = heart failure; HTN = hypertension; NS = not specified; NR = not reported; OR = odds ratio; SD = standard deviation; SE = standard error.

Table 68 Asthma: strength of evidence for shared decisionmaking interventions

Intervention | Number of Studies; Subjects (Analyzed)* | Outcome | Study Design/ Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Shared decision-making vs. clinical decision making | 1; 612 (612) | Medication adherence | RCT Medium | Unknown | Direct | Precise | Difference in medication acquisition ratio for all asthma medications: 0.13 to 0.21 (range) Low for benefit
Shared decision-making vs. clinical decision making | 1; 612 (551) | Pulmonary function | RCT Medium | Unknown | Direct | Precise | Difference in FEV1 percentage points: 2.7 to 3.4 Low for benefit
Shared decision-making vs. clinical decision making | 1; 612 (612) | Symptom improvement | RCT Medium | Unknown | Direct | Precise | Difference in mean equivalents of SABA canister equivalents acquired at 2 years between shared decision-making and usual care: 1.6 Low for benefit
Shared decision-making vs. clinical decision making | 1; 612 (551) | Quality of life | RCT Medium | Unknown | Direct | Precise | Difference in subscale scores on 5-item Mini Asthma Quality of Life Questionnaire: 0.3 to 0.4 Low for benefit
Shared decision-making vs. clinical decision making | 1; 612 (612) | Health care utilization | NA | Unknown | Direct | Precise | Difference of 0.3 to 0.4 fewer asthma-related visits per year Low for benefit

Abbreviations: FEV1 = forced expiratory volume at 1 minute; NA = not applicable; RCT = randomized controlled trial; SABA = short-acting beta agonists.

##### Other Outcomes

One trial reported no significant difference in improved pulmonary function for the shared decision-making group compared with the clinical decision-making group (Appendix G).127 Although both intervention arms had a higher odds of reporting no asthma control problems and lower acquisition of short-acting beta agonists SABA (total days supply acquired in a year/365 days) compared with usual care at 1 year, no statistically significant difference was found between the two arms for these two morbidity outcomes. Similarly, at 2 years, although only the shared decision-making arm reported lower SABA use than usual care, no statistically significant difference existed between the two intervention arms in this regard. No differences between clinical- and shared decision-making arms were found for quality of life or asthma-related visits.

#### Detailed Synthesis for Decision Aids

##### Medication Adherence

The decision-aid intervention increased the number of people who missed no doses in the last week compared with controls but no difference was found based on who delivered the aid (Table 67), suggesting insufficient strength of evidence (Table 69). This same study assessed medication persistence (the proportion of patients still on treatment at followup) but found no difference between the groups.93

Table 69 Decision aids for hypertension: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Study Design/ Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Statin decision aid vs. standard written information about lipids | 1; 98 (NR) | Medication adherence | RCT Medium | NA | Direct | Precise | Insufficient

Abbreviations: NA = not applicable; NR = not reported; RCT = randomized controlled trial.

#### Detailed Synthesis for Video and Telephone Reminders

##### Medication Adherence

Although the heart failure study showed statistically significant improvement in at least one measure of medication adherence in the intervention group compared to the control group,115 the difference between the two intervention groups, which differed by mode of delivery, was not statistically significant (Table 67), resulting in insufficient strength of evidence (Table 70).

Table 70 Heart failure: strength of evidence for reminders delivered by video and telephone

Intervention | Number of Studies; Subjects (Analyzed)* | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Heart failure: Video and telephone reminders | 1; 60 (50) | Medication adherence | RCT Medium | Unknown (sig improved) | Indirect | Imprecise | Insufficient
Heart failure: Video and telephone reminders | 0 | Mortality | NA | NA | NA | NA | Insufficient
Heart failure: Video and telephone reminders | 0 | Biomarkers | NA | NA | NA | NA | Insufficient
Heart failure: Video and telephone reminders | 0 | Health care Utilization | NA | NA | NA | NA | Insufficient
Heart failure: Video and telephone reminders | 0 | Quality of care | NA | NA | NA | NA | Insufficient
Heart failure: Video and telephone reminders | 0 | Patient satisfaction | NA | NA | NA | NA | Insufficient

Abbreviations: NA = not applicable; RCT = randomized controlled trial.

#### Detailed Synthesis of High and Low Intensity Telemonitoring and Education

##### Medication Adherence

All three arms had improved adherence at 6-month followup but the difference between the groups was not statistically significantly different from each other (Table 67).103 The difference between the two intervention groups, which varied by dose, was not statistically significant, resulting in insufficient strength of evidence (Table 71).

Table 71 Hyperlipidemia: strength of evidence for education and behavioral support interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Hyperlipidemia: Education + behavioral support | 5; 18,492 (9,411 + NR in 1 study) | Medication adherence, persistence | RCT Medium | Consistent | Direct | Imprecise | Variable measures (self-report, pharmacy refill) with variable outcomes Low

Abbreviations: NA = not applicable; RCT = randomized controlled trial.

## Key Question 4 Vulnerable Populations

### Description of Included Studies

#### Overview

Fifteen studies tested interventions intended to improve medication adherence in vulnerable populations.78,87,89,100,101,103,115,117,121,134,135,137,138,147,151 We present PICOTS below, followed by key points and a detailed discussion for each vulnerable population. Because KQ 1 presents detailed results for all studies, this section presents only strength-of-evidence grades.

#### Population

Vulnerable populations of interest to our review included, but were not limited to, the following: racial and ethnic minorities; populations with various complex situations such as those with low health literacy, coexisting conditions or persistent or severe disease; the elderly; and low-income, underinsured or uninsured, and inner-city or rural populations. We considered studies as including elderly populations if the subjects were 65 years of age or older. In 12 of these 15 studies, the study was conducted entirely in the vulnerable population; that is, the vulnerable population was not a subgroup but comprised the entire study sample.78,87,89,100,101,103,115,117,121,138,147,151 In the remaining three studies, the vulnerable populations were subgroups within the overall study sample;134,135,137 two studies conducted subgroup analyses based on major depression134,135 and one study focused on moderate- to high-severity depression.137

Among the 12 studies in which the entire study was conducted in vulnerable groups, the various populations differed. In five studies, the vulnerable populations were the elderly; of these, four defined the elderly as those who were ages 65 or older,78,100,115,151 and one defined elderly as those who were more than 70 years of age.117 In four studies, the vulnerable population involved patients with depression. Of these, two involved patients with depression and diabetes,87,89 one included patients with depression and HIV,138 and one focused on patients with depression and hypertension.101 In another study, the vulnerable population included patients with diabetes and hypertension.103 In two studies, the vulnerable population involved patients from rural communities.121,147 One of the studies that examined coexisting conditions also included Black primary care patients.87

#### Intervention

Eight studies involved systems changes. Of these, six examined some form of collaborative care or multifaceted interventions involving patient interaction with multiple types of health care providers.89,117,134,135,137,138 One study examined a collaborative care model with HIV and mental health clinicians;138 three others examined collaborative care provided by a primary care physician and a psychologist and psychiatrist;134,135,137 one tested a multidisciplinary intervention that included teaching by a study team, the involvement of a nurse, registered dietician, social services representative, and a geriatric cardiologist;117 and one described an individualized management of depression that involved psychiatric consultations and group services among other features.89

The same team conducted two integrated care interventions that dealt with patients with depression.87,101 The studies were identical except for the coexisting condition on which the study focused: diabetes87 or hypertension.101 In addition to telephone calls and care coordination, the care management interventions in these studies included multiple in-person visits.

Six other studies focused primarily on the patient.78,100,115,121,147 In one, patients in the intervention group received medication in a daily-dose adherence blister package that had information on what to do if a dose was not taken.100 Another study had a prospective observational phase with three distinct elements: medication education, usage of blister packs as an adherence aid, and followup with clinical pharmacists.78 After this initial phase was completed, meetings with pharmacists and use of medications aids both continued but the medication education continued only on an as-needed basis.78 A third study used a video reminder call for one group of patients and a telephone reminder call (without video) for the other group.115 One study examined the effectiveness of case management—specifically a nurse-administered self-management program on compliance.121 Another study examined the use and effectiveness of a nurse-managed home telehealth intervention to improve outcomes.103 The final study in this group examined the effect of a pharmaceutical intervention.147

Finally, a single study focused on policy change, specifically, the impact of Medicare Part D prescription drug coverage on medication adherence.151

#### Comparator

All studies compared the active intervention with usual-care or control-group populations.78,87,89,100,101,103,115,117,121,134,135,137,138,147,151 In certain studies in which the intervention focused on collaborative care, usual care was described as involving depression care by primary care physicians, which included antidepressants and referrals to specialty mental health services on an as-needed basis.89,134–138 In one study, patients in the usual-care group received conventional care from a physician without the collaborative care process that the intervention group received.117 In the two integrated care studies, usual care was described generally as routine care appropriate to the setting.87,101 In one study in which the intervention group received blister-packaged medication, the usual care group received traditional bottles of medication.100 Similarly, in a study that combined medication education, pharmacist followup, and adherence aid use in the intervention, the usual care group did not receive education or blister-packaged medication.78 In another study, the comparator group did not receive the reminder calls that the intervention groups received.115 In the only study focusing on policy change, the comparator for the Medicare Part D intervention groups was described as retiree health benefits with no deductible but copayments for each monthly prescription.151 In one study, usual care was minimally described.121

#### Outcome and Timing

All studies reported on medication adherence for the relevant vulnerable population described, either as a subgroup analysis or as the overall main analysis in nine studies in which the entire study sample comprised members of a vulnerable population.78,87,89,100,101,103,115,117,121,134,135,137,138,147,151 However, medication adherence outcomes varied markedly across the studies; some studies reported multiple outcomes. The types of medication adherence outcomes reported included measures of adherence using thresholds of 80 percent or greater78,87,101,138,147 and 95 percent or greater.138 Other types of medication adherence outcomes included MPRs,100,151 adherence to adequate dosage from pharmacy refill data,137 self-reported medication adherence,121,135 percentage of patients receiving adequate dosage of medication,134 percentage of patients who had prescription filled on time,100 percentage of patients who were adherent in specified time frames,78 monitoring devices (MDI Chronolog) used to assess compliance with inhaler use,121 and percentage of prescribed doses taken using the MEMS.115 In one study, adherence was measured by two scales, one of which was the Self-Reported Medication Taking scale155 and the other was a validated regimen adherence scale.103

Most studies reported on medication adherence outcomes during the intervention period, immediately following it, or within a period after the conclusion of the intervention that ranged from a few weeks to 12 months.87,89,100,101,103,117,121,134,135,138,147 In one study, adherence was monitored during a 2-week pre-intervention phase in addition to measurements at the end of the study and 2 weeks following the end of the study.115 One study reported on long-term outcomes up to 28 months after initial randomization was complete.137 One study, which was 14 months with an initial 2-month run-in period followed by a 6-month cohort intervention, ended with a final 6-month RCT.78 In this particular study, outcomes obtained at 14 months were considered to be 6-month outcomes for the RCT portion.78 In the only study in the set focused on policy change, MPRs were tracked for 2 years before and 2 years after the introduction of Medicare Part D in four different groups.151

#### Setting

Two integrated care studies were set in community-based primary care clinics.87,101 Several collaborative care studies took place within primary care clinics belonging to the Group Health Cooperative in Washington State.89,134,135,137 One collaborative care study was conducted in a university teaching hospital117 and another was set in a VA HIV clinic.138 The blister-packaging study was conducted in ambulatory care clinics in Columbus, Ohio, and Tucson, Arizona.100 Another study was set in a university-affiliated tertiary care U.S. military medical center.78 The video-reminder study recruited patients from a large urban home health agency and an urban ambulatory clinic, with the intervention delivered via telephone calls.115 In the self-management intervention, participants were recruited directly from the community.121 The case management intervention study focused on a primary care population.103 In another study, the setting was community-based physician offices in rural Alabama.147 The policy change study was conducted by examining administrative data of patients enrolled in a large insurer’s Medicare Advantage products.151

### Key Points

- Interventions to improve medication adherence among vulnerable populations had varying strength of evidence. Interventions aimed at improving medication adherence generally had a positive impact for most vulnerable populations for which we found evidence, improving adherence in all but four populations considered. The interventions, the diseases being treated, and the methods for measuring medication adherence outcomes differed considerably between studies.
  – Medication adherence improved for the following: patients with major depression, severe depression, multiple chronic conditions, or with depression and hypertension as coexisting conditions; Black patients with depression and diabetes as coexisting conditions; and elderly patients with diabetes, hyperlipidemia, heart failure, or hypertension (all low strength of evidence).
  – Medication adherence did not improve for patients with depression and HIV as coexisting conditions (insufficient evidence).
  – Medication adherence did not improve for patients with coexisting diabetes and depression, except for one study of Black patients with coexisting diabetes and depression (insufficient evidence).
  – Medication adherence did not improve for patients with coexisting hypertension and diabetes (insufficient evidence).
  – Medication adherence for patients from rural communities improved for patients in one study but did not improve for patients in another study (insufficient evidence).
  – No evidence was available for the following: (a) racial and ethnic minorities with the exception of those who identified as Black race; (b) populations of low literacy, low incomes, and no or poor health insurance (insufficient evidence).

### Detailed Synthesis

The following synthesis presents results for each vulnerable populations considered. Table 72 presents strength-of-evidence grades.

Table 72 Vulnerable populations: strength of evidence

Intervention Vulnerable Population, Condition Details | Number of Studies; Subjects (Analyzed) | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Medicare Part D Elderly patients with diabetes, hypertension or hyperlipidemia | 1; 20,889 (20,889)151 | Before-after study Medium | Unknown | Direct | Precise | Varied measures and magnitude Low
Collaborative intervention Diabetes patients with depression | 1; 329(329)89 | RCT Medium | Unknown | Direct | Imprecise | Insufficient
Blister packaging Elderly patients with hypertension | 1; 93(85)100 | RCT Low | Unknown | Direct | Precise | Difference in percentage points for patients who refilled prescriptions on time: 14.3 Difference in medication possession ratio: 0.06 Low
Video- or telephone-based intervention Elderly patients with heart failure | 1; 60(50)115 | RCT Medium | Unknown | Direct | Precise | Difference in percentage points for prescribed medication doses taken: 27 for video-telephone reminder group; 17 for telephone reminder group Low
Multidisciplinary intervention: collaborative care Elderly patients with heart failure | 1; 156(156)117 | RCT Medium | Unknown | Direct | Precise | Varied measures and magnitude Low
Multidisciplinary intervention: collaborative care Patients with major depression | 2: 370 (177+NR for one study):134,135 | RCT Medium | Consistent | Direct | Precise | Varied measures and magnitude Low
Multidisciplinary intervention: collaborative care Patients with severe depression | 1228 (at 6 months: 229; at 28 months: 187)137 | RCT Medium | Unknown | Direct | Precise | Varied measures and magnitude Low
Integrated care Patients with depression with hypertension | 1;64 (64)101 | RCT Medium | Unknown | Direct | Precise | Difference in percentage points for adherence to depression medication: 40.6 Difference in percentage points for adherence to hypertension medication: 10 Low
Integrated care Black patients with depression and diabetes | 1; 58 (58)87 | RCT Medium | Unknown | Direct | Precise | Difference in percentage points of patients with ≥80% adherence to an antidepressant: 13.8 Difference in percentage points of patients with ≥80% adherence to hypoglycemic agent: 13.8 Low
Collaborative care Patients with depression and HIV | 1; 276 (249)138 | RCT Medium | Unknown | Direct | Imprecise | Insufficient
Pharmacy care program Elderly patients with multiple conditions | 1; 159 (159)78 | RCT Medium | Unknown | Direct | Precise | Difference in percentage points in medication adherence: 26.4 Difference in percentage points of patients with ≥80% adherence to all medications: 75.7 Low
Asthma self-management Patients from a rural community | 1; 55 (55)121 | RCT Medium | Unknown | Direct | Precise | Difference in percentage points in medication adherence: 17 Low
Case management nurse-managed home telehealth Patients with diabetes and hypertension | 1; 394 (NR)103 | RCT | Unknown | Direct | Imprecise | NR Insufficient
Pharmaceutical care Patients from a rural community | 1; 81 (69)147 | RCT | Unknown | Direct | Imprecise | Difference in percentage points in medication adherence: 11.1 Insufficient

Abbreviations: G = group; NR = not reported; RCT = randomized controlled trial.

#### Racial and Ethnic Minorities

Among Black patients with depression and diabetes, an integrated care intervention improved adherence to medications for both diabetes and depression.87 This study also dealt with coexisting conditions.

#### Populations With Persistent Disease, Severe Disease, or Coexisting Conditions

One study demonstrated statistically significant improvement in medication adherence compared with usual care for populations with either major or minor depression at 7 months after randomization.134 Another study found significantly improved medication adherence in the intervention arm compared with the control arm at 4 and 7 months after randomization for major and minor depression groups for percentage adherent, with the exception of the 7-month followup for major depression.135

In another study, adherence outcomes were recorded during 6-month intervals through a 28-month period; overall differences by intervention arms were recorded at 3 and 6 months after randomization.137 Among patients who were severely depressed at baseline, the intervention arm continued to show benefits of the intervention on medication adherence at 12 months; among those with moderately severe depression, improvement in adherence in the intervention arm was seen for the 6 months after randomization.137

A multifaceted collaborative care intervention did not significantly improve medication adherence for either antidepressants or HIV medication adherence for patients who were depressed and had an HIV diagnosis.138 Among patients with diabetes who suffered from depression, a collaborative intervention did not improve medication adherence to ACE-inhibitors, oral hypoglycemic agents, and lipid-lowering agents.89 Among patients ages 50 years or older with depression and hypertension, an integrated care intervention improved adherence to medications for both hypertension and depression.101 Among Black patients with coexisting conditions of depression and diabetes, an integrated care intervention improved adherence to medications for both diabetes and depression.87 This study falls under the minority population category. In a case management intervention for patients with comorbid diabetes and hypertension, the intervention improved medication adherence, although improvement was seen across all groups, without significant differences between groups.103

#### Elderly Populations

Among elderly patients with diabetes, Medicare Part D improved adherence to medications for prevention of cardiovascular disease. This effect was much greater among those who had had no prior insurance coverage before Medicare Part D than for those who did have some prior coverage.151 Among elderly patients with hyperlipidemia, Medicare Part D improved adherence to lipid-lowering medications; the pattern was the same as for cardiovascular disease greater impact among those without (rather than with) prior insurance coverage.151

Among elderly patients with hypertension, an intervention involving daily-dose blister packaging improved adherence.100 A video- or telephone-based intervention improved medication adherence among elderly patients with heart failure when compared with a usual-care control group.115 A multidisciplinary intervention improved medication adherence outcomes among elderly patients with heart failure.101,117 In one study among elderly patients taking at least four medications for chronic diseases, a pharmacy care program significantly improved medication adherence.78

#### Rural Populations

A self-management intervention for asthma directed at patients in a rural population produced statistically significant improvement in adherence in the intervention arm compared with the control arm.121 A pharmaceutical intervention directed at patients in rural Alabama, however, did not report any significant difference in adherence between the intervention and control arms.147

## Key Question 5 Harms

### Description of Included Studies

Three RCTs addressed unintended consequences, or harms, associated with interventions to improve medication adherence (Table 73).98,104,116

Table 73 Harms: trial characteristics

Author, Year N at Randomization | Population Setting | Intervention and Comparator
Carter et al., 2009^104^ N=402 | Adults >21 years diagnosed with hypertension Community-based family medicine residency programs | G1: Physician/pharmacist collaborative model in which pharmacists addressed suboptimal medication regimens and poor medication adherence and gave feedback to physicians. Study nurses gave patients educational information and encouraged lifestyle modifications. G2: Patients received blood pressure measurements at baseline, 3 and 6 months and educational information from nurses. Clinical pharmacists abstained from providing care to patients in control group.
Murray et al., 2007^116^ N=314 | Adults ≥ 50 years of age with heart failure University-affiliated ambulatory care practice | G1: Pharmacist-led intervention providing verbal instructions, literacy-sensitive written materials, and labeling of medications with icons to promote medication adherence G2: No contact with intervention pharmacist other than initial medication history
Schectman et al., 1994^98^ N=102 (Niacin) N=62 (Bile acid sequestrant) | Adults with hyperlipidemia requiring treatment with either niacin or a bile acid sequestrant Veterans Affairs medical center | G1: Following initial clinic visit, received five calls over 28 days from a certified medical assistant to address problems and adverse events associated with medications; when needed, additional telephone contact arranged with physician or clinical pharmacist G2: No telephone contact following initial clinic visit

Abbreviations: G = group; N = number.

#### Population

One trial included adults older than 21 years of age who had been diagnosed with essential hypertension, were taking zero to three antihypertensive medications, did not have diabetes, and had systolic blood pressure values or diastolic blood pressure values within specific ranges (systolic blood pressure, 140 to 179 mm Hg; diastolic blood pressure, 90 to 109 mm Hg).104 It included hypertensive patients who had diabetes if their systolic blood pressure was between 130 to 179 mm Hg or diastolic blood pressure between 90 to 109 mm Hg.104 Another trial included patients ages 50 years or older who had a confirmed diagnosis of heart failure.116 Furthermore, participants had to receive all their care at Wishard Health services, regularly have used at least one specified medication for heart failure, and not have plans to use a medication adherence aid. In the third trial at a VAMC, participants were patients with hyperlipidemia who required treatment with either niacin or BAS therapy but had not taken either before.98

#### Intervention

One trial evaluated a collaborative model including care from a physician and a pharmacist.104 In another trial the intervention was pharmacist-led.116 In the third trial, the intervention was based on telephone contact that trained health care professionals made to patients.98

#### Comparator

In the trial using the collaborative model, the comparison group received no clinical pharmacist intervention.104 In the pharmacist-led trial, the control group comparison was the absence of clinical pharmacist intervention but the patients received usual care.116 Usual care was defined as receiving prescriptions from pharmacists who did not have specialized training from a multidisciplinary team and did not have access to patient-centered study materials.116 In the telephone-based trial, the comparison group received no telephone intervention.98

#### Outcome and Timing

All trials presented various medication adherence outcomes. For KQ 5, we focused on outcomes related to side effects, harms, and unintended consequences. In the collaborative model trial, patients provided information on a 47-item questionnaire. This questionnaire, developed and used originally in a previous study, was administered here by trial nurses; it centered on symptoms that were suggestive of adverse events.104,156 This questionnaire was administered at baseline and again at 6-month followup. In this questionnaire, each subject was asked, “In the past 4 weeks, how much have you been bothered by…” for every potential reaction. Subjects could respond with one of the following responses, and the scores for these responses were summed (with a total score range of 0 to 188): not at all (score: 0); a little bit (score: 1); somewhat (score: 2); quite a bit (score: 3) or very much (score: 4).156 The resulting symptom score, which was a sum of the score for each item on potential reactions, is thought to be indicative of adverse events. This measured was conducted once at baseline and once at the 6-month followup. In the pharmacy-ambulatory care practice trial, the investigators measured the number of patients who experienced an adverse events or medication error using a program that identified adverse events from the medical record system.116 They did not indicate the exact timing of these measurements.116 In the VAMC trial, patients reported adverse events associated with medications to clinic staff. Although the investigators collected these self-reported data at 2, 4, and 6 months after randomization, they reported results for only the 2-month point.98

#### Setting

The trials were conducted in various settings: community-based family medicine residency programs,104 a university-affiliated ambulatory care practice,116 and a VA lipid clinic.98

### Key Points

- In the collaborative model trial, the questionnaire-based symptom score, which was indicative of adverse events, decreased for both the intervention and control groups.104 In the other two trials, the number of adverse events in the intervention group did not differ significantly from the number in the control group. In the ambulatory practice trial, adverse events included frequently occurring events such as cough or allergy related to ACE inhibitors; they included serum digoxin concentrations at toxic levels and use of nonsteroidal anti-inflammatory medications in patients with either high serum potassium or renal insufficiency. Finally, in the VA trial, adverse events included frequently reported effects upon receiving niacin or BAS; these were specifically flushing, pruritus, rash and heartburn (for patients receiving niacin) and constipation, bloating, flatulence, and heartburn (for patients receiving BAS).98
- The results offer no evidence of greater adverse events in the intervention than in the comparison groups. Because of the differences in the kinds of adverse events assessed in these three studies, in the interventions, and in the diseases and medications, the evidence is insufficient to draw any conclusions about unintended consequences associated with interventions to improve medication adherence.

### Detailed Synthesis

In two trials, medication adherence did not improve with the intervention98,104 (Table 74). In the ambulatory care practice trial, medication adherence improved during the 9-month intervention period, but this result was not seen in the 3-month post-study period.116 In two of the three studies, the intervention group did not have a significantly different number of adverse events from the control group.98,116 In the collaborative model trial, medication use (but not medication adherence) increased for both the control and the intervention groups, but the symptom score decreased in both groups; differences in the intervention group from 6 months to baseline were statistically significant, as were differences between control and intervention groups at 6 months.104 Therefore, among the three trials included, the number of adverse events did not differ between the intervention arms and the control arms;98,116 in one case, the difference in adverse events favored the intervention arm.104

Table 74 Harms: adverse events outcomes

Author, Year N Analyzed | Adverse Event Outcome | Timing of Adverse Event Measurement and Data Source | Results
Carter et al., 2009^104^ G1: 192 G2: 210 | Mean total adverse event score | Measured twice, once at baseline and once at 6-month followup Adverse event questionnaire with 47 items, developed for another study and administered by study nurses | Baseline: Mean (SD) G1: 28.0 (23.0) G2: 42.1 (24.2) 95% CI, NR p<0.001 6-month followup: Mean (SD) G1: 16.6 (12.5) G2: 39.2 (24.2) 95% CI, NR p<0.001 Between-group difference at 6 months p<0.001. However, this does not adjust for difference at baseline.
Murray et al., 2007^116^ G1: 112 G2: 192 | Number of patients who had an adverse drug events or medication error | NR Measured using a program that identified adverse events from the medical record system | G1: 42 (37.5%) G2: 91 (47.4%) 95% CI, NR p: 0.094
Schectman et al., 1994^98^ Niacin: G1: 40 G2: 40 BAS: G1: 18 G2: 20 | Percentage of patients reporting adverse events associated with medications at 2 months | 2 months; measured at 2, 4, and 6 months; only 2-month results reported Self-report to clinic staff | Niacin: flushing, pruritis, rash, heartburn (%) G1: 70, 32, 15, 9 G2: 63, 29, 12, 5 95% CI: NR p: NS, no number given BAS: constipation, bloating, flatulence, heartburn (%) G1: 44, 23, 19, 15 G2: 26, 22, 11, 11 95% CI, NR p: NS, no number given

Abbreviations: BAS = bile acid sequestrant therapy; CI = confidence interval; G = group; NR = not reported; NS = not significant; SD = standard deviation.