# References

1 Priority Areas for National Action: Transforming Health Care Quality Summary of Institute of Medicine report. Agency for Healthcare Research and Quality. Rockville, MD. January. 2003. www.ahrq.gov/qual/iompriorities.htm.
2 Pathman DE, Konrad TR, Freed GL, et al. The awareness-to-adherence model of the steps to clinical guideline compliance. The case of pediatric vaccine recommendations. Med Care. Sep. 1996;34(9):873-89. [pmid: 8792778].
3 Osterberg L, Blaschke T. Adherence to medication. N Engl J Med. Aug. 4. 2005;353(5):487-97. [pmid: 16079372].
4 Cramer JA, Roy A, Burrell A, et al. Medication compliance and persistence: terminology and definitions. Value Health. Jan–Feb. 2008;11(1):44-7. [pmid: 18237359].
5 Urquhart J, Vrijens B. New findings about patient adherence to prescribed drug dosing regimens: an introduction to pharmionics. European Journal of Hospital Pharmacy Science. 2005;11(5):103-6.
6 Vrijens B, Vincze G, Kristanto P, et al. Adherence to prescribed antihypertensive drug treatments: longitudinal study of electronically compiled dosing histories. BMJ. May. 17. 2008;336(7653):1114-7. [pmid: 18480115].
7 Haynes RB, Ackloo E, Sahota N, et al. Interventions for enhancing medication adherence. Cochrane Database Syst Rev. Apr. 16. 2008;(2):CD000011. [pmid: 18425859].
8 Paterson DL, Swindells S, Mohr J, et al. Adherence to protease inhibitor therapy and outcomes in patients with HIV infection. Ann Intern Med. Jul. 4. 2000;133(1):21-30. [pmid: 10877736].
9 Munger MA, Van Tassell BW, LaFleur J. Medication nonadherence: an unrecognized cardiovascular risk factor. MedGenMed. 2007;9(3):58. [pmid: 18092064].
10 The Diabetes Control and Complications Trial Research Group. The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. N Engl J Med. Sep. 30. 1993;329(14):977-86. [pmid: 8366922].
11 Lin V, Holman JR, Jamieson B. Clinical Inquiries: Which drugs should post-MI patients routinely receive?. J Fam Pract. Sep. 2010;59(9):527-9. [pmid: 20824230].
12 Baker JG, Hill SJ, Summers RJ. Evolution of beta-blockers: from anti-anginal drugs to ligand-directed signalling. Trends Pharmacol Sci. Apr. 2011;32(4):227-34. [pmid: 21429598].
13 Expert Panel Report 3 (EPR-3): Guidelines for the Diagnosis and Management of Asthma-Summary Report 2007. J Allergy Clin Immunol. Nov. 2007;120(5 Suppl):S94-138. [pmid: 17983880].
14 LaRosa JC. Understanding risk in hypercholesterolemia. Clin Cardiol. Jan. 2003;26(1 Suppl 1):I3-6. [pmid: 12539815].
15 Glasgow RE, Hiss RG, Anderson RM, et al. Report of the health care delivery work group: behavioral research related to the establishment of a chronic disease model for diabetes care. Diabetes Care. Jan. 2001;24(1):124-30. [pmid: 11194217].
16 DiMatteo MR, Giordani PJ, Lepper HS, et al. Patient adherence and medical treatment outcomes: a meta-analysis. Med Care. Sep. 2002;40(9):794-811. [pmid: 12218770].
17 Krueger KP, Berger BA, Felkey B. Medication adherence and persistence: a comprehensive review. Adv Ther. Jul–Aug. 2005;22(4):313-56. [pmid: 16418141].
18 Noncommunicable Diseases and Mental Health Cluster. Adherence to Long Term Therapies: Evidence for Action. Geneva, Switzerland. World Health Organization. 2003.
19 Peterson AM, Takiya L, Finley R. Meta-analysis of trials of interventions to improve medication adherence. Am J Health Syst Pharm. Apr. 1. 2003;60(7):657-65. [pmid: 12701547].
20 Liu H, Golin CE, Miller LG, et al. A comparison study of multiple measures of adherence to HIV protease inhibitors. Ann Intern Med. May. 15. 2001;134(10):968-77. [pmid: 11352698].
21 Wagner EH. Chronic disease management: what will it take to improve care for chronic illness?. Eff Clin Pract. Aug–Sep. 1998;1(1):2-4. [pmid: 10345255].
22 World Health Organization. Adherence to Long Term Therapies: Evidence for Action. Switzerland. WHO. 2003.
23 Management of MDD Working Group. VA/DoD clinical practice guideline for management of major depressive disorder (MDD) Version 2.0. US Department of Veteran Affairs, US Department of Defense. Washington, DC. May. 2009.
24 Management of Asthma Working Group. VA/DoD clinical practice guideline for management of asthma in children and adults. Version 2.0. Washington (DC). Department of Veteran Affairs, Department of Defense. 2009.
25 Management of Overweight and Obesity Working Group. A/DoD clinical practice guideline for screening and management of overweight and obesity. Version 1.0. Washington, DC. U.S. Department of Veterans Affairs, U.S. Department of Defense. 2006.
26 Nunes V, Neilson J, O’Flynn N, et al. for the National Collaborating Centre for Primary Care. Medicines adherence involving patients in decisions about prescribed medicines and supporting adherence. National Institute for Health and Clinical Excellence and Royal College of General Practitioners. Clinical Guideline No. 76. London. January. 2009.
27 New York State Department of Health. Adherence to antiretroviral therapy among HIV-infected patients with mental health disorders. New York. New York State Department of Health. 2006.
28 Haynes RB, Ackloo E, Sahota N, et al. Interventions for enhancing medication adherence. Cochrane Database of Systematic Reviews. 2008;(2):CD000011. [pmid: 18425859].
29 World Health Organization. The world health report 2002: reducing risks, promoting healthy life. Geneva. World Health Organization. 2002.
30 Dunbar-Jacob J, Erlen JA, Schlenk EA, et al. Adherence in chronic disease. Annu Rev Nurs Res. 2000;18:48-90. [pmid: 10918932].
31 Sarquis LM, Dellacqua MC, Gallani MC, et al. Compliance in antihypertensive therapy: analyses in scientific articles. Rev Esc Enferm USP. Dec. 1998;32(4):335-53. [pmid: 10896654].
32 Schiff GD, Fung S, Speroff T, et al. Decompensated heart failure: symptoms, patterns of onset, and contributing factors. Am J Med. Jun. 1. 2003;114(8):625-30. [pmid: 12798449].
33 Waeber B, Burnier M, Brunner HR. How to improve adherence with prescribed treatment in hypertensive patients?. J Cardiovasc Pharmacol. Suppl 3. 2000;35:S23-6. [pmid: 10854048].
34 Psaty BM, Koepsell TD, Wagner EH, et al. The relative risk of incident coronary heart disease associated with recently stopping the use of beta-blockers. JAMA. Mar. 23–30. 1990;263(12):1653-7. [pmid: 1968518].
35 Beckles GL, Engelgau MM, Narayan KM, et al. Population-based assessment of the level of care among adults with diabetes in the U.S. Diabetes Care. Sep. 1998;21(9):1432-8. [pmid: 9727887].
36 Rogers PG, Bullman W. Prescription medicine compliance: review of the baseline of knowledge – report of the National Council on Patient Information and Education. Journal of Pharmacoepidemiology. 1995;3:3-36.
37 Mahoney JJ, ABJ, Fleming WK, Butterworth SW. The unhidden cost of noncompliance. J Manag Care Pharm. 2008;14(6-b):S1-S29.
38 New England Healthcare Institute. Thinking outside the pillbox: A system-wide approach to improving patient medication adherence for chronic disease. 2009.
39 Showalter A. Costs of patient noncompliance. Crystal Lake, IL. AlignMap. 2006:1-4.
40 Task Force for Compliance. Noncompliance with medications: An economic tragedy with important implications for health care reform. 1994.
41 Liebl A, Neiss A, Spannheimer A, et al. Costs of type 2 diabetes in Germany. Results of the CODE-2 study. Dtsch Med Wochenschr. May. 18. 2001;126(20):585-9. [pmid: 11402924].
42 Holman HR, Lorig KR, Sobel DS, et al. Evidence that an education program for self-management of chronic disease can improve health status while reducing health care costs: a randomized trial. Abstr Book Assoc Health Serv Res Meet. 1997;14:19-20.
43 Tuldra A, Fumaz CR, Ferrer MJ, et al. Prospective randomized two-Arm controlled study to determine the efficacy of a specific intervention to improve long-term adherence to highly active antiretroviral therapy. J Acquir Immune Defic Syndr. Nov. 1. 2000;25(3):221-8. [pmid: 11115952].
44 Gibson PG, Coughlan J, Wilson AJ, et al. Self-management education and regular practitioner review for adults with asthma. Cochrane Database Syst Rev. 2000;(2):CD001117. [pmid: 10796600].
45 Sloss EM, Solomon DH, Shekelle PG, et al. Selecting target conditions for quality of care improvement in vulnerable older adults. J Am Geriatr Soc. Apr. 2000;48(4):363-9. [pmid: 10798460].
46 Mar J, Rodriguez-Artalejo F. Which is more important for the efficiency of hypertension treatment: hypertension stage, type of drug or therapeutic compliance?. J Hypertens. Jan. 2001;19(1):149-55. [pmid: 11204296].
47 Massanari MJ. Asthma management: curtailing costs and improving patient outcomes. J Asthma. Dec. 2000;37(8):641-51. [pmid: 11192228].
48 Valenti WM. Treatment adherence improves outcomes and manages costs. AIDS Read. Feb. 2001;11(2):77-80. [pmid: 11279875].
49 Golin CE, Liu H, Hays RD, et al. A prospective study of predictors of adherence to combination antiretroviral medication. J Gen Intern Med. Oct. 2002;17(10):756-65. [pmid: 12390551].
50 Bosworth HB, Dudley T, Olsen MK, et al. Racial differences in blood pressure control: potential explanatory factors. Am J Med. Jan. 2006;119(1):70 e9-15. [pmid: 16431192].
51 Gifford AL, Bormann JE, Shively MJ, et al. Predictors of self-reported adherence and plasma HIV concentrations in patients on multidrug antiretroviral regimens. J Acquir Immune Defic Syndr. Apr. 15. 2000;23(5):386-95. [pmid: 10866231].
52 Bryson CL, Au DH, Sun H, et al. Alcohol screening scores and medication nonadherence. Ann Intern Med. Dec. 2. 2008;149(11):795-804. [pmid: 19047026].
53 Kilbourne AM, Reynolds CFr, Good CB, et al. How does depression influence diabetes medication adherence in older patients?. Am J Geriatr Psychiatry. Mar. 2005;13(3):202-10. [pmid: 15728751].
54 Muma RD, Ross MW, Parcel GS, et al. Zidovudine adherence among individuals with HIV infection. AIDS Care. 1995;7(4):439-47. [pmid: 8547359].
55 Laine C, Newschaffer CJ, Zhang D, et al. Adherence to antiretroviral therapy by pregnant women infected with human immunodeficiency virus: a pharmacy claims-based analysis. Obstet Gynecol. Feb. 2000;95(2):167-73. [pmid: 10674574].
56 Schlenk EA, Dunbar-Jacob J, Engberg S. Medication non-adherence among older adults: a review of strategies and interventions for improvement. J Gerontol Nurs. Jul. 2004;30(7):33-43. [pmid: 15287325].
57 U.S. Department of Health and Human Services. Healthy People 2010. Washington, DC. U.S. Government Printing Office. 2000. Originally developed for Ratzan SC, Parker RM. Introduction. In National Library of Medicine Current Bibliographies in Medicine: Health Literacy. Selden CR, Zorn M, Ratzan SC, Parker RM, Editors. NLM Pub. No. CBM 2000-1. Bethesda, MD: National Institutes of Health, U.S. Department of Health and Human Services; 2000.
58 Pignone M, DeWalt DA, Sheridan S, et al. Interventions to improve health outcomes for patients with low literacy. A systematic review. J Gen Intern Med. Feb. 2005;20(2):185-92. [pmid: 15836553].
59 Williams MV, Baker DW, Parker RM, et al. Relationship of functional health literacy to patients’ knowledge of their chronic disease. A study of patients with hypertension and diabetes. Arch Intern Med. Jan. 26. 1998;158(2):166-72. [pmid: 9448555].
60 TenHave TR, Van Horn B, Kumanyika S, et al. Literacy assessment in a cardiovascular nutrition education setting. Patient Educ Couns. Jun. 1997;31(2):139-50. [pmid: 9216355].
61 Baker DW, Gazmararian JA, Williams MV, et al. Functional health literacy and the risk of hospital admission among Medicare managed care enrollees. Am J Public Health. Aug. 2002;92(8):1278-83. [pmid: 12144984].
62 Baker DW, Parker RM, Williams MV, et al. Health literacy and the risk of hospital admission. J Gen Intern Med. Dec. 1998;13(12):791-8. [pmid: 9844076].
63 Schillinger D, Grumbach K, Piette J, et al. Association of health literacy with diabetes outcomes. JAMA. Jul. 24–31. 2002;288(4):475-82. [pmid: 12132978].
64 Schillinger D, Barton LR, Karter AJ, et al. Does literacy mediate the relationship between education and health outcomes? A study of a low-income population with diabetes. Public Health Rep. May–Jun. 2006;121(3):245-54. [pmid: 16640146].
65 Welk G, Wood K, Jones S, et al. The validity of three different accelerometers for assessment of lifestyle physical activity. Med Science Sports Exercise. 1999;31:S142.
66 Kalichman SC, Ramachandran B, Catz S. Adherence to combination antiretroviral therapies in HIV patients of low health literacy. J Gen Intern Med. May. 1999;14(5):267-73. [pmid: 10337035].
67 Sawaya AL, Tucker K, Tsay R, et al. Evaluation of four methods for determining energy intake in young and older women: comparison with doubly labeled water measurements of total energy expenditure. Am J Clin Nutr. Apr. 1996;63(4):491-9. [pmid: 8599311].
68 Sheridan SL, Halpern DJ, Viera AJ, et al. Interventions for individuals with low health literacy: a systematic review. J Health Commun. Sep. 30. Suppl 3. 2011;16:30-54. [pmid: 21951242].
69 Berkman ND, Sheridan SL, Donahue KE, et al. Low health literacy and health outcomes: an updated systematic review. Ann Intern Med. Jul. 19. 2011;155(2):97-107. [pmid: 21768583].
70 Paasche-Orlow MK, Riekert KA, Bilderback A, et al. Tailored education may reduce health literacy disparities in asthma self-management. Am J Respir Crit Care Med. Oct. 15. 2005;172(8):980-6. [pmid: 16081544].
71 Kim S, Love F, Quistberg DA, et al. Association of health literacy with self-management behavior in patients with diabetes. Diabetes Care. Dec. 2004;27(12):2980-2. [pmid: 15562219].
72 Miller LG, Liu H, Hays RD, et al. Knowledge of antiretroviral regimen dosing and adherence: a longitudinal study. Clin Infect Dis. Feb. 15. 2003;36(4):514-8. [pmid: 12567311].
73 Eaton ML, Holloway RL. Patient comprehension of written drug information. Am J Hosp Pharm. Feb. 1980;37(2):240-3. [pmid: 7361799].
74 de Bruin M, Viechtbauer W, Schaalma HP, et al. Standard care impact on effects of highly active antiretroviral therapy adherence interventions: A meta-analysis of randomized controlled trials. Arch Intern Med. Feb. 8. 2010;170(3):240-50. [pmid: 20142568].
75 Shojania KG, McDonald KM, Wachter R, et al. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Volume 1—Series Overview and Methodology Technical Review 9. (Contract No. 290-02-0017 to the Stanford University-UCSF Evidence-based Practice Center). Agency for Healthcare Research and Quality. AHRQ Publication No. 04-005101. Rockville, MD. 2004. www.ahrq.gov/clinic/tp/gaprevover.htm.
76 Institute of Medicine (U.S.), Committee on Identifying Priority Areas for Quality Improvement. Priority areas for national action: transforming health care quality. Washington, DC. National Academies Press. 2003.
77 Roter DL, Hall JA, Merisca R, et al. Effectiveness of interventions to improve patient compliance: a meta-analysis. Med Care. Aug. 1998;36(8):1138-61. [pmid: 9708588].
78 Lee JK, Grace KA, Taylor AJ. Effect of a pharmacy care program on medication adherence and persistence, blood pressure, and low-density lipoprotein cholesterol: a randomized controlled trial. JAMA. Dec. 6. 2006;296(21):2563-71. [pmid: 17101639].
79 Crepaz N, Lyles CM, Wolitski RJ, et al. Do prevention interventions reduce HIV risk behaviours among people living with HIV? A meta-analytic review of controlled trials. AIDS. Jan. 9. 2006;20(2):143-57. [pmid: 16511407].
80 Simoni JM, Pearson CR, Pantalone DW, et al. Efficacy of interventions in improving highly active antiretroviral therapy adherence and HIV-1 RNA viral load. A meta-analytic review of randomized controlled trials. J Acquir Immune Defic Syndr. Dec. 1. Suppl 1. 2006;43:S23-35. [pmid: 17133201].
81 Amico KR, Harman JJ, Johnson BT. Efficacy of antiretroviral therapy adherence interventions: a research synthesis of trials, 1996 to 2004. J Acquir Immune Defic Syndr. Mar. 2006;41(3):285-97. [pmid: 16540929].
82 Simoni JM, Amico KR, Smith L, et al. Antiretroviral adherence interventions: translating research findings to the real world clinic. Curr HIV/AIDS Rep. Feb. 2010;7(1):44-51. [pmid: 20425057].
83 Agency for Healthcare Research and Quality. Methods guide for effectiveness and comparative effectiveness reviews. 2011.
84 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. 2011. Sep. 28. [pmid: 21959223].
85 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
86 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
87 Bogner HR, de Vries HF. Integrating type 2 diabetes mellitus and depression treatment among African Americans: a randomized controlled pilot trial. Diabetes Educ. Mar–Apr. 2010;36(2):284-92. [pmid: 20040705].
88 Grant RW, Devita NG, Singer DE, et al. Improving adherence and reducing medication discrepancies in patients with diabetes. Ann Pharmacother. Jul–Aug. 2003;37(7–8):962-9. [pmid: 12841801].
89 Lin EH, Katon W, Rutter C, et al. Effects of enhanced depression treatment on diabetes self-care. Ann Fam Med. Jan–Feb. 2006;4(1):46-53. [pmid: 16449396].
90 Wolever RQ, Dreusicke M, Fikkan J, et al. Integrative health coaching for patients with type 2 diabetes: a randomized clinical trial. Diabetes Educ. Jul–Aug. 2010;36(4):629-39. [pmid: 20534872].
91 Pearce KA, Love MM, Shelton BJ, et al. Cardiovascular risk education and social support (CaRESS): report of a randomized controlled trial from the Kentucky Ambulatory Network (KAN). J Am Board Fam Med. Jul–Aug. 2008;21(4):269-81. [pmid: 18612053].
92 Mann DM, Ponieman D, Montori VM, et al. The Statin Choice decision aid in primary care: a randomized trial. Patient Educ Couns. Jul. 2010;80(1):138-40. [pmid: 19959322].
93 Weymiller AJ, Montori VM, Jones LA, et al. Helping patients with type 2 diabetes mellitus make treatment decisions: statin choice randomized trial. Arch Intern Med. May. 28. 2007;167(10):1076-82. [pmid: 17533211].
94 Jones LA, Weymiller AJ, Shah N, et al. Should clinicians deliver decision aids? Further exploration of the statin choice randomized trial results. Med Decis Making. Jul–Aug. 2009;29(4):468-74. [pmid: 19605885].
95 Guthrie RM. The effects of postal and telephone reminders on compliance with pravastatin therapy in a national registry: results of the first myocardial infarction risk reduction program. Clin Ther. Jun. 2001;23(6):970-80. [pmid: 11440296].
96 Johnson SS, Driskell MM, Johnson JL, et al. Transtheoretical model intervention for adherence to lipid-lowering drugs. Dis Manag. Apr. 2006;9(2):102-14. [pmid: 16620196].
97 Powell KM, Edgren B. Failure of educational videotapes to improve medication compliance in a health maintenance organization. Am J Health Syst Pharm. Oct. 15. 1995;52(20):2196-9. [pmid: 8564589].
98 Schectman G, Hiatt J, Hartz A. Telephone contacts do not improve adherence to niacin or bile acid sequestrant therapy. Ann Pharmacother. Jan. 1994;28(1):29-35. [pmid: 8123955].
99 Stacy JN, Schwartz SM, Ershoff D, et al. Incorporating tailored interactive patient solutions using interactive voice response technology to improve statin adherence: results of a randomized clinical trial in a managed care setting. Popul Health Manag. Oct. 2009;12(5):241-54. [pmid: 19848566].
100 Schneider PJ, Murphy JE, Pedersen CA. Impact of medication packaging on adherence and treatment outcomes in older ambulatory patients. J Am Pharm Assoc. 2008. Jan–Feb. 2003;48(1):58-63. [pmid: 18192132].
101 Bogner HR, de Vries HF. Integration of depression and hypertension treatment: a pilot, randomized controlled trial. Ann Fam Med. Jul–Aug. 2008;6(4):295-301. [pmid: 18626028].
102 Rudd P, Miller NH, Kaufman J, et al. Nurse management for hypertension. A systems approach. Am J Hypertens. Oct. 2004;17(10):921-7. [pmid: 15485755].
103 Wakefield BJ, Holman JE, Ray A, et al. Effectiveness of home telehealth in comorbid diabetes and hypertension: a randomized, controlled trial. Telemed J E Health. May. 2011;17(4):254-61. [pmid: 21476945].
104 Carter BL, Ardery G, Dawson JD, et al. Physician and pharmacist collaboration to improve blood pressure control. Arch Intern Med. Nov. 23. 2009;169(21):1996-2002. [pmid: 19933962].
105 Hunt JS, Siemienczuk J, Pape G, et al. A randomized controlled trial of team-based care: impact of physician-pharmacist collaboration on uncontrolled hypertension. J Gen Intern Med. Dec. 2008;23(12):1966-72. [pmid: 18815843].
106 Bosworth HB, Olsen MK, Neary A, et al. Take Control of Your Blood Pressure (TCYB) study: a multifactorial tailored behavioral and educational intervention for achieving blood pressure control. Patient Educ Couns. Mar. 2008;70(3):338-47. [pmid: 18164894].
107 Bosworth HB, Olsen MK, Dudley T, et al. The Take Control of Your Blood pressure (TCYB) study: Study design and methodology. Contemporary Clinical Trials. 2007;28(1):33-47. [pmid: 16996808].
108 Bosworth HB, Olsen MK, Gentry P, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Educ Couns. Apr. 2005;57(1):5-14. [pmid: 15797147].
109 Friedman RH, Kazis LE, Jette A, et al. A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control. Am J Hypertens. Apr. 1996;9(4 Pt 1):285-92. [pmid: 8722429].
110 Johnson SS, Driskell MM, Johnson JL, et al. Efficacy of a transtheoretical model-based expert system for antihypertensive adherence. Dis Manag. Oct. 2006;9(5):291-301. [pmid: 17044763].
111 Solomon DK, Portner TS, Bass GE, et al. Clinical and economic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). Sep–Oct. 1998;38(5):574-85. [pmid: 9782691].
112 Gourley GA, Portner TS, Gourley DR, et al. Humanistic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). Sep–Oct. 1998;38(5):586-97. [pmid: 9782692].
113 Vivian EM. Improving blood pressure control in a pharmacist-managed hypertension clinic. Pharmacotherapy. Dec. 2002;22(12):1533-40. [pmid: 12495164].
114 Powers BJ, Danus S, Grubber JM, et al. The effectiveness of personalized coronary heart disease and stroke risk communication. Am Heart J. 2011;161(4):673-80. [pmid: 21473965].
115 Fulmer TT, Feldman PH, Kim TS, et al. An intervention study to enhance medication compliance in community-dwelling elderly individuals. J Gerontol Nurs. Aug. 1999;25(8):6-14. [pmid: 10711101].
116 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. [pmid: 17502632].
117 Rich MW, Gray DB, Beckham V, et al. Effect of a multidisciplinary intervention on medication compliance in elderly patients with congestive heart failure. Am J Med. Sep. 1996;101(3):270-6. [pmid: 8873488].
118 Ross SE, Moore LA, Earnest MA, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. May. 14. 2004;6(2):e12. [pmid: 15249261].
119 Smith DH, Kramer JM, Perrin N, et al. A randomized trial of direct-to-patient communication to enhance adherence to beta-blocker therapy following myocardial infarction. Arch Intern Med. Mar. 10. 2008;168(5):477-83. discussion 83; quiz 47. [pmid: 18332291].
120 Bender BG, Apter A, Bogen DK, et al. Test of an interactive voice response intervention to improve adherence to controller medications in adults with asthma. J Am Board Fam Med. Mar–Apr. 2010;23(2):159-65. [pmid: 20207925].
121 Berg J, Dunbar-Jacob J, Sereika SM. An evaluation of a self-management program for adults with asthma. Clin Nurs Res. Aug. 1997;6(3):225-38. [pmid: 9281927].
122 Janson SL, Fahy JV, Covington JK, et al. Effects of individual self-management education on clinical, biological, and adherence outcomes in asthma. Am J Med. Dec. 1. 2003;115(8):620-6. [pmid: 14656614].
123 Janson SL, McGrath KW, Covington JK, et al. Individualized asthma self-management improves medication adherence and markers of asthma control. J Allergy Clin Immunol. Apr. 2009;123(4):840-6. [pmid: 19348923].
124 Schaffer SD, Tian L. Promoting adherence: effects of theory-based asthma education. Clin Nurs Res. Feb. 2004;13(1):69-89. [pmid: 14768768].
125 Weinberger M, Murray MD, Marrero DG, et al. Effectiveness of pharmacist care for patients with reactive airways disease: a randomized controlled trial. JAMA. Oct. 2. 2002;288(13):1594-602. [pmid: 12350190].
126 Williams LK, Peterson EL, Wells K, et al. A cluster-randomized trial to provide clinicians inhaled corticosteroid adherence information for their patients with asthma. J Allergy Clin Immunol. Aug. 2010;126(2):225-31. 31 e1. 4. [pmid: 20569973].
127 Wilson SR, Strub P, Buist AS, et al. Shared treatment decision making improves adherence and outcomes in poorly controlled asthma. Am J Respir Crit Care Med. Mar. 15. 2010;181(6):566-77. [pmid: 20019345].
128 Rickles NM, Svarstad BL, Statz-Paynter JL, et al. Pharmacist telemonitoring of antidepressant use: effects on pharmacist-patient collaboration. J Am Pharm Assoc. 2005. May–Jun. 2003;45(3):344-53. [pmid: 15991756].
129 Simon GE, Ludman EJ, Operskalski BH. Randomized trial of a telephone care management program for outpatients starting antidepressant treatment. Psychiatr Serv. Oct. 2006;57(10):1441-5. [pmid: 17035563].
130 Katon W, Rutter C, Ludman EJ, et al. A randomized trial of relapse prevention of depression in primary care. Arch Gen Psychiatry. Mar. 2001;58(3):241-7. [pmid: 11231831].
131 Ludman E, Katon W, Bush T, et al. Behavioural factors associated with symptom outcomes in a primary care-based depression prevention intervention trial. Psychol Med. Aug. 2003;33(6):1061-70. [pmid: 12946090].
132 Von Korff M, Katon W, Rutter C, et al. Effect on disability outcomes of a depression relapse prevention program. Psychosom Med. Nov–Dec. 2003;65(6):938-43. [pmid: 14645770].
133 Capoccia KL, Boudreau DM, Blough DK, et al. Randomized trial of pharmacist interventions to improve depression care and outcomes in primary care. Am J Health Syst Pharm. Feb. 15. 2004;61(4):364-72. [pmid: 15011764].
134 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve treatment guidelines. Impact on depression in primary care. JAMA. Apr. 5. 1995;273(13):1026-31. [pmid: 7897786].
135 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Arch Gen Psychiatry. Oct. 1996;53(10):924-32. [pmid: 8857869].
136 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: A randomized trial. Arch Gen Psychiatry. 1999;56(12):1109-15. [pmid: 10591288].
137 Katon W, Russo J, Von Korff M, et al. Long-term effects of a collaborative care intervention in persistently depressed primary care patients. J Gen Intern Med. Oct. 2002;17(10):741-8. [pmid: 12390549].
138 Pyne JM, Fortney JC, Curran GM, et al. Effectiveness of collaborative care for depression in human immunodeficiency virus clinics. Arch Intern Med. Jan. 10. 2011;171(1):23-31. [pmid: 21220657].
139 Hoffman L, Enders J, Luo J, et al. Impact of an antidepressant management program on medication adherence. Am J Manag Care. Jan. 2003;9(1):70-80. [pmid: 12549816].
140 Okeke CO, Quigley HA, Jampel HD, et al. Interventions improve poor adherence with once daily glaucoma medications in electronically monitored patients. Ophthalmology. Dec. 2009;116(12):2286-93. [pmid: 19815286].
141 Berger BA, Liang H, Hudmon KS. Evaluation of software-based telephone counseling to enhance medication persistency among patients with multiple sclerosis. J Am Pharm Assoc. 2005. Jul–Aug. 2003;45(4):466-72. [pmid: 16128502].
142 Rudd RE, Blanch DC, Gall V, et al. A randomized controlled trial of an intervention to reduce low literacy barriers in inflammatory arthritis management. Patient Educ Couns. Jun. 2009;75(3):334-9. [pmid: 19345053].
143 Waalen J, Bruning AL, Peters MJ, et al. A telephone-based intervention for increasing the use of osteoporosis medication: a randomized controlled trial. Am J Manag Care. Aug. 2009;15(8):e60-70. [pmid: 19659407].
144 Montori VM, Shah ND, Pencille LJ, et al. Use of a decision aid to improve treatment decisions in osteoporosis: the osteoporosis choice randomized trial. Am J Med. Jun. 2011;124(6):549-56. [pmid: 21605732].
145 Nietert PJ, Tilley BC, Zhao W, et al. Two pharmacy interventions to improve refill persistence for chronic disease medications: a randomized, controlled trial. Med Care. Jan. 2009;47(1):32-40. [pmid: 19106728].
146 Schnipper JL, Kirwin JL, Cotugno MC, et al. Role of pharmacist counseling in preventing adverse drug events after hospitalization. Arch Intern Med. Mar. 13. 2006;166(5):565-71. [pmid: 16534045].
147 Taylor CT, Byrd DC, Krueger K. Improving primary care in rural Alabama with a pharmacy initiative. Am J Health Syst Pharm. Jun. 1. 2003;60(11):1123-9. [pmid: 12816022].
148 Sledge WH, Brown KE, Levine JM, et al. A randomized trial of primary intensive care to reduce hospital admissions in patients with high utilization of inpatient services. Dis Manag. Dec. 2006;9(6):328-38. [pmid: 17115880].
149 Chernew ME, Shah MR, Wegh A, et al. Impact of decreasing copayments on medication adherence within a disease management environment. Health Aff (Millwood). Jan–Feb. 2008;27(1):103-12. [pmid: 18180484].
150 Choudhry NK, Fischer MA, Avorn J, et al. At Pitney Bowes, value-based insurance design cut copayments and increased drug adherence. Health Aff (Millwood). Nov. 2010;29(11):1995-2001. [pmid: 21041738].
151 Zhang Y, Lave JR, Donohue JM, et al. The impact of Medicare Part D on medication adherence among older adults enrolled in Medicare-Advantage products. Med Care. May. 2010;48(5):409-17. [pmid: 20393360].
152 Maciejewski ML, Farley JF, Parker J, et al. Copayment reductions generate greater medication adherence in targeted patients. Health Aff (Millwood). Nov. 2010;29(11):2002-8. [pmid: 21041739].
153 Choudhry NK, Avorn J, Glynn RJ, et al. Full coverage for preventive medications after myocardial infarction. N Engl J Med. Dec. 1. 2011;365(22):2088-97. [pmid: 22080794].
154 Gold M, Jacobson G, Damico A, et al. Medicare Advantage enrollment market update Kaiser Family Foundation. Program on Medicare Policy. Sep. 2011:1-13.
155 Morisky DE, Green LW, Levine DM. Concurrent and predictive validity of a self-reported measure of medication adherence. Med Care. Jan. 1986;24(1):67-74. [pmid: 3945130].
156 Kaboli P, Hoth A, Carter BL, et al. The VA Enhanced Pharmacy Outpatient Clinic (EPOC) Study: A randomized-controlled pharmacist-physician intervention trial. J Gen Intern Med. Apr. 2004;19(Suppl 1):227.
157 Rueda S, Park-Wyllie Laura Y, Bayoumi A, et al. Patient support and education for promoting adherence to highly active antiretroviral therapy for HIV/AIDS. Cochrane Database of Systematic Reviews. 2006;(3). [pmid: 16855968].
158 Davidoff F, Batalden P, Stevens D, et al. Publication guidelines for quality improvement in health care: evolution of the SQUIRE project. Quality & safety in health care. Oct. Suppl 1. 2008;17:i3-9. [pmid: 18836063].
159 Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. Aug. 28. 1996;276(8):637-9. [pmid: 8773637].