# Introduction

## Background

Achieving the goals of quantitatively improving both the quality and the effectiveness of health care for all Americans requires both knowledge and tools. Although medical researchers have demonstrated that many efficacious medical treatments can improve health outcomes, a recent Institute of Medicine (IOM) report identified a disquieting discrepancy between present treatment success rates and those thought to be achievable.1 This gap has been attributed partly to barriers that providers face in implementing best practice guidelines.1,2 Patients’ adherence to treatment, however, provides an additional explanation for the discontinuity between recommended treatment and actual treatment outcomes. Of particular concern is adherence to recommendations about medications.

### Defining Medication Adherence

Medication adherence is defined as “the extent to which patients take medication as prescribed by their health care providers.”3^(p.487)^ The International Society for Pharmacoeconomics and Outcomes Research (ISPOR) Medication Compliance and Persistence Workgroup, as well as other medication adherence experts, recently recommended distinguishing two different types of nonadherence that may have distinctive causes and likely have different effects on health outcomes. Specifically, increasing emphasis has been placed on differentiating medication persistence from medication adherence.4–6

Medication adherence refers to the patient’s conformance with the provider’s recommendation with respect to timing, dosage, and frequency of medication taking during the prescribed length of time.4,5 In contrast, persistence refers to the act of continuing the treatment for the prescribed duration and may be defined as the total length of time a patient takes a medication, demarcated by the time between first and last dose.5,6 Health outcomes may be improved by helping patients better adhere to and persist with recommended treatment, in much the same sense that such outcomes may be improved by enhancing provider implementation of best practice guidelines.7–9

### Linking Poor Medication Adherence and Health Outcomes

Since 1950, pharmacological management of many acute and chronic health problems has advanced rapidly; among the conditions benefiting from this progress are diabetes, hypertension, hypercholesterolemia, asthma, and cardiovascular disease10–14 When left untreated or undertreated, these conditions often lead to complications (e.g., myocardial infarction, stroke, kidney failure, immune compromise) that decrease patients’ quality of life and increase their risk of death.15,16

Despite the established capacity for many medications to reduce both mortality and morbidity, many patients do not use their medications as recommended by health care providers.3,8,16–18 Although the specific consequences of suboptimal adherence to medications vary greatly, depending on the condition treated and the prescribed treatment, poor adherence clearly poses a threat to the health of the U.S. population.18,19 To reduce the gap between potential and actual health care quality, this problem must be addressed directly.

Researchers have suggested that factors affecting adherence differ, depending on the chronicity of the illness.15,20,21 Glasgow and colleagues have proposed that, as a result, chronic illness cannot be addressed adequately with a traditional, directive acute-care model.15 Instead, they argue, supporting adherence to treatment of chronic illness requires active engagement of patients in their treatment over time. This view calls for using a newer chronic care model.

Medication adherence is particularly salient for several vulnerable populations of interest to the Agency for Healthcare Research and Quality (AHRQ) and the IOM; these include racial and ethnic minorities, people with low literacy, and the elderly. The World Health Organization (WHO) has pointed out that economically disadvantaged groups not only have higher incidence and prevalence of many chronic illnesses than other populations, but also face greater barriers to medication taking than those who are more advantaged.22 Thus, understanding approaches to enhancing medication adherence may provide a way to reduce health disparities. Because medication adherence is becoming more recognized as an important issue in health care quality, treatment guidelines often include recommendations for providers to consider adherence.

### Linking Medication Adherence and Clinical Practice Guidelines

Guidelines and recommendations released over the past 5 years (from 2006 onward) that address medication adherence-related issues are predominantly disease specific and focus on a particular condition, such as depression, asthma, overweight/obesity, and HIV/AIDS. Furthermore, adherence is not the focus of these guidelines; rather, it is one among several issues typically discussed in the area of disease treatment and management. Recent disease-specific recommendations include those published by the U.S. Department of Veterans Affairs and the New York State Department of Health. Guidelines from the National Collaborating Centre for Primary Care on behalf of the United Kingdom-based National Institute for Health and Clinical Excellence (NICE) provide recommendations pertaining to medication adherence that are not disease specific.23–27

### Burden of Medication Nonadherence and Prevalence of Medication Nonadherence

Poor medication adherence is relatively common.3,18 Studies have shown consistently that 20 to 30 percent of medication prescriptions are never filled and that, on average, 50 percent of medications for chronic disease are not taken as prescribed.19,28 A meta-analysis of studies examining the prevalence of medication nonadherence estimated that 21 percent of patients do not take their medications as recommended.16 Nonadherence tends to occur with greater frequency when patients use medications to treat asymptomatic chronic conditions such as hypertension and hypercholesterolemia. The literature suggests that 20 to 75 percent of patients who are prescribed medications for these conditions are not adhering to the regimen at their 1-year followup.3,17

### Effects of Nonadherence on Health Outcomes and Health Care Costs

This lack of adherence to medications is prevalent and has dramatic effects on individual and population-level health. The WHO identified medication adherence as a primary determinant of treatment effectiveness.22,29–31 In the United States, the lack of adherence to medications has been estimated to cause approximately 125,000 deaths, at least 10 percent of hospital admissions,19 and substantial worsening of morbidity and mortality.16,32 For example, poor adherence—including but not limited to medication adherence—has been identified as the primary cause of inadequate blood pressure control33 and of complications of hypertension34–36 and poor treatment outcomes in depressed patients.

Nonadherence has been estimated to cost the U.S. health care system between $100 billion and $289 billion annually in direct costs.3,19,37–40 In one study, the direct costs of complications attributable to poor control of diabetes in Europe were three to four times higher than the costs among patients with good control.41 Strong evidence suggests that benefits attributable to improved self-management of chronic diseases could result in a cost-to-savings ratio of approximately 1:10.^42–48^

### Causes of Medication Nonadherence

Although experts agree that poor adherence to medications is a widespread phenomenon with far-reaching, costly individual and public health effects, the specific causes of and solutions to the problem are less clear. Observational studies focusing on the factors that cause medication nonadherence have shown that it is a complex behavior with multiple determinants. Factors at four levels can lead to medication nonadherence or foster better adherence: (1) health policies; (2) the health system;32 (3) health care provider; and (4) the patient. Many studies have examined the multiple factors associated with medication adherence.

Health policies support health care systems and influence broader societal factors that affect the patient’s ability to adhere to medication recommendations; these include gaining access to health care and health insurance or paying for medical treatment.

Health system factors that affect medication adherence include clinicians’ behaviors and broader infrastructural features of a health system, such as communication systems for interdisciplinary teams that may contribute to better medication adherence. At the systems level, lack of access to a provider who will monitor the response to medication and change the dosage or medication type accordingly may negatively affect long-term adherence to medication regimens.

Assuming a patient has access to a health care provider who prescribes an appropriate medication, at the correct dose, and for the correct duration, the health system and health provider factors related to nonadherence include many potential problems. Examples include inadequate instructions given for taking the medication, insufficient labeling of the medication container to promote correct adherence, and inadequate information given about the benefits and risks of and alternatives to the prescribed medication. Many health care systems operate on an acute care model that fails to engage patients in their own care; this approach to clinical care is a barrier to promoting adherence to chronic illness treatment that requires such engagement.15 Hence, understanding ways to overcome such barriers at the system level is particularly important in the setting of long-term treatment for chronic diseases.

Many patient factors underlie nonadherence. Patients may lack the cognitive ability to understand the need for the medication or how to take it. Others may not feel motivated to take the medication or may lack the skills and resources that support adherence.49–51 Substance abuse, depression,8,49,52,53 lack of medical insurance, competing demands on time, and an erratic daily routine can all impede optimal medication use.18,49 The factors that most influence adherence differ across individuals.49 Therefore, interventions to improve adherence are often multipronged and tailored. The cognitive barriers that patients with psychosis, mania, or bipolar disorder face in taking medication likely differ from those associated with other chronic conditions; for purposes of this review, we exclude studies involving patients with psychosis, mania, and bipolar disorder.

Patients may be nonadherent in many ways. Some patients may omit doses of a medication, whereas others may take extra doses. They may take the wrong amount of the medication—either too little or too much—or take the medication at the wrong time of day. Patients can be nonadherent simply by not following instructions on how to take the medication (e.g., with or without food). Other nonadherence examples include taking drug holidays (purposefully discontinuing the medication for a period of time) or even stopping the medication altogether.

### Health and Health Care Disparities

Health and health care disparities exist for many common chronic diseases, including cardiovascular disease, diabetes mellitus, hypertension, HIV infection, and depression. However, the extent to which these differences can be attributed to medication adherence is unclear. Ethnic differences in medication-adherence rates may partly explain observed health disparities.51,54,55 For example, multiple studies have documented that African-American patients are less adherent, particularly to antiretroviral treatment, than White patients and have postulated that this phenomenon may explain differences in clinical outcomes.50,51,54,55 Although the reasons for these differences in adherence are not fully understood, phenomena such as less trust in the health care system have been suggested. Similarly, poor adherence has been identified as particularly problematic for older adults, who often must take multiple medications in the face of physical and cognitive limitations.56

Low health literacy may be linked to poor adherence and poor health outcomes and partly explain heath disparities. Health literacy is defined in Healthy People 2010 as the degree to which individuals can obtain, process, and understand the basic health information and services they need to make appropriate health decisions.57 In a systematic review of 44 studies that assessed the relationship between health literacy and health outcomes, 16 evaluated the association between health literacy and knowledge.58 Health literacy was associated with greater knowledge in 14 of the 16 studies reviewed, including studies that examined patient knowledge of diabetes, hypertension, and heart health.59,60 Low literacy has been associated with greater risk of hospitalization61,62 and poorer control of type 2 diabetes.59,63–65 Only a handful of studies have examined the association between health literacy and medication adherence, however, and the results of these studies have been conflicting. Whereas Kalichman and colleagues found low health literacy to be associated with poorer compliance with medication,66 other studies failed to replicate this finding.49,67 A recently updated systematic review of health literacy found insufficient evidence to identify a definitive link between low health literacy and medication adherence.68,69 This same review identified only two quasi-experimental trials of interventions to enhance adherence by addressing low health literacy.70,71 The investigators found no difference in the effect of their self-management interventions by health literacy level, although they reported insufficient information to determine overall or subgroup effect sizes.68 Nonetheless, other studies demonstrate that patients with low literacy skills have difficulty understanding prescription warning labels and identifying their medications correctly.72,73 Although patients with limited literacy skills may be at greater risk than others for medication misadministration, conclusive data about whether this is the case, and if so, how best to address the issue are not yet available.

### Possible Improvement Strategies for Medication Nonadherence

This review seeks to synthesize evidence regarding the efficacy and effectiveness of interventions to improve adherence to medication regimens used to treat an array of chronic illness among adults. Although intervention labels and components vary greatly, we list below some common characteristics of interventions. These common characteristics of interventions may be less applicable for interventions that target policy levels.

- Intervention Target: The target refers to the person, people, health system, or policy to which intervention activities are directed. Although the ultimate goal of adherence interventions is to improve patient medication-taking behavior, interventions may do this by directly targeting providers, patients, aspects of a health system, health policies, or some combination of these four.
- Intervention Agent: An intervention agent is the person, people, or technology used to deliver the intervention. Examples of possible intervention agents include physicians, nurses, pharmacists, case managers, multidisciplinary teams, or family members. Some interventions may have more than one agent delivering an intervention or a part of an intervention.
- Mode of Delivery: The mode of delivery refers to the manner by which the agent delivers the intervention. For example, interventions may be delivered face-to-face, by telephone; with print materials, by computer, or by a DVD, video, or CD/audio. Like intervention target and agent, an intervention may have more than one mode of delivery.
- Intensity of Intervention: Medication adherence interventions vary in their intensity or dose. Intensity refers to the total amount of time an intervention lasts, taking into account the duration and number of all individual sessions.
- Duration of Intervention: In contrast to intensity, the duration of an intervention is a description of the total length of calendar time over which any series of individual sessions are delivered. Two interventions may have the same total intensity (e.g., five 30-minute sessions) but be spread out over different total durations of time (e.g., one over 1 month, another over 1 year).
- Components of Intervention: De Bruin et al. developed a taxonomy of mutually exclusive medication adherence intervention components that may or may not be present in an adherence intervention.74 We have based our taxonomy of intervention characteristics or elements on the De Bruin approach (Table 1). An intervention may include one or more of these components or attributes.

Table 1 Components of medication adherence interventions

Component | Examples
Knowledge-based | General information about behavior-related health consequences, use of individualized information, increase in understanding/memory enhancement
Awareness-based | Risk communication, self-monitoring, reflective listening, behavioral feedback
Social influence | Information about peers or social influence of peers
Attitudes | Targets attitudes toward behavior
Self-efficacy | Modeling, practice, verbal persuasion, coping responses, graded tasks, reattribution of success/failure
Self-monitoring skills | Teaching skills in self-monitoring and self-management
Intention formation | General intention, medication schedule, goals, behavioral contract
Action control | Cues/reminders, self-persuasion, social support
Maintenance | Maintenance goals, relapse prevention
Facilitation | Ongoing professional support, dealing with adverse effects, individualizing/simplifying regimen (fewer pills, fewer medications, less frequent dosing, timing of dosing to fit individual schedule), reducing environmental barriers
Contingent reward | Payment or other reward for conducting behavior
Motivational interviewing | Client-centered yet directive counseling style that facilitates behavior change through helping clients resolve ambivalence
Stress management | Methods to reduce or manage stress, such as biofeedback
Organizational learning strategies | Use of implementation toolkits or learning collaboratives
Systems change—clinical champion | Use of clinician patient advocate
Systems change--quality | Continuous quality improvement system

Practitioners developing and implementing medication adherence interventions can (and do) combine any of these key characteristics with various other characteristics. This approach generates very diverse sets of interventions; for that reason, any given intervention is most often compared only with a usual care program rather than with any other intervention.

To deal with this heterogeneity, this report had two important goals: (1) to identify features of interventions that clustered together into broader categories of intervention types and (2) to determine whether such intervention types exist across diseases or tend to cluster within diseases. For example, integrated care models are often used in settings dealing with chronic mental illness and generally are delivered by multidisciplinary teams; they target the health system by creating new structures through which clinicians may interact with one another to care for the patient. Such models may have common components that could be combined to address adherence among patients with other chronic illnesses.

The types and features of intervention studies may have important implications for the cost, feasibility, and scalability of the interventions tested. For example, face-to-face interventions may be more costly than other modes. As their intensity increases, and as the training level required of the delivery agent rises, their costs will likely rise and their feasibility will likely drop. Nonetheless, greater intensity may be needed to achieve efficacy in improving adherence. Because intensity and other features of an intervention often covary, isolating the effects of one over another in the absence of a direct comparison is not possible.

Few harms are associated with the interventions being considered. Some studies have assessed patients’ satisfaction with their health care and/or with their health care practitioner to ensure that the intervention does not interfere with ongoing relationships with a clinic or doctor. Interventions that improve patients’ medication taking might result in patients’ experiencing increased medication side effects if these patients were previously taking too little of their medication. Hence, some studies have assessed whether an adherence intervention led to any untoward medication side effects. Conversely, particularly for interventions that involve more interactions with health professionals, other benefits may occur that are not fully attributable to enhanced medication taking, such as improved quality of life or increases in perceived social support.

Thus, the causal pathways among such factors, the intervention, levels of medication adherence, and the attendant benefits and harms are complex, difficult to tease apart, and potentially circular. For example, an intervention may directly enhance quality of life through increased social support, but this improved quality of life may also be a mechanism that enhances medication adherence, which in turn further enhances health and quality of life. Few studies of adherence interventions are designed to distinguish such causal pathways.

## Scope and Key Questions

### Scope of the Review

This report is part of a larger initiative, the Closing the Quality Gap: Revisiting the State of the Science (CQG) series, which builds on the AHRQ 2004 to 2007 collection of publications—Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies—that summarized the evidence on quality improvement strategies for chronic conditions.75 This new series continues to summarize evidence on means to improve quality of care, but it focuses on selected settings, interventions, and clinical conditions. Both series were launched in response to an IOM study, Priority Areas for National Action: Transforming Health Care Quality, that identified several gaps or discrepancies between medical treatment expected to be efficacious when optimal care is delivered based on known evidence and what actually happens across populations of patients.76 Our report, one of eight in the second series, addresses the comparative effectiveness of adherence intervention strategies, one keystone to improving the gap between potential and realized quality health care.

As described above, to improve health care quality, interventions used to improve medication adherence have been developed that address health system, health care provider, or patient factors; some address factors on more than one level. In addition, a few studies have tried to assess the effect of broader policy-level changes on medication adherence of individuals. Previous reviews demonstrate considerable variability across interventions in terms of both approach and effectiveness.7,77 In a recently published meta-analysis of 61 trials of individual-level programs to improve medication adherence,19 the effect size for improved adherence in the behavioral cohorts (the only ones meeting homogeneity criteria) was 7 percent (95% confidence interval [CI], 4 to 9); for educational interventions, it was 11 percent (95% CI, 6 to 15); and for combined interventions, it was 8 percent (95% CI, 4 to 12). Although most adherence-intervention trials have demonstrated only modest improvement, a recent trial of a pharmacy care program reported substantial improvement in adherence, suggesting that assessing both individual and health systems-level interventions is important.78

Questions about the types of programs most likely to be effective in various settings remain unanswered. For example, reviews of behavioral interventions have shown that those developed to address specific constructs based on a specific behavioral theory are more effective than those that were not;79 however, this feature has not been compared for medication adherence80 or across diseases. The last comprehensive review on this topic was a 2008 update of a Cochrane review.28 It found that “several quite simple interventions increased adherence and improved patient outcomes, but the effects were inconsistent from study to study with less than half of studies showing benefits.”7^(p.2)^. The authors, however, analyzed the results by clinical condition rather than by the type of intervention, vulnerable subpopulations, methods used to assess adherence, purpose of medication (primary, secondary, or tertiary prevention), or disease-specific measures (severity/stage of disease), all of which would provide more guidance for strategies to improve health care quality.

Patterns of adherence and factors influencing it have been shown to differ between acute disease and chronic disease,20 likely because of the longer duration of medication taking required with chronic disease. For this reason, and because their longer duration means that chronic diseases cause greater disease burden, our review focuses on adherence to medication for chronic illness; this permits us to maintain some comparability across intervention types.

The earlier Cochrane review and update did not assess the impact of health system-level or policy-level interventions on adherence.7 In our review, we assess these types of interventions and those at the patient and provider levels. In contrast, several recent reviews and meta-analyses have assessed the impact of interventions to improve medication adherence in the context of HIV treatment,80–82 so we excluded antiretroviral adherence intervention studies from our review.

To address the issues outlined above, the overarching goal of our systematic review is to maximize the quality of care processes that affect outcomes for adults with chronic disease. The means to this end are to identify patient-, provider-, health system-, and policy-level interventions that have been shown to improve medication adherence, to clarify key components of effective interventions, and to document how intervention effectiveness varies for vulnerable subpopulations (such as racial and ethnic minorities, low-health-literacy groups, the elderly, and so on). Because severe mental illness adds a layer of complexity to the cognitive features of medication adherence that make it less generalizable across other diseases, we did not include studies of medication adherence interventions for schizophrenia, bipolar disorder, or substance abuse; we did, however, include mild to moderate depression, which does not typically impair cognition in the same severe manner as the other mental health conditions

We elected to focus our review on studies that sought specifically to assess intervention effects on medication adherence, regardless of whether they assessed additional health outcomes. In previous Cochrane reviews of adherence interventions,28 the authors included studies only if they assessed health outcomes beyond medication adherence, such as mortality or morbidity measures. Although we recognize that the ultimate goal of improving medication adherence is to improve health outcomes, to go beyond the previous review and to avoid missing studies of interventions that may have had an effect on adherence behavior that could suggest mechanisms by which such interventions work, we included all eligible studies that assessed intervention effects on medication adherence. For those that had an effect on adherence and measured other health outcomes, we assessed the effects on those outcomes as well. We reviewed the literature from 1994 onward to look at the evidence from the last search date for an early and comprehensive review.77

### Key Questions

This report addresses five Key Questions (KQs), three of which have subquestions. Specifically, they are:

- KQ 1a: Among patients with chronic diseases with self-administered medication prescribed by a provider, what is the comparative effectiveness of interventions aimed at patients, providers, systems, and combinations of audiences in improving medication adherence?
- KQ 1b: Is improved medication adherence associated with improvement in patient outcomes?
- KQ 2a: Among patients with chronic diseases with self-administered medication prescribed by a provider, what is the comparative effectiveness of policy interventions in improving medication adherence?
- KQ 2b: Is improved medication adherence associated with improvement in patient outcomes?
- KQ 3a: How do medication-adherence intervention characteristics (e.g., mode of delivery, intervention target, intensity) vary?
- KQ 3b: To what extent do the effects of adherence interventions vary based upon their characteristics?
- KQ 4: To what extent do the effects of adherence interventions vary based on differences in vulnerable populations?
- KQ 5: What unintended consequences are associated with interventions to improve medication adherence?

### Analytic Framework

We developed an analytic framework to guide the systematic review process (Figure 1). Both KQ 1 and KQ 2 assess the comparative effectiveness of adherence interventions among our study populations. However, because researchers used unique study designs to test policy-level interventions studies, we elected to separate interventions aimed at nonpolicy targets (i.e., patient, provider, health system) (KQ 1) from those aimed at policy-level targets (KQ 2). Because we sought to go beyond other reviews by assessing all interventions targeting medication adherence (i.e., not limited to those that assessed health outcomes), we split these two questions into their effects on adherence (KQ 1a; KQ 2a) and on other health outcomes (KQ 1b; KQ 2b). Because of the broad diversity of interventions and the paucity of studies that directly compared or isolated the effects of specific intervention features, in KQ 3 we first sought to describe, characterize, and quantify the features of interventions tested (KQ 3a) and then to determine the relationship between such characteristics and their effects (KQ 3b). To gain an understanding of intervention effects among specific populations identified by AHRQ and IOM as vulnerable, priority populations, we asked KQ 4. Finally, KQ 5 focuses on identifying adverse effects of interventions on health outcomes.

Figure 1 Analytic framework

Abbreviation: KQ = Key Question.

Figure 1. The analytical framework depicts the Key Questions (KQs) within the context of the populations, interventions, comparators, outcomes, timing, and settings (PICOTS) framework described in the previous section. In general, the figure illustrates how patients with self-administered medications for chronic disease may be given interventions to improve medication adherence and other outcomes. These interventions may be directed at patients, providers, or policymakers (KQ 1) or at health systems (KQ 2). KQ 1a and KQ 2a evaluate the effect of interventions on medication adherence. Changes in medication adherence may be followed by changes in intermediate outcomes, such as biomarkers, or in other health outcomes, such as morbidity and mortality, health care utilization, and quality of life (KQ 1b and KQ 2b). KQ 3a catalogues the characteristics of interventions; KQ 3b examines whether the effectiveness of these interventions is influenced by characteristics of the intervention. KQ 4 explores the effectiveness of interventions to improve medication adherence and other outcomes for vulnerable subpopulations. These interventions may have unanticipated consequences (KQ 5).

### Population, Intervention, Comparator, Outcomes, Timing, and Setting

We provide the following detailed description of relevant populations, interventions, comparators, outcomes, timing, and settings (PICOTS).

#### Populations

The primary populations of interest are community-dwelling adult patients who are prescribed self-administered medications for single or multiple chronic diseases. Vulnerable populations of interest may include (but are not limited to) racial and ethnic minorities; populations with special health care needs (such as low health literacy, comorbid disease, or severe illness); the elderly; and low-income, underinsured, uninsured, and inner-city or rural populations. Relevant medications include all prescribed medications, including over-the-counter drugs. The specific medications vary by clinical condition.

#### Interventions

As noted above, we have two main categories of interventions.

1. Any intervention intended to improve adherence with prescribed, self-administered medications. Examples include:
  – Patient education
  – Face-to-face or telephone counseling or therapy (individual, couple, family, or group)
  – Behavioral interventions
  – Case management
  – Simplified dosing
  – Reminders
  – System changes
  – Changes to medication formulations (e.g., oral vs. subcutaneous)
  – Augmented pharmacy services
  – Shared decisionmaking
  – Dose-dispensing units of medication or medication charts
  – Rewards.
2. Any intervention intended to address policy barriers. Examples include changes in insurance copay and refill practices (e.g., how long medications are prescribed for, how often patients have to order refills) and changes in formularies.

Characteristics of the intervention that may influence effectiveness include but are not limited to the following:

- Target of the intervention
- Agent delivering the intervention (e.g., physician, nurse, or health educator) and his/her characteristics/level of training
- Intensity (contact time)
- Duration (number of sessions over a given time period)
- Delivery mode (e.g., face-to-face, written material, text message, computer, phone)
- Role of theory
- Number of components
- Type of components74 (Table 1).

#### Comparators

These can be either (1) usual or routine care, defined as the absence of an intervention to improve medication adherence or (2) some type of active intervention intended to improve medication adherence.

#### Outcome Measures

We will examine three types of outcomes:

1. Medication adherence
2. Other outcomes
  a. Biomarkers of clinical outcomes
  b. Clinical outcomes (mortality, morbidity measures defined by the clinical condition)
  c. Quality of life
  d. Patient satisfaction
  e. Health care utilization (including associated costs), and
  f. Quality of care
3. Adverse events.

#### Timing

We consider all possible lengths of interventions and followup periods.

#### Setting

Outpatient primary and specialty care settings are included. Institutional settings such as inpatient care, nursing homes, and prisons are excluded. Studies conducted outside the United States are excluded; studies conducted in other settings may be of limited applicability in the United States.

## Organization of This Report

The remainder of this review describes our methods in detail, documents our results, and provides a discussion of our findings and recommendations for filling important research gaps. Appendixes provide details of the search strategy (Appendix A), forms used for review and abstraction (Appendix B), studies excluded at the full-text review stage (Appendix C), comprehensive evidence tables (Appendix D), risk of bias ratings (Appendix E), a list of scales and abbreviations used in included studies (Appendix F), summary tables for health and other outcomes for KQ 1 (Appendix G).