# Peer Reviewers

K. Rivet Amico, Ph.D.

University of Connecticut

Center for Health, Intervention, and Prevention

Storrs, CT

Hayden Bosworth, Ph.D.

Duke University School of Medicine

Department of Medicine

VA Health Services Research and Development

Durham, NC

Barry L. Carter, Pharm.D.

University of Iowa Hospitals and Clinics

Iowa City, IA

Jacqueline Dunbar-Jacob, Ph.D., R.N., FAAN

University of Pittsburgh

School of Nursing

Pittsburgh, PA

Michael Fischer, M.D., M.S.

Brigham & Women’s Hospital

Department of Medicine

Division of Pharmacoepidemiology & Pharmacoeconomics

Boston, MA

David Nau, Ph.D.

University of Kentucky

College of Pharmacy

Lexington, KY

Wendy Nilsen, Ph.D.

Office of Behavioral and Social Sciences Research

National Institutes of Health

Bethesda, MD

Michael Pignone, M.D., M.P.H., FACP

University of North Carolina School of Medicine

Diabetes Center for Research

Chapel Hill, NC

John Steiner, M.D.

Aurora Health Center

Fond du Lac, WI