# Technical Expert Panel

Hayden Bosworth, Ph.D.

Duke University School of Medicine

Department of Medicine

VA Health Services Research and Development

Durham, NC

Barry L. Carter, Pharm.D.

University of Iowa Hospitals and Clinics

Iowa City, IA

Jacqueline Dunbar-Jacob, Ph.D., R.N., FAAN

University of Pittsburgh

School of Nursing

Pittsburgh, PA

Michael Fischer, M.D., M.S.

Brigham & Women’s Hospital

Department of Medicine

Division of Pharmacoepidemiology & Pharmacoeconomics

Boston, MA

Michael Wolf, Ph.D., M.P.H.

Institute for Healthcare Studies

Northwestern University

Chicago, IL