# Patient, Provider, and Policy Interventions: Summary Evidence Tables

Table G1 Diabetes: biomarker hemoglobin A1C (HbA1C)

Author, Year N in Each Group | Outcome | Results
Bogner et al., 2010^1^ G1: 29 G2: 29 | Biomarkers: HbA1c | Baseline (%) G1: Mean (SD): 7.3 (2.3) G2: Mean (SD): 7.3 (2.0) 95% CI, NR p=0.70 Endpoint (%) G1: Mean (SD): 6.7 (2.3) G2: Mean (SD): 7.9 (2.6) 95% CI, NR p=0.019

Abbreviations: CI = confidence interval; G = group; HbA1c = hemoglobin A1C; N = number; NR = not reported; SD = standard deviation.

Table G2 Hyperlipidemia: biomarkers

Author, Year N in Each Group | Outcome | Results
Lee et al., 2006^2^
G1: 64 G2: 57 | Among patients with drug-treated hyperlipidemia: LDL-C at 14 months | G1: 87.5 mean (SD 24.2) G2: 88.4 mean (SD 21.0) p=0.84
G1: 64 G2: 57 | Among patients with drug-treated hyperlipidemia: difference between LDL-C at 2 months and 14 months | G1: −2.8 (95% CI, −8.1 to 2.5) G2: −5.8 (95% CI, −11.0 to 0.6) p=0.85
G1: 73 G2: 62 | Among patients with drug-treated hypertension: systolic blood pressure at 14 months | G1: 124.4 mm Hg (SD 14.0) G2: 133.3 mm Hg (SD 21.5) p=0.005
G1: 73 G2: 62 | Among patients with drug-treated hypertension: difference between systolic blood pressure measures at 2 months and 14 months | G1: −6.9 mm Hg (95% CI, −10.7 to −3.1) G2: −1.0 mm Hg (95% CI, −5.9 to 3.9) p=0.04
G1: 73 G2: 62 | Among patients with drug-treated hypertension: diastolic blood pressure at 14 months | G1: 67.5 mm Hg (SD 9.9) G2: 68.6 mm Hg (SD 10.5) p=0.54
G1: 73 G2: 62 | Among patients with drug-treated hypertension: difference between diastolic blood pressure measures at 2 months and 14 months | G1: −2.5 mm Hg (SD −4.9 to −0.2) G2: −1.2 mm Hg (SD −3.7 to 1.2) p=0.39

Abbreviations: G = group; LDL-C = Low-density lipoprotein cholesterol; SD = standard deviation.

Table G3 Hyperlipidemia: patient satisfaction

Author, Year N in Each Group | Outcome | Results
Weymiller et al., 2007^3^ Jones et al., 2009^4^ G1: 26 G2: 26 G3: 23 G4: 23 | Patient satisfaction: Acceptable amount of information (higher scores indicate better satisfaction) Self-report | N (%) responding 6 or 7 out of 7 G1: 23 (88%) G2: 23 (92%) G3: 16 (70%) G4: 17 (74%) 95% CI, NR; p: NR Odds ratio for decision aid (G1 & G2) vs. control (G3 & G4)=3.4 95% CI, 1.7 to 6.7; p: NR Mean (95% CI) G1: 7.0 (6 to 7) G2: 7.0 (6 to 7) G3: 7.0 (5 to 7) G4: 7.0 (5 to 7) 95% CI, NR; p: NR
Weymiller et al., 2007^3^ Jones et al., 2009^4^ G1: 26 G2: 26 G3: 23 G4: 23 | Patient satisfaction: Acceptable clarity of information (higher scores indicate better satisfaction) Self-report | N (%) responding 6 or 7 of 7 G1: 19 (73%) G2: 13 (52%) G3: 12 (52%) G4: 12 (52%) 95% CI, NR p: NR Odds ratio for decision aid (G1 & G2) vs. control (G3 & G4)=1.6 95% CI, 0.8 to 3.2 p: NR Mean (95% CI) G1: 6.0 (5 to 7) G2: 6.5 (5 to 7) G3: 6.0 (4 to 7) G4: 6.0 (4 to 6) 95% CI, NR p: NR
Weymiller et al., 2007^3^ Jones et al., 2009^4^ G1: 26 G2: 26 G3: 23 G4: 23 | Patient satisfaction: Acceptable helpfulness of information (higher scores indicate better satisfaction) Self-report | N (%) responding 6 or 7 of 7 G1: 18 (69%) G2: 12 (48%) G3: 8 (35%) G4: 10 (43%) 95% CI, NR p: NR Odds ratio for decision aid (G1 & G2) vs. control (G3 & G4)=2.3 95% CI, 1.4 to 3.8 p: NR Mean (95% CI) G1: 5.0 (4 to 7) G2: 7.0 (5 to 7) G3: 5.0 (4 to 7) G4: 5.0 (4 to 7) 95% CI, NR p: NR
Weymiller et al., 2007^3^ Jones et al., 2009^4^ G1: 26 G2: 26 G3: 23 G4: 23 | Patient satisfaction: Would recommend to others deciding on statins. (higher scores indicate better satisfaction) Self-report | N (%) responding 6 or 7 of 7 G1: 21 (84%) G2: 16 (64%) G3: 13 (57%) G4: 11 (50%) 95% CI, NR p: NR Odds ratio for decision aid (G1 & G2) vs. control (G3 & G4)=2.6 95% CI, 0.8 to 8.0 p: NR Mean (95% CI) G1: 6.0 (4 to 7) G2: 7.0 (7 to 7) G3: 5.5 (4 to 7) G4: 6.0 (5 to 7) 95% CI, NR p: NR
Weymiller et al., 2007^3^ Jones et al., 2009^4^ G1: 26 G2: 26 G3: 23 G4: 23 | Patient satisfaction: Would prefer similar approach for other treatment choices (higher scores indicate better satisfaction) Self-report | N (%) responding 6 or 7 of 7 G1: 18 (72%) G2: 16 (64%) G3: 14 (61%) G4: 12 (55%) 95% CI, NR p: NR Odds ratio for decision aid (G1 & G2) vs. control (G3 & G4)=1.5 95% CI, 0.6–3.8 p: NR Mean (95% CI) G1: 6.0 (4 to 7) G2: 7.0 (5 to 7) G3: 6.0 (4 to 7) G4: 6.0 (4 to 7) 95% CI, NR p: NR
Weymiller et al., 2007^3^ Jones et al., 2009^4^ G1: 26 G2: 26 G3: 23 G4: 23 | Patient satisfaction: Overall acceptability (higher scores indicate better satisfaction) Self-report | N (%) responding 6 or 7 of 7 G1: 20 (77%) G2: 14 (56%) G3: 9 (39%) G4: 10 (43%) 95% CI, NR p: NR Odds ratio for decision aid (G1 & G2) vs. control (G3 & G4)=2.8 95% CI, 1.2–6.9 p: NR Mean (95% CI) G1: 6.0 (4.6 to 6.6) G2: 6.6 (6.0 to 7.0) G3: 5.4 (4.6 to 6.8) G4: 5.4 (4.6 to 6.6) 95% CI, NR p: NR

Abbreviations: CI = confidence interval; G = group; N = number; NR = not reported.

Table G4 Hypertension: morbidity

Author, Year N in Each Group | Outcome | Results
Bogner et al. 2007^5^
G1: 32 G2: 32 | Systolic blood pressure (mm Hg) Automated BP monitor | Mean (SD) at 6 weeks: G1: 127.3 mm Hg (17.7) G2: 141.3 mm Hg (18.8) p: 0.003
G1: 32 G2: 32 | Diastolic blood pressure (mm Hg) Automated BP monitor | Mean (SD) at 6 weeks: G1: 75.8 mm Hg (10.7) G2: 85.0 mm Hg (11.9) p: 0.002
Friedman et al., 1996^6^
G1: 133 G2: 134 | Systolic blood pressure (mm Hg) change from baseline to 6 months Measured by field technicians | G1: 11 mm Hg (mean decrease) G2: 10.6 mm Hg (mean decrease) 95% CI, NR p: 0.85
G1: 133 G2: 134 | Diastolic blood pressure (mm Hg) change from baseline to 6 months Measured by field technicians | G1: 5.4 mm Hg (mean decrease) G2: 3.3 mm Hg (mean decrease) 95% CI, NR p: 0.09
Lee et al., 2006^2^
G1: 73 G2: 62 | Among patients with hypertension: systolic blood pressure at 14 months (6-month RCT outcome) Measured by pharmacist | G1: 124.4 mm Hg (SD 14.0) G2: 133.3 mm Hg (SD 21.5) p=0.005
G1: 73 G2: 62 | Among patients with hypertension: difference between systolic blood pressure at 2 months and 14 months (6-month cohort + 6-month RCT outcome) | G1: −6.9 mm Hg (95% CI, −10.7, −3.1) G2: −1.0 mm Hg (95% CI, −5.9, 3.9) p: 0.04
G1: 73 G2: 62 | Among patients with hypertension: diastolic blood pressure at 14 months (6-month RCT outcome) Measured by pharmacist | G1: 67.5 mm Hg (SD 9.9) G2: 68.6 mm Hg (SD 10.5) p: 0.54
G1: 73 G2: 62 | Among patients with hypertension: difference between systolic blood pressure at 2 months and 14 months (6-month cohort + 6-month RCT outcome) | G1: −2.5 mm Hg (95% CI, −4.9, −0.2) G2: −1.2 mm Hg (95% CI, −3.7, 1.2) p: 0.39
Rudd, et al., 2004^7^
G1: 74 G2: 76 | Change in systolic blood pressure between baseline and 6 months Measured by blinded study personnel | G1: −14.2 mm Hg (95% CI, −18.2 to −10.0) G2: −5.7 mm Hg (95% CI, −10.2 to −1.3) p<0.01
G1: 74 G2: 76 | Change in diastolic blood pressure between baseline and 6 months Measured by blinded study personnel | G1: −6.5 mm Hg (95% CI, −8.8 to −4.1) G2: −3.4 mm Hg (95% CI, −5.3 to −1.5) p<0.05
Schneider et al., 2008^8^
G1: 47 G2: 38 | Absolute change in systolic blood pressure (from baseline) Medical chart review | Mean (SD) absolute change in mm Hg: 6 months G1: −4.2 (21.5) G2: −4.2 (20.9) 95% CI, NR p: 0.992 12 months G1: −2.7 (16.5) G2: −1.3 (17.8) 95% CI, NR p: 0.669
G1: 47 G2: 38 | Absolute change in diastolic blood pressure (from baseline) Medical chart review | Mean (SD) absolute change in mm Hg: 6 months G1: −0.8 (12.4) G2: 1.8 (9.1) 95% CI, NR p: 0.287 12 months G1: −3.0 (11.6) G2: 2.7 (10.7) 95% CI, NR p: 0.125
G1: 47 G2: 38 | Proportion of patients with reduced systolic blood pressure Medical chart review | At 6 months: G1: 48.9% G2: 62.9% p: 0.213 At 12 months: G1: 46.0% G2: 40.9% p: 0.312
G1: 47 G2: 38 | Proportion of patients with reduced diastolic blood pressure Medical chart review | At 6 months: G1: 46.7 G2: 37.1 p: 0.393 At 12 months: G1: 48.0 G2: 18.2 p=0.031
G1: 47 G2: 38 | Occurrence of angina Medical chart review | G1: NR G2: NR 95% CI, NR p: NR Numbers not reported, but results were not significant
G1: 47 G2: 38 | Occurrence of MI Medical chart review | G1: NR G2: NR 95% CI, NR p: NR Numbers not reported, but results were not significant
G1: 47 G2: 38 | Occurrence of stroke Medical chart review | G1: NR G2: NR 95% CI, NR p: NR Numbers not reported, but results were not significant
Solomon et al., 1998^9,10^
G1: 63 G2: 70 | Hypertension group: First systolic BP taken at visit Measured by pharmacist | Visit 1 (baseline G1: 146.7 mm Hg (16.8 SD) G2: 146.2 mm Hg (17.0 SD) 95% CI, NR p: NR Visit 5 (between 4 and 6 months) G1: 138.5 mm Hg (13.9 SD) G2: 144.9 mm Hg (21.3 SD) 95% CI, NR p: 0.044
G1: 63 G2: 70 | Hypertension group: Within-group comparison of first systolic BP taken at Visit 1 (baseline) and Visit 5 (between 4 and 6 weeks) Measured by pharmacist | G1 (Visit 1): 146.7 (16.8 SD) G1 (Visit 5): 138.5 (13.9 SD) 95% CI, NR p<0.01 G2 (Visit 1): 146.2 (17.0 SD) G2 (Visit 5): 144.9 (21.3 SD) 95% CI, NR p: NR
G1: 63 G2: 70 | Hypertension group: First diastolic BP taken at Visit 1 (baseline) Measured by pharmacist | G1: 84.6 mm Hg (13.2 SD) G2: 87.0 mm Hg (10.9 SD) 95% CI, NR p: NR
G1: 63 G2: 70 | Hypertension group: First diastolic BP taken at Visit 5 (between 4 and 6 weeks) Measured by pharmacist | G1: 80.2 mm Hg (9.6 SD) G2: 83.2 mm Hg (11.5 SD) 95% CI, NR p: NR
G1: 63 G2: 70 | Hypertension group: Within-group comparison of first diastolic BP taken at Visit 1 (baseline) and Visit 5 (between 4 and 6 weeks) Measured by pharmacist | G1 (Visit 1): 84.6 mm Hg (13.2 SD) G1 (Visit 5): 80.2 mm Hg (9.6 SD) 95% CI, NR p: NR G2 (Visit 1): 87.0 mm Hg (10.9 SD) G2 (Visit 5): 83.2 mm Hg (11.5 SD) 95% CI, NR p: NR

Abbreviations: BP = blood pressure; CI = confidence interval; G = group; mm Hg = millimeters of mercury; LDL-C = low density lipoprotein cholesterol; mm = millimeter; NR = not reported; RCT = randomized controlled trial; SD = standard deviation.

Table G5 Hypertension: quality of life

Author, Year N in Each Group | Outcome | Results
Solomon et al., 1998^9,10^
G1: NR G2: NR | Hypertension group: Proportion of participants reporting problems with sexual functioning during previous 4 weeks; - From Lipid Form 5.1 developed by the Health Outcomes Institute; Self-report | Visit 1 (baseline) G1: 22 (34.0%) G2: 19 (26.0%) 95% CI, NR p: NR Visit 5 (between 4 and 6 months) G1: 8 (2.5%) G2: 8 (25.0%) 95% CI, NR p: NR
G1: NR G2: NR | Hypertension group: Participants reporting problems with sexual functioning during previous 4 weeks, within-group comparison; - From Lipid Form 5.1 developed by the Health Outcomes Institute; Self-report | G1 (baseline): 22 (34.0%) G1 (between 4 and 6 months): 8 (2.5%) 95% CI, NR p: 0.003 G2 (baseline): 19 (26.0%) G2 (between 4 and 6 months): 8 (25.0%) 95% CI, NR p: NR
G1: NR G2: NR | Hypertension group: “Feeling dizzy upon standing up,” mean score on Likert scale of 1 (never) to 5 (very often); - From Lipid Form 5.1 developed by the Health Outcomes Institute; Self-report | Visit 1 (baseline) G1: 1.7 (1.1 SD) G2: 2.0 (1.1 SD) 95% CI, NR p: NR Visit 5 (between 4 and 6 months) G1: 1.4 (0.8 SD) G2:1.4 (0.8 SD) 95% CI, NR p: NR
G1: NR G2: NR | Hypertension group: “Headaches more than usual,” mean score on a Likert scale of 1 (never) to 5 (very often); - From Lipid Form 5.1 developed by the Health Outcomes Institute; Self-report | Visit 1 (baseline) G1: 1.5 (1.0) G2: 1.6 (1.2) 95% CI, NR p: NR Visit 5 (between 4 and 6 months) G1: 1.2 (0.8) G2:1.2 (0.8) 95% CI, NR p: NR

Abbreviations: CI = confidence interval; G = group; NR = not reported; SD = standard deviation.

Table G6 Hypertension: patient satisfaction

Author, Year N in Each Group | Outcome | Results: Mean (SD)
Solomon et al., 1998^9,10^
G1: 62 G2: 68 | Answer to PCQ that intervention: “Makes me feel secure about taking my medications”; - Likert scale of 1 (strongly agree) to 5 (strongly disagree); Self-report | G1: 1.39 (0.49) G2: 1.69 (0.68) 95% CI, NR p: 0.004
G1: 62 G2: 68 | Answer to PCQ that intervention: “Helps me understand my illness”; - Likert scale of 1 (strongly agree) to 5 (strongly disagree); Self-report | G1:1.45 (0.59) G2: 1.84 (0.77) 95% CI, NR p: 0.002
G1: 62 G2: 68 | Answer to PCQ that pharmacist: “Does not take time to make sure I understand the importance of my medications”; - Likert scale of 1 (strongly agree) to 5 (strongly disagree); Self-report | G1: 4.21 (1.03) G2: 3.88 (1.08) 95% CI, NR p: 0.079
G1: 62 G2: 68 | Answer to PCQ that pharmacist: “Gives complete explanations about my medications”; - Likert scale of 1 (strongly agree) to 5 (strongly disagree); Self-report | G1: 1.48 (0.54) G2: 1.82 (0.80) 95% CI, NR p: 0.006
G1: 62 G2: 68 | Answer to PCQ item 6 that pharmacist: “Should give more complete explanation about my medications”; - Likert scale of 1 (strongly agree) to 5 (strongly disagree); Self-report | G1 4.16 (0.93) G2 3.81 (1.03) 95% CI, NR p=0.042

Abbreviations: CI = confidence interval; G = group; NR = not reported; PCQ = Pharmaceutical Care Questionnaire.

Table G7 Hypertension: health care utilization

Author, Year N in Each Group | Outcome | Results
Schneider et al., 2008^8^
G1: 47 G2: 38 | Emergency department visits and hospitalizations at 6 and 12 months (for prior 6-month period) Medical chart review | G1: NR G2: NR 95% CI, NR p: NR Numbers not reported, but results were not significant
Solomon et al., 1998^9,10^
G1: 63 G2: 61 | Hypertension group: Mean number of Emergency Room visits in 4 weeks prior - at 4–6 month visit Self-report | G1: 0.05 (0.22 SD) G2: 0.13 (0.39 SD) 95% CI, NR p: NR
G1: 63 G2: 61 | Hypertension group: Mean number of hospitalizations in 4 weeks prior—at 4–6 month visit Self-report | G1: 0.02 (0.13 SD) G2: 0.10 (0.35 SD) 95% CI, NR p<0.05 (one-tailed)
G1: 63 G2: 61 | Hypertension group: contacts with “other health care providers” (MD, NP, PA or RN) in 4 weeks prior—at 4–6 month visit Self-report | G1: 0.59 (0.78 SD) G2: 1.0 (0.82 SD) 95% CI, NR p: <0.05 (one-tailed)

Abbreviations: CI = confidence interval; G = group; NR = not reported; SD = standard deviation.

Table G8 Heart failure: quality of life

Author, Year N in Each Group | Outcome | Results
Fulmer et al., 1999^11^
G1: 15 G2: 13 G3: 14 | MLHF questionnaire score 21-item scale, each item scored 0 to 5 (lower score indicates lower impact of heart failure treatment on quality of life)/Self-report | Baseline mean score (SD) G1: 43.1 (20.8) G2: 54.4 (21.1) G3: 46.6 (27.7) 95% CI, NR p: NR 10-week mean score (SD) G1: 36.7 (19.9) G2: 32.9 (25.2) G3: 32.9 (22.9) 95% CI, NR p: NR Per text, all groups had an improvement in MLHF scores from baseline to follow-up (p<0.001) that did not differ between groups.
G1: 15 G2: 13 G3: 14 | SF-36 score 100-point scale (higher score indicates more favorable state of health)/Self-report | Baseline mean score (SD) G1: 86.1 (17.0) G2: 81.0 (15.2) G3: 87.3 (24.3) 95% CI, NR p: NR 10-week mean score (SD) G1: 85.9 (18.9) G2: 90.1 (20.6) G3: 91.7 (22.7) 95% CI, NR p: NR Per text “there was no significant change in the SF-36 scores for the sample… Group membership did not make a difference…”
Murray et al., 2007^12^
G1: NR G2: NR | Improved Chronic Heart Failure Questionnaire Average scores (range 1–7) from 4 dimensions (higher scores indicate better function)/Self-report | Change from baseline at 6 months: G1: 0.28 G2: 0.21 95% CI, NR p=0.52 Change from baseline at 12 months: G1: 0.39 G2: 0.24 95% CI, NR p=0.21
Ross et al., 2004^13^
G1: NR G2: NR | Results from KCCQ domains scored 1 to 100 (higher scores indicate higher quality of life) Self-efficacy | Baseline average for both groups: 85 6 months: G1: 88 G2: 84 Difference: 4 95% CI, −3, 9 p: NR 12 months: G1: 91 G2: 85 Difference: 6 95% CI, −1, 11 p=0.08
G1: NR G2: NR | Symptom stability | Baseline average for both groups: 49 6 months: G1: 45 G2: 49 Difference: −4 95% CI, −15, 6 p: NR 12 months: G1: 63 G2: 46 Difference: 17 95% CI, 4, 29 p<0.01; p=0.06 when adjusted for multiple comparisons
G1: NR G2: NR | Symptoms | Baseline average for both groups: 63 6 months: G1: 61 G2: 65 Difference: −4 95% CI, −11, 3 p: NR 12 months: G1: 64 G2: 65 Difference: 0 95% CI, −8, 8 p=0.96
G1: NR G2: NR | Quality of life | Baseline average for both groups: 56 6 months: G1: 64 G2: 59 Difference: 5 95% CI, −5, 13 p: NR 12 months: G1: 64 G2: 62 Difference: 2 95% CI, −7, 11 p=0.63
G1: NR G2: NR | Functional status | Baseline average for both groups: 66 6 months: G1: 63 G2: 69 Difference: −6 95% CI, −12, 0 p: NR 12 months: G1: 67 G2: 70 Difference: −3 95% CI, −11, 3 p=0.31
G1: NR G2: NR | Clinical summary | Baseline average for both groups: 64 6 months: G1: 62 G2: 66 Difference: −4 95% CI, −10, 2 p: NR 12 months: G1: 69 G2: 66 Difference: −3 95% CI, −10, 4 p=0.38
G1: NR G2: NR | Physical limitations | Baseline average for both groups: 66 6 months: G1: 63 G2: 70 Difference: −7 95% CI, −13, −1 p: NR 12 months: G1: 69 G2: 73 Difference: −4 95% CI, −12, 3 p=0.26

Abbreviations: CI = confidence interval; G = group; KCCQ = Kansas City Cardiomyopathy Questionnaire; MLHF = Minnesota Living with Heart Failure; NR = not reported = SD = standard deviation; SF-36 = Short Form (36) Health Survey.

Table G9 Heart failure: patient satisfaction

Author, Year N in Each Group | Outcome | Results
Murray et al., 2007^12^ G1: NR G2: NR | Improvement in patient satisfaction with pharmacy services from baseline to 12 months 12-item validated instrument (unclear directionality)/Self-report | G1: 1.0 G2: 0.7 95% CI, NR p=0.022
Ross et al., 2004^13^ G1: NR G2: NR | Modified Art of Medicine questionnaire; patient satisfaction scored 1 to 5 (higher score indicates higher satisfaction)/Self-report “Overall, how well do the heart doctors understand your problems?” | Baseline average for both groups: 4.5 6 months: G1: 4.4 G2: 4.4 Difference: 0 95% CI, −0.3, 0.2 p: NR 12 months: G1: 4.6 G2: 4.2 Difference: 0.4 95% CI, 0.1, 0.6 p=0.02; 0.13 when adjusted for multiple comparisons
Ross et al., 2004^13^ G1: NR G2: NR | “Overall, how well do the heart doctors explain to you what they are doing and why?” | Baseline average for both groups: 4.2 6 months: G1: 4.5 G2: 4.1 Difference: 0.4 95% CI, 0.1, 0.7 p: NR 12 months: G1: 4.5 G2: 4.1 Difference: 0.4 95% CI, 0.1, 0.7 p=0.02, 0.13 when adjusted for multiple comparisons
Ross et al., 2004^13^ G1: NR G2: NR | “Overall, how well do the heart doctors speak to you using words that are easy for you to understand?” | Baseline average for both groups: 4.2 6 months: G1: 4.2 G2: 4.3 Difference: −0.1 95% CI, −0.4, 0.1 p: NR 12 months: G1: 4.1 G2: 4.3 Difference: −0.2 95% CI, −0.5, 0.1 p=0.15
Ross et al., 2004^13^ G1: NR G2: NR | “Overall, how well do the heart doctors listen to your concerns and questions?” | Baseline average for both groups: 6 months: 4.5 G1: 4.6 G2: 4.3 Difference: 0.3 95% CI, 0.02, 0.5 p: NR 12 months: G1: 4.5 G2: 4.3 Difference: 0.2 95% CI, −0.1, 0.5 p=0.26
Ross et al., 2004^13^ G1: NR G2: NR | “Overall, how much confidence do you have in the ability or competence of the heart doctors?” | Baseline average for both groups: 4.5 6 months: G1: 4.6 G2: 4.4 Difference: 0.2 95% CI, −0.1, 0.4 p: NR 12 months: G1: 4.5 G2: 4.5 Difference: 0 95% CI, −0.2, 0.3 p=0.80
Ross et al., 2004^13^ G1: NR G2: NR | “Overall, how satisfied are you with the service that you received from the heart doctors?” | Baseline average for both groups: 4.5 6 months: G1: 4.5 G2: 4.5 Difference: 0 95% CI, −0.2, 0.3 p: NR 12 months: G1: 4.6 G2: 4.4 Difference: 0.2 95% CI, −0.2, 0.5 p=0.07; 0.30 when adjusted for multiple comparisons

Abbreviations: CI = confidence interval; G = group; NR = not reported.

Table G10 Heart failure: healthcare utilization including emergency department visits, hospitalizations, and clinic visits

Author, Year N in Each Group | Outcome | Results
Murray et al., 2007^12^
G1: 122 G2: 192 | All-cause ED visits over 12 months | Mean (SD) G1: 2.16 (3.31), 1 median G2: 2.68 (4.87), 1 median IRR: 0.82 95% CI, 0.70, 0.95 p: NR
G1: 122 G2: 192 | All-cause hospitalizations over 12 months | Mean (SD) G1: 0.78 (1.66), 0 median G2: 0.97 (1.78), 0 median IRR: 0.81 95% CI, 0.64, 1.04 p: NR
G1: 122 G2: 192 | Combined all-cause ED visits and hospitalizations over 12 months | Mean (SD) G1: 2.94 (4.69), 1 median G2: 3.65 (6.26), 1.5 median IRR: 0.82 95% CI, 0.72, 0.93 p: NR
G1: 122 G2: 192 | Combined cardiovascular-related ED visits and hospitalizations over 12 months | Mean (SD) G1: 0.61 (1.72) G2: 0.67 (1.95) IRR 0.96 95% CI, 0.48 to 1.91 p: NR
G1: 122 G2: 192 | Combined heart failure-related ED visits and hospitalizations over 12 months | Mean (SD) G1: 0.40 (1.47) G2: 0.44 (1.79) IRR 1.00 (95% CI, 0.36 to 2.77) p: NR
Rich et al., 1996^14^
G1: 80 G2: 76 | Number of patients with all-cause readmissions at 90 days following discharge | G1: 22.5% G2: 28.9% 95% CI, NR p: NR, not significant
G1: 80 G2: 76 | Number of all-cause readmissions at 90 days following discharge | G1: 22 G2: 31 95% CI, NR p: NR, not significant
G1: 80 G2: 76 | Days of all-cause hospitalization from readmissions | G1: 188 G2: 258 95% CI, NR p: NR, not significant
Ross et al., 2004^13^
G1: NR G2: NR | Number of patients with all-cause hospitalizations (%) | G1: 11 (20%) G2: 12 (23%) 95% CI, NR p=0.81
G1: NR G2: NR | Number of all-cause hospitalizations | G1: 22 G2: 21 95% CI, NR p=1.00
G1: NR G2: NR | Number of patients with all-cause ED visits (%) | G1: 11 (20%) G2: 7 (13%) 95% CI, NR p=0.44
G1: NR G2: NR | Number of all-cause ED visits | G1: 20 G2: 8 95% CI, NR p=0.03
G1: NR G2: NR | Number of patients with heart failure practice visits (%) | G1: 50 (93%) G2: 49 (92%) 95% CI, NR p=1.00
G1: NR G2: NR | Number of heart failure practice visits | G1: 324 G2: 325 95% CI, NR p=0.66

Abbreviations: CI = confidence interval; ED = emergency department; G = group; IRR = incidence rate ratio; relative risk; NR = not reported; SD = standard deviation.

Table G11 Heart failure: cost

Author, Year N in Each Group | Outcome | Results
Murray et al., 2007^12^
G1: 122 G2: 192 | Annual outpatient health care costs | Mean (SD) G1: $5,483 (6,434) G2: $6,373 (6,501) Difference: −866 95% CI, −2,289 to 660 p: NR
G1: 122 G2: 192 | Annual inpatient health care costs | Mean (SD) G1: $5,550 (13,847) G2: $7,827 (20,413) Difference: −2277 95% CI, −6,329 to 1,225 p: NR
G1: 122 G2: 192 | Annual total health care costs (inpatient + outpatient) | Mean (SD) G1: $11,034 (17,211) G2: $14,199 (23,672) Difference: −3165 95% CI, −7,800 to 1,138 p: NR

Abbreviations: CI = confidence interval; G = group; NR = not reported; SD = standard deviation.

Table G12 Heart failure: mortality

Author, Year N in Each Group | Outcome | Results
Ross et al., 2004^13^ G1: NR G2: NR | Deaths (%) | 12 months: G1: 6 (11%) G2: 6 (11%) 95% CI, NR p=1.00

Abbreviations: CI = confidence interval; G = group; NR = not reported.

Table G13 Reactive airway disease: biomarker percentage forced expiratory volume in one second (FEV1%)

Author, Year N in Each Group | Outcome Source/Method | Results
Janson et al., 2003 15 G1: 33 G2: 32 | FEV1% Spirometry | Group difference (95% CI) from baseline to 7 weeks: G1: 90 (16) G2: 80 (20) Between group difference: 5 (−1 to 10) 95% CI, NR p=0.09
Janson et al., 2009 16 G1: 45 G2:39 | Mean change in FEV1% Spirometry | From 0–4 weeks G1: 1.47 G2: 2.72 p=0.32 From 4–14 weeks G1:1.13 G2: −0.37 p=0.25 From 0–14 weeks G1:2.60 G2: 1.13 p= 0.25 95% CI, NR
Wilson et al., 2010 17 G1: 182 G2: 180 G3: 189 | FEV1% Spirometry | Means at 1 year: G1: 76.5% G2: 75.8% G3: 73.1% (95% CIs): G1–G3: (NR), p=0.0068 G1–G2: (NR), p=0.47 G2–G3: (NR), p=0.457
Wilson et al., 2010 17 G1: 182 G2: 180 G3: 189 | FEV1:FEV6 ratio Spirometry | Means at 1 year: G1: 72.8% G2: 71.8% G3:70.0% (95% CIs): G1–G3: (NR), p=0.0005 G1–G2: (NR), p=0.09 G2–G3: (NR), p=0.07

Abbreviations: CI = confidence interval; FEV1% = forced expiratory volume in one second; FEV6 = forced expiratory volume in 6 seconds; G = group; NR = not reported.

Table G14 Reactive airway diseases: morbidity

Author, Year N in Each Group | Outcome Source/Method | Results
Bender et al., 2010^18^ G1: 25 G2: 25 | Asthma control ACT 5 items; Range NR (higher score =better) | Mean change (SD) in ACT score at 10 weeks G1: 1.120 (3.90) G2: 1.840 (4.14) 95% CI, NR p=0.530
Berg et al., 1997^19^ G1: 31 G2: 24 | Symptoms per day Daily journal recording the presence or absence of 4 symptoms | Mean (SD) at week 7: G1: 1.1 (0.91) G2: 0.85 (0.93) 95% CI, NR p: Not significant
Berg et al., 1997^19^ G1: 31 G2: 24 | Percent symptom-free days Daily journal recording the presence or absence of 4 symptoms | Mean (SD) at week 7: G1: 44 (38) G2: 60 (37) 95% CI, NR p<0.1
Janson et al., 2003^15^ G1: 33 G2: 32 | Symptom severity Severity of Asthma Symptoms scale Items: NR; Range 0–10 (lower score=better) | Group difference (95% CI) from baseline to 7 weeks: G1: 8 (7) G2: 7 (6) Between group change: −0.9 (−4 to 2) p=0.56
Janson et al., 2003^15^ G1: 33 G2: 32 | Perceived asthma control PCAQ 11 items; Range NR (directionality NR) | Group difference (95% CI) from baseline to 7 weeks: G1: 42 (5) G2: 42 (5) Between group difference: 2.6 (0.1 to 5) p=0.04
Janson et al., 2009^16^ G1: 45 G2:39 | Frequency of nighttime awakenings Daily self-report | Odds ratios: From 0–4 weeks G1: 0.2 G2: 0.7 p=0.13 From 4–14 weeks: G1: 0.7 G2: 1.2 p=0.45 From 0–14 weeks G1: 0.2 G2: 0.8 p=0.03 95% CI, NR
Janson et al., 2009^16^ G1: 45 G2:39 | Symptom-free days Daily self-report | Odds ratios From 0–4 weeks G1: 2.2 G2:1.6 p=0.48 From 4–14 weeks G1: 2.7 G2: 1.8 p=0.63 From 0–14 weeks G1: 5.9 G2: 2.8 p=0.51 95% CI, NR
Janson et al., 2009^16^ G1: 45 G2:39 | Symptom severity Symptom severity scale Items NR; Range 0–10 (lower score=better) Daily self-report | Mean change in symptom score: From 0–4 weeks G1: −1.28 G2: −1.41 p=0.84 From 4–14 weeks G1: −0.97 G2: 0.11 p=0.06 From 0–14 weeks: G1: −2.25 G2: −1.30 p=0.19 95% CI, NR
Janson et al., 2009^16^ G1: 45 G2:39 | Beta-agonist use Pharmacy refill data | Incidence ratios: From 0–4 weeks G1: 0.6 G2: 0.8 p=0.01 From 4–14 weeks G1: 0.5 G2: 0.5 p=0.98 From 0–14 weeks G1: 0.3 G2: 0.4 p=0.3 95% CI, NR
Schaffer et al., 2004 20 G1: 11 G2: 10 G3: 12 G4: 13 | Asthma control Asthma Control Questionnaire 7 items; Range NR (lower score =better) | Mean (SD) G1: 1.10 (0.58)—p: NS; text does not clearly indicate comparator G2: 1.62 (1.04)—p=0.6 for G2 vs. G4 G3: 1.39 (1.0)—p: NS; text does not clearly indicate comparator G4: 1.71 (1.18) 95% CI, NR Mean(SD): G1: 1.30 (0.76)—p: NS; text does not clearly indicate comparator G2: 1.47 (1.14)—p=0.4, for G2 vs. G4 G3: 1.30 (0.76)—p: NS; text does not clearly indicate comparator G4: 1.25 (1.07) 95% CI, NR
Schaffer et al., 2004 20 G1: 11 G2: 10 G3: 12 G4: 13 | Asthma control PCAQ 11 items; Range NR (higher score=better) | Mean (SD)—p-values reflect comparisons with G4 at 3 months: G1: 49.90 (4.6)—p=0.6 G2: 44.0 (4.97)—p=0.8 G3: 45.75 (6.27)—p=0.3 G4: 44.67 (6.82) 95% CI, NR Mean(SD)—p values reflect comparisons with G4 at 6 months: G1: 43.33 (14.43)—p=0.8 G2: 44.20 (6.16)—p=0.4 G3: 43.33 (14.44)—p=0.2 G4: 45.27 (5.57) 95% CI, NR
Wilson et al., 2010 17 G1: 182 G2: 180 G3: 189 | Asthma control in previous 4 weeks ATAQ 4 items; Range NR (lower score=better) No asthma control problems (ATAQ score=0) | Mean change in ATAQ score at 1 year G1: −0.80 G2: −0.54 G3: −0.46 95% CI, NR p: NR OR (95% CI) at 1 year G1 vs. G3: 1.9 (1.3–2.9) 95% CI, NR p=0.002 G2 vs.G3: 1.6 (1.1–2.4) 95% CI, NR p=0.0239
Wilson et al., 2010 17 G1: 204 G2: 204 G3: 204 | Mean equivalents of SABA acquired Pharmacy refill data | Means in Year 1: G1: 6.5 G2: 7.1 G3:8.1 G1–G3: p=0.002 G1–G2: p=0.09 G2–G3: p=0.038 95% CI, NR Means in Year 2: G1: 4.7 G2: 6.0 G3: 6.3 G1–G3: p=0.0141 G1–G2: p=0.06 G2–G3: p>0.05 95% CI, NR

Abbreviations: ACT = Asthma Control Test; ATAQ = Asthma Therapy Assessment Questionnaire; CI = confidence interval; G = group; NR = not reported; NS = not significant; OR = odds ratio; PCAQ = Perceived Control of Asthma Questionnaire; SABA = short-acting beta-agonists; SD = standard deviation.

Table G15 Reactive airway diseases: quality of life

Author, Year N in Each Group | Outcome Source/Method | Results
Bender et al., 2010 18 G1: 25 G2: 25 | Quality of life AQLQ 32-items; Range NR (higher score=better) | Mean change in score (SD) at 10 weeks G1: −0.152 (0.92) G2: −0.381 (1.06) p=0.419
Janson et al., 2003 15 G1: 33 G2: 32 | Quality of life Asthma-related quality of life scale Items: NR; Range NR (directionality NR) | Group difference (95% CI) from baseline to 7 weeks: G1: 17 (9) G2: 19 (13) Between group difference: −4.4 (−9 to 0.2) p=0.06
Janson et al., 2009 16 G1: 45 G2:39 | Quality of life Quality of life questionnaire Items NR; Range 0–80 (lower score=better) | Mean change in QOL score From 0–4 weeks: G1: −2.71 G2: −1.39 95% CI, NR p=0.36 From 4–14 weeks G1: −1.11 G2: 0.58 95% CI, NR p=0.27 From 0–14 weeks G1: −3.82 G2: −0.80 95% CI, NR p=0.06
Schaffer et al., 2004 20 G1: 11 G2: 10 G3: 12 G4: 13 | Asthma-related quality of life in preceding 2 weeks Mini-AQLQ 15-items; Range NR (higher score=better) | Mean (SD), p-values reflect comparisons with G4 at 3 months: G1: 5.15 (0.91), p=0.3 G2: 4.94 (0.97), p=0.5 G3: 5.13 (1.32), p=0.6 G4: 4.68 (1.49) 95% CI, NR Mean(SD), P values reflect comparisons with G4 at 6 months: G1: 5.22 (0.99), p=0.8 G2: 5.30 (0.8), p=0.4 G3:5.22 (0.98), p=0.2 G4: 4.87 (1.2) 95% CI, NR
Wilson et al., 2010 17 G1: 182 G2: 180 G3: 189 | Quality of life Symptom Subscale of the (Mini AQLQ 5 items; Range NR (higher score=better) | Mean symptom subscale scores at year 1 G1: 5.5 G2: 5.4 G3: 5.1 95% CI, NR G1–G3: p=0.0003 G1–G2: p>0.05 G2–G3: p=0.0009

Abbreviations: AQLQ = Asthma Quality of Life Questionnaire; CI = confidence interval; G = group; Mini-AQLQ = Mini-Asthma Quality of Life Questionnaire; NR = not reported; QOL = quality of life; SD = standard deviation.

Table G16 Asthma: health care utilization

Author, Year N in Each Group | Outcome Source/Method | Results
Wilson et al., 2010 17 G1: 204 G2: 204 G3: 204 | Number of asthma-related visits per year Electronic medical records | Means at 1 year post-randomization: G1: 1.0 G2: 1.1 G3: 1.4 (95% CI): G1–G3: (−0.66 to −0.07), p=0.0161 G1–G2: (−0.29–0.30), p=0.97 G2–G3: (−0.67–0.07), p=0.0147

Abbreviations: CI = confidence interval; G = group.

Table G17 Depression: morbidity

Author, Year N in Each Group | Outcome Source | Results
Bogner et al., 2007^5^ G1: 32 G2: 32 | Depression severity Center for Epidemiologic Studies-Depression Scale | Mean (SD) score at 6 weeks G1: 9.9 (10.7) G2: 19.3 (15.2) 95%CI, NR p=0.006
Bogner et al., 2010^1^ G1: 29 G2: 29 | Depression severity Center for Epidemiologic Studies-Depression Scale | Mean (SD) score at 12 weeks: G1: 9.6 (9.4) G2: 16.6 (14.5) 95% CI, NR p=0.035
Katon et al., 1995^21^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Patients responding to treatment (SCL-20 score improved ≥50%) | Percentage at 4 months: Bivariate analysis: Major depression group G1: 74.4 % G2: 43.8 % 95% CI, NR p<0.01 Minor depression group G1: 60.0 % G2: 67.9 % 95% CI, NR p=0.40 Multivariate analysis: Major depression group p<0.005 Minor depression group p=NS Group-by-time interaction Major depression group p<0.004
Katon et al., 1995^21^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Patients improved Inventory of Depressive Symptomatology (IDS) score ≥50% | Percentage at 4 months: Bivariate analysis: Major depression group G1: 61.5 % G2: 40.6 % 95% CI, NR p<0.08 Minor depression group G1: 48.0 % G2: 55.4 % 95% CI, NR p=0.50 Multivariate analysis Major depression group p<0.02 Minor depression group p=NS Group-by-time Major depression group p: NR, but statistically significant
Katon et al., 1996^22^ Overall G1: 77 G2: 76 Major depression: 65 G1: 31 G2: 34 Minor depression: 88 G1: 46 G2: 42 | Patients meeting criteria for depression at 4 months DSM-III-R | Major depression group: Percentage meeting criteria for major depression: G1: 7.4% G2: 23.1% 95% CI, NR p: NR Percentage meeting criteria for minor depression: G1: 33.8% G2: 30.8% 95% CI, NR p: NR Minor depression group: Percentage meeting criteria for minor depression: G1: 25.6% G2: 33.3% 95% CI, NR p: NR
Katon et al., 1996^22^ Overall G1: 77 G2: 76 Major depression: 65 G1: 31 G2: 34 Minor depression: 88 G1: 46 G2: 42 | Patients responding to treatment at 4 months (SCL-20 score improved ≥50%) | Major depression group—Percentage: G1: 70.4% G2: 42.3% 95% CI, NR p=0.04 Minor depression group—Percentage: G1: 66.7% G2: 52.8% 95% CI, NR p=0.22
Katon et al., 1999;^23^ Katon et al. 2002^24^ G1: 114 G2: 114 | Depression severity SCL-20 depression score [0–4 range] | Rate of change in score at 3 months: 95% CI, NR F(1,186): 12.38 p=0.001 Rate of change in score at 6 months: 95% CI, NR F(1,185): 3.09 p=0.08
Katon et al., 1999;^23^ Katon et al. 2002^24^ G1: 114 G2: 114 | Depression severity among patients with moderate depression (defined as SCL-20 score ≤ 2.0 at baseline) SCL-20 depression score [0–4 range] N=149 | Adjusted mean (SD) over 28 months: G1: 0.88 (0.52) G2: 1.23 (0.62) F(1, 187): 8.65 95% CI, NR p=0.004
Katon et al., 1999;^23^ Katon et al. 2002^24^ G1: 114 G2: 114 | Depression severity among patients with severe depression (defined as SCL-20 score > 2.0 at baseline) SCL-20 depression score [0–4 range] N=79 | Adjusted mean, (SD) over 28 months: G1: 1.16, (0.85) G2: 1.19, (0.72) F(1.51): 0.02 95% CI, NR p=0.88
Katon et al., 1999;^23^ Katon et al. 2002^24^ G1: 114 G2: 114 | Asymptomatic patients DSM-IV score of 0 or 1 | Percentage at 3 months G1: 40% G2: 23% 95% CI, NR Chi-square (1 df): 6.18 p=0.01 Percentage at 6 months G1: 44% G2: 31% 95% CI, NR Chi-square (1 df): 3.90 p=0.05
Katon et al., 1999;^23^ Katon et al. 2002^24^ G1: 114 G2: 114 | Functional impairment, Disability, among patients with moderate depression (defined as SCL-20 score ≤ 2.0 at baseline) Sheehan Disability Scale | Adjusted mean (SD) over 28 months: G1: 3.09 (2.30) G2: 3.58 (2.37) F(1.87): 1.21 95% CI, NR p=0.27
Katon et al., 1999;^23^ Katon et al. 2002^24^ G1: 114 G2: 114 | Functional impairment, Disability, among patients with severe depression (defined as SCL-20 score > 2.0 at baseline) Sheehan Disability Scale | Adjusted mean (SD) over 28 months: G1: 3.41 (2.61) G2: 3.20 (2.66) F (1.51): 0.09 95% CI, NR p=0.76
Katon et al., 2001;^25^ Ludman et al., 2003;^26^ Von Korff et al., 2003^27^ G1: 170 G2: 145 | Depression severity among patients with severe depression (defined as SCL-20 score >2.0 at baseline) N=79 | Mean difference in scores between groups across 12 months: 0.08 p=0.04 Mean (SD) score at 3 months G1: 0.75 (0.55) G2: 0.79 (0.47) 95% CI, NR p: NR *Sig difference between 2 depression specialists Mean (SD) score at 6 months G1: 0.74 (0.54) G2: 0.78 (0.51) 95% CI, NR p: NR Mean (SD) score at 9 months G1: 0.69 (0.56) G2: 0.86 (0.57) 95% CI, NR p: NR Mean (SD) score at 12 months G1: 0.65 (0.51) G2: 0.74 (0.54) 95% CI, NR p: NR
Katon et al., 2001;^25^ Ludman et al., 2003;^26^ Von Korff et al., 2003^27^ G1: 170 G2: 145 | Functional impairment, Disability Sheehan Disability Scale | Mean score (SD) at 3 months G1: 2.79 (3.94) G2: 2.08 (2.07) 95% CI, NR p: NR Mean score (SD) at 6 months G1: 2.41 (3.23) G2: 2.23 (2.22) 95% CI, NR p: NR Mean score (SD) at 9 months G1: 2.30 (2.06) G2: 2.30 (2.28) 95% CI, NR p: NR Mean score (SD) at 12 months G1: 2.09 (1.98) G2: 2.08 (2.07) 95% CI, NR p: NR Intervention effect (SD): Estimate: 0.15 (0.17) T-statistic: 0.86 p=0.39 Time effects (SD) Estimate: −0.06 (0.06) T-statistic: 1.06 p=0.29 Intervention x time effects (SD) Estimate: −0.12 (0.08) T-statistic: 1.47 p=0.14
Katon et al., 2001;^25^ Ludman et al., 2003;^26^ Von Korff et al., 2003^27^ G1: 170 G2: 145
Katon et al., 2001;^25^ Ludman et al., 2003;^26^ Von Korff et al., 2003^27^ G1: 170 G2: 145 | Functional impairment, SF-36 Social Functioning scale, using imputed data and adjusting for baseline characteristics | Mean score (SD) at 3 months G1: 81.4 (20.5) G2: 81.1 (21.1) 95% CI, NR p: NR Mean score (SD) at 6 months G1: 83.3 (20.2) G2: 83.0 (20.9) 95% CI, NR p: NR Mean score (SD) at 9 months G1: 84.7 (19.7) G2: 81.4 (22.4) 95% CI, NR p: NR Mean score (SD) at 12 months G1: 86.9 (17.8) G2: 81.7 (20.4) 95% CI, NR p: NR Intervention effects (SD): Estimate: 0.27 (1.42) T-statistic: 0.19 p=0.85 Time effects (SD) Estimate: 0.66 (0.48) T-statistic: 1.38 p=0.17 Intervention x time effects (SD) Estimate: 1.31 (0.66) T-statistic: 1.98 p=0.047
Katon et al., 2001;^25^ Ludman et al., 2003;^26^ Von Korff et al., 2003^27^ G1: 170 G2: 145
Katon et al., 2001;^25^ Ludman et al., 2003;^26^ Von Korff et al., 2003^27^ G1: 170 G2: 145 | Functional impairment, SF-36 Role-Emotional scale, using imputed data and adjusting for baseline characteristics | Mean score (SD) at 3 months G1: 67.2 (35.6) G2: 68.3 (35.6) 95% CI, NR p: NR Mean score (SD) at 6 months G1: 67.8 (36.5) G2: 72.1 (31.8) 95% CI, NR p: NR Mean score (SD) at 9 months G1: 70.8 (36.3) G2: 71.0 (34.3) 95% CI, NR p: NR Mean score (SD) at 12 months G1: 75.9 (32.2) G2: 73.9 (36.2) 95% CI, NR p: NR Intervention effects (SD): Estimate: −1.52 (2.21) T-statistic: 0.69 p=0.49 Time effects (SD) Estimate: 2.51 (0.88) T-statistic: 2.86 p=0.004 Intervention x time effects (SD) Estimate: 0.32 (1.16) T-statistic: 0.28 p=0.78

Abbreviations: CI = confidence interval; df = degree of confidence; G = group; IDS = Inventory of Depressive Symptomatology; ITT = intention to treat; N = number; NR = not reported; NS = not statistically significant; SCL-20 = Hopkins Symptom Checklist-20; SD = standard deviation.

Table G18 Depression: patient satisfaction

Author, Year N in Each Group | Outcome Source | Results
Katon et al., 1995^21^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Patients reporting antidepressant medications as helping somewhat to a great deal Questionnaire with 4-point ordinal scale | Percentage at 4 months: Major depression group G1: 88.1 % G2: 63.3 % 95% CI, NR p<0.01 Minor depression group G1: 81.8 % G2: 61.4 % 95% CI, NR p<0.02
Katon et al. 1996^22^ Overall G1: 77 G2: 76 Major depression: 65 G1: 31; G2: 34 Minor depression: 88 G1: 46; G2: 42 | Patients rating antidepressant medication as helping somewhat to a great deal Questionnaire with 4-point ordinal scale | Percentage, at 4 months: Major depression group G1: 80% G2: 58.3% 95% CI, NR p<0.10 Minor depression group G1: 94.6% G2: 88.6% 95% CI, NR p=0.36

Abbreviations: CI = confidence interval; G = group; N = number; NR = not reported; NS = not statistically significant; SD = standard deviation.

Table G19 Depression: health care utilization

Author, Year N in Each Group | Outcome Source | Results
Katon et al.,1995^21^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Number of study visits for collaborative care intervention (G1 only: N: 108) Medical records | Mean (SD) at 12 months: 3.9 (2.5)
Katon et al.,1995^21^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Number of visits with primary care provider for depression (not study-related) Medical records | Mean (SD) at 12 months: G1: 4.5 (3.7) G2: 3.7 (2.4) 95% CI, NR p: NR
Katon et al.,1995^21^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Patients seen by a mental health specialist (not study-related) Medical records | Number (%) at 12 months: G1: 30 (27%) G2: 34 (31%) 95% CI, NR p: NR
Katon et al.,1995^21^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Patients seen by a psychiatrist (not study-related) Medical records | Number (%) at 12 months: G1: 3 (3%) G2: 11 (10%) 95% CI, NR p: NR
Katon et al., 1996^22^ Overall G1: 77 G2: 76 | Number of visits with primary care provider Medical records | Within first 12 weeks of treatment: Mean (SD) G1: 3.1 (1.7) G2: 2.9 (1.4) 95% CI, NR p=0.30 Within first 6 months after primary care referral visit: Mean (SD) G1: 4.6 (2.6) G2: 4.1 (2) 95% CI, NR p=0.19
Katon et al., 1996^22^ Overall G1: 77 G2: 76 | Patients seen by a mental health specialist Medical records | Within first 12 weeks of treatment: Percentage: G1: 20% G2: 29% 95% CI, NR p=0.21 Within first 6 months after primary care referral visit: G1: 24% G2: 33% 95% CI, NR p=0.21
Katon et al., 1999;^23^ Katon et al., 2002^24^ G1: 114 G2: 114 | Number of visits with primary care provider Data source unspecified | Mean (SD) at 3 months: G1: 1.6 (1.8) G2: 1.8 (1.8) 95% CI, NR Chi-square (1 df): 1.46 p=0.23 Mean (SD) at 6 months: G1: 3.4 (4.3) G2: 3.3 (3.1) 95% CI, NR Chi-square (1 df): 0.35 p=0.55
Katon et al., 1999;^23^ Katon et al., 2002^24^ G1: 114 G2: 114 | Patients with ≥1 visit to a non-study mental health specialist Data source unspecified | Percentage at 3 months: G1: 17.5% G2: 24.6% 95% CI, NR Chi-square (1 df): 1.29 p=0.26 Percentage at 6 months: G1: 24.6% G2:27.2% 95% CI, NR Chi-square (1 df): 0.09 p=0.76
Katon et al., 1999;^23^ Katon et al., 2002^24^ G1: 114 G2: 114 | Number of visits to a non-study mental health specialist Data source unspecified | Mean (SD) at 3 months: G1: 0.6 (1.7) G2: 0.8 (1.9) 95% CI, NR p=0.34 Mean (SD) at 6 months: G1: 1.3 (2.9) G2: 1.3 (2.9) 95% CI, NR p=0.85

Abbreviations: CI = confidence interval; df = degrees of freedom; G = group; N = number; NR = not reported; NS = not statistically significant; SD = standard deviation.

Table G20 Depression: costs

Author, Year N in Each Group | Outcome Source | Results
Katon et al., 1999;^23^ Katon et al., 2002^24^ G1: 114 G2: 114 | Total ambulatory costs Health plan computerized data | Mean (95%CI) over 36 months: G1: $8,524 (5,059–8,188) G2: $7,787 (6,595–8,980) F(1,180): 0.77 p=0.40
Katon et al., 1999;^23^ Katon et al., 2002^24^ G1: 114 G2: 114 | Total health care costs Health plan computerized data | Mean (95%CI) over 36 months: G1: $9,799 (7,763–11,834) G2: 9,192 (7,504–10,880) F(1,180): 0.91 p=0.34
Katon et al., 1999;^23^ Katon et al., 2002^24^ G1: 114 G2: 114 | Depression treatment costs Health plan computerized data | Over 36 months: F(1,173): 2.65 p=0.10
Katon et al., 1999;^23^ Katon et al., 2002^24^ G1: 114 G2: 114 | Non-depression related outpatient costs Health plan computerized data | Mean (95%CI) over 36 months: G1: $6,769 (5,351–8,188) G2: $5,470 (4,431–6,510) F(1,180): 0.11 p=0.74

Abbreviations: CI = confidence interval; F = Fisher-Snedecor distribution; G = group; N = number; NR = not reported.

Table G21 Depression: quality of care

Author, Year N in Each Group | Outcome | Results
Katon et al., 1995^21^ Major depression: 91 G1: 49 G2: 42 Minor depression: 126 G1: 59 G2: 67 | Patients rating quality of depression care as good to excellent on a 5-point scale from poor to excellent | Percentage at 4 months: Major depression group G1: 93.0 % G2: 75.0 % 95% CI, NR p<0.03 Minor depression group G1: 94.4 % G2: 89.3 % 95% CI, NR p=0.30
Katon et al., 1996^22^ Overall G1: 77 G2: 76 Major depression: 65 G1: 31; G2: 34 Minor depression: 88 G1: 46; G2: 42 | Patients rating quality of depression care as good to excellent on a 5-point scale from poor to excellent | Percentage at 4 months: Major depression group G1: 88.5% G2: 56% 95% CI, NR p<0.009 Minor depression group G1: 97.1% G2: 71.4% 95% CI, NR p=0.003
Katon et al., 1999;^23^ Katon et al., 2002^24^ G1: 114 G2: 114 | Patients rating the quality of care received for depression as good to excellent on a 5-point scale from poor to excellent | Percentage at 3 months: G1: 94.5% G2: 63.9% 95% CI, NR Chi-square (1 df): 23.51 p<0.00001 Percentage at 6 months: G1: 79.5% G2: 63.5% 95% CI, NR Chi-square (1 df): 4.21 p=0.04

Abbreviations: CI = confidence interval; df = degrees of freedom; G = group; N = number; NR = not reported.

Table G22 Glaucoma: morbidity

Author, Year N in Each Group | Outcome | Results
Okeke et al., 2009^28^ G1: NR G2: NR | Intraocular pressure | G1: NR, Applantoin G2: NR, Applantoin 95 % CI, NR p: 0.81

Abbreviations: CI = confidence interval; G = group; NR = not reported

Table G23 Musculoskeletal diseases: patient satisfaction

Author, Year N in Each Group | Outcome | Results
Waalen et al., 2009^29^ G1: 68 G2: 58 | Patient satisfaction with care assessed by response to the question: “Overall my treatment for osteoporosis has been a good experience” Measured at 1 year and 30 days after study entry | Percentage of patients responding All/most of the time: G1: 58 (85.3) G2: 52 (89.7) 95% CI, NR Some of the time: G1: 4 (5.9) G2: 0 (0) 95% CI, NR A little/none of the time: G1: 6 (8.8) G2: 6 (10.3) Overall p: 0.17
Montori et al., 2011^30^ G1: NR G2: NR | Mean satisfaction with knowledge transfer measured using 16-item decision conflict scale NR | Amount of information G1: 6.6 G2: 6.3 95% CI, NR p: 0.798 Clarity of information G1: 6 G2: 6 95% CI, NR p: 0.296 Helpfulness of information G1: 6 G2: 5.8 95% CI, NR p: 0.624 Would want other decisions G1: 6.1 G2: 5.8 95% CI, NR p: 0.248 Would recommend to others G1: 6.4 G2: 6.2 95% CI, NR p: 0.435

Abbreviation: G = group.

Table G24 Policy interventions: clinical outcomes

Author, Year N in Each Group | Outcome Source | Results
Choudhry et al., 2011^31^ G1: 2845 G2: 3010 | Death from cardiovascular causes (rate/100 person-years) Health claims records | G1: 1.7 G2: 2.0 HR (95% CI): 0.85 (0.60–1.21)
Choudhry et al., 2011^31^ G1: 2845 G2: 3010 | Rate of first fatal or nonfatal vascular event or revascularization (rate/100 person-years) Health claims records | G1: 17.6 G2: 18.8 HR (95% CI): 0.93 (0.82–1.04)
Choudhry et al., 2011^31^ G1: 2845 G2: 3010 | Rate of all fatal or nonfatal vascular events or revascularization Health claims records | G1: 21.5 G2: 23.3 HR (95% CI): 0.89 (0.80–0.99)
Choudhry et al., 2011^31^ G1: 2845 G2: 3010 | Rate of first fatal or nonfatal vascular event Health claims records | G1: 11.0 G2: 12.8 HR (95% CI): 0.86 (0.74–0.99)

Abbreviations: G = group; N = number; NA = not applicable; CI = confidence interval; ACE Inhibitor = angiotensin-converting-enzyme inhibitor; ARBs = angiotensin-receptor blockers; HR = hazard ratio.

Table G25 Policy interventions: economic outcomes

Author, Year N in Each Group | Outcome Source | Results
Choudhry et al., 2011^31^ G1: 2845 G2: 3010 | Total insurer spending (US dollars) Health claims records | Mean (SD) G1: 64,726 (639,683) G2: 69,997 (617,650) Relative Spending (95% CI): 0.92 (0.55–1.56)
Choudhry et al., 2011^31^ G1: 2845 G2: 3010 | Total patient spending (US dollars) Health claims records | G1: 1,282 (1,549) G2: 1,781 (2,263) Relative Spending (95% CI): 0.74 (0.68–0.80)
Choudhry et al., 2011^31^ G1: 2845 G2: 3010 | Combined insurer and patient total spending (US dollars) Health claims records | G1: 66,008 (639,970) G2: 71,778 (618,055) Relative Spending (95% CI): 0.89 (0.50–1.56)

Abbreviations: G = group; N = number; NA = not applicable; CI = confidence interval; ACE Inhibitor = angiotensin-converting-enzyme inhibitor; ARBs = angiotensin-receptor blockers; HR = hazard ratio

Table G26 Harms: adverse events outcomes

Author, Year N Analyzed in Each Group | Adverse Event Outcome Source | Results
Carter et al., 2009^32^ G1: 192 G2: 210 | Mean total adverse event score Adverse event questionnaire with 47 items, developed for another study and administered by study nurses | Measured twice, once at baseline and once at 6-month followup Baseline: Mean (SD) G1: 28.0 (23.0) G2: 42.1 (24.2) 95% CI, NR p<0.001 6-month followup (Mean (SD)) G1: 16.6 (12.5) G2: 39.2 (24.2) 95% CI, NR p<0.001 Between-group difference at 6 months p<0.001. However, this does not adjust for difference at baseline.
Murray et al., 2007^12^ G1: 112 G2: 192 | Number of patients who had an adverse drug event or medication error Measured using a program that identified adverse events from the medical record system | G1: 42 (37.5%) G2: 91 (47.4%) 95% CI, NR p: 0.094
Schectman et al., 1994^33^ Niacin: G1: 40 G2: 40 BAS: G1: 18 G2: 20 | Percentage of patients reporting adverse events associated with medications at 2 months Self-report to clinic staff | 2 months; measured at 2, 4, and 6 months; only 2-month results reported Niacin: flushing, pruritis, rash, heartburn (%) G1: 70, 32, 15, 9 G2: 63, 29, 12, 5 95% CI, NR p: NS, no number given BAS: constipation, bloating, flatulence, heartburn (%) G1: 44, 23, 19, 15 G2: 26, 22, 11, 11 95% CI, NR p: NS, no number given

Abbreviations: BAS = bile acid sequestrant therapy; G = group; NR = not reported; NS = not significant.

## References

1 Bogner HR, de Vries HF. Integrating type 2 diabetes mellitus and depression treatment among African Americans: a randomized controlled pilot trial. Diabetes Educ. Mar–Apr. 2010;36(2):284-92. [pmid: 20040705].
2 Lee JK, Grace KA, Taylor AJ. Effect of a pharmacy care program on medication adherence and persistence, blood pressure, and low-density lipoprotein cholesterol: a randomized controlled trial. JAMA. Dec. 6. 2006;296(21):2563-71. [pmid: 17101639].
3 Weymiller AJ, Montori VM, Jones LA, et al. Helping patients with type 2 diabetes mellitus make treatment decisions: statin choice randomized trial. Arch Intern Med. May. 28. 2007;167(10):1076-82. [pmid: 17533211].
4 Jones LA, Weymiller AJ, Shah N, et al. Should clinicians deliver decision aids? Further exploration of the statin choice randomized trial results. Med Decis Making. Jul–Aug. 2009;29(4):468-74. [pmid: 19605885].
5 Bogner HR, de Vries HF. Integration of depression and hypertension treatment: a pilot, randomized controlled trial. Ann Fam Med. Jul–Aug. 2008;6(4):295-301. [pmid: 18626028].
6 Friedman RH, Kazis LE, Jette A, et al. A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control. Am J Hypertens. Apr. 1996;9(4 Pt 1):285-92. [pmid: 8722429].
7 Rudd P, Miller NH, Kaufman J, et al. Nurse management for hypertension. A systems approach. Am J Hypertens. Oct. 2004;17(10):921-7. [pmid: 15485755].
8 Schneider PJ, Murphy JE, Pedersen CA. Impact of medication packaging on adherence and treatment outcomes in older ambulatory patients. J Am Pharm Assoc. 2008. Jan–Feb. 2003;48(1):58-63. [pmid: 18192132].
9 Solomon DK, Portner TS, Bass GE, et al. Clinical and economic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). Sep–Oct. 1998;38(5):574-85. [pmid: 9782691].
10 Gourley GA, Portner TS, Gourley DR, et al. Humanistic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). Sep–Oct. 1998;38(5):586-97. [pmid: 9782692].
11 Fulmer TT, Feldman PH, Kim TS, et al. An intervention study to enhance medication compliance in community-dwelling elderly individuals. J Gerontol Nurs. Aug. 1999;25(8):6-14. [pmid: 10711101].
12 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. [pmid: 17502632].
13 Ross SE, Moore LA, Earnest MA, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. May. 14. 2004;6(2):e12. [pmid: 15249261].
14 Rich MW, Gray DB, Beckham V, et al. Effect of a multidisciplinary intervention on medication compliance in elderly patients with congestive heart failure. Am J Med. Sep. 1996;101(3):270-6. [pmid: 8873488].
15 Janson SL, Fahy JV, Covington JK, et al. Effects of individual self-management education on clinical, biological, and adherence outcomes in asthma. Am J Med. Dec. 1. 2003;115(8):620-6. [pmid: 14656614].
16 Janson SL, McGrath KW, Covington JK, et al. Individualized asthma self-management improves medication adherence and markers of asthma control. J Allergy Clin Immunol. Apr. 2009;123(4):840-6. [pmid: 19348923].
17 Wilson SR, Strub P, Buist AS, et al. Shared treatment decision making improves adherence and outcomes in poorly controlled asthma. Am J Respir Crit Care Med. Mar. 15. 2010;181(6):566-77. [pmid: 20019345].
18 Bender BG, Apter A, Bogen DK, et al. Test of an interactive voice response intervention to improve adherence to controller medications in adults with asthma. J Am Board Fam Med. Mar–Apr. 2010;23(2):159-65. [pmid: 20207925].
19 Berg J, Dunbar-Jacob J, Sereika SM. An evaluation of a self-management program for adults with asthma. Clin Nurs Res. Aug. 1997;6(3):225-38. [pmid: 9281927].
20 Schaffer SD, Tian L. Promoting adherence: effects of theory-based asthma education. Clin Nurs Res. Feb. 2004;13(1):69-89. [pmid: 14768768].
21 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve treatment guidelines. Impact on depression in primary care. JAMA. Apr. 5. 1995;273(13):1026-31. [pmid: 7897786].
22 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Arch Gen Psychiatry. Oct. 1996;53(10):924-32. [pmid: 8857869].
23 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: A randomized trial. Arch Gen Psychiatry. 1999;56(12):1109-15. [pmid: 10591288].
24 Katon W, Russo J, Von Korff M, et al. Long-term effects of a collaborative care intervention in persistently depressed primary care patients. J Gen Intern Med. Oct. 2002;17(10):741-8. [pmid: 12390549].
25 Katon W, Rutter C, Ludman EJ, et al. A randomized trial of relapse prevention of depression in primary care. Arch Gen Psychiatry. Mar. 2001;58(3):241-7. [pmid: 11231831].
26 Ludman E, Katon W, Bush T, et al. Behavioural factors associated with symptom outcomes in a primary care-based depression prevention intervention trial. Psychol Med. Aug. 2003;33(6):1061-70. [pmid: 12946090].
27 Von Korff M, Katon W, Rutter C, et al. Effect on disability outcomes of a depression relapse prevention program. Psychosom Med. Nov–Dec. 2003;65(6):938-43. [pmid: 14645770].
28 Okeke CO, Quigley HA, Jampel HD, et al. Interventions improve poor adherence with once daily glaucoma medications in electronically monitored patients. Ophthalmology. Dec. 2009;116(12):2286-93. [pmid: 19815286].
29 Waalen J, Bruning AL, Peters MJ, et al. A telephone-based intervention for increasing the use of osteoporosis medication: a randomized controlled trial. Am J Manag Care. Aug. 2009;15(8):e60-70. [pmid: 19659407].
30 Montori VM, Shah ND, Pencille LJ, et al. Use of a decision aid to improve treatment decisions in osteoporosis: the osteoporosis choice randomized trial. Am J Med. Jun. 2011;124(6):549-56. [pmid: 21605732].
31 Choudhry NK, Avorn J, Glynn RJ, et al. Full coverage for preventive medications after myocardial infarction. N Engl J Med. Dec. 1. 2011;365(22):2088-97. [pmid: 22080794].
32 Carter BL, Ardery G, Dawson JD, et al. Physician and pharmacist collaboration to improve blood pressure control. Arch Intern Med. Nov. 23. 2009;169(21):1996-2002. [pmid: 19933962].
33 Schectman G, Hiatt J, Hartz A. Telephone contacts do not improve adherence to niacin or bile acid sequestrant therapy. Ann Pharmacother. Jan. 1994;28(1):29-35. [pmid: 8123955].