# Adherence and Clinical Outcome Scales Commonly Used in Medication Adherence Studies

General Health Measures

Abbreviated Name | Complete Name of Measure or Instrument | Range or mean of Scores | Improvement Denoted by
ACT | Asthma Control Test | 0–25. | Increase
ACQ | Asthma Control Questionnaire | Total score is mean of scores for all 7 items. | Decrease
AQLQ | Asthma Quality of Life Questionnaire | 0–4. A score change of 0.5 points is considered to be clinically important. | Increase
ATAQ | Asthma Therapy Assessment Questionnaire | 0–4 | Decrease
CES-D | Center for Epidemiologic Studies – Depression Scale | 0–60 | Decrease
DSM-III/IV | Diagnostic and Symptom Manual III/IV | N/A | N/A
N/A | Hypertension/Lipid Form 5.1 (developed by The Health Outcomes Institute)
IDS | Inventory of Depressive Symptomatology | 0–84 | Decrease
MLHF | Minnesota Living with Heart Failure | NR | Increase
SCL-20 | Symptom Checklist with 20 items | NR | Decrease
SF-36 | Medical Outcomes Study Short Form 36 Health Survey | 0–100 | Increase
N/A | Sheehan Disability Scale | 0–10 | Decrease

Medication Adherence Measures

Abbreviated Name | Complete Name of Measure or Instrument | Range or mean of Scores | Improvement Denoted by
HEDIS | Healthcare Effectiveness Data and Information Set guidelines for measuring adherence based on pharmacy refill data | N/A | N/A
MPR | Medication possession ratio (i.e, number of eligible days in the yearly quarter the person was in possession of the medication divided by the number of days in the quarter) | 0–1.0 | Increase
MEMS | Medication event monitoring systems | N/A | Increase
N/A | Morisky 8-item adherence scale | 0–8 | Decrease
N/A | Proportion of days covered (i.e., estimated number of days of medication available to each patient) | Continuous | Increase
N/A | Time-to-refill | Measured in days | Decrease