# Risk of Bias Tables

Table E1 Risk of bias ratings, part 1

Table E2 Risk of bias ratings, part 2

Table E3 Risk of bias ratings, part 3

Table E4 Risk of bias ratings, part 4

## References

1 Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. Feb. 2009;36(1):113-26. [pmid: 19188371].
2 Bender BG, Apter A, Bogen DK, et al. Test of an interactive voice response intervention to improve adherence to controller medications in adults with asthma. J Am Board Fam Med. Mar–Apr. 2010;23(2):159-65. [pmid: 20207925].
3 Berg J, Dunbar-Jacob J, Sereika SM. An evaluation of a self-management program for adults with asthma. Clin Nurs Res. Aug. 1997;6(3):225-38. [pmid: 9281927].
4 Berger BA, Liang H, Hudmon KS. Evaluation of software-based telephone counseling to enhance medication persistency among patients with multiple sclerosis. J Am Pharm Assoc. 2005. Jul–Aug. 2003;45(4):466-72. [pmid: 16128502].
5 Bogner HR, de Vries HF. Integration of depression and hypertension treatment: a pilot, randomized controlled trial. Ann Fam Med. Jul–Aug. 2008;6(4):295-301. [pmid: 18626028].
6 Bogner HR, de Vries HF. Integrating type 2 diabetes mellitus and depression treatment among African Americans: a randomized controlled pilot trial. Diabetes Educ. Mar–Apr. 2010;36(2):284-92. [pmid: 20040705].
7 Bosworth HB, Olsen MK, Gentry P, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Educ Couns. Apr. 2005;57(1):5-14. [pmid: 15797147].
8 Bosworth HB, Olsen MK, Neary A, et al. Take Control of Your Blood Pressure (TCYB) study: a multifactorial tailored behavioral and educational intervention for achieving blood pressure control. Patient Educ Couns. Mar. 2008;70(3):338-47. [pmid: 18164894].
9 Bosworth HB, Olsen MK, Dudley T, et al. The Take Control of Your Blood pressure (TCYB) study: Study design and methodology. Contemporary Clinical Trials. 2007;28(1):33-47. [pmid: 16996808].
10 Brown R, Peikes D, Chen A, et al. 15-site randomized trial of coordinated care in Medicare FFS. Health Care Financ Rev. Fall. 2008;30(1):5-25. [pmid: 19040171].
11 Capoccia KL, Boudreau DM, Blough DK, et al. Randomized trial of pharmacist interventions to improve depression care and outcomes in primary care. Am J Health Syst Pharm. Feb. 15. 2004;61(4):364-72. [pmid: 15011764].
12 Carter BL, Bergus GR, Dawson JD, et al. A cluster randomized trial to evaluate physician/pharmacist collaboration to improve blood pressure control. J Clin Hypertens (Greenwich). Apr. 2008;10(4):260-71. [pmid: 18401223].
13 Carter BL, Ardery G, Dawson JD, et al. Physician and pharmacist collaboration to improve blood pressure control. Arch Intern Med. Nov. 23. 2009;169(21):1996-2002. [pmid: 19933962].
14 Chernew ME, Shah MR, Wegh A, et al. Impact of decreasing copayments on medication adherence within a disease management environment. Health Aff (Millwood). Jan–Feb. 2008;27(1):103-12. [pmid: 18180484].
15 Choudhry NK, Fischer MA, Avorn J, et al. At Pitney Bowes, value-based insurance design cut copayments and increased drug adherence. Health Aff (Millwood). Nov. 2010;29(11):1995-2001. [pmid: 21041738].
16 Choudhry NK, Avorn J, Glynn RJ, et al. Full coverage for preventive medications after myocardial infarction. N Engl J Med. Dec. 1. 2011;365(22):2088-97. [pmid: 22080794].
17 Esposito L. The effects of medication education on adherence to medication regimens in an elderly population. J Adv Nurs. May. 1995;21(5):935-43. [pmid: 7602002].
18 Fortney JC, Pyne JM, Edlund MJ, et al. A randomized trial of telemedicine-based collaborative care for depression. J Gen Intern Med. Aug. 2007;22(8):1086-93. [pmid: 17492326].
19 Friedman RH, Kazis LE, Jette A, et al. A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control. Am J Hypertens. Apr. 1996;9(4 Pt 1):285-92. [pmid: 8722429].
20 Fulmer TT, Feldman PH, Kim TS, et al. An intervention study to enhance medication compliance in community-dwelling elderly individuals. J Gerontol Nurs. Aug. 1999;25(8):6-14. [pmid: 10711101].
21 Grant RW, Devita NG, Singer DE, et al. Improving adherence and reducing medication discrepancies in patients with diabetes. Ann Pharmacother. Jul–Aug. 2003;37(7–8):962-9. [pmid: 12841801].
22 Guthrie RM. The effects of postal and telephone reminders on compliance with pravastatin therapy in a national registry: results of the first myocardial infarction risk reduction program. Clin Ther. Jun. 2001;23(6):970-80. [pmid: 11440296].
23 Hoffman L, Enders J, Luo J, et al. Impact of an antidepressant management program on medication adherence. Am J Manag Care. Jan. 2003;9(1):70-80. [pmid: 12549816].
24 Hunkeler EM, Meresman JF, Hargreaves WA, et al. Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care. Arch Fam Med. Aug. 2000;9(8):700-8. [pmid: 10927707].
25 Hunt JS, Siemienczuk J, Pape G, et al. A randomized controlled trial of team-based care: impact of physician-pharmacist collaboration on uncontrolled hypertension. J Gen Intern Med. Dec. 2008;23(12):1966-72. [pmid: 18815843].
26 Janson SL, Fahy JV, Covington JK, et al. Effects of individual self-management education on clinical, biological, and adherence outcomes in asthma. Am J Med. Dec. 1. 2003;115(8):620-6. [pmid: 14656614].
27 Janson SL, McGrath KW, Covington JK, et al. Objective airway monitoring improves asthma control in the cold and flu season: a cluster randomized trial. Chest. Nov. 2010;138(5):1148-55. [pmid: 20538819].
28 Janson SL, McGrath KW, Covington JK, et al. Individualized asthma self-management improves medication adherence and markers of asthma control. J Allergy Clin Immunol. Apr. 2009;123(4):840-6. [pmid: 19348923].
29 Johnson SS, Driskell MM, Johnson JL, et al. Efficacy of a transtheoretical model-based expert system for antihypertensive adherence. Dis Manag. Oct. 2006;9(5):291-301. [pmid: 17044763].
30 Johnson SS, Driskell MM, Johnson JL, et al. Transtheoretical model intervention for adherence to lipid-lowering drugs. Dis Manag. Apr. 2006;9(2):102-14. [pmid: 16620196].
31 Johnston B, Wheeler L, Deuser J, et al. Outcomes of the Kaiser Permanente Tele-Home Health Research Project. Arch Fam Med. Jan. 2000;9(1):40-5. [pmid: 10664641].
32 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve treatment guidelines. Impact on depression in primary care. JAMA. Apr. 5. 1995;273(13):1026-31. [pmid: 7897786].
33 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Arch Gen Psychiatry. Oct. 1996;53(10):924-32. [pmid: 8857869].
34 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: A randomized trial. Arch Gen Psychiatry. 1999;56(12):1109-15. [pmid: 10591288].
35 Katon W, Russo J, Von Korff M, et al. Long-term effects of a collaborative care intervention in persistently depressed primary care patients. J Gen Intern Med. Oct. 2002;17(10):741-8. [pmid: 12390549].
36 Katon W, Rutter C, Ludman EJ, et al. A randomized trial of relapse prevention of depression in primary care. Arch Gen Psychiatry. Mar. 2001;58(3):241-7. [pmid: 11231831].
37 Ludman E, Katon W, Bush T, et al. Behavioural factors associated with symptom outcomes in a primary care-based depression prevention intervention trial. Psychol Med. Aug. 2003;33(6):1061-70. [pmid: 12946090].
38 Von Korff M, Katon W, Rutter C, et al. Effect on disability outcomes of a depression relapse prevention program. Psychosom Med. Nov–Dec. 2003;65(6):938-43. [pmid: 14645770].
39 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Arch Gen Psychiatry. Oct. 2004;61(10):1042-9. [pmid: 15466678].
40 Laramee AS, Levinsky SK, Sargent J, et al. Case management in a heterogeneous congestive heart failure population: a randomized controlled trial. Arch Intern Med. Apr. 14. 2003;163(7):809-17. [pmid: 12695272].
41 Lee JK, Grace KA, Taylor AJ. Effect of a pharmacy care program on medication adherence and persistence, blood pressure, and low-density lipoprotein cholesterol: a randomized controlled trial. JAMA. Dec. 6. 2006;296(21):2563-71. [pmid: 17101639].
42 Lin EH, Katon W, Rutter C, et al. Effects of enhanced depression treatment on diabetes self-care. Ann Fam Med. Jan–Feb. 2006;4(1):46-53. [pmid: 16449396].
43 Maciejewski ML, Farley JF, Parker J, et al. Copayment reductions generate greater medication adherence in targeted patients. Health Aff (Millwood). Nov. 2010;29(11):2002-8. [pmid: 21041739].
44 Mann DM, Ponieman D, Montori VM, et al. The Statin Choice decision aid in primary care: a randomized trial. Patient Educ Couns. Jul. 2010;80(1):138-40. [pmid: 19959322].
45 Martin MY, Kim YI, Kratt P, et al. Medication adherence among rural, low-income hypertensive adults: a randomized trial of a multimedia community-based intervention. Am J Health Promot. Jul–Aug. 2011;25(6):372-8. [pmid: 21721962].
46 Montori VM, Shah ND, Pencille LJ, et al. Use of a decision aid to improve treatment decisions in osteoporosis: the osteoporosis choice randomized trial. Am J Med. Jun. 2011;124(6):549-56. [pmid: 21605732].
47 Mundt JC, Clarke GN, Burroughs D, et al. Effectiveness of antidepressant pharmacotherapy: the impact of medication compliance and patient education. Depress Anxiety. 2001;13(1):1-10. [pmid: 11233454].
48 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. [pmid: 17502632].
49 Nietert PJ, Tilley BC, Zhao W, et al. Two pharmacy interventions to improve refill persistence for chronic disease medications: a randomized, controlled trial. Med Care. Jan. 2009;47(1):32-40. [pmid: 19106728].
50 Odegard PS, Goo A, Hummel J, et al. Caring for poorly controlled diabetes mellitus: a randomized pharmacist intervention. Ann Pharmacother. Mar. 2005;39(3):433-40. [pmid: 15701763].
51 Okeke CO, Quigley HA, Jampel HD, et al. Interventions improve poor adherence with once daily glaucoma medications in electronically monitored patients. Ophthalmology. Dec. 2009;116(12):2286-93. [pmid: 19815286].
52 Park JJ, Kelly P, Carter BL, et al. Comprehensive pharmaceutical care in the chain setting. J Am Pharm Assoc (Wash). Jul. 1996;NS36(7):443-51. [pmid: 8840744].
53 Pearce KA, Love MM, Shelton BJ, et al. Cardiovascular risk education and social support (CaRESS): report of a randomized controlled trial from the Kentucky Ambulatory Network (KAN). J Am Board Fam Med. Jul–Aug. 2008;21(4):269-81. [pmid: 18612053].
54 Planas LG, Crosby KM, Mitchell KD, et al. Evaluation of a hypertension medication therapy management program in patients with diabetes. J Am Pharm Assoc. 2009. Mar–Apr. 2003;49(2):164-70. [pmid: 19289342].
55 Powell KM, Edgren B. Failure of educational videotapes to improve medication compliance in a health maintenance organization. Am J Health Syst Pharm. Oct. 15. 1995;52(20):2196-9. [pmid: 8564589].
56 Powers BJ, Danus S, Grubber JM, et al. The effectiveness of personalized coronary heart disease and stroke risk communication. Am Heart J. 2011;161(4):673-80. [pmid: 21473965].
57 Pyne JM, Fortney JC, Curran GM, et al. Effectiveness of collaborative care for depression in human immunodeficiency virus clinics. Arch Intern Med. Jan. 10. 2011;171(1):23-31. [pmid: 21220657].
58 Rich MW, Gray DB, Beckham V, et al. Effect of a multidisciplinary intervention on medication compliance in elderly patients with congestive heart failure. Am J Med. Sep. 1996;101(3):270-6. [pmid: 8873488].
59 Rickles NM, Svarstad BL, Statz-Paynter JL, et al. Pharmacist telemonitoring of antidepressant use: effects on pharmacist-patient collaboration. J Am Pharm Assoc. 2005. May–Jun. 2003;45(3):344-53. [pmid: 15991756].
60 Rodin HA, Heaton AH, Wilson AR, et al. Plan designs that encourage the use of generic drugs over brand-name drugs: an analysis of a free generic benefit. Am J Manag Care. Dec. 2009;15(12):881-8. [pmid: 20001169].
61 Ross SE, Moore LA, Earnest MA, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. May. 14. 2004;6(2):e12. [pmid: 15249261].
62 Rudd P, Miller NH, Kaufman J, et al. Nurse management for hypertension. A systems approach. Am J Hypertens. Oct. 2004;17(10):921-7. [pmid: 15485755].
63 Rudd RE, Blanch DC, Gall V, et al. A randomized controlled trial of an intervention to reduce low literacy barriers in inflammatory arthritis management. Patient Educ Couns. Jun. 2009;75(3):334-9. [pmid: 19345053].
64 Ruskin PE, Silver-Aylaian M, Kling MA, et al. Treatment outcomes in depression: comparison of remote treatment through telepsychiatry to in-person treatment. Am J Psychiatry. Aug. 2004;161(8):1471-6. [pmid: 15285975].
65 Schaffer SD, Tian L. Promoting adherence: effects of theory-based asthma education. Clin Nurs Res. Feb. 2004;13(1):69-89. [pmid: 14768768].
66 Schectman G, Hiatt J, Hartz A. Telephone contacts do not improve adherence to niacin or bile acid sequestrant therapy. Ann Pharmacother. Jan. 1994;28(1):29-35. [pmid: 8123955].
67 Schneider PJ, Murphy JE, Pedersen CA. Impact of medication packaging on adherence and treatment outcomes in older ambulatory patients. J Am Pharm Assoc. 2008. Jan–Feb. 2003;48(1):58-63. [pmid: 18192132].
68 Schnipper JL, Kirwin JL, Cotugno MC, et al. Role of pharmacist counseling in preventing adverse drug events after hospitalization. Arch Intern Med. Mar. 13. 2006;166(5):565-71. [pmid: 16534045].
69 Shu AD, Stedman MR, Polinski JM, et al. Adherence to osteoporosis medications after patient and physician brief education: post hoc analysis of a randomized controlled trial. Am J Manag Care. Jul. 2009;15(7):417-24. [pmid: 19589009].
70 Simon GE, Ludman EJ, Operskalski BH. Randomized trial of a telephone care management program for outpatients starting antidepressant treatment. Psychiatr Serv. Oct. 2006;57(10):1441-5. [pmid: 17035563].
71 Sledge WH, Brown KE, Levine JM, et al. A randomized trial of primary intensive care to reduce hospital admissions in patients with high utilization of inpatient services. Dis Manag. Dec. 2006;9(6):328-38. [pmid: 17115880].
72 Smith DH, Kramer JM, Perrin N, et al. A randomized trial of direct-to-patient communication to enhance adherence to beta-blocker therapy following myocardial infarction. Arch Intern Med. Mar. 10. 2008;168(5):477-83. discussion 83; quiz 47. [pmid: 18332291].
73 Solomon DK, Portner TS, Bass GE, et al. Clinical and economic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). Sep–Oct. 1998;38(5):574-85. [pmid: 9782691].
74 Gourley GA, Portner TS, Gourley DR, et al. Humanistic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). Sep–Oct. 1998;38(5):586-97. [pmid: 9782692].
75 Stacy JN, Schwartz SM, Ershoff D, et al. Incorporating tailored interactive patient solutions using interactive voice response technology to improve statin adherence: results of a randomized clinical trial in a managed care setting. Popul Health Manag. Oct. 2009;12(5):241-54. [pmid: 19848566].
76 Stuart GW, Laraia MT, Ornstein SM, et al. An interactive voice response system to enhance antidepressant medication compliance. Top Health Inf Manage. Jan–Mar. 2003;24(1):15-20. [pmid: 12674391].
77 Taylor CT, Byrd DC, Krueger K. Improving primary care in rural Alabama with a pharmacy initiative. Am J Health Syst Pharm. Jun. 1. 2003;60(11):1123-9. [pmid: 12816022].
78 Vivian EM. Improving blood pressure control in a pharmacist-managed hypertension clinic. Pharmacotherapy. Dec. 2002;22(12):1533-40. [pmid: 12495164].
79 Waalen J, Bruning AL, Peters MJ, et al. A telephone-based intervention for increasing the use of osteoporosis medication: a randomized controlled trial. Am J Manag Care. Aug. 2009;15(8):e60-70. [pmid: 19659407].
80 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemed J E Health. Oct. 2008;14(8):753-61. [pmid: 18954244].
81 Wakefield BJ, Holman JE, Ray A, et al. Outcomes of a home telehealth intervention for patients with heart failure. J Telemed Telecare. 2009;15(1):46-50. [pmid: 19139220].
82 Wakefield BJ, Holman JE, Ray A, et al. Effectiveness of home telehealth in comorbid diabetes and hypertension: a randomized, controlled trial. Telemed J E Health. May. 2011;17(4):254-61. [pmid: 21476945].
83 Weinberger M, Murray MD, Marrero DG, et al. Effectiveness of pharmacist care for patients with reactive airways disease: a randomized controlled trial. JAMA. Oct. 2. 2002;288(13):1594-602. [pmid: 12350190].
84 Weymiller AJ, Montori VM, Jones LA, et al. Helping patients with type 2 diabetes mellitus make treatment decisions: statin choice randomized trial. Arch Intern Med. May. 28. 2007;167(10):1076-82. [pmid: 17533211].
85 Jones LA, Weymiller AJ, Shah N, et al. Should clinicians deliver decision aids? Further exploration of the statin choice randomized trial results. Med Decis Making. Jul–Aug. 2009;29(4):468-74. [pmid: 19605885].
86 Williams JW Jr, Katon W, Lin EH, et al. The effectiveness of depression care management on diabetes-related outcomes in older patients. Ann Intern Med. Jun. 15. 2004;140(12):1015-24. [pmid: 15197019].
87 Williams LK, Peterson EL, Wells K, et al. A cluster-randomized trial to provide clinicians inhaled corticosteroid adherence information for their patients with asthma. J Allergy Clin Immunol. Aug. 2010;126(2):225-31. 31 e1. 4. [pmid: 20569973].
88 Wilson SR, Strub P, Buist AS, et al. Shared treatment decision making improves adherence and outcomes in poorly controlled asthma. Am J Respir Crit Care Med. Mar. 15. 2010;181(6):566-77. [pmid: 20019345].
89 Wolever RQ, Dreusicke M, Fikkan J, et al. Integrative health coaching for patients with type 2 diabetes: a randomized clinical trial. Diabetes Educ. Jul–Aug. 2010;36(4):629-39. [pmid: 20534872].
90 Zeng F, An JJ, Scully R, et al. The impact of value-based benefit design on adherence to diabetes medications: a propensity score-weighted difference in difference evaluation. Value Health. Sep–Oct. 2010;13(6):846-52. [pmid: 20561344].
91 Zhang Y, Lave JR, Donohue JM, et al. The impact of Medicare Part D on medication adherence among older adults enrolled in Medicare-Advantage products. Med Care. May. 2010;48(5):409-17. [pmid: 20393360].
92 Gould KA. A randomized controlled trial of a discharge nursing intervention to promote self-regulation of care for early discharge interventional cardiology patients. Dimens Crit Care Nurs. Mar–Apr. 2011;30(2):117-25. [pmid: 21307692].