# Comprehensive Evidence Tables

Table D1 Description of intervention and comparison groups

Table D2 Study characteristics, part 1

Table D3 Study characteristics, part 2

Table D4 Intervention’s disease focus, goal, and theoretical model

Table D5 Inclusion and exclusion criteria

Table D6 Key Questions 1–3

Table D7 Key Questions 4–5

Table D8 Participant baseline characteristics

Table D9 Medication adherence outcomes 1

Table D10 Medication adherence outcomes 2

Table D11 Medication adherence outcomes 3

Table D12 Medication adherence outcomes 4

Table D13 Medication adherence outcomes 5

Table D14 Medication adherence outcomes 6

Table D15 Medication adherence subgroup outcomes, part 1

Table D16 Medication adherence subgroup outcomes, part 2

Table D17 Intervention components, part 1

Table D18 Intervention components, part 2

Table D19 Intervention components, part 3

Table D20 Intervention components, part 4

Table D21 Mortality data

Table D22 Morbidity outcomes 1

Table D23 Morbidity outcomes 2

Table D24 Morbidity outcomes 3

Table D25 Morbidity outcomes 4

Table D26 Morbidity outcomes 5

Table D27 Morbidity outcomes 6

Table D28 Morbidity outcome 7

Table D29 Patient satisfaction outcomes 1

Table D30 Patient satisfaction outcomes 2

Table D31 Patient satisfaction outcomes 3

Table D32 Patient satisfaction outcomes 4

Table D33 Patient satisfaction outcomes 5

Table D34 Patient satisfaction outcomes 6

Table D35 Quality of life outcomes 1

Table D36 Quality of life outcomes 2

Table D37 Health utilization outcomes 1

Table D38 Health utilization outcomes 2

Table D39 Health utilization outcomes 3

Table D40 Costs outcomes 1

Table D41 Costs outcomes 2

Table D42 Adverse event outcomes 1

Table D43 Other subgroup outcomes 1

Table D44 Other subgroup outcome 2

Table D45 Other subgroup outcome 3

Table D46 Applicability

Abbreviations
95% CI: 95% confidence interval
AA(s): African-American(s)
ACE: Angiotensin-converting enzyme
AD: Antidepressant
Adj: Adjusted
ANCOVA: Analysis of covariance
aOR: Adjusted odds ratio
Approx: Approximately
Appt(s): Appointment(s)
ARB: Angiotensin receptor blockers
Avg: Average
BL: Baseline
BP: Blood pressure
CAD: Coronary artery disease
CBT: Cognitive behavioral therapy
Chi-sq: Chi-square value
CO: Colorado (Table 1B)
Col: Column
Cont’d: Continued
Couns: Counseling
DBP: Diastolic blood pressure
Diff: Difference
Dl: Deciliter(s)
Dx: Diagnosis
Dz(s): Disease(s)
ED: Emergency Department
Educ: Education/Educational
EP: Endpoint
Gov’t: Government
HbA1C or HA1C: Hemoglobin A1C
HF: Heart failure
Hg: Mercury
HIV: Human immunodeficiency virus
HMO(s): Health maintenance organization(s)
HR(s): Hazards ratio(s)
Hr(s): Hour(s)
HTN: Hypertension
ICS: Inhaled Corticosteroid
Info: Information
LDL: Low-density lipoprotein
LDL-C: Low-density lipoprotein cholesterol
MD(s): Medical doctor(s)/Physician(s)
MEMS: Micro-Electro-Mechanical Systems
Mg(s): Milligram(s)
MI: Myocardial infarction
Mm(s): Millimeter(s)
Mo(s): Month(s)
NA: Not applicable
NP(s): Nurse practitioner(s)
NR, N-RNR: Not reported
NS: Not significant or Not specified
OR: Odds ratio
PA(s): Physician assistant
PCP(s): Primary care provider(s)
Pharma: Pharmaceutical
PRD: Pharmacy refill data
PRN: When necessary (from P.R.N., Latin for “pro re nata”)
RCT: Randomized controlled trial
RN(s): Registered nurse(s)
RR: Risk ratio
Rx(s): Prescription(s)
SBP: Systolic blood pressure
SCL: Symptom Checklist Depression scale
SCr: Serum creatinine
SD: Standard deviation
SE: Standard error
SG1, SG2,…SGN: Subgroup 1, 2,…N
T1, T2,…TN: Time 1, 2,…N
VA: Veterans Administration
Vs.: Versus
Wk(s): Week(s)
Yr(s): Year(s)

## References

1 Bender BG, Apter A, Bogen DK, et al. Test of an interactive voice response intervention to improve adherence to controller medications in adults with asthma. J Am Board Fam Med. Mar–Apr. 2010;23(2):159-65. [pmid: 20207925].
2 Berg J, Dunbar-Jacob J, Sereika SM. An evaluation of a self-management program for adults with asthma. Clin Nurs Res. Aug. 1997;6(3):225-38. [pmid: 9281927].
3 Berger BA, Liang H, Hudmon KS. Evaluation of software-based telephone counseling to enhance medication persistency among patients with multiple sclerosis. J Am Pharm Assoc. 2005. Jul–Aug. 2003;45(4):466-72. [pmid: 16128502].
4 Bogner HR, de Vries HF. Integration of depression and hypertension treatment: a pilot, randomized controlled trial. Ann Fam Med. Jul–Aug. 2008;6(4):295-301. [pmid: 18626028].
5 Bogner HR, de Vries HF. Integrating type 2 diabetes mellitus and depression treatment among African Americans: a randomized controlled pilot trial. Diabetes Educ. Mar–Apr. 2010;36(2):284-92. [pmid: 20040705].
6 Bosworth HB, Olsen MK, Gentry P, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Educ Couns. Apr. 2005;57(1):5-14. [pmid: 15797147].
7 Bosworth HB, Olsen MK, Neary A, et al. Take Control of Your Blood Pressure (TCYB) study: a multifactorial tailored behavioral and educational intervention for achieving blood pressure control. Patient Educ Couns. Mar. 2008;70(3):338-47. [pmid: 18164894].
8 Bosworth HB, Olsen MK, Dudley T, et al. The Take Control of Your Blood pressure (TCYB) study: Study design and methodology. Contemporary Clinical Trials. 2007;28(1):33-47. [pmid: 16996808].
9 Capoccia KL, Boudreau DM, Blough DK, et al. Randomized trial of pharmacist interventions to improve depression care and outcomes in primary care. Am J Health Syst Pharm. Feb. 15. 2004;61(4):364-72. [pmid: 15011764].
10 Carter BL, Ardery G, Dawson JD, et al. Physician and pharmacist collaboration to improve blood pressure control. Arch Intern Med. Nov. 23. 2009;169(21):1996-2002. [pmid: 19933962].
11 Chernew ME, Shah MR, Wegh A, et al. Impact of decreasing copayments on medication adherence within a disease management environment. Health Aff (Millwood). Jan–Feb. 2008;27(1):103-12. [pmid: 18180484].
12 Choudhry NK, Fischer MA, Avorn J, et al. At Pitney Bowes, value-based insurance design cut copayments and increased drug adherence. Health Aff (Millwood). Nov. 2010;29(11):1995-2001. [pmid: 21041738].
13 Choudhry NK, Avorn J, Glynn RJ, et al. Full coverage for preventive medications after myocardial infarction. N Engl J Med. Dec. 1. 2011;365(22):2088-97. [pmid: 22080794].
14 Friedman RH, Kazis LE, Jette A, et al. A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control. Am J Hypertens. Apr. 1996;9(4 Pt 1):285-92. [pmid: 8722429].
15 Fulmer TT, Feldman PH, Kim TS, et al. An intervention study to enhance medication compliance in community-dwelling elderly individuals. J Gerontol Nurs. Aug. 1999;25(8):6-14. [pmid: 10711101].
16 Grant RW, Devita NG, Singer DE, et al. Improving adherence and reducing medication discrepancies in patients with diabetes. Ann Pharmacother. Jul–Aug. 2003;37(7–8):962-9. [pmid: 12841801].
17 Guthrie RM. The effects of postal and telephone reminders on compliance with pravastatin therapy in a national registry: results of the first myocardial infarction risk reduction program. Clin Ther. Jun. 2001;23(6):970-80. [pmid: 11440296].
18 Hoffman L, Enders J, Luo J, et al. Impact of an antidepressant management program on medication adherence. Am J Manag Care. Jan. 2003;9(1):70-80. [pmid: 12549816].
19 Hunt JS, Siemienczuk J, Pape G, et al. A randomized controlled trial of team-based care: impact of physician-pharmacist collaboration on uncontrolled hypertension. J Gen Intern Med. Dec. 2008;23(12):1966-72. [pmid: 18815843].
20 Janson SL, Fahy JV, Covington JK, et al. Effects of individual self-management education on clinical, biological, and adherence outcomes in asthma. Am J Med. Dec. 1. 2003;115(8):620-6. [pmid: 14656614].
21 Janson SL, McGrath KW, Covington JK, et al. Individualized asthma self-management improves medication adherence and markers of asthma control. J Allergy Clin Immunol. Apr. 2009;123(4):840-6. [pmid: 19348923].
22 Johnson SS, Driskell MM, Johnson JL, et al. Transtheoretical model intervention for adherence to lipid-lowering drugs. Dis Manag. Apr. 2006;9(2):102-14. [pmid: 16620196].
23 Johnson SS, Driskell MM, Johnson JL, et al. Efficacy of a transtheoretical model-based expert system for antihypertensive adherence. Dis Manag. Oct. 2006;9(5):291-301. [pmid: 17044763].
24 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve treatment guidelines. Impact on depression in primary care. JAMA. Apr. 5. 1995;273(13):1026-31. [pmid: 7897786].
25 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Arch Gen Psychiatry. Oct. 1996;53(10):924-32. [pmid: 8857869].
26 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: A randomized trial. Arch Gen Psychiatry. 1999;56(12):1109-15. [pmid: 10591288].
27 Katon W, Russo J, Von Korff M, et al. Long-term effects of a collaborative care intervention in persistently depressed primary care patients. J Gen Intern Med. Oct. 2002;17(10):741-8. [pmid: 12390549].
28 Katon W, Rutter C, Ludman EJ, et al. A randomized trial of relapse prevention of depression in primary care. Arch Gen Psychiatry. Mar. 2001;58(3):241-7. [pmid: 11231831].
29 Ludman E, Katon W, Bush T, et al. Behavioural factors associated with symptom outcomes in a primary care-based depression prevention intervention trial. Psychol Med. Aug. 2003;33(6):1061-70. [pmid: 12946090].
30 Von Korff M, Katon W, Rutter C, et al. Effect on disability outcomes of a depression relapse prevention program. Psychosom Med. Nov–Dec. 2003;65(6):938-43. [pmid: 14645770].
31 Lee JK, Grace KA, Taylor AJ. Effect of a pharmacy care program on medication adherence and persistence, blood pressure, and low-density lipoprotein cholesterol: a randomized controlled trial. JAMA. Dec. 6. 2006;296(21):2563-71. [pmid: 17101639].
32 Lin EH, Katon W, Rutter C, et al. Effects of enhanced depression treatment on diabetes self-care. Ann Fam Med. Jan–Feb. 2006;4(1):46-53. [pmid: 16449396].
33 Maciejewski ML, Farley JF, Parker J, et al. Copayment reductions generate greater medication adherence in targeted patients. Health Aff (Millwood). Nov. 2010;29(11):2002-8. [pmid: 21041739].
34 Mann DM, Ponieman D, Montori VM, et al. The Statin Choice decision aid in primary care: a randomized trial. Patient Educ Couns. Jul. 2010;80(1):138-40. [pmid: 19959322].
35 Montori VM, Shah ND, Pencille LJ, et al. Use of a decision aid to improve treatment decisions in osteoporosis: the osteoporosis choice randomized trial. Am J Med. Jun. 2011;124(6):549-56. [pmid: 21605732].
36 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. [pmid: 17502632].
37 Nietert PJ, Tilley BC, Zhao W, et al. Two pharmacy interventions to improve refill persistence for chronic disease medications: a randomized, controlled trial. Med Care. Jan. 2009;47(1):32-40. [pmid: 19106728].
38 Okeke CO, Quigley HA, Jampel HD, et al. Interventions improve poor adherence with once daily glaucoma medications in electronically monitored patients. Ophthalmology. Dec. 2009;116(12):2286-93. [pmid: 19815286].
39 Pearce KA, Love MM, Shelton BJ, et al. Cardiovascular risk education and social support (CaRESS): report of a randomized controlled trial from the Kentucky Ambulatory Network (KAN). J Am Board Fam Med. Jul–Aug. 2008;21(4):269-81. [pmid: 18612053].
40 Powell KM, Edgren B. Failure of educational videotapes to improve medication compliance in a health maintenance organization. Am J Health Syst Pharm. Oct. 15. 1995;52(20):2196-9. [pmid: 8564589].
41 Pyne JM, Fortney JC, Curran GM, et al. Effectiveness of collaborative care for depression in human immunodeficiency virus clinics. Arch Intern Med. Jan. 10. 2011;171(1):23-31. [pmid: 21220657].
42 Rich MW, Gray DB, Beckham V, et al. Effect of a multidisciplinary intervention on medication compliance in elderly patients with congestive heart failure. Am J Med. Sep. 1996;101(3):270-6. [pmid: 8873488].
43 Rickles NM, Svarstad BL, Statz-Paynter JL, et al. Pharmacist telemonitoring of antidepressant use: effects on pharmacist-patient collaboration. J Am Pharm Assoc. 2005. May–Jun. 2003;45(3):344-53. [pmid: 15991756].
44 Ross SE, Moore LA, Earnest MA, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. May. 14. 2004;6(2):e12. [pmid: 15249261].
45 Rudd P, Miller NH, Kaufman J, et al. Nurse management for hypertension. A systems approach. Am J Hypertens. Oct. 2004;17(10):921-7. [pmid: 15485755].
46 Rudd RE, Blanch DC, Gall V, et al. A randomized controlled trial of an intervention to reduce low literacy barriers in inflammatory arthritis management. Patient Educ Couns. Jun. 2009;75(3):334-9. [pmid: 19345053].
47 Schaffer SD, Tian L. Promoting adherence: effects of theory-based asthma education. Clin Nurs Res. Feb. 2004;13(1):69-89. [pmid: 14768768].
48 Schectman G, Hiatt J, Hartz A. Telephone contacts do not improve adherence to niacin or bile acid sequestrant therapy. Ann Pharmacother. Jan. 1994;28(1):29-35. [pmid: 8123955].
49 Schneider PJ, Murphy JE, Pedersen CA. Impact of medication packaging on adherence and treatment outcomes in older ambulatory patients. J Am Pharm Assoc. 2008. Jan–Feb. 2003;48(1):58-63. [pmid: 18192132].
50 Schnipper JL, Kirwin JL, Cotugno MC, et al. Role of pharmacist counseling in preventing adverse drug events after hospitalization. Arch Intern Med. Mar. 13. 2006;166(5):565-71. [pmid: 16534045].
51 Simon GE, Ludman EJ, Operskalski BH. Randomized trial of a telephone care management program for outpatients starting antidepressant treatment. Psychiatr Serv. Oct. 2006;57(10):1441-5. [pmid: 17035563].
52 Sledge WH, Brown KE, Levine JM, et al. A randomized trial of primary intensive care to reduce hospital admissions in patients with high utilization of inpatient services. Dis Manag. Dec. 2006;9(6):328-38. [pmid: 17115880].
53 Smith DH, Kramer JM, Perrin N, et al. A randomized trial of direct-to-patient communication to enhance adherence to beta-blocker therapy following myocardial infarction. Arch Intern Med. Mar. 10. 2008;168(5):477-83. discussion 83; quiz 47. [pmid: 18332291].
54 Solomon DK, Portner TS, Bass GE, et al. Clinical and economic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). Sep–Oct. 1998;38(5):574-85. [pmid: 9782691].
55 Gourley GA, Portner TS, Gourley DR, et al. Humanistic outcomes in the hypertension and COPD arms of a multicenter outcomes study. J Am Pharm Assoc (Wash). Sep–Oct. 1998;38(5):586-97. [pmid: 9782692].
56 Stacy JN, Schwartz SM, Ershoff D, et al. Incorporating tailored interactive patient solutions using interactive voice response technology to improve statin adherence: results of a randomized clinical trial in a managed care setting. Popul Health Manag. Oct. 2009;12(5):241-54. [pmid: 19848566].
57 Taylor CT, Byrd DC, Krueger K. Improving primary care in rural Alabama with a pharmacy initiative. Am J Health Syst Pharm. Jun. 1. 2003;60(11):1123-9. [pmid: 12816022].
58 Vivian EM. Improving blood pressure control in a pharmacist-managed hypertension clinic. Pharmacotherapy. Dec. 2002;22(12):1533-40. [pmid: 12495164].
59 Waalen J, Bruning AL, Peters MJ, et al. A telephone-based intervention for increasing the use of osteoporosis medication: a randomized controlled trial. Am J Manag Care. Aug. 2009;15(8):e60-70. [pmid: 19659407].
60 Wakefield BJ, Holman JE, Ray A, et al. Effectiveness of home telehealth in comorbid diabetes and hypertension: a randomized, controlled trial. Telemed J E Health. May. 2011;17(4):254-61. [pmid: 21476945].
61 Weinberger M, Murray MD, Marrero DG, et al. Effectiveness of pharmacist care for patients with reactive airways disease: a randomized controlled trial. JAMA. Oct. 2. 2002;288(13):1594-602. [pmid: 12350190].
62 Weymiller AJ, Montori VM, Jones LA, et al. Helping patients with type 2 diabetes mellitus make treatment decisions: statin choice randomized trial. Arch Intern Med. May. 28. 2007;167(10):1076-82. [pmid: 17533211].
63 Jones LA, Weymiller AJ, Shah N, et al. Should clinicians deliver decision aids? Further exploration of the statin choice randomized trial results. Med Decis Making. Jul–Aug. 2009;29(4):468-74. [pmid: 19605885].
64 Williams LK, Peterson EL, Wells K, et al. A cluster-randomized trial to provide clinicians inhaled corticosteroid adherence information for their patients with asthma. J Allergy Clin Immunol. Aug. 2010;126(2):225-31. 31 e1. 4. [pmid: 20569973].
65 Wilson SR, Strub P, Buist AS, et al. Shared treatment decision making improves adherence and outcomes in poorly controlled asthma. Am J Respir Crit Care Med. Mar. 15. 2010;181(6):566-77. [pmid: 20019345].
66 Wolever RQ, Dreusicke M, Fikkan J, et al. Integrative health coaching for patients with type 2 diabetes: a randomized clinical trial. Diabetes Educ. Jul–Aug. 2010;36(4):629-39. [pmid: 20534872].
67 Zhang Y, Lave JR, Donohue JM, et al. The impact of Medicare Part D on medication adherence among older adults enrolled in Medicare-Advantage products. Med Care. May. 2010;48(5):409-17. [pmid: 20393360].
68 Powers BJ, Danus S, Grubber JM, et al. The effectiveness of personalized coronary heart disease and stroke risk communication. Am Heart J. 2011;161(4):673-80. [pmid: 21473965].