# Excluded Studies

Studies excluded at the full text level.

The list below includes 637 studies excluded at the full text level for the following reasons:

X1 Intervention not related to medication adherence
X2 No intervention
X3 Non-US
X4 Infectious conditions, HIV-related, mental illness involving psychosis, sub abuse
X5 Ineligible study design
X6 Ineligible setting
X7 Ineligible comparator
X8 Sample size <40
X9 Ineligible publication type
X10 Pre-1994
X12 No medication adherence outcomes
X13 Ineligible population
X14 Ineligible systematic review

Studies excluded for high risk of bias (N = 24) are listed in Appendix E.

| Study Information | Exclusion Code
1 | Implementation of treatment protocols in the Diabetes Control and Complications Trial. Diabetes Care. 1995 Mar;18(3):361–76. | X1
2 | Testing combined pharmacotherapies and behavioral interventions for alcohol dependence (the COMBINE study): a pilot feasibility study. Alcohol Clin Exp Res. 2003 Jul;27(7):1123–31. | X13
3 | Abrahams N, Jewkes R, Lombard C, Mathews S, Campbell J, Meel B. Impact of telephonic psycho-social support on adherence to post-exposure prophylaxis (PEP) after rape. AIDS Care. 2010 Oct;22(10):1173–81. | X3
4 | Abraira C, Colwell JA, Nuttall FQ, Sawin CT, Nagel NJ, Comstock JP, et al. Veterans Affairs Cooperative Study on glycemic control and complications in type II diabetes (VA CSDM). Results of the feasibility trial. Veterans Affairs Cooperative Study in Type II Diabetes. Diabetes Care. 1995 Aug;18(8):1113–23. | X1
5 | Adler DA, Bungay KM, Wilson IB, Pei Y, Supran S, Peckham E, et al. The impact of a pharmacist intervention on 6-month outcomes in depressed primary care patients. Gen Hosp Psychiatry. 2004 May–Jun;26(3):199–209. | X12
6 | Akerblad AC, Bengtsson F, Ekselius L, von Knorring L. Effects of an educational compliance enhancement programme and therapeutic drug monitoring on treatment adherence in depressed patients managed by general practitioners. Int Clin Psychopharmacol. 2003 Nov;18(6):347–54. | X3
7 | Al-aqeel S, Al-sabhan J. Strategies for improving adherence to antiepileptic drug treatment in patients with epilepsy. Cochrane Database of Systematic Reviews. 2011(1). | X14
8 | Al-Eidan FA, McElnay JC, Scott MG, McConnell JB. Management of Helicobacter pylori eradication--the influence of structured counselling and follow-up. Br J Clin Pharmacol. 2002 Feb;53(2):163–71. | X3
9 | Al-Rashed SA, Wright DJ, Roebuck N, Sunter W, Chrystyn H. The value of inpatient pharmaceutical counselling to elderly patients prior to discharge. Br J Clin Pharmacol. 2002 Dec;54(6):657–64. | X3
10 | Altice FL, Maru DS, Bruce RD, Springer SA, Friedland GH. Superiority of directly administered antiretroviral therapy over self-administered therapy among HIV-infected drug users: a prospective, randomized, controlled trial. Clin Infect Dis. 2007 Sep 15;45(6):770–8. | X4
11 | Altice FL, Mezger JA, Hodges J, Bruce RD, Marinovich A, Walton M, et al. Developing a directly administered antiretroviral therapy intervention for HIV-infected drug users: implications for program replication. Clin Infect Dis. 2004 Jun 1;38 Suppl 5:S376–87. | X4
12 | Amado Guirado E, Pujol Ribera E, Pacheco Huergo V, Borras JM. Knowledge and adherence to antihypertensive therapy in primary care: results of a randomized trial. Gac Sanit. 2011 Jan–Feb;25(1):62–7. | X3
13 | Aminzadeh F. Adherence to recommendations of community-based comprehensive geriatric assessment programmes. Age Ageing. 2000 Sep;29(5):401–7. | X12
14 | Anastasio GD, Little JM, Jr., Robinson MD, Pettice YL, Leitch BB, Norton HJ. Impact of compliance and side effects on the clinical outcome of patients treated with oral erythromycin. Pharmacotherapy. 1994 Mar–Apr;14(2):229–34. | X1
15 | Andersen BL, Farrar WB, Golden-Kreutz DM, Glaser R, Emery CF, Crespin TR, et al. Psychological, behavioral, and immune changes after a psychological intervention: a clinical trial. J Clin Oncol. 2004 Sep 1;22(17):3570–80. | X13
16 | Andersen BL, Yang HC, Farrar WB, Golden-Kreutz DM, Emery CF, Thornton LM, et al. Psychologic intervention improves survival for breast cancer patients: a randomized clinical trial. Cancer. 2008 Dec 15;113(12):3450–8. | X1
17 | Andrejak M, Genes N, Vaur L, Poncelet P, Clerson P, Carre A. Electronic pill-boxes in the evaluation of antihypertensive treatment compliance: comparison of once daily versus twice daily regimen. Am J Hypertens. 2000 Feb;13(2):184–90. | X3
18 | Anton RF, Moak DH, Waid LR, Latham PK, Malcolm RJ, Dias JK. Naltrexone and cognitive behavioral therapy for the treatment of outpatient alcoholics: results of a placebo-controlled trial. A J Psychiatry. 1999 Nov;156(11):1758–64. | X4
19 | Antonicelli R, Mazzanti I, Abbatecola AM, Parati G. Impact of home patient telemonitoring on use of beta-blockers in congestive heart failure. Drugs Aging. 2010 Oct 1;27(10):801–5. | X12
20 | Atherton-Naji A, Hamilton R, Riddle W, Naji S. Improving adherence to antidepressant drug treatment in primary care: a feasibility study for a randomized controlled trial of educational intervention. Primary Care Psychia. 2001 Jun;7(2):61–7. | X3
21 | Aubert RE, Fulop G, Xia F, Thiel M, Maldonato D, Woo C. Evaluation of a depression health management program to improve outcomes in first or recurrent episode depression. Am J Manag Care. 2003 May;9(5):374–80. | X5
22 | Audet MC, Moreau M, Koltun WD, Waldbaum AS, Shangold G, Fisher AC, et al. Evaluation of contraceptive efficacy and cycle control of a transdermal contraceptive patch vs an oral contraceptive: a randomized controlled trial. JAMA. 2001 May 9;285(18):2347–54. | X1
23 | Babarykin D, Adamsone I, Amerika D, Spudass A, Moisejev V, Berzina N, et al. Calcium-enriched bread for treatment of uremic hyperphosphatemia. J Ren Nutr. 2004 Jul;14(3):149–56. | X1
24 | Bailey B, Carney SL, Gillies AA, Smith AJ. Antihypertensive drug treatment: a comparison of usual care with self blood pressure measurement. J Hum Hypertens. 1999 Feb;13(2):147–50. | X3
25 | Ball JR, Mitchell PB, Corry JC, Skillecorn A, Smith M, Malhi GS. A randomized controlled trial of cognitive therapy for bipolar disorder: focus on long-term change. J Clin Psychiatry. 2006 Feb;67(2):277–86. | X4
26 | Bambauer KZ, Adams AS, Zhang F, Minkoff N, Grande A, Weisblatt R, et al. Physician alerts to increase antidepressant adherence: fax or fiction? Arch Intern Med. 2006 Mar 13;166(5):498–504. | X5
27 | Bara-Carril N, Williams CJ, Pombo-Carril MG, Reid Y, Murray K, Aubin S, et al. A preliminary investigation into the feasibility and efficacy of a CD-ROM-based cognitive-behavioral self-help intervention for bulimia nervosa. Int J Eat Disord. 2004 May;35(4):538–48. | X1
28 | Barnett CW, Nykamp D, Ellington AM. Patient-guided counseling in the community pharmacy setting. J Am Pharm Assoc (Wash). 2000 Nov–Dec;40(6):765–72. | X13
29 | Barnett PG, Sorensen JL, Wong W, Haug NA, Hall SM. Effect of incentives for medication adherence on health care use and costs in methadone patients with HIV. Drug Alcohol Depend. 2009 Feb 1;100(1–2):115–21. | X4
30 | Barrett B, Brown R, Rakel D, Mundt M, Bone K, Barlow S, et al. Echinacea for treating the common cold: a randomized trial. Ann Intern Med. 2010 Dec 21;153(12):769–77. | X1
31 | Barron TI, Bennett K, Feely J. A competing risks prescription refill model of compliance and persistence. Value Health. 2010 Sep–Oct;13(6):796–804. | X2
32 | Barrowclough C, Haddock G, Wykes T, Beardmore R, Conrod P, Craig T, et al. Integrated motivational interviewing and cognitive behavioural therapy for people with psychosis and comorbid substance misuse: randomised controlled trial. BMJ. 2010;341:c6325. | X1
33 | Beaucage K, Lachance-Demers H, Ngo TT, Vachon C, Lamarre D, Guevin JF, et al. Telephone follow-up of patients receiving antibiotic prescriptions from community pharmacies. Am J Health Syst Pharm. 2006 Mar 15;63(6):557–63. | X3
34 | Begley S, Livingstone C, Hodges N. Impact of domiciliary pharmacy visits on medication management in an elderly population. Int J Pharm Pract. 1997:111–21. | X3
35 | Bennett H, Laird K, Margolius D, Ngo V, Thom DH, Bodenheimer T. The effectiveness of health coaching, home blood pressure monitoring, and home-titration in controlling hypertension among low-income patients: protocol for a randomized controlled trial. BMC public health. 2009;9:456. | X12
36 | Bentz L, Enel P, Dunais B, Durant J, Poizot-Martin I, Tourette-Turgis C, et al. Evaluating counseling outcome on adherence to prophylaxis and follow-up after sexual HIV-risk exposure: a randomized controlled trial. AIDS Care. 2010 Dec;22(12):1509–16. | X3
37 | Berg J, Dunbar-Jacob J, Rohay JM. Compliance with inhaled medications: the relationship between diary and electronic monitor. nn Behav Med. 1998 Winter;20(1):36–8. | X1
38 | Berg KM, Mouriz J, Li X, Duggan E, Goldberg U, Arnsten JH. Rationale, design, and sample characteristics of a randomized controlled trial of directly observed antiretroviral therapy delivered in methadone clinics. Contemporary clinical trials. 2009 Sep;30(5):481–9. | X12
39 | Berger S, Schad T, von Wyl V, Ehlert U, Zellweger C, Furrer H, et al. Effects of cognitive behavioral stress management on HIV-1 RNA, CD4 cell counts and psychosocial parameters of HIV-infected persons. AIDS. 2008 Mar 30;22(6):767–75. | X3
40 | Berkowitz K, Peters R, Kjos SL, Goico J, Marroquin A, Dunn ME, et al. Effect of troglitazone on insulin sensitivity and pancreatic beta-cell function in women at high risk for NIDDM. Diabetes. 1996 Nov;45(11):1572–9. | X1
41 | Berrien VM, Salazar JC, Reynolds E, McKay K. Adherence to antiretroviral therapy in HIV-infected pediatric patients improves with home-based intensive nursing intervention. Aids Patient Care STDS. 2004 Jun;18(6):355–63. | X13
42 | Beswick AD, Rees K, West RR, Taylor FC, Burke M, Griebsch I, et al. Improving uptake and adherence in cardiac rehabilitation: literature review (Structured abstract). J Adv Nurs. 2005(5):538–55. | X1
43 | Billault B, Degoulet P, Devries C, Plouin PF, Chatellier G, Menard J. Use of a standardized personal medical record by patients with hypertension: a randomized controlled prospective trial. MD Comput. 1995 Jan–Feb;12(1):31–5. | X3
44 | Bocchi EA, Cruz F, Guimaraes G, Pinho Moreira LF, Issa VS, Ayub Ferreira SM, et al. Long-term prospective, randomized, controlled study using repetitive education at six-month intervals and monitoring for adherence in heart failure outpatients: the REMADHE trial. Circulation Heart failure. 2008 Jul;1(2):115–24. | X3
45 | Boissel JP, Meillard O, Perrin-Fayolle E, Ducruet T, Alamercery Y, Sassano P, et al. Comparison between a bid and a tid regimen: improved compliance with no improved antihypertensive effect. The EOL Research Group. Eur J Clin Pharmacol. 1996;50(1–2):63–7. | X3
46 | Borah B, Sacco P, Zarotsky V. Predictors of adherence among Alzheimer's disease patients receiving oral therapy. Curr Med Res Opin. 2010 Aug;26(8):1957–65. | X4
47 | Bosch-Capblanch X, Abba K, Prictor M, Garner P. Contracts between patients and healthcare practitioners for improving patients' adherence to treatment, prevention and health promotion activities. Cochrane Database of Systematic Reviews. 2007(2). | X14
48 | Bosworth HB, Olsen MK, Grubber JM, Neary AM, Orr MM, Powers BJ, et al. Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. 2009 Nov 17;151(10):687–95. | X12
49 | Boudreau DM, Capoccia KL, Sullivan SD, Blough DK, Ellsworth AJ, Clark DL, et al. Collaborative care model to improve outcomes in major depression. Ann Pharmacother. 2002 Apr;36(4):585–91. | X9
50 | Bradley-Ewing A, Thomson D, Pinkston M, Goggin KJ. A qualitative examination of the indirect effects of modified directly observed therapy on health behaviors other than adherence. Aids Patient Care STDS. 2008 Aug;22(8):663–8. | X5
51 | Braun E, Baidusi A, Alroy G, Azzam ZS. Telephone follow-up improves patients satisfaction following hospital discharge. Eur J Intern Med. 2009 Mar;20(2):221–5. | X3
52 | Braverman J, Dedier J. Predictors of medication adherence for African American patients diagnosed with hypertension. Ethn Dis. 2009 Autumn;19(4):396–400. | X5
53 | Bright JI, Baker KD, Neimeyer RA. Professional and paraprofessional group treatments for depression: a comparison of cognitive-behavioral and mutual support interventions. J Consult Clin Psychol. 1999 Aug;67(4):491–501. | X1
54 | Brown I, Sheeran P, Reuber M. Enhancing antiepileptic drug adherence: a randomized controlled trial. Epilepsy & behavior : E&B. 2009 Dec;16(4):634–9. | X3
55 | Brown RL, Dimond AR, Hulisz D, Saunders LA, Bobula JA. Pharmacoepidemiology of potential alcohol-prescription drug interactions among primary care patients with alcohol-use disorders. J Am Pharm Assoc (2003). 2007 Mar–Apr;47(2):135–9. | X12
56 | Brus HL, van de Laar MA, Taal E, Rasker JJ, Wiegman O. Effects of patient education on compliance with basic treatment regimens and health in recent onset active rheumatoid arthritis. Ann Rheum Dis. 1998 Mar;57(3):146–51. | X3
57 | Buchkremer G, Klingberg S, Holle R, Schulze Monking H, Hornung WP. Psychoeducational psychotherapy for schizophrenic patients and their key relatives or care-givers: results of a 2-year follow-up. Acta Psychiatr Scand. 1997 Dec;96(6):483–91. | X4
58 | Buckley Brian S, Byrne Mary C, Smith Susan M. Service organisation for the secondary prevention of ischaemic heart disease in primary care. Cochrane Database of Systematic Reviews. 2010(3). | X1
59 | Buist DS, LaCroix AZ, Black DM, Harris F, Blank J, Ensrud K, et al. Inclusion of older women in randomized clinical trials: factors associated with taking study medication in the fracture intervention trial. J Am Geriatr Soc. 2000 Sep;48(9):1126–31. | X1
60 | Burnett-Bowie SA, McKay EA, Lee H, Leder BZ. Effects of aromatase inhibition on bone mineral density and bone turnover in older men with low testosterone levels. J Clin Endocrinol Metab. 2009 Dec;94(12):4785–92. | X1
61 | Busch AB, Wilder CM, Van Dorn RA, Swartz MS, Swanson JW. Changes in guideline-recommended medication possession after implementing Kendra's law in New York. Psychiatr Serv. 2010 Oct;61(10):1000–5. | X4
62 | Bushnell FK, Forbes B, Goffaux J, Dietrich M, Wells N. Smoking cessation in military personnel. Mil Med. 1997 Nov;162(11):715–9. | X1
63 | Cahn P, Vibhagool A, Schechter M, Soto-Ramirez L, Carosi G, Smaill F, et al. Predictors of adherence and virologic outcome in HIV-infected patients treated with abacavir- or indinavir-based triple combination HAART also containing lamivudine/zidovudine. Curr Med Res Opin. 2004 Jul;20(7):1115–23. | X3
64 | Callan JA, Howland RH, Puskar K. Using computers and the Internet for psychiatric nursing intervention. J Psychosoc Nurs Ment Health Serv. 2009 Jan;47(1):13–4. | X5
65 | Cano A, Tarin JJ, Duenas JL. Two-year prospective, randomized trial comparing an innovative twice-a-week progestin regimen with a continuous combined regimen as postmenopausal hormone therapy. Fertil Steril. 1999 Jan;71(1):129–36. | X1
66 | Carlbring P, Gunnarsdottir M, Hedensjo L, Andersson G, Ekselius L, Furmark T. Treatment of social phobia: randomised trial of internet-delivered cognitive-behavioural therapy with telephone support. Br J Psychiatry. 2007 Feb;190:123–8. | X1
67 | Carney RM, Freedland KE, Rubin EH, Rich MW, Steinmeyer BC, Harris WS. Omega-3 augmentation of sertraline in treatment of depression in patients with coronary heart disease: a randomized controlled trial. JAMA. 2009 Oct 21;302(15):1651–7. | X1
68 | Carrico AW, Antoni MH, Duran RE, Ironson G, Penedo F, Fletcher MA, et al. Reductions in depressed mood and denial coping during cognitive behavioral stress management with HIV-Positive gay men treated with HAART. nn Behav Med. 2006 Apr;31(2):155–64. | X4
69 | Carter BL, Doucette WR, Franciscus CL, Ardery G, Kluesner KM, Chrischilles EA. Deterioration of blood pressure control after discontinuation of a physician-pharmacist collaborative intervention. Pharmacotherapy. 2010 Mar;30(3):228–35. | X12
70 | Cartledge Hoff A, Haaga DA. Effects of an education program on radiation oncology patients and families. J Psychosoc Oncol. 2005;23(4):61–79. | X1
71 | Casebeer LL, Klapow JC, Centor RM, Stafford MA, Renkl LA, Mallinger AP, et al. An intervention to increase physicians' use of adherence-enhancing strategies in managing hypercholesterolemic patients. Acad Med. 1999 Dec;74(12):1334–9. | X12
72 | Cegala DJ, Marinelli T, Post D. The effects of patient communication skills training on compliance. Arch Fam Med. 2000 Jan;9(1):57–64. | X12
73 | Chaisson RE, Barnes GL, Hackman J, Watkinson L, Kimbrough L, Metha S, et al. A randomized, controlled trial of interventions to improve adherence to isoniazid therapy to prevent tuberculosis in injection drug users. Am J Med. 2001 Jun 1;110(8):610–5. | X4
74 | Chan DC, Watts GF, Gan SK, Ooi EM, Barrett PH. Effect of ezetimibe on hepatic fat, inflammatory markers, and apolipoprotein B-100 kinetics in insulin-resistant obese subjects on a weight loss diet. Diabetes Care. 2010 May;33(5):1134–9. | X1
75 | Chan V, Cooke CE. Pharmacotherapy after myocardial infarction: disease management versus usual care. Am J Manag Care. 2008 Jun;14(6):352–8. | X5
76 | Chang MC, Chang YC, Chiou JF, Tsou TS, Lin CC. Overcoming patient-related barriers to cancer pain management for home care patients. A pilot study. Cancer Nurs. 2002 Dec;25(6):470–6. | X8
77 | Charles T, Quinn D, Weatherall M, Aldington S, Beasley R, Holt S. An audiovisual reminder function improves adherence with inhaled corticosteroid therapy in asthma. J Allergy Clin Immunol. 2007 Apr;119(4):811–6. | X3
78 | Chen E, Cole SW, Kato PM. A review of empirically supported psychosocial interventions for pain and adherence outcomes in sickle cell disease (Provisional abstract). J Pediatr Psychol. 2004(3):197–209. | X1
79 | Chen SY, Sheu S, Chang CS, Wang TH, Huang MS. The effects of the self-efficacy method on adult asthmatic patient self-care behavior. The journal of nursing research : JNR. 2010 Dec;18(4):266–74. | X3
80 | Cheng EM, Cunningham WE, Towfighi A, Sanossian N, Bryg RJ, Anderson TL, et al. Randomized, controlled trial of an intervention to enable stroke survivors throughout the los angeles county safety net to "stay with the guidelines". Circulation: Cardiovascular Quality and Outcomes. 2011;4(2):229–34. | X12
81 | Chervin RD, Theut S, Bassetti C, Aldrich MS. Compliance with nasal CPAP can be improved by simple interventions. Sleep. 1997 Apr;20(4):284–9. | X8
82 | Chiou PY, Kuo BI, Lee MB, Chen YM, Chuang P, Lin LC. A programme of symptom management for improving quality of life and drug adherence in AIDS/HIV patients. J Adv Nurs. 2006 Jul;55(2):169–79. | X3
83 | Chisholm MA, Mulloy LL, Jagadeesan M, DiPiro JT. Impact of clinical pharmacy services on renal transplant patients' compliance with immunosuppressive medications. Clin Transplant. 2001 Oct;15(5):330–6. | X8
84 | Chisholm-Burns MA, Kim Lee J, Spivey CA, Slack M, Herrier RN, Hall-Lipsy E, et al. US pharmacists' effect as team members on patient care: systematic review and meta-analyses (Provisional abstract). Med Care. 2010(10):923–33. | X1
85 | Choe HM, Stevenson JG, Streetman DS, Heisler M, Sandiford CJ, Piette JD. Impact of patient financial incentives on participation and outcomes in a statin pill-splitting program. Am J Manag Care. 2007 Jun;13(6 Part 1):298–304. | X1
86 | Christensen A, Christrup LL, Fabricius PE, Chrostowska M, Wronka M, Narkiewicz K, et al. The impact of an electronic monitoring and reminder device on patient compliance with antihypertensive therapy: a randomized controlled trial. J Hypertens. 2010 Jan;28(1):194–200. | X3
87 | Christensen DB, Roth M, Trygstad T, Byrd J. Evaluation of a pilot medication therapy management project within the North Carolina State Health Plan. J Am Pharm Assoc (2003). 2007 Jul–Aug;47(4):471–83. | X5
88 | Claiborne N. Effectiveness of a care coordination model for stroke survivors: a randomized study. Health Soc Work. 2006 May;31(2):87–96. | X8
89 | Clarkin JF, Carpenter D, Hull J, Wilner P, Glick I. Effects of psychoeducational intervention for married patients with bipolar disorder and their spouses. Psychiatr Serv. 1998 Apr;49(4):531–3. | X4
90 | Claxton A, de Klerk E, Parry M, Robinson JM, Schmidt ME. Patient compliance to a new enteric-coated weekly formulation of fluoxetine during continuation treatment of major depressive disorder. J Clin Psychiatry. 2000 Dec;61(12):928–32. | X3
91 | Clowes JA, Peel NF, Eastell R. The impact of monitoring on adherence and persistence with antiresorptive treatment for postmenopausal osteoporosis: a randomized controlled trial. J Clin Endocrinol Metab. 2004 Mar;89(3):1117–23. | X3
92 | Cockburn J, Thompson SC, Marks R, Jolley D, Schofield P, Hill D. Behavioural dynamics of a clinical trial of sunscreens for reducing solar keratoses in Victoria, Australia. J Epidemiol Community Health. 1997 Dec;51(6):716–21. | X3
93 | Cohen HW, Shmukler C, Ullman R, Rivera CM, Walker EA. Measurements of medication adherence in diabetic patients with poorly controlled HbA(1c). Diabet Med. 2010 Feb;27(2):210–6. | X12
94 | Colombo J. Establishing pharmaceutical care services in an HIV clinic. J Am Pharm Assoc (Wash). 1997 Sep–Oct;NS37(5):581–92; quiz 93–4. | X4
95 | Cook PF, Emiliozzi S, Waters C, El Hajj D. Effects of telephone counseling on antipsychotic adherence and emergency department utilization. Am J Manag Care. 2008 Dec;14(12):841–6. | X5
96 | Cooper A, Drake J, Brankin E. Treatment persistence with once-monthly ibandronate and patient support vs. once-weekly alendronate: results from the PERSIST study. Int J Clin Pract. 2006 Aug;60(8):896–905. | X3
97 | Cooper TV, DeBon MW, Stockton M, Klesges RC, Steenbergh TA, Sherrill-Mittleman D, et al. Correlates of adherence with transdermal nicotine. Addict Behav. 2004 Nov;29(8):1565–78. | X4
98 | Cosman F, Borges JL, Curiel MD. Clinical evaluation of novel bisphosphonate dosing regimens in osteoporosis: the role of comparative studies and implications for future studies. Clin Ther. 2007 Jun;29(6):1116–27. | X5
99 | Cote J, Bowie DM, Robichaud P, Parent JG, Battisti L, Boulet LP. Evaluation of two different educational interventions for adult patients consulting with an acute asthma exacerbation. Am J Respir Crit Care Med. 2001 May;163(6):1415–9. | X3
100 | Cote J, Cartier A, Robichaud P, Boutin H, Malo JL, Rouleau M, et al. Influence on asthma morbidity of asthma education programs based on self-management plans following treatment optimization. Am J Respir Crit Care Med. 1997 May;155(5):1509–14. | X3
101 | Cotte FE, Fardellone P, Mercier F, Gaudin AF, Roux C. Adherence to monthly and weekly oral bisphosphonates in women with osteoporosis. Osteoporos Int. 2010 Jan;21(1):145–55. | X5
102 | Cramer J, Rosenheck R, Kirk G, Krol W, Krystal J. Medication compliance feedback and monitoring in a clinical trial: predictors and outcomes. Value Health. 2003 Sep–Oct;6(5):566–73. | X1
103 | Cramer J, Vachon L, Desforges C, Sussman NM. Dose frequency and dose interval compliance with multiple antiepileptic medications during a controlled clinical trial. Epilepsia. 1995 Nov;36(11):1111–7. | X3
104 | Criswell TJ, Weber CA, Xu Y, Carter BL. Effect of self-efficacy and social support on adherence to antihypertensive drugs. Pharmacotherapy. 2010 May;30(5):432–41. | X5
105 | Dahlof B, Devereux RB, Julius S, Kjeldsen SE, Beevers G, de Faire U, et al. Characteristics of 9194 patients with left ventricular hypertrophy: the LIFE study. Losartan Intervention For Endpoint Reduction in Hypertension. Hypertension. 1998 Dec;32(6):989–97. | X1
106 | Dangour AD, Allen E, Elbourne D, Fasey N, Fletcher AE, Hardy P, et al. Effect of 2-y n-3 long-chain polyunsaturated fatty acid supplementation on cognitive function in older people: a randomized, double-blind, controlled trial. Am J Clin Nutr. 2010 Jun;91(6):1725–32. | X1
107 | Das M, Santos D, Matheson T, Santos GM, Chu P, Vittinghoff E, et al. Feasibility and acceptability of a phase II randomized pharmacologic intervention for methamphetamine dependence in high-risk men who have sex with men. AIDS. 2010 Apr 24;24(7):991–1000. | X1
108 | Datto CJ, Thompson R, Horowitz D, Disbot M, Oslin DW. The pilot study of a telephone disease management program for depression. Gen Hosp Psychiatry. 2003 May–Jun;25(3):169–77. | X7
109 | Davis CE, Applegate WB, Gordon DJ, Curtis RC, McCormick M. An empirical evaluation of the placebo run-in. Control Clin Trials. 1995 Feb;16(1):41–50. | X1
110 | De Bleser L, Matteson M, Dobbels F, Russell C, De Geest S. Interventions to improve medication-adherence after transplantation: a systematic review (Structured abstract). Transpl Int. 2009(8):780–97. | X14
111 | de Bruin M, Hospers HJ, van Breukelen GJ, Kok G, Koevoets WM, Prins JM. Electronic monitoring-based counseling to enhance adherence among HIV-infected patients: a randomized controlled trial. Health Psychol. 2010 Jul;29(4):421–8. | X3
112 | de Castro MS, Fuchs FD, Santos MC, Maximiliano P, Gus M, Moreira LB, et al. Pharmaceutical care program for patients with uncontrolled hypertension. Report of a double-blind clinical trial with ambulatory blood pressure monitoring. Am J Hypertens. 2006 May;19(5):528–33. | X3
113 | de Lusignan S, Wells S, Johnson P, Meredith K, Leatham E. Compliance and effectiveness of 1 year's home telemonitoring. The report of a pilot study of patients with chronic heart failure. Eur J Heart Fail. 2001 Dec;3(6):723–30. | X12
114 | De Wildt WA, Schippers GM, Van Den Brink W, Potgieter AS, Deckers F, Bets D. Does psychosocial treatment enhance the efficacy of acamprosate in patients with alcohol problems? Alcohol Alcohol. 2002 Jul–Aug;37(4):375–82. | X1
115 | de Wit R, van Dam F, Loonstra S, Zandbelt L, van Buuren A, van der Heijden K, et al. Improving the quality of pain treatment by a tailored pain education programme for cancer patients in chronic pain. Eur J Pain. 2001;5(3):241–56. | X1
116 | Deitz DK, Cook RF, Hendrickson A. Preventing prescription drug misuse: field test of the SmartRx Web program. Subst Use Misuse. 2011;46(5):678–86. | X1
117 | Delaronde S, Peruccio DL, Bauer BJ. Improving asthma treatment in a managed care population. Am J Manag Care. 2005 Jun;11(6):361–8. | X1
118 | Delate T, Henderson R. Effect of patient notification of formulary change on formulary adherence. Journal of managed care pharmacy : JMCP. 2005 Jul–Aug;11(6):493–8. | X1
119 | Delmas PD, Vrijens B, Eastell R, Roux C, Pols HA, Ringe JD, et al. Effect of monitoring bone turnover markers on persistence with risedronate treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab. 2007 Apr;92(4):1296–304. | X3
120 | Delp C, Jones J. Communicating information to patients: the use of cartoon illustrations to improve comprehension of instructions. Acad Emerg Med. 1996 Mar;3(3):264–70. | X4
121 | Demyttenaere K, Mesters P, Boulanger B, Dewe W, Delsemme MH, Gregoire J, et al. Adherence to treatment regimen in depressed patients treated with amitriptyline or fluoxetine. J Affect Disord. 2001 Aug;65(3):243–52. | X1
122 | Desplenter FA, Simoens S, Laekeman G. The impact of informing psychiatric patients about their medication: a systematic review (Structured abstract). Pharm World Sci. 2006(6):329–41. | X4
123 | Devine EC. Meta-analysis of the effects of psychoeducational care in adults with asthma (Structured abstract). Res Nurs Health. 1996(5):367–76. | X4
124 | Devine EC, Pearcy J. Meta-analysis of the effects of psychoeducational care in adults with chronic obstructive pulmonary disease (Structured abstract). Patient Educ Couns. 1996(2):167–78. | X14
125 | Devine EC, Reifschneider E. A meta-analysis of the effects of psychoeducational care in adults with hypertension (Structured abstract). Nurs Res. 1995(4):237–45. | X6
126 | Dew MA, Goycoolea JM, Harris RC, Lee A, Zomak R, Dunbar-Jacob J, et al. An internet-based intervention to improve psychosocial outcomes in heart transplant recipients and family caregivers: development and evaluation. J Heart Lung Transplant. 2004 Jun;23(6):745–58. | X5
127 | Dhillon V, Creiger J, Hannan J, Hurst N, Nuki G. The effect of DXA scanning on clinical decision making by general practitioners: a randomized, prospective trial of direct access versus referral to a hospital consultant. Osteoporos Int. 2003 Jun;14(4):326–33. | X3
128 | Diaz E, Levine HB, Sullivan MC, Sernyak MJ, Hawkins KA, Cramer JA, et al. Use of the Medication Event Monitoring System to estimate medication compliance in patients with schizophrenia. J Psychiatry Neurosci. 2001 Sep;26(4):325–9. | X1
129 | Diiorio C, McCarty F, Resnicow K, McDonnell Holstad M, Soet J, Yeager K, et al. Using motivational interviewing to promote adherence to antiretroviral medications: a randomized controlled study. AIDS Care. 2008 Mar;20(3):273–83. | X4
130 | DiIorio C, Resnicow K, McDonnell M, Soet J, McCarty F, Yeager K. Using motivational interviewing to promote adherence to antiretroviral medications: a pilot study. J Assoc Nurses AIDS Care. 2003 Mar–Apr;14(2):52–62. | X8
131 | Doshi JA, Zhu J, Lee BY, Kimmel SE, Volpp KG. Impact of a prescription copayment increase on lipid-lowering medication adherence in veterans. Circulation. 2009 Jan 27;119(3):390–7. | X1
132 | Dowse R, Ehlers M. Medicine labels incorporating pictograms: do they influence understanding and adherence? Patient Educ Couns. 2005 Jul;58(1):63–70. | X3
133 | du Treil S, Rice J, Leissinger CA. Quantifying adherence to treatment and its relationship to quality of life in a well-characterized haemophilia population. Haemophilia. 2007 Sep;13(5):493–501. | X1
134 | Dunbar-Jacob J, Erlen JA, Schlenk EA, Ryan CM, Sereika SM, Doswell WM. Adherence in chronic disease. Annu Rev Nurs Res. 2000;18:48–90. | X5
135 | Dunbar-Jacob J, Sereika SM, Foley SM, Bass DC, Ness RB. Adherence to oral therapies in pelvic inflammatory disease. Journal of women's health (2002). 2004 Apr;13(3):285–91. | X4
136 | Dusing R, Handrock R, Klebs S, Tousset E, Vrijens B. Impact of supportive measures on drug adherence in patients with essential hypertension treated with valsartan: the randomized, open-label, parallel group study VALIDATE. J Hypertens. 2009 Apr;27(4):894–901. | X1
137 | Ebbing M, Bonaa KH, Arnesen E, Ueland PM, Nordrehaug JE, Rasmussen K, et al. Combined analyses and extended follow-up of two randomized controlled homocysteine-lowering B-vitamin trials. J Intern Med. 2010 Oct;268(4):367–82. | X1
138 | Edworthy SM, Baptie B, Galvin D, Brant RF, Churchill-Smith T, Manyari D, et al. Effects of an enhanced secondary prevention program for patients with heart disease: a prospective randomized trial. Can J Cardiol. 2007 Nov;23(13):1066–72. | X3
139 | Edworthy SM, Devins GM. Improving medication adherence through patient education distinguishing between appropriate and inappropriate utilization. Patient Education Study Group. J Rheumatol. 1999 Aug;26(8):1793–801. | X3
140 | Egan DA, Garg R, Wilt TJ, Pettinger MB, Davis KB, Crouse J, et al. Rationale and design of the Arterial Disease Multiple Intervention Trial (ADMIT) pilot study. Am J Cardiol. 1999 Feb 15;83(4):569–75. | X5
141 | Elkjaer M, Shuhaibar M, Burisch J, Bailey Y, Scherfig H, Laugesen B, et al. E-health empowers patients with ulcerative colitis: a randomised controlled trial of the web-guided 'Constant-care' approach. Gut. 2010 Dec;59(12):1652–61. | X3
142 | Ell K, Vourlekis B, Xie B, Nedjat-Haiem FR, Lee PJ, Muderspach L, et al. Cancer treatment adherence among low-income women with breast or gynecologic cancer: a randomized controlled trial of patient navigation. Cancer. 2009 Oct 1;115(19):4606–15. | X6
143 | Eron JJ, Yetzer ES, Ruane PJ, Becker S, Sawyer GA, Fisher RL, et al. Efficacy, safety, and adherence with a twice-daily combination lamivudine/zidovudine tablet formulation, plus a protease inhibitor, in HIV infection. AIDS. 2000 Apr 14;14(6):671–81. | X1
144 | Eussen SR, van der Elst ME, Klungel OH, Rompelberg CJ, Garssen J, Oosterveld MH, et al. A pharmaceutical care program to improve adherence to statin therapy: a randomized controlled trial. Ann Pharmacother. 2010 Dec;44(12):1905–13. | X3
145 | Fabacher D, Josephson K, Pietruszka F, Linderborn K, Morley JE, Rubenstein LZ. An in-home preventive assessment program for independent older adults: a randomized controlled trial. J Am Geriatr Soc. 1994 Jun;42(6):630–8. | X12
146 | Fairley CK, Levy R, Rayner CR, Allardice K, Costello K, Thomas C, et al. Randomized trial of an adherence programme for clients with HIV. Int J STD AIDS. 2003 Dec;14(12):805–9. | X4
147 | Fallab-Stubi CL, Zellweger JP, Sauty A, Uldry C, Iorillo D, Burnier M. Electronic monitoring of adherence to treatment in the preventive chemotherapy of tuberculosis. Int J Tuberc Lung Dis. 1998 Jul;2(7):525–30. | X5
148 | Farber H, Oliveria L. Trial of an asthma education program in an inner-city pediatric emergency department. Pediatr Asthma Allergy Immunol. 2004;17(2):107–15. | X13
149 | Farmer AJ, Wade AN, French DP, Simon J, Yudkin P, Gray A, et al. Blood glucose self-monitoring in type 2 diabetes: a randomised controlled trial. Health Technol Assess. 2009 Feb;13(15):iii–iv, ix–xi, 1–50. | X3
150 | Farup PG, Hovde O, Halvorsen FA, Raknerud N, Brodin U. Mesalazine suppositories versus hydrocortisone foam in patients with distal ulcerative colitis. A comparison of the efficacy and practicality of two topical treatment regimens. Scand J Gastroenterol. 1995 Feb;30(2):164–70. | X3
151 | Faulkner MA, Wadibia EC, Lucas BD, Hilleman DE. Impact of pharmacy counseling on compliance and effectiveness of combination lipid-lowering therapy in patients undergoing coronary artery revascularization: a randomized, controlled trial. Pharmacotherapy. 2000 Apr;20(4):410–6. | X8
152 | Feaster DJ, Brincks AM, Mitrani VB, Prado G, Schwartz SJ, Szapocznik J. The efficacy of structural ecosystems therapy for HIV medication adherence with African American women. Journal of family psychology : JFP : journal of the Division of Family Psychology of the American Psychological Association (Division 43). 2010 Feb;24(1):51–9. | X4
153 | Fife KH, Barbarash RA, Rudolph T, Degregorio B, Roth R. Valaciclovir versus acyclovir in the treatment of first-episode genital herpes infection. Results of an international, multicenter, double-blind, randomized clinical trial. The Valaciclovir International Herpes Simplex Virus Study Group. Sex Transm Dis. 1997 Sep;24(8):481–6. | X4
154 | Fihn SD, Bucher JB, McDonell M, Diehr P, Rumsfeld JS, Doak M, et al. Collaborative care intervention for stable ischemic heart disease. Arch Intern Med. 2011 Sep 12;171(16):1471–9. | X1
155 | Finkelstein JS, Wyland JJ, Lee H, Neer RM. Effects of teriparatide, alendronate, or both in women with postmenopausal osteoporosis. J Clin Endocrinol Metab. 2010 Apr;95(4):1838–45. | X1
156 | Finley PR, Rens HR, Pont JT, Gess SL, Louie C, Bull SA, et al. Impact of a collaborative pharmacy practice model on the treatment of depression in primary care. Am J Health Syst Pharm. 2002 Aug 15;59(16):1518–26. | X5
157 | Flandre P, Peytavin G, Meiffredy V, Saidi Y, Descamps D, Delagnes M, et al. Adherence to antiretroviral therapy and outcomes in HIV-infected patients enrolled in an induction/maintenance randomized trial. Antivir Ther. 2002 Jun;7(2):113–21. | X4
158 | Fogarty L, Roter D, Larson S, Burke J, Gillespie J, Levy R. Patient adherence to HIV medication regimens: a review of published and abstract reports. Patient Educ Couns. 2002 Feb;46(2):93–108. | X5
159 | Fogel NR, Weissberg-Benchell J. Preventing poor psychological and health outcomes in pediatric type 1 diabetes. Curr Diab Rep. 2010 Dec;10(6):436–43. | X13
160 | Fonarow GC, Albert NM, Curtis AB, Stough WG, Gheorghiade M, Heywood JT, et al. Improving evidence-based care for heart failure in outpatient cardiology practices: primary results of the Registry to Improve the Use of Evidence-Based Heart Failure Therapies in the Outpatient Setting (IMPROVE HF). Circulation. 2010 Aug 10;122(6):585–96. | X1
161 | Fox PJ, Breuer W, Wright JA. Effects of a health promotion program on sustaining health behaviors in older adults. Am J Prev Med. 1997 Jul–Aug;13(4):257–64. | X1
162 | Freeman EW, Rickels K, Sondheimer SJ, Polansky M, Xiao S. Continuous or intermittent dosing with sertraline for patients with severe premenstrual syndrome or premenstrual dysphoric disorder. A J Psychiatry. 2004 Feb;161(2):343–51. | X12
163 | Fujioka K, Pans M, Joyal S. Glycemic control in patients with type 2 diabetes mellitus switched from twice-daily immediate-release metformin to a once-daily extended-release formulation. Clin Ther. 2003 Feb;25(2):515–29. | X1
164 | Fumaz CR, Tuldra A, Ferrer MJ, Paredes R, Bonjoch A, Jou T, et al. Quality of life, emotional status, and adherence of HIV-1-infected patients treated with efavirenz versus protease inhibitor-containing regimens. J Acquir Immune Defic Syndr. 2002 Mar 1;29(3):244–53. | X4
165 | Fungladda W, Honrado ER, Thimasarn K, Kitayaporn D, Karbwang J, Kamolratanakul P, et al. Compliance with artesunate and quinine + tetracycline treatment of uncomplicated falciparum malaria in Thailand. Bull World Health Organ. 1998;76 Suppl 1:59–66. | X3
166 | Galan P, Kesse-Guyot E, Czernichow S, Briancon S, Blacher J, Hercberg S. Effects of B vitamins and omega 3 fatty acids on cardiovascular diseases: a randomised placebo controlled trial. BMJ. 2010;341:c6273. | X1
167 | Gallefoss F, Bakke PS. How does patient education and self-management among asthmatics and patients with chronic obstructive pulmonary disease affect medication? Am J Respir Crit Care Med. 1999 Dec;160(6):2000–5. | X3
168 | Gallefoss F, Bakke PS, Rsgaard PK. Quality of life assessment after patient education in a randomized controlled study on asthma and chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1999 Mar;159(3):812–7. | X1
169 | Gallegos EC, Ovalle-Berumen F, Gomez-Meza MV. Metabolic control of adults with type 2 diabetes mellitus through education and counseling. J Nurs Scholarsh. 2006;38(4):344–51. | X5
170 | Galliher JM, Post DM, Weiss BD, Dickinson LM, Manning BK, Staton EW, et al. Patients' question-asking behavior during primary care visits: a report from the AAFP National Research Network. Annals of family medicine. 2010 Mar–Apr;8(2):151–9. | X13
171 | Garcia-Caballos M, Ramos-Diaz F, Jimenez-Moleon JJ, Bueno-Cavanillas A. Drug-related problems in older people after hospital discharge and interventions to reduce them. Age Ageing. 2010 Jul;39(4):430–8. | X14
172 | Garland WH, Wohl AR, Valencia R, Witt MD, Squires K, Kovacs A, et al. The acceptability of a directly-administered antiretroviral therapy (DAART) intervention among patients in public HIV clinics in Los Angeles, California. AIDS Care. 2007 Feb;19(2):159–67. | X12
173 | Gazmararian J, Jacobson KL, Pan Y, Schmotzer B, Kripalani S. Effect of a pharmacy-based health literacy intervention and patient characteristics on medication refill adherence in an urban health system. Ann Pharmacother. 2010 Jan;44(1):80–7. | X5
174 | Gensichen J, Petersen JJ, Karroum T, Rauck S, Ludman E, Konig J, et al. Positive impact of a family practice-based depression case management on patient's self-management. Gen Hosp Psychiatry. 2011;33(1):23–8. | X3
175 | Gensichen J, von Korff M, Peitz M, Muth C, Beyer M, Guthlin C, et al. Case management for depression by health care assistants in small primary care practices: a cluster randomized trial. Ann Intern Med. 2009 Sep 15;151(6):369–78. | X3
176 | George J, Elliott RA, Stewart DC. A systematic review of interventions to improve medication taking in elderly patients prescribed multiple medications. Drugs Aging. 2008;25(4):307–24. | X14
177 | Gibson TB, Mark TL, Axelsen K, Baser O, Rublee DA, McGuigan KA. Impact of statin copayments on adherence and medical care utilization and expenditures. Am J Manag Care. 2006 Dec;12 Spec no.:SP11–9. | X2
178 | Gibson TB, Song X, Alemayehu B, Wang SS, Waddell JL, Bouchard JR, et al. Cost sharing, adherence, and health outcomes in patients with diabetes. Am J Manag Care. 2010 Aug;16(8):589–600. | X5
179 | Gilliam M, Knight S, McCarthy M, Jr. Success with oral contraceptives: a pilot study. Contraception. 2004 May;69(5):413–8. | X13
180 | Gilutz H, Novack L, Shvartzman P, Zelingher J, Bonneh DY, Henkin Y, et al. Computerized community cholesterol control (4C): meeting the challenge of secondary prevention. Isr Med Assoc J. 2009 Jan;11(1):23–9. | X1
181 | Girvin BG, Johnston GD. Comparison of the effects of a 7-day period of non-compliance on blood pressure control using three different antihypertensive agents. J Hypertens. 2004 Jul;22(7):1409–14. | X3
182 | Glaser NS, Iden SB, Green-Burgeson D, Bennett C, Hood-Johnson K, Styne DM, et al. Benefits of an insulin dosage calculation device for adolescents with type 1 diabetes mellitus. J Pediatr Endocrinol Metab. 2004 Dec;17(12):1641–51. | X13
183 | Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M, Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med. 2003 Apr;36(4):410–9. | X1
184 | Glasgow RE, Christiansen SM, Kurz D, King DK, Woolley T, Faber AJ, et al. Engagement in a diabetes self-management website: usage patterns and generalizability of program use. Journal of medical Internet research. 2011;13(1):e9. | X5
185 | Godleski LS, Goldsmith LJ, Vieweg WV, Zettwoch NC, Stikovac DM, Lewis SJ. Switching from depot antipsychotic drugs to olanzapine in patients with chronic schizophrenia. J Clin Psychiatry. 2003 Feb;64(2):119–22. | X1
186 | Goessens BM, Visseren FL, Sol BG, de Man-van Ginkel JM, van der Graaf Y. A randomized, controlled trial for risk factor reduction in patients with symptomatic vascular disease: the multidisciplinary Vascular Prevention by Nurses Study (VENUS). Eur J Cardiovasc Prev Rehabil. 2006 Dec;13(6):996–1003. | X12
187 | Goldbach-Mansky R, Wilson M, Fleischmann R, Olsen N, Silverfield J, Kempf P, et al. Comparison of Tripterygium wilfordii Hook F versus sulfasalazine in the treatment of rheumatoid arthritis: a randomized trial. Ann Intern Med. 2009 Aug 18;151(4):229–40, W49–51. | X1
188 | Goldberg HI, Neighbor WE, Hirsch IB, Cheadle AD, Ramsey SD, Gore E. Evidence-based management: using serial firm trials to improve diabetes care quality. Jt Comm J Qual Improv. 2002 Apr;28(4):155–66. | X1
189 | Goldstein RS, Gort EH, Stubbing D, Avendano MA, Guyatt GH. Randomised controlled trial of respiratory rehabilitation. Lancet. 1994 Nov 19;344(8934):1394–7. | X1
190 | Golin CE, Earp J, Tien HC, Stewart P, Porter C, Howie L. A 2-arm, randomized, controlled trial of a motivational interviewing-based intervention to improve adherence to antiretroviral therapy (ART) among patients failing or initiating ART. J Acquir Immune Defic Syndr. 2006 May;42(1):42–51. | X4
191 | Goodyer LI, Miskelly F, Milligan P. Does encouraging good compliance improve patients' clinical condition in heart failure? Br J Clin Pract. 1995 Jul–Aug;49(4):173–6. | X3
192 | Goujard C, Bernard N, Sohier N, Peyramond D, Lancon F, Chwalow J, et al. Impact of a patient education program on adherence to HIV medication: a randomized clinical trial. J Acquir Immune Defic Syndr. 2003 Oct 1;34(2):191–4. | X3
193 | Gourley DR, Gourley GA, Solomon DK, Portner TS, Bass GE, Holt JM, et al. Development, implementation, and evaluation of a multicenter pharmaceutical care outcomes study. J Am Pharm Assoc (Wash). 1998 Sep–Oct;38(5):567–73. | X12
194 | Gray Trish A, Orton Lois C, Henson D, Harper R, Waterman H. Interventions for improving adherence to ocular hypotensive therapy. Cochrane Database of Systematic Reviews. 2009(2). | X14
195 | Graziano JA, Gross CR. The effects of isolated telephone interventions on glycemic control in type 2 diabetes: a literature review. ANS Adv Nurs Sci. 2009 Jul–Sep;32(3):E28–41. | X12
196 | Gross R, Tierney C, Andrade A, Lalama C, Rosenkranz S, Eshleman SH, et al. Modified directly observed antiretroviral therapy compared with self-administered therapy in treatment-naive HIV-1-infected patients: a randomized trial. Arch Intern Med. 2009 Jul 13;169(13):1224–32. | X4
197 | Grosset KA, Bone I, Reid JL, Grosset D. Measuring therapy adherence in Parkinson's disease: a comparison of methods. J Neurol Neurosurg Psychiatry. 2006 Feb;77(2):249–51. | X3
198 | Grosset KA, Grosset DG. Effect of educational intervention on medication timing in Parkinson's disease: a randomized controlled trial. BMC neurology. 2007;7:20. | X3
199 | Guerci B, Drouin P, Grange V, Bougneres P, Fontaine P, Kerlan V, et al. Self-monitoring of blood glucose significantly improves metabolic control in patients with type 2 diabetes mellitus: the Auto-Surveillance Intervention Active (ASIA) study. Diabetes Metab. 2003 Dec;29(6):587–94. | X1
200 | Guilera M, Fuentes M, Grifols M, Ferrer J, Badia X. Does an educational leaflet improve self-reported adherence to therapy in osteoporosis? The OPTIMA study. Osteoporos Int. 2006;17(5):664–71. | X3
201 | Gump BB, Matthews KA. Special intervention reduces CVD mortality for adherent participants in the multiple risk factor intervention trial. nn Behav Med. 2003 Aug;26(1):61–8. | X1
202 | Guo X, Zhai J, Liu Z, Fang M, Wang B, Wang C, et al. Effect of antipsychotic medication alone vs combined with psychosocial intervention on outcomes of early-stage schizophrenia: A randomized, 1-year study. Arch Gen Psychiatry. 2010 Sep;67(9):895–904. | X3
203 | Gwadry-Sridhar FH, Arnold JM, Zhang Y, Brown JE, Marchiori G, Guyatt G. Pilot study to determine the impact of a multidisciplinary educational intervention in patients hospitalized with heart failure. Am Heart J. 2005 Nov;150(5):982. | X3
204 | Hall H, Papas A, Tosi M, Olness K. Directional changes in neutrophil adherence following passive resting versus active imagery. Int J Neurosci. 1996 Apr;85(3–4):185–94. | X8
205 | Hamann J, Cohen R, Leucht S, Busch R, Kissling W. Shared decision making and long-term outcome in schizophrenia treatment. J Clin Psychiatry. 2007 Jul;68(7):992–7. | X3
206 | Hanlon JT, Weinberger M, Samsa GP, Schmader KE, Uttech KM, Lewis IK, et al. A randomized, controlled trial of a clinical pharmacist intervention to improve inappropriate prescribing in elderly outpatients with polypharmacy. Am J Med. 1996 Apr;100(4):428–37. | X1
207 | Hansen RA, Kim MM, Song L, Tu W, Wu J, Murray MD. Comparison of methods to assess medication adherence and classify nonadherence. Ann Pharmacother. 2009 Mar;43(3):413–22. | X1
208 | Hardstaff R, Green K, Talbot D. Measurement of compliance posttransplantation--the results of a 12-month study using electronic monitoring. Transplant Proc. 2003 Mar;35(2):796–7. | X3
209 | Harrington J, Noble LM, Newman SP. Improving patients' communication with doctors: a systematic review of intervention studies. Patient Educ Couns. 2004 Jan;52(1):7–16. | X12
210 | Harris SB, Leiter LA, Webster-Bogaert S, Van DM, O'Neill C. Teleconferenced educational detailing: diabetes education for primary care physicians. J Contin Educ Health Prof. 2005 Spring;25(2):87–97. | X1
211 | Hawkes AL, Atherton J, Taylor CB, Scuffham P, Eadie K, Miller NH, et al. Randomised controlled trial of a secondary prevention program for myocardial infarction patients ('ProActive Heart'): study protocol. Secondary prevention program for myocardial infarction patients. BMC Cardiovasc Disord. 2009;9:16. | X12
212 | Hawthorne AB, Rubin G, Ghosh S. Review article: medication non-adherence in ulcerative colitis--strategies to improve adherence with mesalazine and other maintenance therapies. Aliment Pharmacol Ther. 2008 Jun;27(12):1157–66. | X9
213 | Haynes RB, Ackloo E, Sahota N, McDonald Heather P, Yao X. Interventions for enhancing medication adherence. Cochrane Database of Systematic Reviews. 2008(2). | X14
214 | Haynes RB, McKibbon KA, Kanani R. Systematic review of randomised trials of interventions to assist patients to follow prescriptions for medications (Brief record). Lancet. 1996(9024):383–6. | X10
215 | He J, Streiffer RH, Muntner P, Krousel-Wood MA, Whelton PK. Effect of dietary fiber intake on blood pressure: a randomized, double-blind, placebo-controlled trial. J Hypertens. 2004 Jan;22(1):73–80. | X1
216 | Hedrick SC, Chaney EF, Felker B, Liu CF, Hasenberg N, Heagerty P, et al. Effectiveness of collaborative care depression treatment in Veterans' Affairs primary care. J Gen Intern Med. 2003 Jan;18(1):9–16. | X1
217 | Heffner JL, Tran GQ, Johnson CS, Barrett SW, Blom TJ, Thompson RD, et al. Combining motivational interviewing with compliance enhancement therapy (MI-CET): development and preliminary evaluation of a new, manual-guided psychosocial adjunct to alcohol-dependence pharmacotherapy. J Stud Alcohol Drugs. 2010 Jan;71(1):61–70. | X1
218 | Heneghan Carl J, Glasziou Paul P, Perera R. Reminder packaging for improving adherence to self-administered long-term medications. Cochrane Database of Systematic Reviews. 2006(1). | X14
219 | Hill J, Bird H, Johnson S. Effect of patient education on adherence to drug treatment for rheumatoid arthritis: a randomised controlled trial. Ann Rheum Dis. 2001 Sep;60(9):869–75. | X3
220 | Hirsch JD, Rosenquist A, Best BM, Miller TA, Gilmer TP. Evaluation of the first year of a pilot program in community pharmacy: HIV/AIDS medication therapy management for Medi-Cal beneficiaries. Journal of managed care pharmacy : JMCP. 2009 Jan–Feb;15(1):32–41. | X4
221 | Holzemer WL, Bakken S, Portillo CJ, Grimes R, Welch J, Wantland D, et al. Testing a nurse-tailored HIV medication adherence intervention. Nurs Res. 2006 May–Jun;55(3):189–97. | X4
222 | Homer D, Nightingale P, Jobanputra P. Providing patients with information about disease-modifying anti-rheumatic drugs: Individually or in groups? A pilot randomized controlled trial comparing adherence and satisfaction. Musculoskeletal Care. 2009 Jun;7(2):78–92. | X3
223 | Hornnes N, Larsen K, Boysen G. Blood pressure 1 year after stroke: the need to optimize secondary prevention. Journal of stroke and cerebrovascular diseases : the official journal of National Stroke Association. 2011 Jan–Feb;20(1):16–23. | X3
224 | Hornung WP, Kieserg A, Feldmann R, Buchkremer G. Psychoeducational training for schizophrenic patients: background, procedure and empirical findings. Patient Educ Couns. 1996 Dec;29(3):257–68. | X4
225 | Hornung WP, Klingberg S, Feldmann R, Schonauer K, Schulze Monking H. Collaboration with drug treatment by schizophrenic patients with and without psychoeducational training: results of a 1-year follow-up. Acta Psychiatr Scand. 1998 Mar;97(3):213–9. | X4
226 | Hou MY, Hurwitz S, Kavanagh E, Fortin J, Goldberg AB. Using daily text-message reminders to improve adherence with oral contraceptives: a randomized controlled trial. Obstet Gynecol. 2010 Sep;116(3):633–40. | X13
227 | Hudson TJ, Owen RR, Thrush CR, Armitage TL, Thapa P. Guideline implementation and patient-tailoring strategies to improve medication adherence for schizophrenia. J Clin Psychiatry. 2008 Jan;69(1):74–80. | X4
228 | Hudson TJ, Owen RR, Thrush CR, Han X, Pyne JM, Thapa P, et al. A pilot study of barriers to medication adherence in schizophrenia. J Clin Psychiatry. 2004 Feb;65(2):211–6. | X2
229 | Huffman JC, Mastromauro CA, Sowden G, Fricchione GL, Healy BC, Januzzi JL. Impact of a depression care management program for hospitalized cardiac patients. Circulation Cardiovascular quality and outcomes. 2011 Mar;4(2):198–205. | X1
230 | Hulse GK, Ngo HT, Tait RJ. Risk factors for craving and relapse in heroin users treated with oral or implant naltrexone. Biol Psychiatry. 2010 Aug 1;68(3):296–302. | X12
231 | Huskamp HA, Deverka PA, Landrum MB, Epstein RS, McGuigan KA. The effect of three-tier formulary adoption on medication continuation and spending among elderly retirees. Health Serv Res. 2007 Oct;42(5):1926–42. | X1
232 | Hwang LY, Grimes CZ, Tran TQ, Clark A, Xia R, Lai D, et al. Accelerated hepatitis B vaccination schedule among drug users: a randomized controlled trial. J Infect Dis. 2010 Nov 15;202(10):1500–9. | X13
233 | Imaz I, Zegarra P, Gonzalez-Enriquez J, Rubio B, Alcazar R, Amate JM. Poor bisphosphonate adherence for treatment of osteoporosis increases fracture risk: systematic review and meta-analysis (Provisional abstract). Osteoporos Int. 2010(11):1943–51. | X1
234 | Ingersoll KS, Cropsey KL, Heckman CJ. A test of motivational plus nicotine replacement interventions for HIV positive smokers. AIDS and behavior. 2009 Jun;13(3):545–54. | X1
235 | Ironson G, Weiss S, Lydston D, Ishii M, Jones D, Asthana D, et al. The impact of improved self-efficacy on HIV viral load and distress in culturally diverse women living with AIDS: the SMART/EST Women's Project. AIDS Care. 2005 Feb;17(2):222–36. | X12
236 | Iskedjian M, Einarson TR, MacKeigan LD, Shear N, Addis A, Mittmann N, et al. Relationship between daily dose frequency and adherence to antihypertensive pharmacotherapy: evidence from a meta analysis (Structured abstract). Clin Ther. 2002(2):302–16. | X14
237 | Jackson C, Lawton RJ, Raynor DK, Knapp P, Conner MT, Lowe CJ, et al. Promoting adherence to antibiotics: a test of implementation intentions. Patient Educ Couns. 2006 May;61(2):212–8. | X4
238 | Jameson J, VanNoord G, Vanderwoud K. The impact of a pharmacotherapy consultation on the cost and outcome of medical therapy. J Fam Pract. 1995 Nov;41(5):469–72. | X12
239 | Jameson JP, Baty PJ. Pharmacist collaborative management of poorly controlled diabetes mellitus: a randomized controlled trial. Am J Manag Care. 2010 Apr;16(4):250–5. | X1
240 | Jamison RN, Ross EL, Michna E, Chen LQ, Holcomb C, Wasan AD. Substance misuse treatment for high-risk chronic pain patients on opioid therapy: a randomized trial. Pain. 2010 Sep;150(3):390–400. | X1
241 | Jansen A, Andersen KF, Bruning H. Evaluation of a compliance device in a subgroup of adult patients receiving specific immunotherapy with grass allergen tablets (GRAZAX) in a randomized, open-label, controlled study: an a priori subgroup analysis. Clin Ther. 2009 Feb;31(2):321–7. | X3
242 | Janssen MJ, van der Kuy A, ter Wee PM, van Boven WP. Aluminum hydroxide, calcium carbonate and calcium acetate in chronic intermittent hemodialysis patients. Clin Nephrol. 1996 Feb;45(2):111–9. | X3
243 | Javanbakht M, Prosser P, Grimes T, Weinstein M, Farthing C. Efficacy of an individualized adherence support program with contingent reinforcement among nonadherent HIV-positive patients: results from a randomized trial. J Int Assoc Physicians AIDS Care (Chic). 2006 Dec;5(4):143–50. | X12
244 | Johns SA, Kroenke K, Theobald DE, Wu J, Tu W. Telecare management of pain and depression in patients with cancer: patient satisfaction and predictors of use. The Journal of ambulatory care management. 2011 Apr–Jun;34(2):126–39. | X1
245 | Johnson BA, Ait-Daoud N, Aubin HJ, Van Den Brink W, Guzzetta R, Loewy J, et al. A pilot evaluation of the safety and tolerability of repeat dose administration of long-acting injectable naltrexone (Vivitrex) in patients with alcohol dependence. Alcohol Clin Exp Res. 2004 Sep;28(9):1356–61. | X8
246 | Johnson CJ, Heckman TG, Hansen NB, Kochman A, Sikkema KJ. Adherence to antiretroviral medication in older adults living with HIV/AIDS: a comparison of alternative models. AIDS Care. 2009 May;21(5):541–51. | X1
247 | Johnson KA, Chen S, Cheng IN, Lou M, Gregerson P, Blieden C, et al. The impact of clinical pharmacy services integrated into medical homes on diabetes-related clinical outcomes. Ann Pharmacother. 2010 Dec;44(12):1877–86. | X1
248 | Johnson MO, Charlebois E, Morin SF, Remien RH, Chesney MA. Effects of a behavioral intervention on antiretroviral medication adherence among people living with HIV: the healthy living project randomized controlled study. J Acquir Immune Defic Syndr. 2007 Dec 15;46(5):574–80. | X4
249 | Johnson MO, Gamarel KE, Dawson Rose C. Changing HIV treatment expectancies: a pilot study. AIDS Care. 2006 Aug;18(6):550–3. | X8
250 | Jones DL, Ishii M, LaPerriere A, Stanley H, Antoni M, Ironson G, et al. Influencing medication adherence among women with AIDS. AIDS Care. 2003 Aug;15(4):463–74. | X4
251 | Joos SK, Hickam DH, Gordon GH, Baker LH. Effects of a physician communication intervention on patient care outcomes. J Gen Intern Med. 1996 Mar;11(3):147–55. | X5
252 | Joosten EA, DeFuentes-Merillas L, de W, G H, Sensky T, van der Staak CP, et al. Systematic review of the effects of shared decision-making on patient satisfaction, treatment adherence and health status (Structured abstract). Psychother Psychosom. 2008(4):219–26. | X1
253 | Jorgensen P, Nordentoft M, Abel MB, Gouliaev G, Jeppesen P, Kassow P. Early detection and assertive community treatment of young psychotics: the Opus Study Rationale and design of the trial. Soc Psychiatry Psychiatr Epidemiol. 2000 Jul;35(7):283–7. | X12
254 | Jovicic A, Holroyd-Leduc JM, Straus SE. Effects of self-management intervention on health outcomes of patients with heart failure: a systematic review of randomized controlled trials (Structured abstract). BMC Cardiovascular Disorders. 2006. | X1
255 | Kaboli P, Hoth A, Carter BL, Chrischilles EA, Shorr RI, Bhattacharyya A, et al. The VA Enhanced Pharmacy Outpatient Clinic (EPOC) Study: A randomized-controlled pharmacist-physician intervention trial. J Gen Intern Med. 2004 Apr;19(Suppl 1):227. | X9
256 | Kalichman SC, Cherry C, Kalichman MO, Amaral CM, White D, Pope H, et al. Integrated behavioral intervention to improve HIV/AIDS treatment adherence and reduce HIV transmission. Am J Public Health. 2011 Mar;101(3):531–8. | X4
257 | Kalsekar I, Iyer S, Mody R, Rajagopalan R, Kavookjian J. Utilization and costs for compliant patients initiating therapy with pioglitazone or rosiglitazone versus insulin in a Medicaid fee-for-service population. Journal of managed care pharmacy : JMCP. 2006 Mar;12(2):121–9. | X5
258 | Kaplan B, Mason NA, Shimp LA, Ascione FJ. Chronic hemodialysis patients. Part I: Characterization and drug-related problems. Ann Pharmacother. 1994 Mar;28(3):316–9. | X8
259 | Karkkainen MK, Tuppurainen M, Salovaara K, Sandini L, Rikkonen T, Sirola J, et al. Does daily vitamin D 800 IU and calcium 1000 mg supplementation decrease the risk of falling in ambulatory women aged 65–71 years? A 3-year randomized population-based trial (OSTPRE-FPS). Maturitas. 2010 Apr;65(4):359–65. | X1
260 | Kastrissios H, Suarez JR, Hammer S, Katzenstein D, Blaschke TF. The extent of non-adherence in a large AIDS clinical trial using plasma dideoxynucleoside concentrations as a marker. AIDS. 1998 Dec 3;12(17):2305–11. | X4
261 | Katlama C, Fenske S, Gazzard B, Lazzarin A, Clumeck N, Mallolas J, et al. TRIZAL study: switching from successful HAART to Trizivir (abacavir-lamivudine-zidovudine combination tablet): 48 weeks efficacy, safety and adherence results. HIV Med. 2003 Apr;4(2):79–86. | X4
262 | Kato PM, Cole SW, Bradlyn AS, Pollock BH. A video game improves behavioral outcomes in adolescents and young adults with cancer: a randomized trial. Pediatrics. 2008 Aug;122(2):e305–17. | X3
263 | Katzelnick DJ, Simon GE, Pearson SD, Manning WG, Helstad CP, Henk HJ, et al. Randomized trial of a depression management program in high utilizers of medical care. Arch Fam Med. 2000 Apr;9(4):345–51. | X1
264 | Kemp R, David A. Psychological predictors of insight and compliance in psychotic patients. Br J Psychiatry. 1996 Oct;169(4):444–50. | X6
265 | Kemp R, Kirov G, Everitt B, Hayward P, David A. Randomised controlled trial of compliance therapy. 18-month follow-up. Br J Psychiatry. 1998 May;172:413–9. | X3
266 | Kendler D, Kung AW, Fuleihan Gel H, Gonzalez Gonzalez JG, Gaines KA, Verbruggen N, et al. Patients with osteoporosis prefer once weekly to once daily dosing with alendronate. Maturitas. 2004 Jul 15;48(3):243–51. | X3
267 | Kennedy TM, Chalder T, McCrone P, Darnley S, Knapp M, Jones RH, et al. Cognitive behavioural therapy in addition to antispasmodic therapy for irritable bowel syndrome in primary care: randomised controlled trial. Health Technol Assess. 2006 Jun;10(19):iii–iv, ix–x, 1–67. | X1
268 | Kenny AM, Kleppinger A, Annis K, Rathier M, Browner B, Judge JO, et al. Effects of transdermal testosterone on bone and muscle in older men with low bioavailable testosterone levels, low bone mass, and physical frailty. J Am Geriatr Soc. 2010 Jun;58(6):1134–43. | X1
269 | Kenny AM, Mangano KM, Abourizk RH, Bruno RS, Anamani DE, Kleppinger A, et al. Soy proteins and isoflavones affect bone mineral density in older women: a randomized controlled trial. Am J Clin Nutr. 2009 Jul;90(1):234–42. | X1
270 | Kiarie JN, Kreiss JK, Richardson BA, John-Stewart GC. Compliance with antiretroviral regimens to prevent perinatal HIV-1 transmission in Kenya. AIDS. 2003 Jan 3;17(1):65–71. | X3
271 | Kidder DP, Wolitski RJ, Royal S, Aidala A, Courtenay-Quirk C, Holtgrave DR, et al. Access to housing as a structural intervention for homeless and unstably housed people living with HIV: rationale, methods, and implementation of the housing and health study. AIDS and behavior. 2007 Nov;11(6 Suppl):149–61. | X12
272 | Kim B, Lee SH, Choi TK, Suh S, Kim YW, Lee E, et al. Effectiveness of risperidone long-acting injection in first-episode schizophrenia: in naturalistic setting. Prog Neuropsychopharmacol Bol Psychiatry. 2008 Jul 1;32(5):1231–5. | X5
273 | Kimmelstiel C, Levine D, Perry K, Patel AR, Sadaniantz A, Gorham N, et al. Randomized, controlled evaluation of short- and long-term benefits of heart failure disease management within a diverse provider network: the SPAN-CHF trial. Circulation. 2004 Sep 14;110(11):1450–5. | X12
274 | King AB, Wolfe GS. Evaluation of a diabetes specialist-guided primary care diabetes treatment program. J Am Acad Nurse Pract. 2009 Jan;21(1):24–30. | X12
275 | Kirkman MS, Weinberger M, Landsman PB, Samsa GP, Shortliffe EA, Simel DL, et al. A telephone-delivered intervention for patients with NIDDM. Effect on coronary risk factors. Diabetes Care. 1994 Aug;17(8):840–6. | X12
276 | Klein A, Otto G, Kramer I. Impact of a pharmaceutical care program on liver transplant patientsg(euro)(trademark) compliance with immunosuppressive medication: A prospective, randomized, controlled trial using electronic monitoring. Transplantation. 2009;87(6):839–47. | X3
277 | Ko SH, Song KH, Kim SR, Lee JM, Kim JS, Shin JH, et al. Long-term effects of a structured intensive diabetes education programme (SIDEP) in patients with Type 2 diabetes mellitus--a 4-year follow-up study. Diabet Med. 2007 Jan;24(1):55–62. | X1
278 | Koelling TM, Johnson ML, Cody RJ, Aaronson KD. Discharge education improves clinical outcomes in patients with chronic heart failure. Circulation. 2005 Jan 18;111(2):179–85. | X12
279 | Koenig LJ, Pals SL, Bush T, Pratt Palmore M, Stratford D, Ellerbrock TV. Randomized controlled trial of an intervention to prevent adherence failure among HIV-infected patients initiating antiretroviral therapy. Health Psychol. 2008 Mar;27(2):159–69. | X4
280 | Kothawala P, Badamgarav E, Ryu S, Miller RM, Halbert RJ. Systematic review and meta-analysis of real-world adherence to drug therapy for osteoporosis (Structured abstract). Mayo Clin Proc. 2007(12):1493–501. | X5
281 | Kotowycz MA, Cosman TL, Tartaglia C, Afzal R, Syal RP, Natarajan MK. Safety and feasibility of early hospital discharge in ST-segment elevation myocardial infarction--a prospective and randomized trial in low-risk primary percutaneous coronary intervention patients (the Safe-Depart Trial). Am Heart J. 2010 Jan;159(1):117 e1–6. | X1
282 | Kozuki Y, Schepp KG. Visual-feedback therapy for antipsychotic medication adherence. Int Clin Psychopharmacol. 2006 Jan;21(1):57–61. | X8
283 | Krier BP, Parker RD, Grayson D, Byrd G. Effect of diabetes education on glucose control. J La State Med Soc. 1999 Feb;151(2):86–92. | X1
284 | Kripalani S, Robertson R, Love-Ghaffari MH, Henderson LE, Praska J, Strawder A, et al. Development of an illustrated medication schedule as a low-literacy patient education tool. Patient Educ Couns. 2007 Jun;66(3):368–77. | X5
285 | Kripalani S, Yao X, Haynes B. Interventions to enhance medication adherence in chronic medical conditions (Brief record). Arch Intern Med. 2007(6):540–50. | X14
286 | Krueger KP, Felkey BG, Berger BA. Improving adherence and persistence: a review and assessment of interventions and description of steps toward a national adherence initiative. J Am Pharm Assoc (2003). 2003 Nov–Dec;43(6):668–78; quiz 78–9. | X9
287 | Kruk ME, Schwalbe N. The relation between intermittent dosing and adherence: preliminary insights (Provisional abstract). Clin Ther. 2006(12):1989–95. | X14
288 | Kuo S, Burrill J. Differences in antihypertensive compliance by BCBSRI disease and case management intervention group. Med Health R I. 2007 Dec;90(12):381–4. | X5
289 | Kurtz S, Shemesh G. The efficacy and safety of once-daily versus once-weekly latanoprost treatment for increased intraocular pressure. J Ocul Pharmacol Ther. 2004 Aug;20(4):321–7. | X8
290 | Kutzleb J, Reiner D. The impact of nurse-directed patient education on quality of life and functional capacity in people with heart failure. J Am Acad Nurse Pract. 2006 Mar;18(3):116–23. | X8
291 | LaCroix AZ, Kotchen J, Anderson G, Brzyski R, Cauley JA, Cummings SR, et al. Calcium plus vitamin D supplementation and mortality in postmenopausal women: the Women's Health Initiative calcium-vitamin D randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2009 May;64(5):559–67. | X1
292 | Lai LL. Community pharmacy-based hypertension disease-management program in a Latino/Hispanic-American population. Consult Pharm. 2007 May;22(5):411–6. | X5
293 | Lai P, Chua SS, Chan SP. A systematic review of interventions by healthcare professionals on community-dwelling postmenopausal women with osteoporosis (Provisional abstract). Osteoporos Int. 2010(10):1637–56. | X1
294 | Laine L, Connors L, Griffin MR, Curtis SP, Kaur A, Cannon CP. Prescription rates of protective co-therapy for NSAID users at high GI risk and results of attempts to improve adherence to guidelines. Aliment Pharmacol Ther. 2009 Oct;30(7):767–74. | X1
295 | Lam DH, Watkins ER, Hayward P, Bright J, Wright K, Kerr N, et al. A randomized controlled study of cognitive therapy for relapse prevention for bipolar affective disorder: outcome of the first year. Arch Gen Psychiatry. 2003 Feb;60(2):145–52. | X4
296 | Laporte S, Quenet S, Buchmuller-Cordier A, Reynaud J, Tardy-Poncet B, Thirion C, et al. Compliance and stability of INR of two oral anticoagulants with different half-lives: a randomised trial. Thromb Haemost. 2003 Mar;89(3):458–67. | X1
297 | Lauwo JA, Hombhanje FW, Tulo SP, Maibani G, Bjorge S. Impact of pre-packaging antimalarial drugs and counselling on compliance with malaria treatment at Port Moresby General Hospital Adult Outpatient Department. P N G Med J. 2006 Mar–Jun;49(1–2):14–21. | X3
298 | Lawrence DB, Allison W, Chen JC, Demand M. Improving medication adherence with a targeted, technology-driven disease management intervention. Dis Manag. 2008 Jun;11(3):141–4. | X5
299 | Lee M, Kemp JA, Canning A, Egan C, Tataronis G, Farraye FA. A randomized controlled trial of an enhanced patient compliance program for Helicobacter pylori therapy. Arch Intern Med. 1999 Oct 25;159(19):2312–6. | X4
300 | Lee SS, Cheung PY, Chow MS. Benefits of individualized counseling by the pharmacist on the treatment outcomes of hyperlipidemia in Hong Kong. J Clin Pharmacol. 2004 Jun;44(6):632–9. | X3
301 | Leenen FH, Wilson TW, Bolli P, Larochelle P, Myers M, Handa SP, et al. Patterns of compliance with once versus twice daily antihypertensive drug therapy in primary care: a randomized clinical trial using electronic monitoring. Can J Cardiol. 1997 Oct;13(10):914–20. | X3
302 | Legorreta A, Yu A, Chernicoff H, Gilmore A, Jordan J, Rosenzweig JC. Adherence to combined Lamivudine + Zidovudine versus individual components: a community-based retrospective medicaid claims analysis. AIDS Care. 2005 Nov;17(8):938–48. | X4
303 | Lemstra M, Olszynski WP. The effectiveness of multidisciplinary rehabilitation in the treatment of fibromyalgia: a randomized controlled trial. Clin J Pain. 2005 Mar–Apr;21(2):166–74. | X1
304 | Levy ML, Robb M, Allen J, Doherty C, Bland JM, Winter RJ. A randomized controlled evaluation of specialist nurse education following accident and emergency department attendance for acute asthma. Respir Med. 2000 Sep;94(9):900–8. | X3
305 | Levy RW, Rayner CR, Fairley CK, Kong DC, Mijch A, Costello K, et al. Multidisciplinary HIV adherence intervention: a randomized study. Aids Patient Care STDS. 2004 Dec;18(12):728–35. | X4
306 | Lewiecki EM, Babbitt AM, Piziak VK, Ozturk ZE, Bone HG. Adherence to and gastrointestinal tolerability of monthly oral or quarterly intravenous ibandronate therapy in women with previous intolerance to oral bisphosphonates: a 12-month, open-label, prospective evaluation. Clin Ther. 2008 Apr;30(4):605–21. | X5
307 | Lichtman JH, Amatruda J, Yaari S, Cheng S, Smith GL, Mattera JA, et al. Clinical trial of an educational intervention to achieve recommended cholesterol levels in patients with coronary artery disease. Am Heart J. 2004 Mar;147(3):522–8. | X1
308 | Liel Y, Castel H, Bonneh DY. Impact of subsidizing effective anti-osteoporosis drugs on compliance with management guidelines in patients following low-impact fractures. Osteoporos Int. 2003 Jul;14(6):490–5. | X1
309 | Lin EH, Simon GE, Katon WJ, Russo JE, Von Korff M, Bush TM, et al. Can enhanced acute-phase treatment of depression improve long-term outcomes? A report of randomized trials in primary care. A J Psychiatry. 1999 Apr;156(4):643–5. | X5
310 | Lin EH, Von Korff M, Ludman EJ, Rutter C, Bush TM, Simon GE, et al. Enhancing adherence to prevent depression relapse in primary care. Gen Hosp Psychiatry. 2003 Sep–Oct;25(5):303–10. | X12
311 | Ling W, Casadonte P, Bigelow G, Kampman KM, Patkar A, Bailey GL, et al. Buprenorphine implants for treatment of opioid dependence: a randomized controlled trial. JAMA. 2010 Oct 13;304(14):1576–83. | X1
312 | Linszen D, Lenior M, De Haan L, Dingemans P, Gersons B. Early intervention, untreated psychosis and the course of early schizophrenia. Br J Psychiatry Suppl. 1998;172(33):84–9. | X4
313 | Lisson GL, Rodrigue JR, Reed AI, Nelson DR. A brief psychological intervention to improve adherence following transplantation. Ann Transplant. 2005;10(1):52–7. | X5
314 | Liu CF, Hedrick SC, Chaney EF, Heagerty P, Felker B, Hasenberg N, et al. Cost-effectiveness of collaborative care for depression in a primary care veteran population. Psychiatr Serv. 2003 May;54(5):698–704. | X1
315 | Liu Q, Abba K, Alejandria Marissa M, Balanag Vincent M, Berba Regina P, Lansang Mary Ann D. Reminder systems and late patient tracers in the diagnosis and management of tuberculosis. Cochrane Database of Systematic Reviews. 2008(4). | X4
316 | Llor C, Hernandez S, Sierra N, Moragas A, Hernandez M, Bayona C. Association between use of rapid antigen detection tests and adherence to antibiotics in suspected streptococcal pharyngitis. Scand J Prim Health Care. 2010 Mar;28(1):12–7. | X5
317 | Longmire-Avital B, Golub SA, Parsons JT. Self-reevaluation as a critical component in sustained viral load change for HIV+ adults with alcohol problems. nn Behav Med. 2010 Oct;40(2):176–83. | X4
318 | Lopez Cabezas C, Falces Salvador C, Cubi Quadrada D, Arnau Bartes A, Ylla Bore M, Muro Perea N, et al. Randomized clinical trial of a postdischarge pharmaceutical care program vs regular follow-up in patients with heart failure. Farm Hosp. 2006 Nov–Dec;30(6):328–42. | X3
319 | Lopez-Vina A, del Castillo-Arevalo E. Influence of peak expiratory flow monitoring on an asthma self-management education programme. Respir Med. 2000 Aug;94(8):760–6. | X3
320 | Lowe CJ, Raynor DK, Courtney EA, Purvis J, Teale C. Effects of self medication programme on knowledge of drugs and compliance with treatment in elderly patients. BMJ. 1995 May 13;310(6989):1229–31. | X3
321 | Luther J, Higgins PD, Schoenfeld PS, Moayyedi P, Vakil N, Chey WD. Empiric quadruple vs triple therapy for primary treatment of Helicobacter pylori infection: systematic review and meta-analysis of efficacy and tolerability (Structured abstract). Am J Gastroenterol. 2010(1):65–73. | X1
322 | Ma A, Chen DM, Chau FM, Saberi P. Improving adherence and clinical outcomes through an HIV pharmacist's interventions. AIDS Care. 2010 Oct;22(10):1189–94. | X4
323 | Macalino GE, Hogan JW, Mitty JA, Bazerman LB, Delong AK, Loewenthal H, et al. A randomized clinical trial of community-based directly observed therapy as an adherence intervention for HAART among substance users. AIDS. 2007 Jul 11;21(11):1473–7. | X12
324 | Macera CA. Interventions to increase long-term exercise adherence and weight loss. Clin J Sport Med. 2000 Oct;10(4):306. | X1
325 | Machado M, Bajcar J, Guzzo GC, Einarson TR. Sensitivity of patient outcomes to pharmacist interventions. Part II: Systematic review and meta-analysis in hypertension management. Ann Pharmacother. 2007 Nov;41(11):1770–81. | X5
326 | Machtinger EL, Wang F, Chen LL, Rodriguez M, Wu S, Schillinger D. A visual medication schedule to improve anticoagulation control: a randomized, controlled trial. Jt Comm J Qual Patient Saf. 2007 Oct;33(10):625–35. | X12
327 | Madoff SA, Pristach CA, Smith CM, Pristach EA. Computerized medication instruction for psychiatric inpatients admitted for acute care. MD Comput. 1996 Sep–Oct;13(5):427–31, 41. | X4
328 | Magid DJ, Ho PM, Olson KL, Brand DW, Welch LK, Snow KE, et al. A multimodal blood pressure control intervention in 3 healthcare systems. Am J Manag Care. 2011;17(4):e96–e103. | X1
329 | Mahrer-Imhof R, Froelicher ES, Li WW, Parker KM, Benowitz N. Women's Initiative for Nonsmoking (WINS V): under-use of nicotine replacement therapy. Heart Lung. 2002 Sep–Oct;31(5):368–73. | X13
330 | Mahtani Kamal R, Heneghan Carl J, Glasziou Paul P, Perera R. Reminder packaging for improving adherence to self-administered long-term medications. Cochrane Database of Systematic Reviews. 2011(9). | X10
331 | Maier C, Mustapic D, Schuster E, Luger A, Eher R. Effect of a pocket-size tablet-dispensing device on glycaemic control in Type 2 diabetic patients. Diabet Med. 2006 Jan;23(1):40–5. | X12
332 | Maljanian R, Grey N, Staff I, Conroy L. Intensive telephone follow-up to a hospital-based disease management model for patients with diabetes mellitus. Dis Manag. 2005 Feb;8(1):15–25. | X12
333 | Malone M, Alger-Mayer SA. Pharmacist intervention enhances adherence to orlistat therapy. Ann Pharmacother. 2003 Nov;37(11):1598–602. | X8
334 | Malotte CK, Hollingshead JR, Larro M. Incentives vs outreach workers for latent tuberculosis treatment in drug users. Am J Prev Med. 2001 Feb;20(2):103–7. | X4
335 | Maly RC, Bourque LB, Engelhardt RF. A randomized controlled trial of facilitating information giving to patients with chronic medical conditions: effects on outcomes of care. J Fam Pract. 1999 May;48(5):356–63. | X12
336 | Mann T. Effects of future writing and optimism on health behaviors in HIV-infected women. nn Behav Med. 2001 Winter;23(1):26–33. | X3
337 | Mannheimer SB, Morse E, Matts JP, Andrews L, Child C, Schmetter B, et al. Sustained benefit from a long-term antiretroviral adherence intervention. Results of a large randomized clinical trial. J Acquir Immune Defic Syndr. 2006 Dec 1;43 Suppl 1:S41–7. | X4
338 | Man-Son-Hing M, Laupacis A, O'Connor AM, Biggs J, Drake E, Yetisir E, et al. A patient decision aid regarding antithrombotic therapy for stroke prevention in atrial fibrillation: a randomized controlled trial. JAMA. 1999 Aug 25;282(8):737–43. | X1
339 | Mansoor LE, Dowse R. Medicines information and adherence in HIV/AIDS patients. J Clin Pharm Ther. 2006 Feb;31(1):7–15. | X4
340 | Marino EL, Alvarez-Rubio L, Miro S, Modamio P, Banos F, Lastra CF, et al. Pharmacist intervention in treatment of patients with genotype 1 chronic hepatitis C. Journal of managed care pharmacy : JMCP. 2009 Mar;15(2):147–50. | X7
341 | Markowitz JC, Kocsis JH, Fishman B, Spielman LA, Jacobsberg LB, Frances AJ, et al. Treatment of depressive symptoms in human immunodeficiency virus-positive patients. Arch Gen Psychiatry. 1998 May;55(5):452–7. | X4
342 | Marlowe DB, Kirby KC, Festinger DS, Merikle EP, Tran GQ, Platt JJ. Day treatment for cocaine dependence: incremental utility over outpatient counseling and voucher incentives. Addict Behav. 2003 Mar;28(2):387–98. | X1
343 | Martin J, Sabugal GM, Rubio R, Sainz-Maza M, Blanco JM, Alonso JL, et al. Outcomes of a health education intervention in a sample of patients infected by HIV, most of them injection drug users: possibilities and limitations. AIDS Care. 2001 Aug;13(4):467–73. | X8
344 | Martino S, Carroll KM, Nich C, Rounsaville BJ. A randomized controlled pilot study of motivational interviewing for patients with psychotic and drug use disorders. Addiction. 2006 Oct;101(10):1479–92. | X4
345 | Marwick TH, Branagan H, Venkatesh B, Stewart S. Use of a nurse-led intervention to optimize beta-blockade for reducing cardiac events after major noncardiac surgery. Am Heart J. 2009 Apr;157(4):784–90. | X3
346 | Matteson ML, Russell C. Interventions to improve hemodialysis adherence: a systematic review of randomized-controlled trials (Provisional abstract). Hemodialysis International. 2010(4):370–82. | X1
347 | Mattke S, Jain AK, Sloss EM, Hirscher R, Bergamo G, O'Leary JF. Effect of disease management on prescription drug treatment: what is the right quality measure? Dis Manag. 2007 Apr;10(2):91–100. | X5
348 | McCullough ML, Bostick RM, Daniel CR, Flanders WD, Shaukat A, Davison J, et al. Vitamin D status and impact of vitamin D3 and/or calcium supplementation in a randomized pilot study in the Southeastern United States. J Am Coll Nutr. 2009 Dec;28(6):678–86. | X1
349 | McDonald HP, Garg AX, Haynes RB. Interventions to enhance patient adherence to medication prescriptions (Brief record). JAMA. 2002(22):2868–78. | X14
350 | McDonough RP, Doucette WR. Drug therapy management: an empirical report of drug therapy problems, pharmacists' interventions, and results of pharmacists' actions. J Am Pharm Assoc (2003). 2003 Jul–Aug;43(4):511–8. | X7
351 | McIntosh A, Conlon L, Lawrie S, Stanfield Andrew C. Compliance therapy for schizophrenia. Cochrane Database of Systematic Reviews. 2006(3). | X4
352 | McMurdo ME, Price RJ, Shields M, Potter J, Stott DJ. Should oral nutritional supplementation be given to undernourished older people upon hospital discharge? A controlled trial. J Am Geriatr Soc. 2009 Dec;57(12):2239–45. | X1
353 | Mehos BM, Saseen JJ, MacLaughlin EJ. Effect of pharmacist intervention and initiation of home blood pressure monitoring in patients with uncontrolled hypertension. Pharmacotherapy. 2000 Nov;20(11):1384–9. | X8
354 | Mengden T, Vetter H, Tousset E, Uen S. Management of patients with uncontrolled arterial hypertension--the role of electronic compliance monitoring, 24-h ambulatory blood pressure monitoring and Candesartan/HCTZ. BMC Cardiovasc Disord. 2006;6:36. | X3
355 | Miaskowski C, Dodd M, West C, Schumacher K, Paul SM, Tripathy D, et al. Randomized clinical trial of the effectiveness of a self-care intervention to improve cancer pain management. J Clin Oncol. 2004 May 1;22(9):1713–20. | X1
356 | Miklowitz DJ, George EL, Richards JA, Simoneau TL, Suddath RL. A randomized study of family-focused psychoeducation and pharmacotherapy in the outpatient management of bipolar disorder. Arch Gen Psychiatry. 2003 Sep;60(9):904–12. | X4
357 | Minozzi S, Amato L, Vecchi S, Davoli M, Kirchmayer U, Verster A. Oral naltrexone maintenance treatment for opioid dependence. Cochrane Database of Systematic Reviews. 2011(4). | X1
358 | Mitrani VB, McCabe BE, Robinson C, Weiss-Laxer NS, Feaster DJ. Structural Ecosystems Therapy for recovering HIV-positive women: child, mother, and parenting outcomes. Journal of family psychology : JFP : journal of the Division of Family Psychology of the American Psychological Association (Division 43). 2010 Dec;24(6):746–55. | X12
359 | Moayyedi P, Feltbower R, Crocombe W, Mason S, Atha P, Brown J, et al. The effectiveness of omeprazole, clarithromycin and tinidazole in eradicating Helicobacter pylori in a community screen and treat programme. Leeds Help Study Group. Aliment Pharmacol Ther. 2000 Jun;14(6):719–28. | X4
360 | Mohamed S, Rosenheck R, McEvoy J, Swartz M, Stroup S, Lieberman JA. Cross-sectional and longitudinal relationships between insight and attitudes toward medication and clinical outcomes in chronic schizophrenia. Schizophr Bull. 2009 Mar;35(2):336–46. | X1
361 | Montgomery EB, Jr., Lieberman A, Singh G, Fries JF. Patient education and health promotion can be effective in Parkinson's disease: a randomized controlled trial. PROPATH Advisory Board. Am J Med. 1994 Nov;97(5):429–35. | X12
362 | Mooney ME, Sayre SL, Hokanson PS, Stotts AL, Schmitz JM. Adding MEMS feedback to behavioral smoking cessation therapy increases compliance with bupropion: a replication and extension study. Addict Behav. 2007 Apr;32(4):875–80. | X13
363 | Morgenstern J, Morgan TJ, McCrady BS, Keller DS, Carroll KM. Manual-guided cognitive-behavioral therapy training: a promising method for disseminating empirically supported substance abuse treatments to the practice community. Psychol Addict Behav. 2001 Jun;15(2):83–8. | X12
364 | Morken G, Grawe RW, Widen JH. Effects of integrated treatment on antipsychotic medication adherence in a randomized trial in recent-onset schizophrenia. J Clin Psychiatry. 2007 Apr;68(4):566–71. | X3
365 | Morrison A, Wertheimer AI, Berger ML. Interventions to improve antihypertensive drug adherence: a quantitative review of trials (Structured abstract). Formulary. 2000;35(3):234–55. | X14
366 | Morrow DG, Weiner M, Deer MM, Young JM, Dunn S, McGuire P, et al. Patient-centered instructions for medications prescribed for the treatment of heart failure. Am J Geriatr Pharmacother. 2004 Mar;2(1):44–52. | X5
367 | Mugusi F, Mugusi S, Bakari M, Hejdemann B, Josiah R, Janabi M, et al. Enhancing adherence to antiretroviral therapy at the HIV clinic in resource constrained countries; the Tanzanian experience. Trop Med Int Health. 2009 Oct;14(10):1226–32. | X3
368 | Mullan B, Snyder M, Lindgren B, Finkelstein SM, Hertz MI. Home monitoring for lung transplant candidates. Progress in transplantation (Aliso Viejo, Calif). 2003 Sep;13(3):176–82. | X1
369 | Murphy DA, Lu MC, Martin D, Hoffman D, Marelich WD. Results of a pilot intervention trial to improve antiretroviral adherence among HIV-positive patients. J Assoc Nurses AIDS Care. 2002 Nov–Dec;13(6):57–69. | X8
370 | Murphy JM, Mahoney MC, Cummings KM, Hyland AJ, Lawvere S. A randomized trial to promote pharmacotherapy use and smoking cessation in a Medicaid population (United States). Cancer Causes Control. 2005 May;16(4):373–82. | X1
371 | Murray MD, Harris LE, Overhage JM, Zhou XH, Eckert GJ, Smith FE, et al. Failure of computerized treatment suggestions to improve health outcomes of outpatients with uncomplicated hypertension: results of a randomized controlled trial. Pharmacotherapy. 2004 Mar;24(3):324–37. | X1
372 | Murray MD, Young JM, Morrow DG, Weiner M, Tu W, Hoke SC, et al. Methodology of an ongoing, randomized, controlled trial to improve drug use for elderly patients with chronic heart failure. Am J Geriatr Pharmacother. 2004 Mar;2(1):53–65. | X12
373 | Muyingo SK, Walker AS, Reid A, Munderi P, Gibb DM, Ssali F, et al. Patterns of individual and population-level adherence to antiretroviral therapy and risk factors for poor adherence in the first year of the DART trial in Uganda and Zimbabwe. J Acquir Immune Defic Syndr. 2008 Aug 1;48(4):468–75. | X5
374 | Naar-King S, Parsons JT, Murphy D, Kolmodin K, Harris DR. A multisite randomized trial of a motivational intervention targeting multiple risks in youth living with HIV: initial effects on motivation, self-efficacy, and depression. J Adolesc Health. 2010 May;46(5):422–8. | X1
375 | Naar-King S, Parsons JT, Murphy DA, Chen X, Harris DR, Belzer ME. Improving health outcomes for youth living with the human immunodeficiency virus: a multisite randomized trial of a motivational intervention targeting multiple risk behaviors. Arch Pediatr Adolesc Med. 2009 Dec;163(12):1092–8. | X1
376 | Naber D, Lambert M. The CATIE and CUtLASS studies in schizophrenia: results and implications for clinicians. CNS Drugs. 2009 Aug 1;23(8):649–59. | X1
377 | Narita M, Kellman M, Franchini DL, McMillan ME, Hollender ES, Ashkin D. Short-course rifamycin and pyrazinamide treatment for latent tuberculosis infection in patients with HIV infection: the 2-year experience of a comprehensive community-based program in Broward County, Florida. Chest. 2002 Oct;122(4):1292–8. | X4
378 | Nazareth I, Burton A, Shulman S, Smith P, Haines A, Timberal H. A pharmacy discharge plan for hospitalized elderly patients--a randomized controlled trial. Age Ageing. 2001 Jan;30(1):33–40. | X3
379 | Neugut AI, Subar M, Wilde ET, Stratton S, Brouse CH, Hillyer GC, et al. Association between prescription co-payment amount and compliance with adjuvant hormonal therapy in women with early-stage breast cancer. J Clin Oncol. 2011;29(18):2534–42. | X5
380 | Niedermann K, Fransen J, Knols R, Uebelhart D. Gap between short- and long-term effects of patient education in rheumatoid arthritis patients: a systematic review (Provisional abstract). Arthritis and Rheumatism (Arthritis Care and Research). 2004(3):388–98. | X1
381 | Nielsen D, Ryg J, Nielsen W, Knold B, Nissen N, Brixen K. Patient education in groups increases knowledge of osteoporosis and adherence to treatment: a two-year randomized controlled trial. Patient Educ Couns. 2010 Nov;81(2):155–60. | X3
382 | Norman IJ, Coster S, McCrone P, Sibley A, Whittlesea C. A comparison of the clinical effectiveness and costs of mental health nurse supplementary prescribing and independent medical prescribing: a post-test control group study. BMC health services research. 2010;10:4. | X3
383 | Nyamathi A, Nahid P, Berg J, Burrage J, Christiani A, Aqtash S, et al. Efficacy of nurse case-managed intervention for latent tuberculosis among homeless subsamples. Nurs Res. 2008 Jan–Feb;57(1):33–9. | X4
384 | Nyamathi A, Stein JA, Schumann A, Tyler D. Latent variable assessment of outcomes in a nurse-managed intervention to increase latent tuberculosis treatment completion in homeless adults. Health Psychol. 2007 Jan;26(1):68–76. | X4
385 | Nyamathi AM, Christiani A, Nahid P, Gregerson P, Leake B. A randomized controlled trial of two treatment programs for homeless adults with latent tuberculosis infection. Int J Tuberc Lung Dis. 2006 Jul;10(7):775–82. | X4
386 | O'Connor PJ, Rush WA, Trence DL. Relative effectiveness of niacin and lovastatin for treatment of dyslipidemias in a health maintenance organization. J Fam Pract. 1997 May;44(5):462–7. | X1
387 | Odegard PS, Gray SL. Barriers to medication adherence in poorly controlled diabetes mellitus. Diabetes Educ. 2008 Jul–Aug;34(4):692–7. | X5
388 | O'Donnell C, Donohoe G, Sharkey L, Owens N, Migone M, Harries R, et al. Compliance therapy: a randomised controlled trial in schizophrenia. BMJ. 2003 Oct 11;327(7419):834. | X3
389 | Ogedegbe G, Schoenthaler A. A systematic review of the effects of home blood pressure monitoring on medication adherence (Structured abstract). J Clin Hypertens. 2006(3):174–80. | X2
390 | Ogedegbe G, Schoenthaler A, Richardson T, Lewis L, Belue R, Espinosa E, et al. An RCT of the effect of motivational interviewing on medication adherence in hypertensive African Americans: rationale and design. Contemporary clinical trials. 2007 Feb;28(2):169–81. | X12
391 | Ollivier L, Romand O, Marimoutou C, Michel R, Pognant C, Todesco A, et al. Use of short message service (SMS) to improve malaria chemoprophylaxis compliance after returning from a malaria endemic area. Malaria journal. 2009;8:236. | X3
392 | Olson KL, Delate T, Rasmussen J, Humphries TL, Merenich JA. Outcomes of patients discharged from pharmacy-managed cardiovascular disease management. Am J Manag Care. 2009 Aug;15(8):497–503. | X12
393 | Olthoff CM, Schouten JS, van de Borne BW, Webers CA. Noncompliance with ocular hypotensive treatment in patients with glaucoma or ocular hypertension: an evidence-based review (Structured abstract). Ophthalmology 2004:953–61. | X5
394 | Onyirimba F, Apter A, Reisine S, Litt M, McCusker C, Connors M, et al. Direct clinician-to-patient feedback discussion of inhaled steroid use: its effect on adherence. Ann Allergy Asthma Immunol. 2003 Apr;90(4):411–5. | X8
395 | Orton Lois C, Barnish G. Unit-dose packaged drugs for treating malaria. Cochrane Database of Systematic Reviews. 2005(2). | X4
396 | Oslin DW, Lynch KG, Pettinati HM, Kampman KM, Gariti P, Gelfand L, et al. A placebo-controlled randomized clinical trial of naltrexone in the context of different levels of psychosocial intervention. Alcohol Clin Exp Res. 2008 Jul;32(7):1299–308. | X12
397 | Oslin DW, Pettinati H, Volpicelli JR. Alcoholism treatment adherence: older age predicts better adherence and drinking outcomes. Am J Geriatr Psychiatry. 2002 Nov–Dec;10(6):740–7. | X7
398 | Owen RR, Hudson T, Thrush C, Thapa P, Armitage T, Landes RD. The effectiveness of guideline implementation strategies on improving antipsychotic medication management for schizophrenia. Med Care. 2008 Jul;46(7):686–91. | X12
399 | Owen-Smith A, Diclemente R, Wingood G. Complementary and alternative medicine use decreases adherence to HAART in HIV-positive women. AIDS Care. 2007 May;19(5):589–93. | X1
400 | Pampallona S, Bollini P, Tibaldi G, Kupelnick B, Munizza C. Patient adherence in the treatment of depression (Structured abstract). Br J Psychiatry 2002:104–9. | X5
401 | Pape GA, Hunt JS, Butler KL, Siemienczuk J, LeBlanc BH, Gillanders W, et al. Team-based care approach to cholesterol management in diabetes mellitus: two-year cluster randomized controlled trial. Arch Intern Med. 2011 Sep 12;171(16):1480–6. | X1
402 | Parsons JT, Golub SA, Rosof E, Holder C. Motivational interviewing and cognitive-behavioral intervention to improve HIV medication adherence among hazardous drinkers: a randomized controlled trial. J Acquir Immune Defic Syndr. 2007 Dec 1;46(4):443–50. | X4
403 | Parsons JT, Rosof E, Mustanski B. Medication adherence mediates the relationship between adherence self-efficacy and biological assessments of HIV health among those with alcohol use disorders. AIDS and behavior. 2008 Jan;12(1):95–103. | X13
404 | Patel UB, Ni Q, Clayton C, Lam P, Parks J. An attempt to improve antipsychotic medication adherence by feedback of medication possession ratio scores to prescribers. Popul Health Manag. 2010 Oct;13(5):269–74. | X4
405 | Patton K, Meyers J, Lewis BE. Enhancement of compliance among patients with hypertension. Am J Manag Care. 1997 Nov;3(11):1693–8. | X5
406 | Paulos CP, Nygren CE, Celedon C, Carcamo CA. Impact of a pharmaceutical care program in a community pharmacy on patients with dyslipidemia. Ann Pharmacother. 2005 May;39(5):939–43. | X12
407 | Peikes D, Chen A, Schore J, Brown R. Effects of care coordination on hospitalization, quality of care, and health care expenditures among Medicare beneficiaries: 15 randomized trials. JAMA. 2009 Feb 11;301(6):603–18. | X5
408 | Pekkala Eila T, Merinder Lars B. Psychoeducation for schizophrenia. Cochrane Database of Systematic Reviews. 2002(2). | X4
409 | Pencille LJ, Campbell ME, Van Houten HK, Shah ND, Mullan RJ, Swiglo BA, et al. Protocol for the Osteoporosis Choice trial. A pilot randomized trial of a decision aid in primary care practice. Trials. 2009;10:113. | X12
410 | Perahia DG, Quail D, Gandhi P, Walker DJ, Peveler RC. A randomized, controlled trial of duloxetine alone vs. duloxetine plus a telephone intervention in the treatment of depression. J Affect Disord. 2008 May;108(1–2):33–41. | X3
411 | Pereles L, Romonko L, Murzyn T, Hogan D, Silvius J, Stokes E, et al. Evaluation of a self-medication program. J Am Geriatr Soc. 1996 Feb;44(2):161–5. | X3
412 | Petersen L, Jeppesen P, Thorup A, Abel MB, Ohlenschlaeger J, Christensen TO, et al. A randomised multicentre trial of integrated versus standard treatment for patients with a first episode of psychotic illness. BMJ. 2005 Sep 17;331(7517):602. | X4
413 | Peters-Klimm F, Campbell S, Hermann K, Kunz CU, Muller-Tasch T, Szecsenyi J. Case management for patients with chronic systolic heart failure in primary care: the HICMan exploratory randomised controlled trial. Trials. 2010;11:56. | X1
414 | Peterson AM, Takiya L, Finley R. Meta-analysis of trials of interventions to improve medication adherence (Structured abstract). Am J Health Syst Pharm. 2003(7):657–65. | X14
415 | Peterson GM, Fitzmaurice KD, Naunton M, Vial JH, Stewart K, Krum H. Impact of pharmacist-conducted home visits on the outcomes of lipid-lowering drug therapy. J Clin Pharm Ther. 2004 Feb;29(1):23–30. | X3
416 | Pettinati HM, Volpicelli JR, Pierce JD, Jr., O'Brien CP. Improving naltrexone response: an intervention for medical practitioners to enhance medication compliance in alcohol dependent patients. J Addict Dis. 2000;19(1):71–83. | X5
417 | Peveler R, George C, Kinmonth AL, Campbell M, Thompson C. Effect of antidepressant drug counselling and information leaflets on adherence to drug treatment in primary care: randomised controlled trial. BMJ. 1999 Sep 4;319(7210):612–5. | X3
418 | Phumipamorn S, Pongwecharak J, Soorapan S, Pattharachayakul S. Effects of the pharmacist's input on glycaemic control and cardiovascular risks in Muslim diabetes. Prim Care Diabetes. 2008 Feb;2(1):31–7. | X3
419 | Piette JD, Weinberger M, McPhee SJ, Mah CA, Kraemer FB, Crapo LM. Do automated calls with nurse follow-up improve self-care and glycemic control among vulnerable patients with diabetes? Am J Med. 2000 Jan;108(1):20–7. | X12
420 | Pindolia VK, Stebelsky L, Romain TM, Luoma L, Nowak SN, Gillanders F. Mitigation of medication mishaps via medication therapy management. Ann Pharmacother. 2009 Apr;43(4):611–20. | X5
421 | Pladevall M, Brotons C, Gabriel R, Arnau A, Suarez C, de la Figuera M, et al. Multicenter cluster-randomized trial of a multifactorial intervention to improve antihypertensive medication adherence and blood pressure control among patients at high cardiovascular risk (the COM99 study). Circulation. 2010 Sep 21;122(12):1183–91. | X3
422 | Ponnusankar S, Surulivelrajan M, Anandamoorthy N, Suresh B. Assessment of impact of medication counseling on patients' medication knowledge and compliance in an outpatient clinic in South India. Patient Educ Couns. 2004 Jul;54(1):55–60. | X3
423 | Porthouse J, Cockayne S, King C, Saxon L, Steele E, Aspray T, et al. Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 2005 Apr 30;330(7498):1003. | X13
424 | Post DM, Cegala DJ, Marinelli TM. Teaching patients to communicate with physicians: the impact of race. J Natl Med Assoc. 2001 Jan;93(1):6–12. | X5
425 | Poston WS, Haddock CK, Pinkston MM, Pace P, Reeves RS, Karakoc N, et al. Evaluation of a primary care-oriented brief counselling intervention for obesity with and without orlistat. J Intern Med. 2006 Oct;260(4):388–98. | X1
426 | Pradier C, Bentz L, Spire B, Tourette-Turgis C, Morin M, Souville M, et al. Efficacy of an educational and counseling intervention on adherence to highly active antiretroviral therapy: French prospective controlled study. HIV clinical trials. 2003 Mar–Apr;4(2):121–31. | X4
427 | Preston KL, Silverman K, Umbricht A, DeJesus A, Montoya ID, Schuster CR. Improvement in naltrexone treatment compliance with contingency management. Drug Alcohol Depend. 1999 Apr 1;54(2):127–35. | X4
428 | Price LM. Transition to Community: a program to help clients with schizophrenia move from inpatient to community care; a pilot study. Arch Psychiatr Nurs. 2007 Dec;21(6):336–44. | X8
429 | Priebe S, Burton A, Ashby D, Ashcroft R, Burns T, David A, et al. Financial incentives to improve adherence to anti-psychotic maintenance medication in non-adherent patients - a cluster randomised controlled trial (FIAT). BMC psychiatry. 2009;9:61. | X1
430 | Purcell DW, Latka MH, Metsch LR, Latkin CA, Gomez CA, Mizuno Y, et al. Results from a randomized controlled trial of a peer-mentoring intervention to reduce HIV transmission and increase access to care and adherence to HIV medications among HIV-seropositive injection drug users. J Acquir Immune Defic Syndr. 2007 Nov 1;46 Suppl 2:S35–47. | X4
431 | Puschner B, Angermeyer MC, Leese M, Thornicroft G, Schene A, Kikkert M, et al. Course of adherence to medication and quality of life in people with schizophrenia. Psychiatry Res. 2009 Feb 28;165(3):224–33. | X3
432 | Putnam DE, Finney JW, Barkley PL, Bonner MJ. Enhancing commitment improves adherence to a medical regimen. J Consult Clin Psychol. 1994 Feb;62(1):191–4. | X4
433 | Quinn CC, Clough SS, Minor JM, Lender D, Okafor MC, Gruber-Baldini A. WellDoc mobile diabetes management randomized controlled trial: change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008 Jun;10(3):160–8. | X8
434 | Rabarijaona L, Boisier P, Ratsirahonana O, Razafinimanana J, Rakotomanana F, Ratsitorahina M, et al. Replacement of streptomycin by ethambutol in the intensive phase of tuberculosis treatment: no effect on compliance. Int J Tuberc Lung Dis. 1999 Jan;3(1):42–6. | X4
435 | Racelis MC, Lombardo K, Verdin J. Impact of telephone reinforcement of risk reduction education on patient compliance. J Vasc Nurs. 1998 Mar;16(1):16–20. | X1
436 | Rahman MM, Dondorp AM, Day NP, Lindegardh N, Imwong M, Faiz MA, et al. Adherence and efficacy of supervised versus non-supervised treatment with artemether/lumefantrine for the treatment of uncomplicated Plasmodium falciparum malaria in Bangladesh: a randomised controlled trial. Trans R Soc Trop Med Hyg. 2008 Sep;102(9):861–7. | X12
437 | Rand CS, Nides M, Cowles MK, Wise RA, Connett J. Long-term metered-dose inhaler adherence in a clinical trial. The Lung Health Study Research Group. Am J Respir Crit Care Med. 1995 Aug;152(2):580–8. | X12
438 | Rathbun RC, Farmer KC, Lockhart SM, Stephens JR. Validity of a stage of change instrument in assessing medication adherence in indigent patients with HIV infection. Ann Pharmacother. 2007 Feb;41(2):208–14. | X8
439 | Rauch B, Schiele R, Schneider S, Diller F, Victor N, Gohlke H, et al. OMEGA, a randomized, placebo-controlled trial to test the effect of highly purified omega-3 fatty acids on top of modern guideline-adjusted therapy after myocardial infarction. Circulation. 2010 Nov 23;122(21):2152–9. | X1
440 | Rawlings MK, Thompson MA, Farthing CF, Brown LS, Racine J, Scott RC, et al. Impact of an educational program on efficacy and adherence with a twice-daily lamivudine/zidovudine/abacavir regimen in underrepresented HIV-infected patients. J Acquir Immune Defic Syndr. 2003 Oct 1;34(2):174–83. | X4
441 | Rawson RA, Huber A, McCann M, Shoptaw S, Farabee D, Reiber C, et al. A comparison of contingency management and cognitive-behavioral approaches during methadone maintenance treatment for cocaine dependence. Arch Gen Psychiatry. 2002 Sep;59(9):817–24. | X12
442 | Recker RR, Gallagher R, MacCosbe PE. Effect of dosing frequency on bisphosphonate medication adherence in a large longitudinal cohort of women. Mayo Clin Proc. 2005 Jul;80(7):856–61. | X2
443 | Reid SC, Teesson M, Sannibale C, Matsuda M, Haber PS. The efficacy of compliance therapy in pharmacotherapy for alcohol dependence: a randomized controlled trial. J Stud Alcohol. 2005 Nov;66(6):833–41. | X3
444 | Remien RH, Stirratt MJ, Dolezal C, Dognin JS, Wagner GJ, Carballo-Dieguez A, et al. Couple-focused support to improve HIV medication adherence: a randomized controlled trial. AIDS. 2005 May 20;19(8):807–14. | X4
445 | Reuben DB, Frank JC, Hirsch SH, McGuigan KA, Maly RC. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc. 1999 Mar;47(3):269–76. | X12
446 | Reynolds NR, Testa MA, Su M, Chesney MA, Neidig JL, Frank I, et al. Telephone support to improve antiretroviral medication adherence: a multisite, randomized controlled trial. J Acquir Immune Defic Syndr. 2008 Jan 1;47(1):62–8. | X4
447 | Richter A, Anton SF, Koch P, Dennett SL. The impact of reducing dose frequency on health outcomes (Provisional abstract). Clin Ther. 2003(8):2307–35. | X1
448 | Rickles NM, Svarstad BL, Statz-Paynter JL, Taylor LV, Kobak KA. Improving patient feedback about and outcomes with antidepressant treatment: a study in eight community pharmacies. J Am Pharm Assoc (2003). 2006 Jan–Feb;46(1):25–32. | X5
449 | Rigsby MO, Rosen MI, Beauvais JE, Cramer JA, Rainey PM, O'Malley SS, et al. Cue-dose training with monetary reinforcement: pilot study of an antiretroviral adherence intervention. J Gen Intern Med. 2000 Dec;15(12):841–7. | X4
450 | Rinfret S, Lussier MT, Peirce A, Duhamel F, Cossette S, Lalonde L, et al. The impact of a multidisciplinary information technology-supported program on blood pressure control in primary care. Circulation Cardiovascular quality and outcomes. 2009 May;2(3):170–7. | X3
451 | Rivera-Sarate S, Gonzalez-Cordero ML, Gutierrez-Collazo LM, Rios-Motta R. Knowledge, compliance, and satisfaction: an evaluation of the SIMPLE program. Consult Pharm. 2009 Nov;24(11):823–32. | X5
452 | Robbins JM, Cleves MA, Collins HB, Andrews N, Smith LN, Hobbs CA. Randomized trial of a physician-based intervention to increase the use of folic acid supplements among women. Am J Obstet Gynecol. 2005 Apr;192(4):1126–32. | X13
453 | Robinson P, Katon W, Von Korff M, Bush T, Simon G, Lin E, et al. The education of depressed primary care patients: what do patients think of interactive booklets and a video? J Fam Pract. 1997 Jun;44(6):562–71. | X12
454 | Roblin DW, Platt R, Goodman MJ, Hsu J, Nelson WW, Smith DH, et al. Effect of increased cost-sharing on oral hypoglycemic use in five managed care organizations: how much is too much? Med Care. 2005 Oct;43(10):951–9. | X1
455 | Roca B, Gomez CJ, Arnedo A. A randomized, comparative study of lamivudine plus stavudine, with indinavir or nelfinavir, in treatment-experienced HIV-infected patients. AIDS. 2000 Jan 28;14(2):157–61. | X4
456 | Rohsenow DJ, Colby SM, Monti PM, Swift RM, Martin RA, Mueller TI, et al. Predictors of compliance with naltrexone among alcoholics. Alcohol Clin Exp Res. 2000 Oct;24(10):1542–9. | X1
457 | Rondanelli M, Giacosa A, Opizzi A, Pelucchi C, La Vecchia C, Montorfano G, et al. Effect of omega-3 fatty acids supplementation on depressive symptoms and on health-related quality of life in the treatment of elderly women with depression: a double-blind, placebo-controlled, randomized clinical trial. J Am Coll Nutr. 2010 Feb;29(1):55–64. | X1
458 | Rondinini L, Coceani M, Borelli G, Guideri S, Chini C, Frediani MR, et al. Survival and hospitalization in a nurse-led domiciliary intervention for elderly heart failure patients. J Cardiovasc Med (Hagerstown). 2008 May;9(5):470–5. | X12
459 | Rosal MC, Olendzki B, Reed GW, Gumieniak O, Scavron J, Ockene I. Diabetes self-management among low-income Spanish-speaking patients: a pilot study. nn Behav Med. 2005 Jun;29(3):225–35. | X12
460 | Rosen MI, Dieckhaus K, McMahon TJ, Valdes B, Petry NM, Cramer J, et al. Improved adherence with contingency management. Aids Patient Care STDS. 2007 Jan;21(1):30–40. | X4
461 | Rosen MI, Rigsby MO, Salahi JT, Ryan CE, Cramer JA. Electronic monitoring and counseling to improve medication adherence. Behav Res Ther. 2004 Apr;42(4):409–22. | X8
462 | Rosenzweig M, Brufsky A, Rastogi P, Puhalla S, Simon J, Underwood S. The attitudes, communication, treatment, and support intervention to reduce breast cancer treatment disparity. Oncol Nurs Forum. 2011 Jan 1;38(1):85–9. | X8
463 | Rost K, Nutting P, Smith J, Werner J, Duan N. Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. J Gen Intern Med. 2001 Mar;16(3):143–9. | X1
464 | Rotheram-Borus MJ, Swendeman D, Comulada WS, Weiss RE, Lee M, Lightfoot M. Prevention for substance-using HIV-positive young people: telephone and in-person delivery. J Acquir Immune Defic Syndr. 2004 Oct 1;37 Suppl 2:S68–77. | X4
465 | Rothert ML, Holmes-Rovner M, Rovner D, Kroll J, Breer L, Talarczyk G, et al. An educational intervention as decision support for menopausal women. Res Nurs Health. 1997 Oct;20(5):377–87. | X12
466 | Rubak S, Sandbaek A, Lauritzen T, Borch-Johnsen K, Christensen B. Effect of "motivational interviewing" on quality of care measures in screen detected type 2 diabetes patients: a one-year follow-up of an RCT, ADDITION Denmark. Scand J Prim Health Care. 2011 Jun;29(2):92–8. | X3
467 | Rubio-Valera M, Serrano-Blanco A, Trave P, Penarrubia-Maria MT, Ruiz M, Pujol MM. Community pharmacist intervention in depressed primary care patients (PRODEFAR study): randomized controlled trial protocol. BMC public health. 2009;9:284. | X12
468 | Rueda S, Park-Wyllie Laura Y, Bayoumi A, Tynan A-M, Antoniou T, Rourke S, et al. Patient support and education for promoting adherence to highly active antiretroviral therapy for HIV/AIDS. Cochrane Database of Systematic Reviews. 2006(3). | X4
469 | Ruppar TM, Conn VS, Russell CL. Medication adherence interventions for older adults: literature review. Res Theory Nurs Pract. 2008;22(2):114–47. | X5
470 | Russell CL, Ruppar TM, Matteson M. Improving medication adherence: moving from intention and motivation to a personal systems approach. Nurs Clin North Am. 2011 Sep;46(3):271–81, v. | X5
471 | Ryan R, Santesso N, Hill S, Lowe D, Kaufman C, Grimshaw J. Consumer-oriented interventions for evidence-based prescribing and medicines use: an overview of systematic reviews. Cochrane Database of Systematic Reviews. 2011(5). | X2
472 | Sajatovic M, Davies MA, Ganocy SJ, Bauer MS, Cassidy KA, Hays RW, et al. A comparison of the life goals program and treatment as usual for individuals with bipolar disorder. Psychiatr Serv. 2009 Sep;60(9):1182–9. | X12
473 | Samet JH, Horton NJ, Meli S, Dukes K, Tripps T, Sullivan L, et al. A randomized controlled trial to enhance antiretroviral therapy adherence in patients with a history of alcohol problems. Antivir Ther. 2005;10(1):83–93. | X4
474 | Santschi V, Rodondi N, Bugnon O, Burnier M. Impact of electronic monitoring of drug adherence on blood pressure control in primary care: a cluster 12-month randomised controlled study. Eur J Intern Med. 2008 Oct;19(6):427–34. | X12
475 | Schectman JM, Schorling JB, Nadkarni MM, Lyman JA, Siadaty MS, Voss JD. The effect of physician feedback and an action checklist on diabetes care measures. Am J Med Qual. 2004 Sep–Oct;19(5):207–13. | X7
476 | Schedlbauer A, Davies P, Fahey T. Interventions to improve adherence to lipid lowering medication. Cochrane Database of Systematic Reviews. 2010(3). | X14
477 | Schedlbauer A, Schroeder K, Fahey T. How can adherence to lipid-lowering medication be improved: a systematic review of randomized controlled trials (Brief record). Fam Pract. 2007(4):380–7. | X14
478 | Schlenk EA, Dunbar-Jacob J, Engberg S. Medication non-adherence among older adults: a review of strategies and interventions for improvement. J Gerontol Nurs. 2004 Jul;30(7):33–43. | X5
479 | Schmittdiel JA, Steers N, Duru OK, Ettner SL, Brown AF, Fung V, et al. Patient-provider communication regarding drug costs in Medicare Part D beneficiaries with diabetes: a TRIAD Study. BMC health services research. 2010;10:164. | X5
480 | Schmitz JM, Sayre SL, Stotts AL, Rothfleisch J, Mooney ME. Medication compliance during a smoking cessation clinical trial: a brief intervention using MEMS feedback. J Behav Med. 2005 Apr;28(2):139–47. | X4
481 | Schnoll RA, Patterson F, Wileyto EP, Heitjan DF, Shields AE, Asch DA, et al. Effectiveness of extended-duration transdermal nicotine therapy: a randomized trial. Ann Intern Med. 2010 Feb 2;152(3):144–51. | X1
482 | Schnoor M, Meyer T, Suttorp N, Raspe H, Welte T, Schafer T. Development and evaluation of an implementation strategy for the German guideline on community-acquired pneumonia. Qual Saf Health Care. 2010 Dec;19(6):498–502. | X1
483 | Schousboe J, Debold C, Kuno L. Education and phone follow-up in post menopausal women at risk of osteoporosis. Effects of Calcium intake, Exercise Frequency, and Medication Use. Dis Manage Health Outcomes. 2005:395–404. | X12
484 | Schrader SL, Dressing B, Blue R, Jensen G, Miller D, Zawada ET. The Medication Reduction Project: combating polypharmacy in South Dakota elders through community-based interventions. S D J Med. 1996 Dec;49(12):441–8. | X5
485 | Schroeder K, Fahey T, Ebrahim S. Interventions for improving adherence to treatment in patients with high blood pressure in ambulatory settings. Cochrane Database of Systematic Reviews. 2004(3). | X14
486 | Schroeder K, Fahey T, Ebrahim S. How can we improve adherence to blood pressure-lowering medication in ambulatory care? (Brief record). Arch Intern Med. 2004(7):722–32. | X14
487 | Schumann A, Nyamathi A, Stein JA. HIV risk reduction in a nurse case-managed TB and HIV intervention among homeless adults. J Health Psychol. 2007 Sep;12(5):833–43. | X12
488 | Seck BC, Jackson RT. Determinants of compliance with iron supplementation among pregnant women in Senegal. Public Health Nutr. 2008 Jun;11(6):596–605. | X3
489 | Sedjo RL, Cox ER. Lowering copayments: impact of simvastatin patent expiration on patient adherence. Am J Manag Care. 2008 Dec;14(12):813–8. | X5
490 | Sedjo RL, Cox ER. The influence of targeted education on medication persistence and generic substitution among consumer-directed health care enrollees. Health Serv Res. 2009 Dec;44(6):2079–92. | X5
491 | Sellwood W, Barrowclough C, Tarrier N, Quinn J, Mainwaring J, Lewis S. Needs-based cognitive-behavioural family intervention for carers of patients suffering from schizophrenia: 12-month follow-up. Acta Psychiatr Scand. 2001 Nov;104(5):346–55. | X4
492 | Sharpe M, Hawton K, Simkin S, Surawy C, Hackmann A, Klimes I, et al. Cognitive behaviour therapy for the chronic fatigue syndrome: a randomized controlled trial. BMJ. 1996 Jan 6;312(7022):22–6. | X3
493 | Shearer J. Improving oral medication management in home health agencies. Home Healthc Nurse. 2009 Mar;27(3):184–92. | X5
494 | Sherrard H, Struthers C, Kearns SA, Wells G, Chen L, Mesana T. Using technology to create a medication safety net for cardiac surgery patients: a nurse-led randomized control trial. Can J Cardiovasc Nurs. 2009;19(3):9–15. | X3
495 | Sherrill JT, Frank E, Geary M, Stack JA, Reynolds CF, 3rd. Psychoeducational workshops for elderly patients with recurrent major depression and their families. Psychiatr Serv. 1997 Jan;48(1):76–81. | X5
496 | Sikka R, Waters J, Moore W, Sutton DR, Herman WH, Aubert RE. Renal assessment practices and the effect of nurse case management of health maintenance organization patients with diabetes. Diabetes Care. 1999 Jan;22(1):1–6. | X12
497 | Simmons D, Upjohn M, Gamble GD. Can medication packaging improve glycemic control and blood pressure in 2 diabetes? Results from a randomized controlled trial. Diabetes Care. 2000;23(2):153–6. | X3
498 | Simon GE, Katon W, Rutter C, VonKorff M, Lin E, Robinson P, et al. Impact of improved depression treatment in primary care on daily functioning and disability. Psychol Med. 1998 May;28(3):693–701. | X12
499 | Simon GE, Katon WJ, VonKorff M, Unutzer J, Lin EH, Walker EA, et al. Cost-effectiveness of a collaborative care program for primary care patients with persistent depression. A J Psychiatry. 2001 Oct;158(10):1638–44. | X1
500 | Simon GE, Ludman EJ, Bauer MS, Unutzer J, Operskalski B. Long-term effectiveness and cost of a systematic care program for bipolar disorder. Arch Gen Psychiatry. 2006 May;63(5):500–8. | X12
501 | Simon GE, Manning WG, Katzelnick DJ, Pearson SD, Henk HJ, Helstad CS. Cost-effectiveness of systematic depression treatment for high utilizers of general medical care. Arch Gen Psychiatry. 2001 Feb;58(2):181–7. | X12
502 | Simon GE, Ralston JD, Savarino J, Pabiniak C, Wentzel C, Operskalski BH. Randomized trial of depression follow-up care by online messaging. J Gen Intern Med. 2011;26(7):698–704. | X1
503 | Simon JA, Lewiecki EM, Smith ME, Petruschke RA, Wang L, Palmisano JJ. Patient preference for once-weekly alendronate 70 mg versus once-daily alendronate 10 mg: a multicenter, randomized, open-label, crossover study. Clin Ther. 2002 Nov;24(11):1871–86. | X12
504 | Simoni JM, Frick PA, Pantalone DW, Turner BJ. Antiretroviral adherence interventions: a review of current literature and ongoing studies. Top HIV Med. 2003 Nov–Dec;11(6):185–98. | X3
505 | Simoni JM, Huh D, Frick PA, Pearson CR, Andrasik MP, Dunbar PJ, et al. Peer support and pager messaging to promote antiretroviral modifying therapy in Seattle: a randomized controlled trial. J Acquir Immune Defic Syndr. 2009 Dec 1;52(4):465–73. | X4
506 | Sit JW, Yip VY, Ko SK, Gun AP, Lee JS. A quasi-experimental study on a community-based stroke prevention programme for clients with minor stroke. J Clin Nurs. 2007 Feb;16(2):272–81. | X3
507 | Smith CE, Dauz E, Clements F, Werkowitch M, Whitman R. Patient education combined in a music and habit-forming intervention for adherence to continuous positive airway (CPAP) prescribed for sleep apnea. Patient Educ Couns. 2009 Feb;74(2):184–90. | X13
508 | Smith SR, Rublein JC, Marcus C, Brock TP, Chesney MA. A medication self-management program to improve adherence to HIV therapy regimens. Patient Educ Couns. 2003 Jun;50(2):187–99. | X4
509 | Smith-Rohrberg D, Mezger J, Walton M, Bruce RD, Altice FL. Impact of enhanced services on virologic outcomes in a directly administered antiretroviral therapy trial for HIV-infected drug users. J Acquir Immune Defic Syndr. 2006 Dec 1;43 Suppl 1:S48–53. | X12
510 | Solari A, Martinelli V, Trojano M, Lugaresi A, Granella F, Giordano A, et al. An information aid for newly diagnosed multiple sclerosis patients improves disease knowledge and satisfaction with care. Mult Scler. 2010 Nov;16(11):1393–405. | X3
511 | Solomon DH, Gleeson T, Iversen M, Avorn J, Brookhart MA, Lii J, et al. A blinded randomized controlled trial of motivational interviewing to improve adherence with osteoporosis medications: design of the OPTIMA trial. Osteoporos Int. 2010 Jan;21(1):137–44. | X12
512 | Solomon DH, Polinski JM, Stedman M, Truppo C, Breiner L, Egan C, et al. Improving care of patients at-risk for osteoporosis: a randomized controlled trial. J Gen Intern Med. 2007 Mar;22(3):362–7. | X1
513 | Solomon P, Draine J, Mannion E. The impact of individualized consultation and group workshop family education interventions in ill relative outcomes. J Nerv Ment Dis. 1996 Apr;184(4):252–5. | X13
514 | Sommaruga M, Spanevello A, Migliori GB, Neri M, Callegari S, Majani G. The effects of a cognitive behavioural intervention in asthmatic patients. Monaldi Arch Chest Dis. 1995 Oct;50(5):398–402. | X12
515 | Sookaneknun P, Richards RM, Sanguansermsri J, Teerasut C. Pharmacist involvement in primary care improves hypertensive patient clinical outcomes. Ann Pharmacother. 2004 Dec;38(12):2023–8. | X3
516 | Sorensen JL, Haug NA, Delucchi KL, Gruber V, Kletter E, Batki SL, et al. Voucher reinforcement improves medication adherence in HIV-positive methadone patients: a randomized trial. Drug Alcohol Depend. 2007 Apr 17;88(1):54–63. | X4
517 | Southard BH, Southard DR, Nuckolls J. Clinical trial of an Internet-based case management system for secondary prevention of heart disease. J Cardiopulm Rehabil. 2003 Sep–Oct;23(5):341–8. | X1
518 | Sovani MP, Whale CI, Oborne J, Cooper S, Mortimer K, Ekstrom T, et al. Poor adherence with inhaled corticosteroids for asthma: can using a single inhaler containing budesonide and formoterol help? Br J Gen Pract. 2008 Jan;58(546):37–43. | X3
519 | Spadaro A, De Luca T, Massimiani MP, Ceccarelli F, Riccieri V, Valesini G. Occupational therapy in ankylosing spondylitis: Short-term prospective study in patients treated with anti-TNF-alpha drugs. Joint Bone Spine. 2008 Jan;75(1):29–33. | X8
520 | Spaniel F, Vohlidka P, Hrdlicka J, Kozeny J, Novak T, Motlova L, et al. ITAREPS: information technology aided relapse prevention programme in schizophrenia. Schizophr Res. 2008 Jan;98(1–3):312–7. | X5
521 | Spiess K, Sachs G, Pietschmann P, Prager R. A program to reduce onset distress in unselected type I diabetic patients: effects on psychological variables and metabolic control. Eur J Endocrinol. 1995 May;132(5):580–6. | X8
522 | Stant AD, Castelein S, Bruggeman R, van Busschbach JT, van der Gaag M, Knegtering H, et al. Economic aspects of peer support groups for psychosis. Community Ment Health J. 2011 Feb;47(1):99–105. | X12
523 | Staring AB, Van der Gaag M, Koopmans GT, Selten JP, Van Beveren JM, Hengeveld MW, et al. Treatment adherence therapy in people with psychotic disorders: randomised controlled trial. Br J Psychiatry. 2010 Dec;197:448–55. | X3
524 | Stein MD, Solomon DA, Herman DS, Anthony JL, Ramsey SE, Anderson BJ, et al. Pharmacotherapy plus psychotherapy for treatment of depression in active injection drug users. Arch Gen Psychiatry. 2004 Feb;61(2):152–9. | X1
525 | Stevens VJ, Shneidman RJ, Johnson RE, Boles M, Steele PE, Lee NL. Helicobacter pylori eradication in dyspeptic primary care patients: a randomized controlled trial of a pharmacy intervention. West J Med. 2002 Mar;176(2):92–6. | X13
526 | Stewart A, Noakes T, Eales C, Shepard K, Becker P, Veriawa Y. Adherence to cardiovascular risk factor modification in patients with hypertension. Cardiovasc J S Afr. 2005 Mar–Apr;16(2):102–7. | X3
527 | Stilley CS, Bender CM, Dunbar-Jacob J, Sereika S, Ryan CM. The impact of cognitive function on medication management: three studies. Health Psychol. 2010 Jan;29(1):50–5. | X1
528 | Stringer JS, Sinkala M, Stout JP, Goldenberg RL, Acosta EP, Chapman V, et al. Comparison of two strategies for administering nevirapine to prevent perinatal HIV transmission in high-prevalence, resource-poor settings. J Acquir Immune Defic Syndr. 2003 Apr 15;32(5):506–13. | X13
529 | Strinko JM, Di Bisceglie AM, Hoffmann JA. A descriptive study of the relationship between mood disorders and hepatitis C treatment compliance: does nursing play a role? Issues Ment Health Nurs. 2004 Oct–Nov;25(7):715–22. | X1
530 | Strom O, Borgstrom F, Kanis JA, Jonsson B. Incorporating adherence into health economic modelling of osteoporosis. Osteoporos Int. 2009 Jan;20(1):23–34. | X1
531 | Stromberg A, Dahlstrom U, Fridlund B. Computer-based education for patients with chronic heart failure. A randomised, controlled, multicentre trial of the effects on knowledge, compliance and quality of life. Patient Educ Couns. 2006 Dec;64(1–3):128–35. | X3
532 | Stroup TS, Lieberman JA, McEvoy JP, Davis SM, Swartz MS, Keefe RS, et al. Results of phase 3 of the CATIE schizophrenia trial. Schizophr Res. 2009 Jan;107(1):1–12. | X1
533 | Sturgess IK, McElnay JC, Hughes CM, Crealey G. Community pharmacy based provision of pharmaceutical care to older patients. Pharm World Sci. 2003 Oct;25(5):218–26. | X3
534 | Su WJ, Perng RP. Fixed-dose combination chemotherapy (Rifater/Rifinah) for active pulmonary tuberculosis in Taiwan: a two-year follow-up. Int J Tuberc Lung Dis. 2002 Nov;6(11):1029–32. | X3
535 | Sullivan LE, Barry D, Moore BA, Chawarski MC, Tetrault JM, Pantalon MV, et al. A trial of integrated buprenorphine/naloxone and HIV clinical care. Clin Infect Dis. 2006 Dec 15;43 Suppl 4:S184–90. | X8
536 | Swan GE, McClure JB, Jack LM, Zbikowski SM, Javitz HS, Catz SL, et al. Behavioral counseling and varenicline treatment for smoking cessation. Am J Prev Med. 2010 May;38(5):482–90. | X1
537 | Swanson AJ, Pantalon MV, Cohen KR. Motivational interviewing and treatment adherence among psychiatric and dually diagnosed patients. J Nerv Ment Dis. 1999 Oct;187(10):630–5. | X12
538 | Sylvestre DL, Clements BJ. Adherence to hepatitis C treatment in recovering heroin users maintained on methadone. Eur J Gastroenterol Hepatol. 2007 Sep;19(9):741–7. | X1
539 | Tamblyn R, Reidel K, Huang A, Taylor L, Winslade N, Bartlett G, et al. Increasing the detection and response to adherence problems with cardiovascular medication in primary care through computerized drug management systems: a randomized controlled trial. Med Decis Making. 2010 Mar–Apr;30(2):176–88. | X3
540 | Tanner JL, Craig CB, Bartolucci AA, Allon M, Fox LM, Geiger BF, et al. The effect of a self-monitoring tool on self-efficacy, health beliefs, and adherence in patients receiving hemodialysis. J Ren Nutr. 1998 Oct;8(4):203–11. | X12
541 | Taylor CR, Hepworth JT, Buerhaus PI, Dittus R, Speroff T. Effect of crew resource management on diabetes care and patient outcomes in an inner-city primary care clinic. Qual Saf Health Care. 2007 Aug;16(4):244–7. | X1
542 | Taylor R, Mallinger AG, Frank E, Rucci P, Thase ME, Kupfer DJ. Variability of erythrocyte and serum lithium levels correlates with therapist treatment adherence efforts and maintenance treatment outcome. Neuropsychopharmacology. 2001 Feb;24(2):192–7. | X4
543 | Telles C, Karno M, Mintz J, Paz G, Arias M, Tucker D, et al. Immigrant families coping with schizophrenia. Behavioral family intervention v. case management with a low-income Spanish-speaking population. Br J Psychiatry. 1995 Oct;167(4):473–9. | X4
544 | Thiebaud P, Demand M, Wolf SA, Alipuria LL, Ye Q, Gutierrez PR. Impact of disease management on utilization and adherence with drugs and tests: the case of diabetes treatment in the Florida: a Healthy State (FAHS) program. Diabetes Care. 2008 Sep;31(9):1717–22. | X5
545 | Thom DH. Training physicians to increase patient trust. J Eval Clin Pract. 2000 Aug;6(3):245–53. | X8
546 | Thom DH, Bloch DA, Segal ES. An intervention to increase patients' trust in their physicians. Stanford Trust Study Physician Group. Acad Med. 1999 Feb;74(2):195–8. | X12
547 | Tierney WM, Overhage JM, Murray MD, Harris LE, Zhou XH, Eckert GJ, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003 Dec;18(12):967–76. | X1
548 | Tierney WM, Overhage JM, Murray MD, Harris LE, Zhou XH, Eckert GJ, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005 Apr;40(2):477–97. | X1
549 | Tinoco I, Giron-Gonzalez JA, Gonzalez-Gonzalez MT, Vergara de Campos A, Rodriguez-Felix L, Serrano A, et al. Efficacy of directly observed treatment of HIV infection: experience in AIDS welfare homes. Eur J Clin Microbiol Infect Dis. 2004 Apr;23(4):331–5. | X4
550 | Toelle B, Ram Felix SF. Written individualised management plans for asthma in children and adults. Cochrane Database of Systematic Reviews. 2004(1). | X14
551 | Toelle B, Ram Felix SF. Written individualised management plans for asthma in children and adults. Cochrane Database of Systematic Reviews. 2011(7). | X14
552 | Toh S, Hernandez-Diaz S, Logan R, Rossouw JE, Hernan MA. Coronary heart disease in postmenopausal recipients of estrogen plus progestin therapy: does the increased risk ever disappear? A randomized trial. Ann Intern Med. 2010 Feb 16;152(4):211–7. | X1
553 | Torti C, Quiros-Roldan E, Regazzi M, De Luca A, Mazzotta F, Antinori A, et al. A randomized controlled trial to evaluate antiretroviral salvage therapy guided by rules-based or phenotype-driven HIV-1 genotypic drug-resistance interpretation with or without concentration-controlled intervention: the Resistance and Dosage Adapted Regimens (RADAR) study. Clin Infect Dis. 2005 Jun 15;40(12):1828–36. | X12
554 | Trattler W, Noecker RJ, Earl ML. A multicentre evaluation of the effect of patient education on acceptance of hyperaemia associated with bimatoprost therapy for glaucoma or ocular hypertension. Adv Ther. 2008 Mar;25(3):179–89. | X12
555 | Trent M, Chung SE, Burke M, Walker A, Ellen JM. Results of a randomized controlled trial of a brief behavioral intervention for pelvic inflammatory disease in adolescents. J Pediatr Adolesc Gynecol. 2010 Apr;23(2):96–101. | X13
556 | Tsur L, Kozer E, Berkovitch M. The effect of drug consultation center guidance on contraceptive use among women using isotretinoin: a randomized, controlled study. Journal of women's health (2002). 2008 May;17(4):579–84. | X13
557 | Tsuyuki RT, Fradette M, Johnson JA, Bungard TJ, Eurich DT, Ashton T, et al. A multicenter disease management program for hospitalized patients with heart failure. J Card Fail. 2004 Dec;10(6):473–80. | X3
558 | Tuldra A, Fumaz CR, Ferrer MJ, Bayes R, Arno A, Balague M, et al. Prospective randomized two-Arm controlled study to determine the efficacy of a specific intervention to improve long-term adherence to highly active antiretroviral therapy. J Acquir Immune Defic Syndr. 2000 Nov 1;25(3):221–8. | X3
559 | Tulner LR, Frankfort SV, Wesselius F, van Campen JP, Koks CH, Beijnen JH. Do geriatric outpatients adhere to medication changes advised after assessment? An exploratory pilot study. Curr Clin Pharmacol. 2009 May;4(2):154–8. | X5
560 | Tulsky JP, Pilote L, Hahn JA, Zolopa AJ, Burke M, Chesney M, et al. Adherence to isoniazid prophylaxis in the homeless: a randomized controlled trial. Arch Intern Med. 2000 Mar 13;160(5):697–702. | X4
561 | Turner MO, Taylor D, Bennett R, Fitzgerald JM. A randomized trial comparing peak expiratory flow and symptom self-management plans for patients with asthma attending a primary care clinic. Am J Respir Crit Care Med. 1998 Feb;157(2):540–6. | X3
562 | Tutty S, Simon G, Ludman E. Telephone counseling as an adjunct to antidepressant treatment in the primary care system. A pilot study. Eff Clin Pract. 2000 Jul–Aug;3(4):170–8. | X5
563 | Ulrik CS, Claudius BK, Tamm M, Harving H, Siersted HC, Backer V, et al. Effect of asthma compliance enhancement training on asthma control in patients on combination therapy with salmeterol/fluticasone propionate: a randomised controlled trial. Clin Respir J. 2009 Jul;3(3):161–8. | X12
564 | Vale MJ, Jelinek MV, Best JD, Santamaria JD. Coaching patients with coronary heart disease to achieve the target cholesterol: a method to bridge the gap between evidence-based medicine and the "real world"--randomized controlled trial. J Clin Epidemiol. 2002 Mar;55(3):245–52. | X12
565 | Valenstein M, Copeland LA, Blow FC, McCarthy JF, Zeber JE, Gillon L, et al. Pharmacy data identify poorly adherent patients with schizophrenia at increased risk for admission. Med Care. 2002 Aug;40(8):630–9. | X1
566 | van Bastelaar KM, Pouwer F, Cuijpers P, Twisk JW, Snoek FJ. Web-based cognitive behavioural therapy (W-CBT) for diabetes patients with co-morbid depression: design of a randomised controlled trial. BMC psychiatry. 2008;8:9. | X12
567 | van den Brink W, Hendriks VM, Blanken P, Koeter MW, van Zwieten BJ, van Ree JM. Medical prescription of heroin to treatment resistant heroin addicts: two randomised controlled trials. BMJ. 2003 Aug 9;327(7410):310. | X3
568 | van der Meer FJ, Briet E, Vandenbroucke JP, Sramek DI, Versluijs MH, Rosendaal FR. The role of compliance as a cause of instability in oral anticoagulant therapy. Br J Haematol. 1997 Sep;98(4):893–900. | X1
569 | van der Meij BS, Langius JA, Smit EF, Spreeuwenberg MD, von Blomberg BM, Heijboer AC, et al. Oral nutritional supplements containing (n-3) polyunsaturated fatty acids affect the nutritional status of patients with stage III non-small cell lung cancer during multimodality treatment. J Nutr. 2010 Oct;140(10):1774–80. | X1
570 | van Es SM, Nagelkerke AF, Colland VT, Scholten RJ, Bouter LM. An intervention programme using the ASE-model aimed at enhancing adherence in adolescents with asthma. Patient Educ Couns. 2001 Sep;44(3):193–203. | X3
571 | van Grunsven PM, van Schayck CP, van Deuveren M, van Herwaarden CL, Akkermans RP, van Weel C. Compliance during long-term treatment with fluticasone propionate in subjects with early signs of asthma or chronic obstructive pulmonary disease (COPD): results of the Detection, Intervention, and Monitoring Program of COPD and Asthma (DIMCA) Study. J Asthma. 2000 May;37(3):225–34. | X1
572 | van Servellen G, Carpio F, Lopez M, Garcia-Teague L, Herrera G, Monterrosa F, et al. Program to enhance health literacy and treatment adherence in low-income HIV-infected Latino men and women. Aids Patient Care STDS. 2003 Nov;17(11):581–94. | X4
573 | van Servellen G, Nyamathi A, Carpio F, Pearce D, Garcia-Teague L, Herrera G, et al. Effects of a treatment adherence enhancement program on health literacy, patient-provider relationships, and adherence to HAART among low-income HIV-positive Spanish-speaking Latinos. Aids Patient Care STDS. 2005 Nov;19(11):745–59. | X4
574 | van Steenkiste B, van der Weijden T, Stoffers HE, Kester AD, Timmermans DR, Grol R. Improving cardiovascular risk management: a randomized, controlled trial on the effect of a decision support tool for patients and physicians. Eur J Cardiovasc Prev Rehabil. 2007 Feb;14(1):44–50. | X1
575 | Van Wijk BL, Klungel OH, Heerdink ER, de Boer A. Effectiveness of interventions by community pharmacists to improve patient adherence to chronic medication: a systematic review (Structured abstract). Ann Pharmacother. 2005(2):319–28. | X14
576 | Vanky E, Stridsklev S, Heimstad R, Romundstad P, Skogoy K, Kleggetveit O, et al. Metformin versus placebo from first trimester to delivery in polycystic ovary syndrome: a randomized, controlled multicenter study. J Clin Endocrinol Metab. 2010 Dec;95(12):E448–55. | X1
577 | Varkey P, Cunningham J, Bisping DS. Improving medication reconciliation in the outpatient setting. Jt Comm J Qual Patient Saf. 2007 May;33(5):286–92. | X1
578 | Varma S, McElnay JC, Hughes CM, Passmore AP, Varma M. Pharmaceutical care of patients with congestive heart failure: interventions and outcomes. Pharmacotherapy. 1999 Jul;19(7):860–9. | X3
579 | Velligan DI, Diamond P, Mueller J, Li X, Maples N, Wang M, et al. The short-term impact of generic versus individualized environmental supports on functional outcomes and target behaviors in schizophrenia. Psychiatry Res. 2009 Jul 30;168(2):94–101. | X12
580 | Velligan DI, Diamond PM, Mintz J, Maples N, Li X, Zeber J, et al. The use of individually tailored environmental supports to improve medication adherence and outcomes in schizophrenia. Schizophr Bull. 2008 May;34(3):483–93. | X4
581 | Vergouwen AC, Bakker A, Burger H, Verheij TJ, Koerselman F. A cluster randomized trial comparing two interventions to improve treatment of major depression in primary care. Psychol Med. 2005 Jan;35(1):25–33. | X3
582 | Vergouwen AC, Bakker A, Katon WJ, Verheij TJ, Koerselman F. Improving adherence to antidepressants: a systematic review of interventions (Provisional abstract). J Clin Psychiatry. 2003(12):1415–20. | X14
583 | Vergouwen AC, Burger H, Verheij TJ, Koerselman GF. Hoe kunnen de resultaten van de eerstelijnsbehandeling van depressie worden verbeterd? [How can the results of primary-care treatment for depression be improved?] (Provisional abstract). Tijdschrift voor Psychiatrie. 2007(8):559–67. | X3
584 | Vermeire Etienne IJJ, Wens J, Van Royen P, Biot Y, Hearnshaw H, Lindenmeyer A. Interventions for improving adherence to treatment recommendations in people with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2005(2). | X14
585 | Volmink J, Garner P. Systematic review of randomised controlled trials of strategies to promote adherence to tuberculosis treatment (Brief record). BMJ. 1997(7120):1403–6. | X4
586 | Volmink J, Garner P. Interventions for promoting adherence to tuberculosis management. Cochrane Database of Systematic Reviews. 2000(4). | X4
587 | Von Korff M, Katon W, Bush T, Lin EH, Simon GE, Saunders K, et al. Treatment costs, cost offset, and cost-effectiveness of collaborative management of depression. Psychosom Med. 1998 Mar–Apr;60(2):143–9. | X12
588 | Vreeland B, Minsky S, Yanos PT, Menza M, Gara M, Kim E, et al. Efficacy of the team solutions program for educating patients about illness management and treatment. Psychiatr Serv. 2006 Jun;57(6):822–8. | X4
589 | Vrijens B, Goetghebeur E. Comparing compliance patterns between randomized treatments. Control Clin Trials. 1997 Jun;18(3):187–203. | X3
590 | Wadden TA, Berkowitz RI, Sarwer DB, Prus-Wisniewski R, Steinberg C. Benefits of lifestyle modification in the pharmacologic treatment of obesity: a randomized trial. Arch Intern Med. 2001 Jan 22;161(2):218–27. | X1
591 | Wagner GJ, Kanouse DE, Golinelli D, Miller LG, Daar ES, Witt MD, et al. Cognitive-behavioral intervention to enhance adherence to antiretroviral therapy: a randomized controlled trial (CCTG 578). AIDS. 2006 Jun 12;20(9):1295–302. | X4
592 | Walker EA, Katon WJ, Russo J, Von Korff M, Lin E, Simon G, et al. Predictors of outcome in a primary care depression trial. J Gen Intern Med. 2000 Dec;15(12):859–67. | X1
593 | Walker PC, Bernstein SJ, Jones JN, Piersma J, Kim HW, Regal RE, et al. Impact of a pharmacist-facilitated hospital discharge program: a quasi-experimental study. Arch Intern Med. 2009 Nov 23;169(21):2003–10. | X1
594 | Wall TL, Sorensen JL, Batki SL, Delucchi KL, London JA, Chesney MA. Adherence to zidovudine (AZT) among HIV-infected methadone patients: a pilot study of supervised therapy and dispensing compared to usual care. Drug Alcohol Depend. 1995 Mar;37(3):261–9. | X8
595 | Walley JD, Khan MA, Newell JN, Khan MH. Effectiveness of the direct observation component of DOTS for tuberculosis: a randomised controlled trial in Pakistan. Lancet. 2001 Mar 3;357(9257):664–9. | X3
596 | Ward HJ, Morisky DE, Lees NB, Fong R. A clinic and community-based approach to hypertension control for an underserved minority population: design and methods. Am J Hypertens. 2000 Feb;13(2):177–83. | X9
597 | Waters BM, Jensen L, Fedorak RN. Effects of formal education for patients with inflammatory bowel disease: a randomized controlled trial. Can J Gastroenterol. 2005 Apr;19(4):235–44. | X3
598 | Webel AR. Testing a peer-based symptom management intervention for women living with HIV/AIDS. AIDS Care. 2010 Sep;22(9):1029–40. | X4
599 | Weber R, Christen L, Christen S, Tschopp S, Znoj H, Schneider C, et al. Effect of individual cognitive behaviour intervention on adherence to antiretroviral therapy: prospective randomized trial. Antivir Ther. 2004 Feb;9(1):85–95. | X3
600 | Weiden PJ, Schooler NR, Weedon JC, Elmouchtari A, Sunakawa A, Goldfinger SM. A randomized controlled trial of long-acting injectable risperidone vs continuation on oral atypical antipsychotics for first-episode schizophrenia patients: initial adherence outcome. J Clin Psychiatry. 2009 Oct;70(10):1397–406. | X8
601 | Weinberger M, Kirkman MS, Samsa GP, Shortliffe EA, Landsman PB, Cowper PA, et al. A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. J Gen Intern Med. 1995 Feb;10(2):59–66. | X12
602 | Weingardt KR, Cucciare MA, Bellotti C, Lai WP. A randomized trial comparing two models of web-based training in cognitive-behavioral therapy for substance abuse counselors. J Subst Abuse Treat. 2009 Oct;37(3):219–27. | X12
603 | Weinstein R, Tosolin F, Ghilardi L, Zanardelli E. Psychological intervention in patients with poor compliance. J Clin Periodontol. 1996 Mar;23(3 Pt 2):283–8. | X12
604 | Weiss K, Vanjaka A. An open-label, randomized, multicenter, comparative study of the efficacy and safety of 7 days of treatment with clarithromycin extended-release tablets versus clarithromycin immediate-release tablets for the treatment of patients with acute bacterial exacerbation of chronic bronchitis. Clin Ther. 2002 Dec;24(12):2105–22. | X3
605 | Welch G, Zagarins SE, Feinberg RG, Garb JL. Motivational interviewing delivered by diabetes educators: does it improve blood glucose control among poorly controlled type 2 diabetes patients? Diabetes Res Clin Pract. 2011 Jan;91(1):54–60. | X1
606 | Wells KB, Sherbourne C, Schoenbaum M, Duan N, Meredith L, Unutzer J, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. 2000 Jan 12;283(2):212–20. | X12
607 | Wentzlaff DM, Carter BL, Ardery G, Franciscus CL, Doucette WR, Chrischilles EA, et al. Sustained blood pressure control following discontinuation of a pharmacist intervention. Journal of clinical hypertension (Greenwich, Conn). 2011 Jun;13(6):431–7. | X1
608 | West NJ, Clark SK, Phillips RK, Hutchinson JM, Leicester RJ, Belluzzi A, et al. Eicosapentaenoic acid reduces rectal polyp number and size in familial adenomatous polyposis. Gut. 2010 Jul;59(7):918–25. | X1
609 | Westling E, Garcia K, Mann T. Discovery of meaning and adherence to medications in HIV-infected women. J Health Psychol. 2007 Jul;12(4):627–35. | X4
610 | Weycker D, Macarios D, Edelsberg J, Oster G. Compliance with drug therapy for postmenopausal osteoporosis. Osteoporos Int. 2006;17(11):1645–52. | X5
611 | White HJ, Bettiol SS, Perera R, Roberts NW, Javaid MK, Farmer AJ. A systematic review assessing the effectiveness of interventions to improve persistence with anti-resorptive therapy in women at high risk of clinical fracture (Provisional abstract). Fam Pract. 2010(6):593–603. | X5
612 | White MC, Tulsky JP, Goldenson J, Portillo CJ, Kawamura M, Menendez E. Randomized controlled trial of interventions to improve follow-up for latent tuberculosis infection after release from jail. Arch Intern Med. 2002 May 13;162(9):1044–50. | X4
613 | Wilhide C, Hayes JR, Farah JR. Impact of behavioral adherence on clinical improvement and functional status in a diabetes disease management program. Dis Manag. 2008 Jun;11(3):169–75. | X5
614 | Williams A, Manias E, Walker R. Interventions to improve medication adherence in people with multiple chronic conditions: a systematic review. J Adv Nurs. 2008 Jul;63(2):132–43. | X14
615 | Williams AB, Fennie KP, Bova CA, Burgess JD, Danvers KA, Dieckhaus KD. Home visits to improve adherence to highly active antiretroviral therapy: a randomized controlled trial. J Acquir Immune Defic Syndr. 2006 Jul;42(3):314–21. | X4
616 | Williams JB, Delong ER, Peterson ED, Dokholyan RS, Ou FS, Ferguson TB, Jr. Secondary prevention after coronary artery bypass graft surgery: findings of a national randomized controlled trial and sustained society-led incorporation into practice. Circulation. 2011 Jan 4;123(1):39–45. | X1
617 | Williams ML, Morris MT, 2nd, Ahmad U, Yousseff M, Li W, Ertel N. Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center. Ethn Dis. 2002 Winter;12(1):S1-58–62. | X12
618 | Wilson IB, Laws MB, Safren SA, Lee Y, Lu M, Coady W, et al. Provider-focused intervention increases adherence-related dialogue but does not improve antiretroviral therapy adherence in persons with HIV. J Acquir Immune Defic Syndr. 2010 Mar 1;53(3):338–47. | X4
619 | Wohl AR, Garland WH, Squires K, Witt M, Larsen R, Kovacs A, et al. The feasibility of a community-based directly administered antiretroviral therapy program. Clin Infect Dis. 2004 Jun 1;38 Suppl 5:S388–92. | X9
620 | Wohl AR, Garland WH, Valencia R, Squires K, Witt MD, Kovacs A, et al. A randomized trial of directly administered antiretroviral therapy and adherence case management intervention. Clin Infect Dis. 2006 Jun 1;42(11):1619–27. | X4
621 | Wong FK, Chow SK, Chan TM. Evaluation of a nurse-led disease management programme for chronic kidney disease: a randomized controlled trial. Int J Nurs Stud. 2010 Mar;47(3):268–78. | X3
622 | Wu AW, Snyder CF, Huang IC, Skolasky R, McGruder HF, Celano SA, et al. A randomized trial of the impact of a programmable medication reminder device on quality of life in patients with AIDS. Aids Patient Care STDS. 2006 Nov;20(11):773–81. | X3
623 | Wu JY, Leung WY, Chang S, Lee B, Zee B, Tong PC, et al. Effectiveness of telephone counselling by a pharmacist in reducing mortality in patients receiving polypharmacy: randomised controlled trial. BMJ. 2006 Sep 9;333(7567):522. | X3
624 | Wyatt GE, Longshore D, Chin D, Carmona JV, Loeb TB, Myers HF, et al. The efficacy of an integrated risk reduction intervention for HIV-positive women with child sexual abuse histories. AIDS and behavior. 2004 Dec;8(4):453–62. | X4
625 | Wysocki T, Greco P, Harris MA, Bubb J, White NH. Behavior therapy for families of adolescents with diabetes: maintenance of treatment effects. Diabetes Care. 2001 Mar;24(3):441–6. | X13
626 | Yazaki Y, Faridi Z, Ma Y, Ali A, Northrup V, Njike VY, et al. A pilot study of chromium picolinate for weight loss. J Altern Complement Med. 2010 Mar;16(3):291–9. | X1
627 | Yeboah-Antwi K, Gyapong JO, Asare IK, Barnish G, Evans DB, Adjei S. Impact of prepackaging antimalarial drugs on cost to patients and compliance with treatment. Bull World Health Organ. 2001;79(5):394–9. | X3
628 | Yoo HJ, Park MS, Kim TN, Yang SJ, Cho GJ, Hwang TG, et al. A Ubiquitous Chronic Disease Care system using cellular phones and the internet. Diabet Med. 2009 Jun;26(6):628–35. | X1
629 | Zarani F, Besharat MA, Sadeghian S, Sarami G. The effectiveness of the information-motivation-behavioral skills model in promoting adherence in CABG patients. J Health Psychol. 2010 Sep;15(6):828–37. | X12
630 | Zeber JE, Grazier KL, Valenstein M, Blow FC, Lantz PM. Effect of a medication copayment increase in veterans with schizophrenia. Am J Manag Care. 2007 Jun;13(6 Pt 2):335–46. | X4
631 | Zedler BK, Kakad P, Colilla S, Murrelle L, Shah NR. Does packaging with a calendar feature improve adherence to self-administered medication for long-term use? A systematic review. Clin Ther. 2011 Jan;33(1):62–73. | X5
632 | Ziller V, Kalder M, Albert US, Holzhauer W, Ziller M, Wagner U, et al. Adherence to adjuvant endocrine therapy in postmenopausal women with breast cancer. Ann Oncol. 2009 Mar;20(3):431–6. | X2
633 | Znoj HJ, Messerli-Burgy N, Tschopp S, Weber R, Christen L, Christen S, et al. Psychotherapeutic process of cognitive-behavioral intervention in HIV-infected persons: results from a controlled, randomized prospective clinical trial. Psychother Res. 2010 Mar;20(2):203–13. | X4
634 | Zweben A, Pettinati HM, Weiss RD, Youngblood M, Cox CE, Mattson ME, et al. Relationship between medication adherence and treatment outcomes: the COMBINE study. Alcohol Clin Exp Res. 2008 Sep;32(9):1661–9. | X4
635 | Implementation of treatment protocols in the Diabetes Control and Complications Trial. Diabetes Care. 1995 Mar;18(3):361–76. | X1
636 | Testing combined pharmacotherapies and behavioral interventions for alcohol dependence (the COMBINE study): a pilot feasibility study. Alcohol Clin Exp Res. 2003 Jul;27(7):1123–31. | X13
637 | Abrahams N, Jewkes R, Lombard C, Mathews S, Campbell J, Meel B. Impact of telephonic psycho-social support on adherence to post-exposure prophylaxis (PEP) after rape. AIDS Care. 2010 Oct;22(10):1173–81. | X3