# Abstract and Full-Text Forms

The following are lists of fields used in the abstract and full-text review forms. Please see the Evidence Tables (Appendix D) for fields used in the data abstraction forms.

Reviewers were asked to complete the following fields for screening abstracts for inclusion:

Reviewer
REF ID
Author
Year
Title
Abstract
Include
Exclude (check the box below and then check the box to the right that indicates your first reason for exclusion)
Wrong publication type (e.g. editorials, letters, non-systematic reviews, case-reports, case series)
Wrong country
Wrong Intervention
Wrong study design
Wrong population
No/wrong comparison
Wrong outcome
Wrong Setting
Other (please write in specific reason)
Comments: Please include a comment if you included an abstract, but did so do to a lack of clarity within the abstract. Explain why you think the FT will reveal that the study should be excluded.

Reviewers were asked to consider and complete the following fields when reviewing full texts for inclusion:

Reviewer
Ref ID
Authors
Year
Title
Include?
Exclude?
If Exclude, select most significant reason for exclusion from ordered list. (list of options is provided below) If Other, note reason in next column.
If Exclude Reason is Other, please explain
If Include, is medication adherence SOLELY self-reported? Y or N
If Include AND country is non-US, please write country name
If Include, KQ1a?
If Include for KQ1a: Did study improve Med Adh?
If study improved Med Adh AND KQ1a include: Include for KQ1b?
If Include, KQ2a?
If Include for KQ2a: Did study improve Med Adh?
If study improved Med Adh AND KQ2a include: Include for KQ2b?
If Include, KQ3?
If Include, KQ4?
If Include, KQ5?
If Pilot Study add citation
Other Comments

FT Exclude Reasons (choices provided in drop down list)

Intervention not Med Ad related
No Intervention
No Med Ad outcomes
Ineligible Population
Ineligible Study Design
Pilot Study (add citation)
Ineligible Setting
Ineligible Comparator
Sample Size < 40
Ineligible Publication Type
Other (add comment)