# Search Strategies

Preliminary searches and topic scoping occurred from January 2011 to March 2011. Update searches occurred in November and December 2011. The search strategies below are the final search strategies for randomized controlled trials (RCTs), policy-related publications, and Cochrane reviews.

PubMed Main RCT Search

Main RCT search done April 21, 2011; 2677 results.

Search | Queries | Result
#1 | Search “Patient Compliance”[Mesh] | 42003
#2 | Search “Patient Compliance”[ti] | 714
#3 | Search adherence[tiab] | 48121
#4 | Search “Medication Adherence”[Mesh] | 2291
#5 | Search “medication compliance”[tiab] | 882
#6 | Search “medication persistence”[tiab] | 42
#7 | Search “Medication Reconciliation”[Mesh] | 27
#8 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 | 81627
#9 | Search “Intervention Studies”[Mesh] | 4636
#10 | Search intervention[tiab] OR interventions[tiab] | 385603
#11 | Search “control group”[tiab] OR “control groups”[tiab] OR “treatment group”[tiab] OR “treatment groups”[tiab] | 265702
#12 | Search #8 and #9 | 311
#13 | Search #8 and #10 | 10363
#14 | Search #8 and #11 | 3283
#15 | Search #12 or #13 or #14 | 12246
#16 | Search #15 Limits: Humans, English, All Adult: 19+ years, Publication Date from 1994 | 6150
#17 | Search #16 Limits: Editorial, Letter, Comment, News | 22
#18 | Search #16 NOT #17 | 6128
#19 | Search “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 381238
#20 | Search #18 and #19 | 2677

PubMed Main RCT Search Update

This search was identical to the April 21, 2011 main RCT search described above. Date range: 1994–2011. 225 results (0 duplicates) were unique and imported to the database.

Search | Queries | Result
#1 | Search “Patient Compliance”[Mesh] | 43881
#2 | Search “Patient Compliance”[ti] | 727
#3 | Search adherence[tiab] | 50921
#4 | Search “Medication Adherence”[Mesh] | 3036
#5 | Search “medication compliance”[tiab] | 913
#6 | Search “medication persistence”[tiab] | 48
#7 | Search “Medication Reconciliation”[Mesh] | 70
#8 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 | 85526
#9 | Search “Intervention Studies”[Mesh] | 4913
#10 | Search intervention[tiab] OR interventions[tiab] | 407959
#11 | Search “control group”[tiab] OR “control groups”[tiab] OR “treatment group”[tiab] OR “treatment groups”[tiab] | 277165
#12 | Search #8 and #9 | 334
#13 | Search #8 and #10 | 11176
#14 | Search #8 and #11 | 3465
#15 | Search #12 or #13 or #14 | 13140
#16 | Search #15 Limits: Humans, English, All Adult: 19+ years, Publication Date from 1994 | 6670
#17 | Search #16 Limits: Editorial, Letter, Comment, News | 22
#18 | Search #16 NOT #17 | 6648
#19 | Search “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 394126
#20 | Search #18 and #19 | 2882
#23 | Search 2010/10:2011/11[edat] | 962001
#24 | Search #20 and #23 | 225

PubMed Policy Search

Policy search done April 21, 2011 includes terms suggested by Technical Expert Panel (TEP) and alternate indications for interventions; 1064 results. 371 are unique and were imported to the database.

Search | Most Recent Queries | Result
#1 | Search “Patient Compliance”[Mesh] | 42003
#2 | Search “Patient Compliance”[ti] | 714
#3 | Search adherence[tiab] | 48121
#4 | Search “Medication Adherence”[Mesh] | 2291
#5 | Search “medication compliance”[tiab] | 882
#6 | Search “medication persistence”[tiab] | 42
#7 | Search “Medication Reconciliation”[Mesh] | 27
#8 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 | 81627
#9 | Search “Intervention Studies”[Mesh] | 4636
#10 | Search intervention[tiab] OR interventions[tiab] | 385603
#11 | Search “control group”[tiab] OR “control groups”[tiab] OR “treatment group”[tiab] OR “treatment groups”[tiab] | 265702
#12 | Search #8 and #9 | 311
#13 | Search #8 and #10 | 10363
#14 | Search #8 and #11 | 3283
#15 | Search #12 or #13 or #14 | 12246
#16 | Search #15 Limits: Humans, English, All Adult: 19+ years, Publication Date from 1994 | 6150
#17 | Search #16 Limits: Editorial, Letter, Comment, News | 22
#18 | Search #16 NOT #17 | 6128
#19 | Search “Infection Control”[Mesh] | 44446
#20 | Search #18 and #19 | 25
#21 | Search “Policy Making”[Mesh] | 15482
#22 | Search #18 and #21 | 1
#23 | Search “Public Policy”[Mesh] | 92346
#24 | Search #18 and #23 | 32
#25 | Search “State Health Planning and Development Agencies”[Mesh] | 780
#26 | Search #18 and #25 | 0
#27 | Search “Insurance Claim Review”[Mesh] | 3437
#28 | Search #18 and #27 | 20
#29 | Search “Medicare Part D”[Mesh] | 568
#30 | Search #18 and #29 | 12
#31 | Search “Health Services Accessibility”[Mesh] | 69354
#32 | Search #18 and #31 | 80
#33 | Search “Health Policy”[Mesh] | 67320
#34 | Search #18 and #33 | 32
#35 | Search “Formularies as Topic”[Mesh] | 2537
#36 | Search #18 and #35 | 6
#37 | Search “Gatekeeping”[Mesh] | 453
#38 | Search #18 and #37 | 0
#39 | Search “Community Pharmacy Services”[Mesh] | 2123
#40 | Search #18 and #39 | 61
#41 | Search “Medication Therapy Management”[Mesh] | 270
#42 | Search #18 and #41 | 9
#43 | Search “Cost-Sharing”[Mesh] | 3121
#45 | Search “cost sharing” | 2144
#46 | Search #43 or #45 | 3517
#47 | Search #18 and #46 | 14
#48 | Search “Health Benefit Plans, Employee”[Mesh] | 9132
#49 | Search #18 and #48 | 7
#50 | Search “prior authorization” | 216
#51 | Search #18 and #50 | 0
#52 | Search “Insurance, Pharmaceutical Services”[Mesh] | 3675
#53 | Search #18 and #52 | 31
#54 | Search “Prescription Drugs”[Mesh] | 1151
#55 | Search #18 and #54 | 8
#56 | Search “Drug Costs”[Mesh] | 10161
#57 | Search #18 and #56 | 31
#58 | Search “system-level” | 1253
#59 | Search #18 and #58 | 5
#60 | Search “pharmaceutical care program” OR “pharmaceutical care programs” | 44
#61 | Search #18 and #60 | 13
#62 | Search “Health Services Research”[Mesh] | 99483
#63 | Search #18 and #62 | 186
#64 | Search “Medical Indigency”[Mesh] | 3433
#65 | Search #18 and #64 | 1
#66 | Search “Program Development”[Mesh] | 18203
#67 | Search #18 and #66 | 54
#68 | Search “medication possession ratio” OR “medication possession ratios” OR MPR | 1928
#69 | Search #18 and #68 | 39
#70 | Search “Pharmacy Service, Hospital”[Mesh] | 9015
#71 | Search #18 and #70 | 24
#72 | Search “prescribing pattern” OR “prescribing patterns” | 1392
#73 | Search #18 and #72 | 6
#74 | Search “Medicaid”[Mesh] | 16680
#75 | Search #18 and #74 | 19
#76 | Search “Treatment Refusal”[Mesh] | 9644
#77 | Search #18 and #76 | 123
#78 | Search “Polypharmacy”[Mesh] | 1523
#79 | Search #18 and #78 | 19
#80 | Search “Drug Combinations”[Mesh] | 52143
#81 | Search #18 and #80 | 34
#82 | Search “Drug Packaging”[Mesh] | 8342
#83 | Search #18 and #82 | 35
#84 | Search “Disease Management”[Mesh] | 7390
#85 | Search #18 and #84 | 64
#86 | Search “Drug Administration Schedule”[Mesh] | 75117
#87 | Search #18 and #86 | 188
#88 | Search “Managed Care Programs”[Mesh] | 37687
#89 | Search #18 and #88 | 91
#90 | Search “Health Maintenance Organizations/organization and administration”[Mesh] | 9938
#91 | Search #18 and #90 | 23
#92 | Search “Primary Health Care/economics”[Mesh] | 3422
#93 | Search #18 and #92 | 18
#94 | Search “Primary Health Care/organization and administration”[Mesh] | 25797
#95 | Search #18 and #94 | 117
#96 | Search #20 or #22 or #24 or #26 or #28 or #30 or #32 or #34 or #36 or #38 or #40 or #42 or #47 or #49 or #51 or #53 or #55 or #57 or #59 or #61 or #63 or #65 or #67 or #69 or #71 or #73 or #75 or #77 or #79 or #81 or #83 or #85 or #87 or #89 or #91 or #93 or #95 | 1064

November 14, 2011. PubMed Policy Search Update

This search was identical to the April 21, 2011 policy search described above. Date range: 1994–2011. 87 results (51 duplicates), 36 of which were unique and imported to the database.

Search | Most Recent Queries | Result
#1 | Search “Patient Compliance”[Mesh] | 43881
#2 | Search “Patient Compliance”[ti] | 727
#3 | Search adherence[tiab] | 50921
#4 | Search “Medication Adherence”[Mesh] | 3036
#5 | Search “medication compliance”[tiab] | 913
#6 | Search “medication persistence”[tiab] | 48
#7 | Search “Medication Reconciliation”[Mesh] | 70
#8 | Search #1 or #2 or #3 or #4 or #5 or #6 or #7 | 85526
#9 | Search “Intervention Studies”[Mesh] | 4913
#10 | Search intervention[tiab] OR interventions[tiab] | 407959
#11 | Search “control group”[tiab] OR “control groups”[tiab] OR “treatment group”[tiab] OR “treatment groups”[tiab] | 277165
#12 | Search #8 and #9 | 334
#13 | Search #8 and #10 | 11176
#14 | Search #8 and #11 | 3465
#15 | Search #12 or #13 or #14 | 13140
#16 | Search #15 Limits: Humans, English, All Adult: 19+ years, Publication Date from 1994 | 6670
#17 | Search #16 Limits: Editorial, Letter, Comment, News | 22
#18 | Search #16 NOT #17 | 6648
#19 | Search “Infection Control”[Mesh] | 45461
#20 | Search #18 and #19 | 29
#21 | Search “Policy Making”[Mesh] | 16027
#22 | Search #18 and #21 | 2
#23 | Search “Public Policy”[Mesh] | 95699
#24 | Search #18 and #23 | 34
#25 | Search “State Health Planning and Development Agencies”[Mesh] | 785
#26 | Search #18 and #25 | 0
#27 | Search “Insurance Claim Review”[Mesh] | 3634
#28 | Search #18 and #27 | 22
#29 | Search “Medicare Part D”[Mesh] | 657
#30 | Search #18 and #29 | 16
#31 | Search “Health Services Accessibility”[Mesh] | 71702
#32 | Search #18 and #31 | 91
#33 | Search “Health Policy”[Mesh] | 70065
#34 | Search #18 and #33 | 34
#35 | Search “Formularies as Topic”[Mesh] | 2566
#36 | Search #18 and #35 | 6
#37 | Search “Gatekeeping”[Mesh] | 465
#38 | Search #18 and #37 | 0
#39 | Search “Community Pharmacy Services”[Mesh] | 2224
#40 | Search #18 and #39 | 65
#41 | Search “Medication Therapy Management”[Mesh] | 323
#42 | Search #18 and #41 | 12
#43 | Search “Cost-Sharing”[Mesh] | 3200
#44 | Search “cost sharing” | 2202
#45 | Search #43 or #44 | 3607
#46 | Search #18 and #45 | 17
#47 | Search “Health Benefit Plans, Employee”[Mesh] | 9199
#48 | Search #18 and #47 | 7
#49 | Search “prior authorization” | 221
#50 | Search #18 and #49 | 0
#51 | Search “Insurance, Pharmaceutical Services”[Mesh] | 3821
#52 | Search #18 and #51 | 38
#53 | Search “Prescription Drugs”[Mesh] | 1438
#54 | Search #18 and #53 | 10
#55 | Search “Drug Costs”[Mesh] | 10478
#56 | Search #18 and #55 | 33
#57 | Search “system-level” | 1385
#58 | Search #18 and #57 | 6
#59 | Search “pharmaceutical care program” OR “pharmaceutical care programs” | 46
#60 | Search #18 and #59 | 13
#61 | Search “Health Services Research”[Mesh] | 103503
#62 | Search #18 and #61 | 199
#63 | Search “Medical Indigency”[Mesh] | 3439
#64 | Search #18 and #63 | 1
#65 | Search “Program Development”[Mesh] | 19001
#66 | Search #18 and #65 | 60
#67 | Search “medication possession ratio” OR “medication possession ratios” OR MPR | 2049
#68 | Search #18 and #67 | 44
#69 | Search “Pharmacy Service, Hospital”[Mesh] | 9149
#70 | Search #18 and #69 | 26
#71 | Search “prescribing pattern” OR “prescribing patterns” | 1461
#72 | Search #18 and #71 | 6
#73 | Search “Medicaid”[Mesh] | 17092
#74 | Search #18 and #73 | 19
#75 | Search “Treatment Refusal”[Mesh] | 9798
#76 | Search #18 and #75 | 125
#77 | Search “Polypharmacy”[Mesh] | 1667
#78 | Search #18 and #77 | 22
#79 | Search “Drug Combinations”[Mesh] | 53239
#80 | Search #18 and #79 | 38
#81 | Search “Drug Packaging”[Mesh] | 8514
#82 | Search #18 and #81 | 38
#83 | Search “Disease Management”[Mesh] | 7709
#84 | Search #18 and #83 | 65
#85 | Search “Drug Administration Schedule”[Mesh] | 76914
#86 | Search #18 and #85 | 196
#87 | Search “Managed Care Programs”[Mesh] | 37866
#88 | Search #18 and #87 | 93
#89 | Search “Health Maintenance Organizations/organization and administration”[Mesh] | 9960
#90 | Search #18 and #89 | 23
#91 | Search “Primary Health Care/economics”[Mesh] | 3579
#92 | Search #18 and #91 | 18
#93 | Search “Primary Health Care/organization and administration”[Mesh] | 26856
#94 | Search #18 and #93 | 127
#96 | Search #20 or #22 or #24 or #26 or #28 or #30 or #32 or #34 or #36 or #38 or #40 or #42 or #46 or #48 or #50 or #52 or #54 or #56 or #58 or #60 or #62 or #64 or #66 or #68 or #70 or #72 or #74 or #76 or #78 or #80 or #82 or #84 or #86 or #88 or #90 or #92 or #94 | 1145
#97 | Search 2010/10:2011/11[edat] | 962001
#98 | Search #96 and #97 | 87

April 25, 2011. Wiley Interface of the Cochrane Library

This search covers both main RCT and policy searches, it is not limited to interventions or study types. Date range: 1994–2011. 5,810 results, 38 of which were Cochrane Reviews (1 duplicate), 149 were Other Reviews (0 duplicates), and 17 were technical assessments (0 duplicates); 203 records were imported to the database.

Search | Most Recent Queries | Result
#1 | MeSH descriptor Patient Compliance explode all trees | 7068
#2 | “medication compliance”:ti or “medication compliance”:ab | 251
#3 | “medication persistence”:ti or “medication persistence”:ab | 6
#4 | “medication reconciliation”:ti and “medication reconciliation”:ab | 3
#5 | “patient compliance”:ti | 122
#6 | (#1 OR #2 OR #3 OR #4 OR #5) | 7258
#7 | (#6), from 1994 to 2011 | 5810

December 8, 2011. Update Search for Wiley interface of the Cochrane Library

This search was identical to the April 25, 2011 main RCT search described above, except that it was limited to 2010–2011. Date range: 2010–2011. 764 results, 25 of which were Cochrane Reviews (18 duplicates), 5 were technical assessments (4 duplicates), and 27 were Other Reviews (7 duplicates); 28 records were imported to the database.

Search | Most Recent Queries | Result
#1 | MeSH descriptor Patient Compliance explode all trees | 7079
#2 | “medication compliance”:ti or “medication compliance”:ab | 254
#3 | “medication persistence”:ti or “medication persistence”:ab | 3
#4 | “medication reconciliation”:ti and “medication reconciliation”:ab | 3
#5 | “patient compliance”:ti | 119
#6 | (#1 OR #2 OR #3 OR #4 OR #5) | 7270
#7 | (#6), from 2010 to 2011 | 764