# Acknowledgments

We acknowledge the continuing support of our AHRQ colleagues, Stephanie Chang, M.D., M.P.H., Director of the EPC Program; Christine Chang, M.D., M.P.H.; Deborah Perfetto, Pharm.D.; and Carmen Y. Kelly, Pharm.D., M.P.H, R.Ph.

We extend our appreciation to members of our Technical Expert Panel, all of whom provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina at Chapel Hill. We express our gratitude to the following individuals for their contributions to this project: Timothy S. Carey, M.D., M.P.H, Director of the Cecil G. Sheps Center for Health Services Research at UNC; Christiane Voisin, M.S.L.S., our EPC Librarian; EPC Project Managers Elizabeth Harden, M.P.H., and Audrey R. Holland, M.P.H.; EPC editor, Laura Small, B.A.; and EPC publications specialist, Loraine Monroe.