# Results

This chapter presents the results of the review of quality improvement (QI) strategies to address health care disparities. We present findings for Key Question 1 (KQ 1) beginning with an overview of the content of the literature as a whole, followed by results and detailed analysis organized first by the disparity addressed in the research and then again by clinical conditions. No studies provided information on Key Question 2 (KQ 2), which pertained to harms associated with the interventions.

Studies also are described in more detail in summary tables in the relevant section of text. For information on quality scores for each study, see Appendix H; for information on the strength of evidence for outcomes, see Appendix J.

## Search Results and Included Studies

Using a broad search strategy, we identified 4,278 titles and abstracts with potential relevance for initial screening (Figure 2). From this screening, 791 papers were identified as possibly related and moved forward for full-text review. At this second level, 772 papers did not meet eligibility criteria. The complete list of exclusion reasons is provided in Appendix L.

Figure 2 Flow diagram of the literature search and screening

Abbreviation: QI = quality improvement

Figure 2 illustrates the flow of articles from the literature search and retrieval through the screening process. A total of 4278 citations were retrieved from electronic database searches (N=4055) and hand searches (N=223). Papers were excluded at the level of abstract review (N=3487) and at the level of full text review (N=791) for one or more of the following reasons: not original research (N=192); did not include individuals receiving health care in the U.S. (N=14); number of participants per group less than 50 (N=31); did not address a pre-specified condition (N=3); did not address selected health disparity (N=452); did not address a QI intervention/strategy (N=438); no qualifying referent group (N=741); did not address an outcome of interest (N=12); no control group for the intervention (N=11); not a qualifying study design (N=8). Nineteen papers were included for final data abstraction.

Therefore, for this report, we synthesized data from 19 papers representing 14 unique studies that addressed the following conditions: breast and colorectal cancer screening (n=5); cardiovascular disease, including coronary heart disease and hypertension (n=5); depression (n=3); and diabetes (n=3).

All papers addressed KQ 1. The included studies used an internal referent group to measure disparity; none of the included papers relied upon an external referent group to measure disparities.

## Overview of Included Studies

Nineteen papers qualified for our review (Table 3), reflecting results from 14 unique studies. Results are further summarized with details in the evidence tables (Appendix I).

Table 3 Overview of the studies of QI interventions to address disparities in health outcomes

Characteristic | Race or Ethnicity | Insurance Status | Language Barrier | Health Literacy | Socioeconomic Status | Sex
Intervention category
Patient Education | 10 | 1 | 2 | 1 | 2 | 1
Provider Education | 6 | 0 | 0 | 1 | 2 | 1
Promotion of Self-management | 10 | 1 | 2 | 0 | 2 | 1
Audit and Feedback | 3 | 0 | 0 | 1 | 0 | 1
Facilitated Relay of Clinical Data to Providers | 2 | 0 | 0 | 0 | 1 | 1
Patient Reminder System | 2 | 2 | 2 | 0 | 0 | 0
Provider Reminder System | 1 | 0 | 0 | 0 | 1 | 0
Organizational Change | 1 | 0 | 0 | 0 | 0 | 0
Other | 5 | 0 | 0 | 0 | 2 | 1
Condition
Cancer | 2 | 2 | 2 | 1 | 0 | 0
Cardiovascular Disease | 2 | 0 | 0 | 0 | 0 | 0
Depression | 3 | 0 | 0 | 0 | 2 | 1
Diabetes | 3 | 0 | 0 | 0 | 0 | 0
Design
RCT | 9 | 2 | 2 | 1 | 2 | 1
Retrospective cohort | 2 | 0 | 0 | 0 | 0 | 0
Prospective cohort | 1 | 0 | 0 | 0 | 0 | 0

Abbreviation: RCT = randomized controlled trial.

Of the 14 studies, 11 were randomized controlled trials (RCTs),15-26 including 2 cluster RCTs.15,16,27-30 The remaining studies were cohort studies, including one prospective cohort study,31 one retrospective cohort study,32 and one cohort study with a historical control.33

Included papers targeted or described disparities associated with differences in race or ethnicity (n=14),15-17,21,22,24,28,29,31-34 socioeconomic status (n=3),18,24,32 insurance status (n=2),19,26 language (n=2),20,26 health literacy (n=1),23 and sex (n=1).30 All studies were focused in a specific clinical area. Five studied a QI intervention in cancer screening, three in cardiovascular disease, three in depression care, and three in diabetes.

Outcomes included health care processes and health outcomes. All but one of the studies incorporated multiple components into their QI approach. Patient education was a part of most interventions (12 of 14), although the specific approach differed substantially across the studies. Ten of the studies incorporated self-management; this would, include, for example, teaching individuals with diabetes to check their blood sugar regularly. Most (8 of 14) included some sort of provider education, which may have focused on the clinical issue or on raising awareness about disparities affecting the target population. Nonetheless, given the degree to which the interventions all included multiple components that were implemented as a system, it is not possible to tease apart the effects or implications of individual aspects.

We organize the results in two ways. First, the results are summarized by effect on particular disparities, which is the primary focus of the review; second, descriptions of the studies are organized by clinical condition as a reference for end users interested in implementing QI approaches in individual clinics or clinical specialties.

## Effects on Racial or Ethnic Disparities

### Overview

Eleven studies provided data on the effects of QI interventions on disparities in health care associated with race or ethnicity (Table 4).

Table 4 Summary of effects on disparities in health outcomes associated with race or ethnicity

Author, Year Study Design Clinical Condition(s) | QI Intervention Characteristic(s) | Effect on Health Disparity
Arean et al., 2005^17^ RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Facilitated relay of clinical data to provider; - Other (collaborative care model) | - No disparity in depression severity existed by race or income at baseline.; - The intervention was effective in all racial subgroups with no interaction by race and no amplified effect in any group.; - In subgroup analysis, the intervention was associated with greater use of psychotherapy but not pharmacotherapy within the Black population
Bao et al., 2011^24^ RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Provider reminder system; - Other (collaborative care model) | - At baseline within the usual care group, 22% of minorities had adequate antidepressant use, compared to 39% of White patients.; - The intervention had no effect on this disparity and ethnic minorities did not receive greater benefit from intervention compared with White patients during any time period.
Bosworth et al., 2011^21^ RCT Cardiovascular disease: hypertension | - Patient education; - Promotion of self-management | - The race by time by treatment group effect model suggested differential intervention effects on blood pressure (BP) over time for White patients vs. nonwhite patients for both systolic blood pressure (SBP) (p=0.08) and diastolic blood pressure (DBP) (p=0.01).; - The combination of home BP monitoring and tailored behavioral intervention was most effective in nonwhite participants at 24 months (p=0.04).
Coberley et al., 2007^32^ Retrospective cohort Diabetes | - Patient education; - Promotion of self-management; - Organizational change (disease management) | - Initial racial disparity in HbA1c testing between the health disparity zone (HDZ) group and non-HDZ group was 12%.; - Disparity was not significantly reduced after 12 months (p=0.06).; - Within the HDZ zone (high prevalence of diabetes), testing increased by15% among Black participants but not among White participants, resulting in a reduction in disparity in this subgroup analysis.
Connett and Stamler, 1984^22^ RCT Cardiovascular disease: coronary artery disease and hypertension | - Patient education; - Promotion of self-management | - At baseline, Black participants had higher rates of smoking than White participants (68.7% vs. 63%; p<.001).; - Both racial groups experienced significant reductions in smoking of close to 50% in the intervention group and more than 35% in the usual care group.; - The baseline disparity persisted in the intervention group but was apparently reduced in the usual care group.; - A statistically significant but clinically insignificant disparity in DBP and SBP by race was present at baseline.; - Blood pressures were reduced in both the intervention and control groups, with greater change observed in the intervention group.; - The small disparity observed at baseline was further reduced at followup in the intervention group but not the control group.
Lasser et al., 2011^26^ RCT Cancer: CRC screening | - Patient education; - Promotion of self-management; - Patient reminder system | - No disparity in CRC screening rates at baseline by race or ethnicity.; - The intervention was more effective in White and Black individuals relative to those of other or unknown race.
Mahotiere et al., 2006^31^ Prospective cohort Diabetes | - Patient education; - Provider education; - Promotion of self-management; - Audit and feedback; - Other (community intervention) | - The disparity in biennial lipid profile testing at baseline was 19%.; - The biennial lipid profile testing rate improved by 26.2 percent in African-American beneficiaries with diabetes in the intervention areas following implementation of the QI program.; - The disparity in performance of biennial lipid profile between African-American Medicare fee-for-service beneficiaries and White Medicare fee-for-service beneficiaries reduced to 9.2% following implementation of the QI program.; - An analysis of the direct impact of the selected interventions on reducing the disparity in this uncontrolled database analysis was not feasible.
Miranda et al., 2003^15^; Miranda et al., 2004^34^; Wells et al., 2007^28^; Wells et al., 2004^29^ Cluster RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Audit and feedback; - Facilitated relay of clinical data to provider; - Other (collaborative care model) | - The intervention was associated with decreases in probable depressive disorder among minorities but not White patients at 12 months. (Latino p=0.02; African-American p=0.01).; - At 12 months among intervention recipients, the baseline disparity increased (6.7% to 7.7%) between Latino and White patients, and decreased between African-American and White patients (9.2% to 6.7%).; - Although a statistically significant interaction was seen between intervention and ethnicity at 6 months when minorities were grouped and contrasted with White patients, no such interaction persisted at 12 months.; - The overall effect of the intervention on depression status was not significant at five and nine years, but an interaction with race was seen in the overall model of effectiveness. The intervention was associated with improvements in the Mental Health Inventory among minorities (p=0.008) but not among White patients (p=0.59).; - In subanalysis at five years, QI–Therapy but not QI–Meds was effective within the minority population.
Olomu et al., 2010^33^ Retrospective cohort (historic controls) Cardiovascular disease: coronary artery disease | - Patient education; - Provider education; - Promotion of self-management; - Other (guideline adherence) | - The American College of Cardiology's Acute Myocardial Infarction (AMI) Guidelines Applied in Practice (GAP) strategy was associated with increased inpatient use of beta-blockers among nonwhite patients.; - Racial disparities in use of cardiac catheterization and percutaneous coronary intervention appeared after implementation of the GAP QI strategy despite overall improvements in care.; - The admission tool and inpatient aspirin were more often used post-GAP than pre-GAP in both White and nonwhite patients.
Sequist et al., 2010^16^ Cluster RCT Diabetes | - Provider education; - Audit and feedback | - Disparities were present at baseline in HbA1c levels, BP control, and LDL level.; - The intervention showed no effect overall in either racial group.; - The intervention did not reduce the disparity.
Siddiqui et al., 2011 25 RCT Cancer: CRC screening | - Patient education; - Promotion of self-management; - Patient reminder system | - No disparity in CRC screening rates at baseline by race or ethnicity.; - No statistically significant difference in screening rates between White participants and African-Americans in the control group.; - When intervention groups were combined, the screening rate was significantly higher in White participants compared to African-Americans.

Abbreviations: BP = blood pressure; CRC = colorectal cancer; DBP = diastolic blood pressure; GAP = American College of Cardiology's AMI Guidelines Applied in Practice; HbA1c = hemoglobin A1c; HDZ = health disparity zone; LDL = low density lipoprotein; QI = quality improvement; RCT = randomized controlled trial; SBP = systolic blood pressure.

Two RCTs evaluated the effects of interventions on racial or ethnic disparities in colorectal cancer screening.25,26 Three studies explored the effects of various QI strategies on disparities associated with race in cardiovascular disease, including coronary artery disease and hypertension.21,22,33Three studies evaluated the effect of QI interventions on racial or ethnic disparities in depression outcomes15,17,24,28,29,34 and three studies provided data to assess the impact of QI interventions on racial or ethnic disparities in diabetes outcomes.16,31,32

Most (n=8) were unable to show a reduction in disparity, or suggest that they might be useful for reducing disparity by failing to demonstrate an amplified effect in any one subgroup. Three studies provided data suggesting that their approach had some potential to affect disparities.15,21,28,29,32,34 None provided conclusive information and each studied a different approach in a different disease condition, making synthesis challenging.

One disease management and patient education program32 was associated with a reduction in disparity between Black and White patients in HbA1c testing when it was targeted in a geographic area with very high rates of diabetes. Other interventions did not demonstrate a significant reduction in disparity, but an amplified effect was seen in nonwhite populations with some interventions, including a patient education program to reduce blood pressure,21 and a complex collaborative care model targeted to providers of patients with depression.15,28,29,34 In the latter study, the intervention was significantly more effective in the short term among minorities, although this was no longer the case at 1 year, and the intervention was not effective in any population at five and nine years.

### Detailed Description

#### Studies Focused on Cancer Outcomes

Two studies evaluated the effects of interventions on racial or ethnic disparities in colorectal cancer screening.25,26 Both studies were secondary analyses of RCTs and examined the usefulness of patient education and reminder systems for improving colorectal cancer screening rates, as measured by participation in fecal occult blood testing or colonoscopy within one year after study entry. One study involved a primary care practice-based research network 26 and the other included a single large academic primary care practice. 25 Both trials took place in the United States and targeted patients who were due for CRC screening. The two studies employed a usual care comparison group.

One of the secondary RCT analyses randomized 465 participants, including 221 White patients, 129 Black patients, and 115 patients of other/unknown race. 25 Patients were assigned to either usual care or language-concordant assistance by a patient navigator, a trained individual who promoted self-management strategies and provided patient education and reminders. The patient navigator intervention as compared with usual care was associated with significantly increased screening rates among both White (33.9 vs. 16.5 percent, p=0.003) and Black participants (39.7 vs. 16.7%, p=0.004), with overall similar proportions obtaining screening in both racial groups during the 12 month followup period.

The other secondary RCT analysis randomized 1430 patients, including 578 Whites and 852 Black participants. 26 This trial included a usual care comparison group and employed three intervention arms: a standard intervention including an educational brochure and screening reminder, a tailored intervention including the standard materials plus additional educational information targeting each participant's perceived barriers to screening as assessed at baseline, and a group that received both the tailored intervention plus a reminder phone call. CRC screening rates by 12-month followup were similar in the usual care group for Whites as compared with African-Americans (33 percent vs. 32 percent). An analysis pooling results of the three intervention groups vs. usual care indicated that the interventions had an increased effect on improved screening rates among White participants as compared with their Black counterparts (53 percent vs. 43 percent, adjusted OR 1.44, 95% CI 1-12 to 1.86, p=0.005).

#### Studies Focused on Cardiovascular Disease

##### Coronary Artery Disease

One post hoc analysis of an RCT,22 and one retrospective cohort study33 explored the effects of various QI strategies on racial health care disparities in coronary artery disease. The RCT addressed reduction of associated risk factors,22 while the retrospective cohort examined management of AMI.33 QI strategies included patient education and facilitation of self–management22 and a multifactorial provider– and systems–focused strategy.33 Both studies took place in the United States, in the setting of two multicenter collaborations of academic and community health centers.22,33 The studies each employed an internal usual care comparison group.

For coronary artery disease (CAD), we sought assessments of critically important clinical outcomes, surrogate clinical outcomes, and process measures. No health outcomes (e.g., death, myocardial infarction, myocardial ischemia, and congestive heart failure were reported. One surrogate outcome in the form of a clinical risk factor for CAD (smoking) was reported. Several process measures (cardiac catheterization, PCI, beta-blocker usage, aspirin usage) were reported.

One analysis of RCT data22 evaluated the utility of QI strategies in reducing CAD risk factors and one retrospective cohort study33 evaluated QI strategies for improving management of acute myocardial function among different racial groups.

The RCT was the Multiple Risk Factor Intervention Trial (MRFIT), a large secondary prevention study among men at elevated risk of CAD.22 The intervention included an initial intensive period of ten weekly sessions followed by individual counseling, focused on behavior change and risk factor reduction related to nutrition, smoking cessation, and antihypertensive therapies.35 The study recruited men from 22 academic and community health care centers in the United States. A secondary analysis examined racial differences in CAD risk factor reduction in 11935 White patients (including individuals who identified their race as “other”) and 931 Black patients. The sixth annual followup visit included 5754 in the intervention arm (5338 White patients and 416 Black patients) and 5638 in the usual care group (5227 White patients and 411 Black patients). The incidence of smoking cessation (self–report adjusted for thiocyanate levels) by the sixth annual visit was approximately the same among White and Black patients in the intervention group, 46.0 percent and 43.0 percent, respectively (p=0.26).^*^ In the usual care group at this same time point, Black patients were less likely to have quit smoking than White patients, at 22.5 percent versus 29.0 percent (p<0.004).^*^

* Fisher's Exact Two-Tailed Test, calculated by review authors using original data.

One fair retrospective cohort study, using historical controls33 constructed a retrospective cohort from Medicare patients with history of AMI treated at a group of academic and community hospitals in Michigan, sampling data from one year preceding a rapid cycle QI project and from four months immediately following implementation. The QI strategy involved customization and implementation of the American College of Cardiology's AMI Guidelines Applied in Practice (GAP) toolkit,36 including provider education, standing orders, admission and discharge tools, and pocket guidelines for clinicians. The analysis compared results between the group of patients (including 1158 White and 210 nonwhite patients) treated before implementation of the GAP toolkit (pre-GAP), and a separate group of patients (including 1209 White and 280 nonwhite patients) treated after implementation of the GAP toolkit (post–GAP). A significant improvement in use of the admission tool and aspirin during the inpatient stay were observed in both White and nonwhite patients. Nonwhite patients had a significant increase in inpatient beta–blockade (66.0 percent pre–GAP vs. 83.3 percent post-GAP, p=0.04), while White patients did not (76.8 percent pre-GAP vs. 82.4 percent post-GAP, p=0.13).

Although outcomes improved in other measures for both racial groups, they improved more for White patients, creating or worsening the disparity between the two groups, while improving outcomes overall. For example, pre-GAP, use of the discharge tool was low overall, but similar for White and nonwhite patients (1.8 percent vs. 1.0 percent, p=0.37). After implementation of GAP, the tool was used more overall, but significantly more often with White patients than nonwhite patients (30.1 percent vs. 23.6 percent, p=0.03). A similar effect was observed for smoking cessation counseling, which was similar pre-GAP among White and nonwhite patients (39.4 percent vs. 34.2 percent, p=0.57), but post-GAP, increased significantly more among White patients (73.4 percent vs. 50.0 percent, p=0.002).

Disparities also developed in use of invasive procedures. For example, the use of cardiac catheterization, which was similar among White and nonwhite patients pre-GAP, increased significantly among White patients post-GAP (from 45.5 percent to 50.8 percent, p=0.01), though it tended to decrease among nonwhite patients (from 44.8 percent pre-GAP to 36.8 percent post-GAP, p=0.07). Among White patients, PCI increased from 19.8 percent to 25.6 percent, p=0.0008; however among nonwhite patients, PCI remained flat (15.7 percent pre-GAP vs. 13.2 percent post-GAP, p=0.44). Consequently, in the post-GAP period, use of these invasive procedures was significantly less common among nonwhite patients than White patients (for cardiac catheterization, OR 0.56, 95% CI, 0.43 to 0.74; for PCI, OR 0.44, 95% CI, 0.31 to 0.64 In summary, this study of the GAP initiative demonstrated mixed results regarding disparities in cardiovascular care. Use of the admission tool and inpatient aspirin increased similarly among White and nonwhite patients; use of inpatient beta-blockade increased more among nonwhite patients; and use of cardiac catheterization and PCI increased more among White patients than nonwhite patients.

##### Hypertension

Two post hoc analyses of RCTs explored the effects of various QI strategies on racial disparities in hypertension.21,22 The RCTs addressed management of hypertension21 and reduction of risk factors for CAD including hypertension.22 QI strategies were patient education and facilitation of self–management.21,22 Both studies took place in the United States, with settings including university clinics21 and multicenter collaborations of academic and community health centers.22 The studies each employed an internal usual care comparison group.

Health outcomes such as death, myocardial infarction, ischemic stroke, and congestive heart failure were not reported. One surrogate clinical outcome (blood pressure) was reported.

Two post hoc analyses of RCT data assessed the impact of QI strategies on hypertension among different racial groups. The MRFIT trial, described above for its modification of coronary artery disease risk factors, assessed the effect of the intervention on systolic and diastolic blood pressure among Black and White participants.22 Men received monitoring of blood pressure and lifestyle counseling; upon being diagnosed with hypertension, they received stepped pharmacotherapy. The study quality was assessed as fair; the data presented here are from post hoc analyses.

At baseline, Black men had higher mean blood pressure than White men (138/94 vs. 135/91, p<0.001). The intervention was reported to have resulted in slightly greater reduction of blood pressure among Black men (reduced systolic blood pressure [SBP] by 11.7 percent and diastolic blood pressure [DBP] by 13.6 percent), compared with White men (reduced SBP by 10.3 percent and DBP by 11.4 percent).^**^ In the control group, less reduction was observed compared with the intervention, and similar changes in blood pressure were reported among Black men (reduced SBP by 5.8 percent and DBP by 8.1 percent) and White men (reduced SBP by 6.4 percent and DBP by 7.9 percent).^**^ At the sixth annual followup visit, among intervention patients, mean blood pressures were reported to be similar in Black (122/81) and White (121/80) men, and a similar proportion of Black (72 percent) and White (71 percent) participants were at or below the DBP goal. Achievement of these goals was not related to baseline DBP. Among control group patients, mean blood pressure was reported as slightly higher among Black men (129/86), than White men (127/84).^**^ Blood pressures in the intervention group were reduced more than were those in the control group. A small, but significant baseline disparity in systolic and diastolic blood pressure measures was not present at followup in the intervention group, but persisted at followup in the control group.

** The authors did not provide statistical tests of significance, and the standard deviations for the means were not reported, so statistical analysis could not be performed by the reviewers.

Another post hoc analysis21 explored racial differences in outcomes following an RCT that assessed two hypertension self–management strategies (home blood pressure [BP] monitoring 3 times weekly, or tailored behavioral self–management intervention by phone every other month) alone or in combination, compared with usual care. Participants included White (n=308) and nonwhite (n=328, 95 percent African-American) patients with a diagnosis of hypertension for at least 1 year before recruitment.21 Participants were treated in two university–affiliated general internal medicine clinics and followed for 24 months. The study quality was assessed as fair; the data presented here are from a post hoc analysis. At baseline, nonwhite patients had significantly higher SBP (128 vs. 121 mm Hg, p<0.0001) and DBP (74 vs. 69 mm Hg, p<0.0001) than White participants, and the initial prevalence of blood pressure control was also lower among nonwhite than White patients (72.5 vs. 88 percent, p<0.0001). A race by time by treatment group effect model suggested differential intervention effects on BP over time for White and nonwhite patients for DBP (p=0.01), but not for SBP (p=0.08).

Among White patients, SBP was not significantly different at 12 or 24 months followup in intervention and control groups. Results for DBP were similar, except mean DBP at 1 year was 3 mm Hg higher in the behavioral only strategy, compared with control (p=0.03). Among nonwhite patients, at 1 year, SBP and DBP improved by 5 mm Hg and 3 mm Hg, respectively, in each of the three intervention groups, compared with usual care (p<0.05). In the combined intervention group (home monitoring + tailored behavioral intervention), persistent improvements in SBP (-7.5 mm Hg) and DBP (-3.5 mm Hg) were present at 24 months, compared with usual care (p<0.05). Thus, the two hypertension self-management strategies were ineffective among White patients, but effective among nonwhite patients. The interventions alone or in combination significantly reduced BP at 1 year in the nonwhite group, and the combined intervention resulted in persistent BP reductions at 24 months, thereby reducing disparities in BP control.

#### Studies Focused on Depression Outcomes

Three studies evaluated the effect of QI interventions on racial or ethnic disparities in depression outcomes.15,17,24,28,29,34 All three studies used a collaborative care model, which involved collaboration among multiple clinical providers to provide a coordinated set of interventions. The clinical model in all three studies included a dedicated mental health coordinator (nurse or case manager), creation of mental health teams (composed of primary provider, facility nurses, and psychiatrists), evidence-based pharmacotherapy and psychotherapy, extensive provider education, and longitudinal patient followup to evaluate clinical status and adherence. Each intervention was designed to address known barriers to the receipt of quality mental health care.

All three trials were prospective, randomized controlled trials, with randomization to types of provider training occurring at the practice level. However, given the nature of the intervention (group-level randomization), individual providers and patients retained ability to select the treatment provided to the individual patient. All three trials took place in the United States.

The Partners in Care (PIC) study18,21,31,34,35,41 delivered a composite intervention of patient and provider education, nurse-assisted patient assessment, and targeted use of medication management and cognitive behavioral therapy. Outcomes were collected through mail surveys at 6 months,34 1 year,15 2 years,30 5 years29 and 9 years.28

The study enrolled 1356 patients, and was conducted in six managed care organizations around the United States (at least one organization was selected in each of the four United States' census regions; study investigators also sought to recruit organizations known to have high enrollment of Mexican Americans).37

Study patients were selected by use of the 12-month Composite International Diagnostic Interview, version 2.1, an unspecified tool designed to evaluate depressed symptoms in the prior month, telephone interviews, and self-administered questionnaire. Fourteen percent of the patients screened for the study were eligible to participate. Of those eligible, 34.7 percent enrolled. The study population included 61.3 percent Caucasians, 30 percent Latinos, and 7.3 percent African-Americans.

PIC was designed to compare usual care versus two interventions: QI–Meds and QI–Therapy. The intervention components: (1) enrolled practices provided in-kind resources (up to one half of the cost) to assist in intervention implementation; (2) provider training at study onset and monthly meeting thereafter to provide feedback on treatment patterns; (3) each practice had a designated staff nurse who was trained as a “depression specialist” who would screen patients for depression, then educate and engage those who screened positive in depression self-management. The QI–Meds intervention contained all above components plus trained nurses who assessed patient adherence to antidepressant pharmacotherapy. The QI–Therapy intervention contained all of the above components plus local psychotherapists who could provide individual or group cognitive behavioral therapy.

The QI educational material was provided to patients in English or Spanish language text. Minority primary care providers were featured in videotapes viewed by intervention participants. Providers in intervention practices were given instruction in how to lower barriers to treatment experienced by Latino and African-American patients. PIC investigators, belonging to ethnic minority subgroups, also provided direct supervision for local experts.

At 1 year,15 the ethnic minorities in the intervention group (QI–Meds and QI–Therapy were combined) had statistically significantly lower rates of probable depression than minorities receiving usual care (Latino 27 percent less, p=0.02; African-American 27 percent less, p=0.01). Conversely, no such effect was observed among White participants. The disparity between Latino participants and the White participants who received the intervention was reported to have increased in the first year of participant followup (6.7 percent at baseline to 7.7 percent at 1 year).^**^ In contrast, the disparity was reported to have decreased when comparing African-Americans to White participants (9.2 percent to 6.7 percent).^**^ However, although a statistically significant interaction was seen between intervention and ethnicity at 6 months when minorities were grouped and contrasted with White participants, no such interaction persisted by 1 year.

At five years, the PIC group provided aggregate and individual results for the two ethnic minorities (Latinos and African-Americans).29 In the aggregated analysis, minorities receiving QI–Therapy had a lower rate of probable depression compared with usual care minorities (35.6 percent vs. 55.8 percent, p=0.01). On the other hand, no statistically significant difference was observed in outcomes of QI–Meds in terms of probable depressive disorder in the minority population (45.4 percent vs. 55.8 percent, p=0.13).29

The overall effect of the intervention on depression status was not significant at five and nine years. No disparity was established at baseline, and the data did not demonstrate a change in disparity associated with the intervention.28

Employment status did not change significantly among minorities as a result of the intervention compared with usual care employment rates (Latino 3.5 percent increase, p=0.38; African-American 5.3 percent decrease, p=0.43).15 A decrease in the disparity in employment between nonwhites and Whites decreased at 6 months from 10 percent to 3.2 percent, but the concordant gap between White participants and the Latino participants increased from 3.6 percent to 5.9 percent at 1 year of followup. The employment status of Black intervention recipients also worsened in the first year of followup: at baseline, 74.1 percent Black participants versus 64.5 percent White participants were employed; at 1 year, 70.3 percent versus 66 percent were employed. None of these changes could be attributed to the intervention, however.

Appropriate care was defined as identifying a patient's need for care and providing guideline concordant treatments. At 1 year,15 minority intervention subgroups experienced improvement in the rate of appropriate care received compared with non-intervention minority groups (Latino 26.6 percent increase, p=0.03; African-American 26.3 percent increase, p=0.33). The disparity between White participants and minority participants was not decreased.

The five year evaluation reported likelihood of unmet need, rather than rates of appropriate depression care, among ethnic minorities.29 Ethnic minority participants in the QI–Meds group were 11.8 percent less likely to have unmet need compared with White participants in the QI–Meds group; ethnic minority participants in the QI–Therapy group were 5.3 percent less likely to have unmet need compared with White participants in the QI–Therapy group at 5 years. Because the baseline incidence of probable unmet need was not disaggregated by ethnicity, no comment can be made on whether the disparity gap was narrowed by either intervention.

The PROSPECT study 24 involved 20 primary care practices and 396 patients, 60 years of age or older, from the Northeastern United States. The intervention included a practice-based depression care manager who offered treatment recommendations to the primary care provider based on a prespecified algorithm. While the treatment algorithm focused on a particular pharmacotherapeutic regimen, the provider or patient could elect to modify the recommended course. If pharmacotherapy was declined, then psychotherapy was recommended. Care managers were also involved with monitoring patient treatment response and adherence. Providers in practices randomized to usual care received videotaped and printed information on depression in older patients; they also received written communication that alerted them if a patient fulfilled diagnostic criteria for depression.

The 2011 publication described a post hoc analysis of data that initially evaluated intervention efficacy among all older depressed primary care patients included in the study population.24 In the original publication,38 investigators reported that the intervention demonstrated efficacy in reduction of suicidal ideation and depression symptoms in the study population. Since that publication, the PROSPECT investigators conducted a subgroup analysis of 134 ethnic minority participants (34 percent) versus 262 non-Hispanic White participants (66 percent), and a separate subgroup analysis of 146 college-educated (31 percent) versus 323 non-college educated participants (69 percent).24

For appropriate use of antidepressants (i.e., adequate dose), a baseline disparity was observed in the usual care group only, in which 22 percent of minorities had adequate antidepressant use, compared with 39 percent of non-Hispanic White participants. The effect on difference in this measure by race was not statistically significant at any point in time.24

The IMPACT trial was initially designed to evaluate whether a collaborative care model would improve clinical and functional outcomes in primary care patients being treated for depression.39 Subsequent subgroup analyses 17,18 were performed to evaluate whether this intervention could decrease outcome disparities among older ethnic minorities 17 and among older adults of higher and lower incomes 18. IMPACT was carried out across five states involving 18 primary care clinics and eight health care organizations. The intervention was a collaborative, stepped care model that consisted of a depression care specialist (DCS) who coordinated (1) primary care provider education about evidence-based treatment, (2) a depression care manager working with the patient and primary care provider to activate patients in the management of their depression, (3) ongoing mood and medication monitoring, (4) brief psychotherapy (known as “Problem Solving Treatment of Primary Care;” PST-PC), (5) a clinical information tracking system, and (6) ready access to a psychiatrist for additional consultation.40

The original study population consisted of 1801 patients, above the age of 60 years, who met criteria for major depression, dysthymic disorder, or both. Though the sample was not stratified by ethnicity at enrollment, representation of ethnicities enrolled in the two treatment groups was fairly balanced (intervention contained 51 percent of the study's White patients, 51 percent of the study's Black patients, and only 41 percent of the study's Latino patients, p= 0.07). The collaborative care intervention itself did not incorporate accommodations for cultural differences. Participant data was collected at baseline, 3, 6, and 1 year.40

Ethnicity was not reported by the investigators to have been associated with any statistically significant differences in study subjects' baseline use of mental health treatment services.

Target responses were a decrease of 50 percent or more in the Hopkins Symptom Checklist-20 (HSCL-20) score from baseline, and treatment remission (i.e., HSCL-20 score less than 0.5). In the overall study population, at 1 year, 45 percent of intervention patients had a 50 percent reduction in depressive symptoms compared with 19 percent of the control group patients (OR 3.45, 95% CI, 2.71 to 4.38). The intervention was equally effective in all groups without cultural adaptation.17

No statistically significant differences existed between ethnic subgroups at baseline in health related functional impairment, assessed with the Short Form Physical Functioning Scale. At 1 year, all ethnic groups had small, statistically significant improvements in functional impairment and there was no difference in effect by race or ethnicity.17

Service use, defined as use of antidepressants or psychotherapy, did not differ statistically by participant ethnicity at baseline.17 At 1 year, collaborative care minorities had accessed significantly more guideline-concordant depression services than minorities in the usual care group (use of antidepressant: 64 percent, 95% CI, 55 to 72 percent vs. 45 percent, 95% CI, 36 to 55 percent, p=0.003; use of psychotherapy: 37 percent, 95% CI, 28 to 47 percent vs. 13 percent, 95% CI, 6.5 to 19 percent, p=0.002). The effect of the intervention was thus similar across ethnic and income groups.17 Although no statistical interaction was observed overall, there were some notable differences in magnitude of effect by race or ethnicity. In particular, in stratified analysis, collaborative care was associated with greater use of psychotherapy among Black patients than usual care, but not with greater use of antidepressants.17

#### Studies Focused on Diabetes Outcomes

Three good quality studies provided data to assess the impact of QI interventions on racial or ethnic disparities in diabetes outcomes.16,31,32 One was a cluster RCT,16 one was a prospective cohort,31 and one was a retrospective cohort study.32 One was a patient reminder system that was a part of a larger diabetes management program,32 one was a comparison of community provider interventions with statewide programming,31 and the third was a program to provide cultural competency training to clinicians.16

No studies reported health outcomes, including death, hypoglycemic coma, adverse drug event, cardiovascular complications, retinopathy progression, nephropathy progression, neurologic complications, or hospitalization for a complication of diabetes. Studies reported surrogate clinical outcomes, clinical risk factors for diabetes comorbidities, and process measures. Clinical outcomes reported in this literature were surrogate measures: achievement of hemoglobin A1C (HbA1c) of less than 7 percent, achievement of target blood pressure (BP), and achievement of target low density lipoprotein (LDL) cholesterol level.

One study provided data on all three surrogate outcomes.16 This good quality cluster RCT was conducted in eight ambulatory health centers in eastern Massachusetts between 2007 and 2008 and randomized 124 primary care clinicians (physicians, nurse practitioners, and physician assistants) caring for 2699 (36 percent) Black diabetic patients and 4858 (64 percent) White diabetic patients to intervention or control.16 Intervention clinicians received cultural competency training and monthly race-stratified performance reports that highlighted racial differences in control of HbA1c and LDL cholesterol levels and BP. Care recommendations for Black diabetic patients along with race-stratified physician-level diabetes performance reports were provided on a monthly basis to clinicians in the intervention group.

White and Black patients differed significantly at baseline for the rate of HbA1c less than 7 percent, with White patients more likely than Black patients to be controlled (46.1 percent vs. 40.0 percent, p<0.001) despite no disparity in receipt of annual HbA1c examinations.16 At followup, no intervention effect was observed in the Black patient population, with the proportion meeting the target in the intervention group just 3.3 percent higher than in the control group (adjusted difference 3.3 percent, 95% CI,-2.1 to 8.6, p= 0.24). By the same token, no intervention effect was seen in the White participants (adjusted difference 1.9 percent, 95% CI, -1.9 to 5.6, p= 0.22), and no effect was observed on the disparity between the two groups.

The same pattern was repeated for blood pressure and LDL outcomes, in which Black participants had consistently poorer health indicators, and the intervention was not shown to be effective in the Black population, and had no impact on disparities.

Process measures assessed in the diabetes QI literature were completion of HbA1c testing and lipid testing. A good quality retrospective cohort used a corporate national health care database to assess the effectiveness of disease management programs on testing for HbA1c levels in socioeconomically disparate areas.32 The study defined a Health Disparity Zone (HDZ) as a zipcode-defined area in which diabetes prevalence was above the national average of diabetes prevalence among minorities. Within a HDZ, individuals were further subdivided by zip code areas, depending upon whether the zip code area contained more than 50 percent minorities or not (minority vs. nonminority). The study defined a non-HDZ as one with diabetes prevalence at or below the national average for minorities. The study population thus included 3359 individuals residing in HDZs and 34,066 individuals residing in non-HDZs. Of the 3359 members living in HDZs, 2068 (61.6 percent) lived within minority zip code areas.

The study assessed the degree to which a patient reminder telephone intervention increased HbA1c testing rates among non-adherent members, and analyzed differences by zone and minority neighborhood status.32 Non-adherent members were defined as those who lacked an HbA1c test in the baseline period.

After 1 year, the rate of testing increased significantly (p<0.0001) in the HDZ group to 59.4 percent. The rate of testing also increased significantly by 4.6 percent to 68.6 percent in the non-HDZ group (p<0.0001). Thus, the initial 12 percent disparity in testing between high disparity and low disparity zones was narrowed by 3 percent to 9 percent after 1 year. The 3 percent reduction in disparity did not reach standard statistical significance by Fisher's exact two-tailed test (p=0.06).^***^

*** Fisher's Exact Two-Tailed Test, calculated by review authors using reported data.

The authors further examined the potential for a differential effect in minority neighborhoods compared to non-minority neighborhoods within the high disparity zone. Rates of testing in zip codes with greater numbers of minority members increased significantly from baseline to 1 year, with an increase in testing of 15.5 percent (p< 0.0001). Conversely, no increase over time was observed in nonminority zip codes in the HDZ. Therefore, a reduction in racial disparity was noted within the population with high prevalence of diabetes, while no reduction in disparity between high and low prevalence zones overall was seen.

Because there was no unexposed group in this study, it is not possible to be certain that observed increases in HbA1c testing in both high disparity and non disparity zones were due to intervention effects. Nonetheless, a racial disparity was decreased within the high disparity zone, where minority zip codes demonstrated greater increases in testing rates compared to non-minority zip codes. Whether this was because it is easiest to “move the dial” in populations that start with the poorest health measures is unknown. Nonetheless, in a “per-protocol” analysis by whether or not the call was actually received, receipt of the phone reminder was associated with increased likelihood of HbA1c testing, suggesting that phone reminders targeted to disadvantaged populations may be a tool for further evaluation.

One study measured lipid testing as the outcome.31 This prospective cohort study used a database of Medicare patients in New York to evaluate an intensive intervention program designed to reduce the recognized racial disparity in the rate of biennial lipid profile testing among New York City residents with diabetes between 1999 and 2004.^31^

The study was quasi-experimental, of good quality, and reported both a before-and-after analysis for the African-American Medicare fee-for-service (FFS) beneficiaries with diabetes living in the Bronx, Kings, New York, and Queens counties, and a comparison against a reference group of all White Medicare FFS beneficiaries with diabetes in the same counties.31 All subjects had diabetes and received care at physician offices, outpatient clinics, and community health centers in the New York City metropolitan area. The QI intervention compared Medicare New York State Quality Improvement Organization (IPRO) multifaceted provider and community “intense” interventions versus statewide interventions that IPRO implemented for the Physician Office Quality Improvement Project. The outcome of interest was the proportion of beneficiaries with diabetes who received a biennial lipid profile test.

The before (April 1999) and after (March 2002 up to March 2004) comparison reported a 26.2 percent improvement in biennial lipid profile testing rate among African-American beneficiaries from 63.8 percent to 80.5 percent and an 8.3 percent improvement in biennial lipid profile testing rate among White beneficiaries (increase from 82.8 percent to 89.7 percent).31

The baseline disparity in the biennial lipid profile testing rate among African-American beneficiaries compared with all eligible White beneficiaries in the intervention areas was 19 percent. The disparity during the 2002 to 2004 retesting period was 9.2 percent, a reduction of 52 percent. The “intervention” itself was multi-faceted, targeting individuals and providers in many settings and with different specific approaches, including a provider toolkit, patient educational materials, provider reminders, on-site visits and cultural competency training. At the same time, community-directed interventions were put into place including outreach, focus groups and community-based education. As a community-level intervention, no attempt was made to assess individual receipt of the intervention itself; rather, the outcomes were measured at the population level. Thus, individuals could move in and out of the population. Nonetheless, a reduction in disparity was observed over the intervention period, and despite the fact that it cannot be directly associated with the intervention itself or to components of the complex intervention, intermediate goals such as participation in cultural competency training were met.31

## Effects on Insurance Disparities

### Overview

Two studies examined a difference in outcomes associated with insurance status (Table 5). Both evaluated interventions to improve cancer screening rates. In one study,19 a patient reminder system was equally successful in commercially insured and Medicare insured women at increasing rates of regular mammography screening. The study was conducted in a large group–model health maintenance organization (HMO) and assessed the use of patient reminders, including a mailed reminder (n=630) or telephone contact with opportunity to schedule screening (n=653) as compared with usual care (n=625) among women aged 50 to75 years who had received a previous mammogram but were overdue for breast cancer screening.19

Table 5 Summary of effects on disparities in health outcomes associated with insurance status

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Barr et al., 2001^19^ RCT Breast cancer screening | - Patient reminder system | - No disparity was observed at baseline.; - The intervention was successful in both groups.; - Reminder interventions improved likelihood of screening mammography in both commercially insured women (p=0.001) and women covered by Medicare (p=0.01) with no difference in improvement between groups.
Lasser et al., 2011^26^ RCT Colorectal cancer screening | - Patient education; - Promotion of self-management; - Patient reminder system | - No disparity in screening rates at baseline by race or ethnicity.; - The intervention increased screening rates in both the private and public insurance groups compared to individuals in the usual care group.; - The intervention was associated with a better screening rate for the privately insured group compared to publicly insured group.

Abbreviations: QI = quality improvement; RCT = randomized controlled trial.

The second study comprised a secondary analysis of an RCT conducted in a large primary care practice-based research network, aimed at increasing colorectal cancer (CRC) screening among eligible adults and including 153 individuals with private insurance and 312 with public insurance.26

### Detailed Description

A subgroup analysis explored variable effects of the QI strategies in commercially insured patients as compared with Medicare patients, representing approximately 96 percent of the original trial population. The quality of this study was assessed as poor. Among commercially insured women, the use of followup mammography was greater among those randomized to telephone contact (55.6 percent), compared with the mail reminder (44.4 percent) or usual care (39.4 percent, p=0.001). Similar effects were observed among women receiving Medicare, who also had greater use of followup mammography when randomized to telephone contact (56.4 percent), compared with the mail reminder (43.6 percent) or usual care (42.7 percent, p=0.01).

Women covered by Medicare had the same likelihood of followup mammography during the study as commercially insured women. Across insurance types, the difference in followup mammography was not significantly different with the mailed reminder, compared with usual care (p=0.25). Thus, compared with usual care, the telephone based intervention improved mammography use for all populations, but the mailed reminders did not. The telephone based intervention did not demonstrate greater effect in disadvantaged women, as women in the commercially insured and Medicare groups derived similar benefit.

The other subgroup analysis involved an RCT in which patients due for CRC screening were assigned to either usual care or language-concordant assistance by a patient navigator, a trained individual who promoted self-management strategies and provided patient education and reminders. The intervention as compared with usual care was associated with significantly increased screening rates among both privately insured (43.4 percent vs. 22.1 percent, p=0.005) and publicly insured participants (28.9 percent vs. 18.9 percent, p=0.04), though the effectiveness of the navigator intervention appeared somewhat increased in the privately insured group during the 12-month followup period.26

## Effects on Language Disparities

### Overview

Two studies examined the degree to which language concordance was associated with increased cancer screening (breast and colorectal) among individuals speaking primarily English or other languages (Table 6). Both of them studied language concordance, in which strategies are provided in the native or preferred language of the participant (e.g., in Spanish for native Spanish speakers).

Table 6 Summary of effects on disparities in health outcomes associated with language barrier

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Beach et al., 2007^20^ RCT Cancer: CRC and breast cancer screening | - Patient education; - Promotion of self-management; - Patient reminder system | - At baseline, Spanish speakers were more likely to be up to date on breast cancer screening.; - The intervention was effective at increasing rates of breast cancer screening overall, with greater effect among Spanish speakers.; - Nonetheless, the difference between observed effects for breast cancer screening in the two language groups was not significant.; - No disparity in CRC screening rate was measured at baseline.; - The intervention was associated with increases in CRC screening in both groups, with neither group associated with a greater effect of the intervention.; - Therefore, although there was no evidence that the intervention might reduce known disparities, the intervention was effective at increasing CRC screening for both groups.
Lasser et al., 2011^26^ RCT Cancer: CRC screening | - Patient education; - Promotion of self-management; - Patient reminder system | - No disparity was measured at baseline; - English speaking participants had a similar incidence of CRC screening during 1 year of followup in the intervention group as compared with usual care.; - Intervention was particularly beneficial for non-English language participants

Abbreviations: CRC = colorectal cancer; QI = quality improvement; RCT = randomized controlled trial.

One study was a secondary analysis of an RCT which provided language-concordant patient education for English speaking and Spanish speaking participants, with the goal of increasing adherence to recommendations for breast and colorectal cancer screening among eligible adults.20 For breast cancer screening, Spanish speakers were more likely to be up to date at baseline than English speakers (OR 1.46; 95% CI: 1.16 – 1.84). The intervention was associated with increased rates of screening overall, with subgroup analysis indicating a greater effect in the Spanish speaking group (OR 1.85; 95% CI: 1.38, 2.47) than the English speaking group (OR 1.18; 95% CI: 0.82, 1.71). However, the overall multivariate analysis failed to confirm these results and providing the intervention in Spanish to Spanish speakers did not make it any more effective in this group. This may suggest that targeted language concordant interventions could warrant further examination, but these results reflect only one study. For colorectal screening, there was no difference in up to date status at baseline, the intervention was again effective overall, and there was no language-by-intervention effect.

Another secondary analysis of an RCT included language-concordant assistance by a patient navigator who promoted self-management strategies and provided patient education and reminders to facilitate adherence to colorectal cancer screening among eligible adults in a large primary care practice-based research network, including 224 individuals speaking English as their primary language and 241 speaking a language other than English, including Spanish, Portuguese, and Haitian Creole.26

### Detailed Description

In one fair RCT20, a prevention care manager periodically called to remind women about screening, assist in overcoming barriers, provide emotional support, and help with scheduling; women also received additional educational materials in their preferred language by mail. A subgroup analysis focused on the impact of this strategy among women who preferred Spanish (n=848) and those who preferred English (n=498). Among Spanish–speaking women, a significantly greater proportion of women (72 percent) in the care management group were up to date on breast cancer screening at followup, compared with 58 percent in those receiving usual care, (adjusted OR 1.86, 95% CI, 1.39 to 2.50). Among English speakers, women in the care management group were not significantly more likely to be up to date on breast screening, compared with women in the usual care group (60 percent and 56 percent, respectively; adjusted OR 1.23, 95% CI, 0.85 to 1.78). Although Spanish-speaking women benefited more from care management than did English-speakers, when assessed statistically as an interaction effect, the result was non-significant (OR 1.51, 95% CI, 0.94 to 2.42). Though women speaking either language were equally likely to receive appointment reminders, access advice, and assistance with making primary care appointments, Spanish-speaking women were more likely than English–speaking women to receive help scheduling appointments for breast cancer screening (26.5 vs. 18.4 percent, p=0.01) and were more likely to have educational materials mailed to them (70.2 vs. 60.6 percent, p=0.01). Although it was not significantly greater than the effect seen in English-speakers, the magnified effect observed in Spanish-speakers may suggest that language concordance is helpful in interventions seeking to achieve up to date cancer screening status.

Another secondary RCT analysis examined whether education and reminders from a language concordant patient navigator led to differences in CRC screening participation among English speakers as compared with non-English speakers. 26 While English speaking participants had a similar incidence of CRC screening during 1 year of followup in the intervention group as compared with usual care (26.8 percent vs. 21.4 percent, p=0.35), assistance from a patient navigator was associated with increased CRC screening among individuals speaking languages other than English as their primary language (28.9 percent vs. 18.9 percent, p=0.04). 26

## Effects on Health Literacy Disparities

### Overview

In one study focusing on improving provider-patient communication, in the VA system, colorectal cancer screening was increased among individuals with limited health literacy (55.7 percent vs. 30 percent; p=.002) but not among individuals with adequate health literacy (39 percent vs. 36 percent; p=.65) in the 20 percent subsample that underwent literacy assessment. The intervention itself included a workshop and feedback sessions for providers and educational materials for patients that included a video (Table 7).

Table 7 Summary of effects on disparities in health outcomes associated with health literacy

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Ferreira et al., 2005^23^ RCT Cancer: CRC screening | - Patient education; - Provider education; - Audit and feedback | - Patients with limited health literacy were significantly more likely to be screened for CRC when treated at the VA clinic implementing the QI strategy as compared with patients treated at the usual care clinic (55.7% vs. 30.0%, p=0.002).; - Patients with adequate health literacy were equally likely to pursue CRC screening when treated at the VA clinic implementing the QI strategy as compared with the patients treated at the usual care clinic (39.0% vs. 36.0%, p=0.65).; - Although the effect of the intervention on disparity was not measured directly, the intervention improved the incidence of up-to-date CRC screening among those with limited health literacy only and not among those with higher health literacy, suggesting that it might be a useful tool for reducing literacy related disparity.

Abbreviations: CRC = colorectal cancer; QI = quality improvement; RCT = randomized controlled trial; VA = Veterans Affairs.

### Detailed Description

The RCT included men aged 50 years or older, without a family history of CRC or polyps, who had not received recent CRC screening. The study randomized one VA clinic to a provider and patient education strategy and one VA clinic to continue usual care.23 The provider education intervention included a two-hour workshop on CRC screening and health literacy–sensitive communication skills, 1-hour feedback sessions every 4 to 6 months on the clinic's CRC screening rates, confidential provider–specific reports on screening rates, and small group role–playing about how to effectively make CRC screening recommendations. The patient education intervention included a video and educational material on CRC screening, though only 204 of 1978 patients in the overall RCT received this. The quality of this study was assessed as poor; randomization was broken, and the participants in this analysis represent a small proportion of the entire data set. A subset of patients completed the Rapid Estimate of Adult Literacy in Medicine (REALM) instrument at baseline, representing approximately 19 percent of the overall study sample (n=382/1978). Patients were classified as limited health literacy if they scored below ninth grade level on the REALM (n=139) and adequate health literacy if they scored at the ninth grade level or above (n=243). Patients with limited health literacy who were treated at the intervention clinic were significantly more likely to undergo CRC screening (55.7 percent) than low literacy patients treated at the usual care clinic (30.0 percent, p=0.002). There was no significant difference in CRC screening between the intervention and usual care clinics for patients with high health literacy (39.0 vs. 36.0 percent, p=0.65). Although the effect of the intervention on disparity was not measured directly, the intervention improved the incidence of up-to-date CRC screening among those with limited health literacy only and not among those with higher health literacy, suggesting that it might be a useful tool for reducing literacy related disparity.

## Effects on Socioeconomic Disparities

### Overview

In the two studies that assessed differences in effect by socioeconomic status, no effect was seen by income, but individuals with less education experienced greater benefits of collaborative care for depression than did those with higher education (Table 8).

Table 8 Summary of effects on disparities in health outcomes associated with socioeconomic status

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Arean et al., 2007^18^ RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Other (collaborative care model); - Facilitated relay of clinical data to provider | - Both low income and high/middle income populations experienced a very small benefit from the collaborative care intervention [fewer depression symptoms (high/middle income adjusted OR -0.41, 95% CI -0.49 to -0.33; low-income adjusted OR -0.39, 95% CI, -0.5 to -0.27; comparator: usual care)], but no disparities in depressive symptoms had existed at baseline.
Bao et al., 2011^24^ RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Other (collaborative care model); - Provider reminder system | - No disparity in depressive symptoms was present at baseline; - At 24 months, participants with no college education had a greater reduction in depression than participants with college.

Abbreviations: OR = odds ratio; QI = quality improvement; RCT = randomized controlled trial.

### Detailed Description

The IMPACT trial on depression care17,18 which also examined racial or ethnic disparities (see description above), included a subgroup analyses to evaluate whether this intervention could decrease outcome disparities among older ethnic minorities17 and among older adults of higher and lower incomes.18 Both low income and high/middle income populations experienced a very small benefit from the collaborative care intervention [fewer depression symptoms (high/middle income adjusted OR -0.41, 95% CI -0.49 to -0.33; low income adjusted OR -0.39, 95% CI, -0.5 to -0.27; comparator: usual care)], but no disparities in depressive symptoms had existed at baseline.18

A functional impairment gap did exist at baseline, with poor individuals scoring lower on the PCS (41.1 ± 7.4 vs. 38.6 ± 7.1; p<0.01). At 1 year, the collaborative care groups did experience a small but nonsignificant benefit when compared with usual care groups across income levels (high/middle income: adjusted OR 1.67, 95% CI, 0.78 to 2.55; low income: adjusted OR 1.46, 95% CI, 0.33 to 2.60), the effect of which was to reduce the gap somewhat between groups. Nonetheless the intervention was not associated with improvements overall.18

The PROSPECT study on depression care,24 which also examined race or ethnicity disparities (see description above) included a subanalysis focused on socioeconomic outcomes, based on degree of college education as a marker for SES. The no-college and some college groups had no statistically significant difference in depression severity as measured by the Hamilton Depression Rating Scale, at baseline or up to18 months post-intervention, although at 24 months, the no-college group reduced their depression scores more than did the group with a college education (difference of -3.8 [-6.8 to -0.4]).24 Nonetheless, no disparity existed to be narrowed, and the authors do not provide data to attribute the effect to the intervention. After adjusting for baseline antidepressant use, the no-college educated recipients of the study intervention had greater benefit in appropriate use of antidepressants (i.e., adequate dose) compared with the college-educated participants who received intervention (23.4 percent difference, 95% CI, 5.5 to 43.7 percent) at 1 year, but a statistically significant difference was not sustained at 24 months.

## Effects on Disparities by Sex

### Overview

One analysis from the PIC depression study examined the degree to which a collaborative care model for depression could reduce known disparities in accessing care and in outcomes by sex (Table 9). The intervention components: (1) enrolled practices provided in-kind resources (up to one half of the cost) to assist in intervention implementation; (2) provider training at study onset and monthly meeting thereafter to provide feedback on treatment patterns; (3) each practice had a designated staff nurse who was trained as a “depression specialist” who would screen patients for depression, then educate and engage those who screened positive in depression self-management. The QI–Meds intervention contained all of the above components plus trained nurses who assessed patient adherence to antidepressant pharmacotherapy. The QI–Therapy intervention contained all of the above components plus local psychotherapists who could provide individual or group cognitive behavioral therapy.

Table 9 Summary of effects on disparities in health outcomes associated with sex

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Sherbourne et al., 2004^30^ Cluster RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Audit and feedback; - Facilitated relay of clinical data to provider; - Other (collaborative care model) | - Women had higher rates of appropriate depression care compared with men at 2 years (p= 0.0001).; - QI–meds and QI–Therapy decreased “probable unmet need” disparity gap between men and women from 10% to 1% (QI–Meds) and to 3% (QI–Therapy) at 24 months.

Abbreviations: QI = quality improvement; RCT = randomized controlled trial.

Women had higher rates of appropriate depression care compared with men at 2 years (p = 0.0001). A medication focused intervention and a therapy focused intervention decreased a disparity gap between men and women in probable unmet need from 10 percent to 1 percent (QI–Meds) and 3 percent (QI–Therapy) at 24 months.

### Detailed Description

Women in QI–Meds group had non-sustained increase in employment rates compared with usual care women (p=0.23); no change occurred among women in QI–Therapy compared with usual care (p=0.10). Men in QI–Therapy also had a non-sustained improvement in employment status compared with the usual care (p=0.61) and QI–Meds (p=0.71) groups. The employment status disparity between men and women widened at 2 years in both intervention groups (QI–Meds gap = 8 percent; QI–Therapy gap = 6 percent) with men less likely to be employed than women.30

Women were 10.2 percent more likely than men at baseline to receive appropriate depression care (p=0.03). Over time, the disparity gap for “probable unmet need for depression care” between men and women was decreased from 10 percent to 1 percent (QI–Meds) and to 3 percent (QI–Therapy) at 2 years.30