# References

1 National Healthcare Disparities Report. AHRQ Publication No. 10-0004. Rockville, MD. Agency for Healthcare Research and Quality. March. 2010. www.ahrq.gov/qual/qrdr09.htm.
2 Smedley BD, Stith AY, Nelson AR. Unequal treatment : confronting racial and ethnic disparities in health care. Washington, D.C. Institute of Medicine Committee on Understanding and Eliminating Racial and Ethnic Disparities in Health Care., National Academies Press. 2003.
3 Centers for Disease Control and Prevention. Health disparities and inequalities report--United States, 2011. MMWR. 2011;60(Suppl). [pmid: 21430612].
4 Seid M, Lotstein D, Williams VL, et al. Quality improvement: Implications for public health preparedness. 2006.
5 Powell A, Rushmer R, Davies H. A systematic review of quality improvement models in health care. NHS Quality Improvement Scotland. 2009.
6 Shojania KG, McDonald KM, Wachter RM, et al. Closing the Quality Gap: A Critical Analysis of Quality Improvement Stategies, Voume 1- Series Overview and Methodology. AHRQ Pub No. 04-0051-1. Rockville, MD. Agency for Healthcare Research and Quality. 2004. www.ahrq.gov/clinic/tp/qgap1tp.htm.
7 Carter-Pokras O, Baquet C. What is a “health disparity”?. Public Health Rep. Sep-Oct. 2002;117(5):426-34. [pmid: 12500958].
8 Beach MC, Gary TL, Price EG, et al. Improving health care quality for racial/ethnic minorities: a systematic review of the best evidence regarding provider and organization interventions. BMC Public Health. Apr. 2006;6. [pmid: 16635262].
9 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions Verson 5.1.0. The Cochrane Collaboration. 2011. www.cochrane-handbook.org.
10 Relevo R, Balshem H. Finding evidence for comparing medical interventions, Methods Guide for Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality.
11 Wilczynski NL, Haynes RB. Optimal search filters for detecting quality improvement studies in Medline. Qual Saf Health Care. Dec. 2010;19(6):e31. [pmid: 20671080].
12 Adams K, Corrigan J, editors. Priority areas for national action:transforming health care quality. Washington, D.C. The National Academies Press. 2003.
13 Wells G, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. wwwohrica/programs/clinical_epidemiology/oxford.asp. August 2011.
14 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
15 Miranda J, Duan N, Sherbourne C, et al. Improving care for minorities: can quality improvement interventions improve care and outcomes for depressed minorities? Results of a randomized, controlled trial. Health Serv Res. Apr. 2003;38(2):613-30. [pmid: 12785564].
16 Sequist TD, Fitzmaurice GM, Marshall R, et al. Cultural competency training and performance reports to improve diabetes care for black patients: a cluster randomized, controlled trial. Ann Intern Med. Jan. 5. 2010;152(1):40-6. [pmid: 20048271].
17 Arean PA, Ayalon L, Hunkeler E, et al. Improving depression care for older, minority patients in primary care. Med Care. Apr. 2005;43(4):381-90. [pmid: 15778641].
18 Arean PA, Gum AM, Tang L, et al. Service use and outcomes among elderly persons with low incomes being treated for depression. Psychiatr Serv. Aug. 2007;58(8):1057-64. [pmid: 17664516].
19 Barr JK, Franks AL, Lee NC, et al. A randomized intervention to improve ongoing participation in mammography. Am J Manag Care. Sep. 2001;7(9):887-94. [pmid: 11570022].
20 Beach ML, Flood AB, Robinson CM, et al. Can language-concordant prevention care managers improve cancer screening rates?. Cancer Epidemiol Biomarkers Prev. Oct. 2007;16(10):2058-64. [pmid: 17932353].
21 Bosworth HB, Olsen MK, Grubber JM, et al. Racial differences in two self-management hypertension interventions. Am J Med. May. 2011;124(5):468 e1-8. [pmid: 21531237].
22 Connett JE, Stamler J. Responses of black and white males to the special intervention program of the Multiple Risk Factor Intervention Trial. Am Heart J. Sep. 1984;108(3 Pt 2):839-48. [pmid: 6475754].
23 Ferreira MR, Dolan NC, Fitzgibbon ML, et al. Health care provider-directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial. J Clin Oncol. Mar. 1. 2005;23(7):1548-54. [pmid: 15735130].
24 Bao Y, Alexopoulos GS, Casalino LP, et al. Collaborative depression care management and disparities in depression treatment and outcomes. Arch Gen Psychiatry. Jun. 2011;68(6):627-36. [pmid: 21646579].
25 Siddiqui AA, Sifri R, Hyslop T, et al. Race and response to colon cancer screening interventions. Prev Med. Mar-Apr. 2011;52(3-4):262-4. [pmid: 21256149].
26 Lasser KE, Murillo J, Lisboa S, et al. Colorectal cancer screening among ethnically diverse, low-income patients: a randomized controlled trial. Arch Intern Med. May. 23. 2011;171(10):906-12. [pmid: 21606094].
27 Miranda J, Cooper LA. Disparities in care for depression among primary care patients. J Gen Intern Med. Feb. 2004;19(2):120-6. [pmid: 15009791].
28 Wells KB, Sherbourne CD, Miranda J, et al. The cumulative effects of quality improvement for depression on outcome disparities over 9 years: results from a randomized, controlled group-level trial. Med Care. Nov. 2007;45(11):1052-9. [pmid: 18049345].
29 Wells K, Sherbourne C, Schoenbaum M, et al. Five-year impact of quality improvement for depression: results of a group-level randomized controlled trial. Arch Gen Psychiatry. Apr. 2004;61(4):378-86. [pmid: 15066896].
30 Sherbourne CD, Weiss R, Duan N, et al. Do the effects of quality improvement for depression care differ for men and women? Results of a group-level randomized controlled trial. Med Care. Dec. 2004;42(12):1186-93. [pmid: 15550798].
31 Mahotiere T, Ocepek-Welikson K, Daley MB, et al. A program to reduce the disparity in the rate of biennial lipid profiles between African-American and white Medicare beneficiaries with diabetes mellitus in New York City. J Community Health. Aug. 2006;31(4):263-88. [pmid: 16894826].
32 Coberley CR, Puckrein GA, Dobbs AC, et al. Effectiveness of disease management programs on improving diabetes care for individuals in health-disparate areas. Dis Manag. Jun. 2007;10(3):147-55. [pmid: 17590145].
33 Olomu AB, Grzybowski M, Ramanath VS, et al. Evidence of disparity in the application of quality improvement efforts for the treatment of acute myocardial infarction: the American College of Cardiology's Guidelines Applied in Practice Initiative in Michigan. Am Heart J. Mar. 2010;159(3):377-84. [pmid: 20211298].
34 Miranda J, Schoenbaum M, Sherbourne C, et al. Effects of primary care depression treatment on minority patients' clinical status and employment. Arch Gen Psychiatry. Aug. 2004;61(8):827-34. [pmid: 15289281].
35 Kjelsberg MO, Cutler JA, Dolecek TA. Brief description of the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. Jan. 1997;65(1 Suppl):191S-5S. [pmid: 8988937].
36 Montoye CK, Mehta RH, Baker PL, et al. A rapid-cycle collaborative model to promote guidelines for acute myocardial infarction. Jt Comm J Qual Saf. Sep. 2003;29(9):468-78. [pmid: 14513670].
37 Wells KB. The design of Partners in Care: evaluating the cost-effectiveness of improving care for depression in primary care. Soc Psychiatry Psychiatr Epidemiol. Jan. 1999;34(1):20-9. [pmid: 10073117].
38 Alexopoulos GS, Reynolds CF 3rd, Bruce ML, et al. Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. Aug. 2009;166(8):882-90. [pmid: 19528195].
39 Unutzer J, Katon W, Williams JW Jr., et al. Improving primary care for depression in late life: the design of a multicenter randomized trial. Med Care. Aug. 2001;39(8):785-99. [pmid: 11468498].
40 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. Dec. 11. 2002;288(22):2836-45. [pmid: 12472325].
41 QIO Efforts to reduce healthcare disparities 2002-2005: Final report of progress findings, and results of QIO projects. Underserved Quality Improvement Organization Support Center. www.ahqa.org/pub/uploads/QIOs_Reduce_Disparities_Final_Report_w_Cover.pdf. 09/2011.
42 Alexander GR, Wingate MS, Bader D, et al. The increasing racial disparity in infant mortality rates: composition and contributors to recent US trends. Am J Obstet Gynecol. Jan. 2008;198(1):51 e1-9. [pmid: 17870043].
43 Weinick RM, Hasnain-Wynia R. Quality improvement efforts under health reform: how to ensure that they help reduce disparities--not increase them. Health Aff (Millwood). Oct. 2011;30(10):1837-43. [pmid: 21976324].