# Methods

## Topic Refinement

Topics for the Closing the Quality Gap series were solicited from the portfolio leads at the Agency for Healthcare Research and Quality (AHRQ). The nominations included a brief background and context; the importance and/or rationale for the topic; the focus or population of interest; relevant outcomes; and references to recent or ongoing work.

Among the topics that were nominated, the following considerations were made in selection for inclusion in the series: the ability to focus and clarify the topic area appropriately; relevance to quality improvement (QI) and a systems approach; applicability to the Evidence-based Practice Center (EPC) program/amenable to systematic review; the potential for duplication and/or overlap with other known or ongoing work; relevance and potential impact in improving care; and fit of the topics as a whole in reflecting AHRQ portfolios.

Following assignment of the topic to the EPC, we identified technical experts on the topics of QI and disparities. The Technical Expert Panel (TEP) members contributed to AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products.

## Literature Search Strategy

### Databases

We searched the following databases: MEDLINE (PubMed interface), the Cumulative Index of Nursing and Allied Health Literature (CINAHL), Web of Science Social Science Index, and PsycINFO (CSA Illumina interface). The search strategies for each of these databases included terms related to QI, disparity, and pre-specified clinical conditions.10,11

Each search strategy used a combination of subject headings (i.e., controlled vocabulary) and keywords (see Appendix A). We carried out hand searches of the reference lists of recent systematic reviews related to QI studies and the reference lists of included papers.

## Study Selection

### Study Populations

Eligible studies included individuals receiving health care in the U.S. Studies had to include data on one or more of the following characteristics known to be associated with health disparities: race or ethnicity, socioeconomic status, insurance status, sex, sexual orientation, health literacy/numeracy, and language barrier.

### Sample Size

As an inclusion criterion, we set the study sample size at a minimum of 50 participants each for the comparison and intervention groups, including subgroups that were stratified for analysis of intervention effect on disparity. The typical study designs used for QI studies have an inherent risk of bias. The maximum improvement possible in a QI trial is 100 percent; if the baseline performance is high, then the margin for improvement is so small that a high number of participants would be required to rule out an observed effect due to chance. Because the conditions and outcomes were very diverse, it was not possible to forecast a single prevalence for the comparison group, nor a single minimum relative effect.

Setting a minimum sample size based on quantitative power calculations would have required studies in excess of 100 individuals per arm. We set the sample size liberally at 50 to allow for the possibility that we might be able to combine studies quantitatively in a meta-analysis.

### Geographic Limit and Publication Dates

Because health care systems, disparity indicators, and groups subject to disparities vary geographically, we limited eligible studies to those of patients in the U.S. health care system. Consistent with this inclusion criterion, only studies published in English were included. Searches were limited to papers published in 1983 or later because seminal work regarding QI strategies began to be published in the early 1980s.

### Study Design

We included randomized controlled trials (RCT), including cluster randomized controlled trials; controlled trials, including quasi-randomized studies; controlled before-after studies; prospective and retrospective cohort studies; interrupted time series with comparison groups; and stepped wedge designs.

### Study Groups

All studies were required to include a comparison group that did not receive the QI intervention or that received a different intervention. In addition, they were required to provide data that could be used to measure a disparity based on one of the population characteristics specified in the protocol before and after the intervention. These data could have included reference to an external reference group, but if they used an external referent group, the data needed to have been collected within four years of the enrollment of the target group and be from a source that was at the state or local level.

### Interventions

We considered both formal QI models and QI strategies for the review. As a starting point, we borrowed the taxonomy of QI strategies described in the antecedent Closing the Quality Gap series.6 To this taxonomy, we added a generic category (i.e., “other”) to ensure retrieval of studies describing a QI strategy not specifically captured by the taxonomy. We did not include papers describing topics or interventions covered by other reports in the Closing the Quality Gap series (e.g., studies targeting public reporting, payment bundling, and medication adherence).

### Conditions

We sought studies of interventions to reduce disparities in health and process outcomes associated with a targeted set of clinical conditions, namely:

- Asthma
- Cancer:
  ○ Colorectal cancer (including screening)
  ○ Breast cancer (including screening)
- Cardiovascular disease:
  ○ Congestive heart failure
  ○ Coronary artery disease (including ischemic heart disease, myocardial infarction, and acute coronary syndrome)
  ○ Hypertension
- Cystic fibrosis
- Depression (major depressive disorder only)
- Diabetes
- End stage renal disease
- Pneumonia (including pneumococcal vaccination)
- Pregnancy

The selection of these conditions was based on priority lists previously published by AHRQ and the Institute of Medicine (IOM)12 and through consultation with the TEP.

### Outcomes

We included studies that captured health outcome measures and/or process measures to answer Key Question (KQ) 1. For KQ 2, we sought studies that reported harms (e.g., negative unintended consequences, misallocation of effort, decreased patient satisfaction, etc.) of the QI intervention to individual participants or the health care system. Table 2 summarizes the inclusion and exclusion criteria.

Table 2 Inclusion and exclusion criteria

Category | Criteria
Population | Individuals receiving health care in the United States for a pre-specified clinical condition:; - Asthma; - Cancer:; ○ Colorectal cancer (including screening); ○ Breast cancer (including screening); - Cardiovascular disease:; ○ Congestive heart failure; ○ Coronary artery disease (including ischemic heart disease, myocardial infarction, and acute coronary syndrome); ○ Hypertension; - Cystic fibrosis; - Depression (major depressive disorder only); - Diabetes; - End stage renal disease; - Pneumonia (including pneumococcal vaccination); - Pregnancy; Studies had to include data on these characteristics of the study population known to be associated with health disparities: race or ethnicity, socioeconomic status, insurance status, sex, sexual orientation, health literacy/numeracy, and/or language barrier.
Intervention | QI strategy: (1) a formal, broad organizational model; or (2) a change process in health care systems, services, or supplier for the purpose of increasing the likelihood of optimal clinical quality of care.
Comparator | Usual care or use of an alternate strategy.
Outcome(s) | Outcome measures of interest included: health outcome measures (e.g., morbidity and mortality, indirect health outcomes such as blood pressure and HbA1c); process measures (e.g., proportion of patients treated according to clinical guidelines); changes in disparity; and harms (i.e., any negative impact of the intervention to the individual patients or the health care system).
Time period | 1983–present
Setting | Strategies conducted in or based out of a hospital, provider office, and/or health care clinic.
Other criteria | - Admissible designs included: randomized controlled trials, including cluster randomized controlled trials; controlled trials, including quasi-randomized trials; controlled before-after studies; prospective and retrospective cohort studies; interrupted time series studies with comparison groups; and stepped-wedge design studies.; - Original research studies with sufficient detail to enable use and adjustment of the data and results.; - Inclusion of a target group and an internal or external referent group to measure changes in disparities.; - A minimum sample size of 50 individuals per study and intervention group or subgroup.; - Extractable data on relevant outcomes from text or tables.; - English language publications only

## Screening of Studies

We conducted screening in two phases: abstract and full text screening. Two reviewers independently reviewed each abstract. All papers with inclusion–exclusion conflicts at the abstract review level or lacking adequate information to make a determination were promoted to full text review. Two reviewers independently reviewed the full text of papers included at the abstract phase. Disagreements between reviewers at the full-text screening level were resolved by a senior investigator.

## Data Extraction and Management

### Evidence Tables

Two reviewers independently extracted relevant data (e.g., setting, condition, patient population, QI strategy, outcomes, and disparity) from all included papers using a predefined evidence table shell. A senior investigator reviewed the evidence table for accuracy and completeness. The research team met regularly during the data extraction period and discussed global issues related to the process. The final evidence table is presented in Appendix I. When possible to identify, analyses resulting from the same study were grouped together.

## Statistical Tests

When provided in the study paper, we report p values for tests of significance and confidence coefficients with confidence intervals for reliability of estimates in the evidence tables and results section of the report. In rare cases, the report authors calculated the statistical significance of study results using a standard statistical test (Fisher's Exact Two-Tailed Test). These are indicated in footnotes.

## Quality Assessment of Studies

To interpret study results and grade the strength of evidence, we assessed the methodological quality of individual studies using two existing tools. Senior investigators assigned a study design to each of the included papers according to the description of the study methods. Two investigators independently assessed the quality of individual studies. A senior investigator resolved discrepancies between reviewers.

### Quality Assessment Tools

We assessed quality for each outcome of interest from included studies using design-specific criteria for RCTs and cohort studies. To assess internal validity of RCTs, we used the Cochrane Collaboration Risk of Bias tool,9 which evaluates domains including sequence generation, allocation concealment, blinding, outcome data reporting, and reporting bias (see Appendix D and Appendix E).

For nonrandomized and observational studies, we used the Newcastle-Ottawa scale13 to assess three broad perspectives: (1) the selection of the study groups; (2) the comparability of the groups; and (3) the ascertainment of either the exposure or outcome of interest for case-control or cohort studies, respectively (see Appendix F).

The Newcastle-Ottawa Quality Assessment Scale includes eight multiple choice questions from three broad domains: four items related to selection of cohorts, one item related to comparability of cohorts, and three items related to assessment of outcomes. 13

### Determining Quality Ratings

These risk of bias scoring and quality assessment tool ratings were based upon study design and conduct (i.e., internal study validity). We rated individual studies as good, fair, or poor and included data from good and fair quality studies in our analysis. We designated thresholds to rate individual studies as “good,” “fair,” or “poor” quality. Appendix G outlines requirements for each rating.

Several of the included papers reported data from a post hoc or secondary analysis of a previously completed RCT. Because the balance between groups achieved by randomization does not reliably extend to subgroups, the team modified the risk of bias/quality assessment on a case-by-case basis, considering the methods of the individual paper and parent study methods when appropriate.

## Data Synthesis

Meta-analysis was not appropriate in this review due to the substantial heterogeneity of study interventions, patient populations and outcomes; therefore, all analysis is narrative and based on evidence and summary tables. Studies are summarized by the disparity addressed in the research and in categories of clinical conditions. We use the race and ethnicity categorizations that were used by the authors of the included studies.

## Grading the Strength of Evidence for a Body of Evidence

The assessment of the literature is done by considering both the observed effectiveness of interventions and the confidence that we have in the stability of those effects in the face of future research. The degree of confidence that the observed effect of an intervention is unlikely to change is presented as strength of evidence, and it can be regarded as insufficient, low, moderate, or high. Thus, strength of evidence describes the adequacy of the current research, both in terms of quantity and quality, as well as the degree to which the entire body of current research provides a consistent and precise estimate of effect. Interventions that have demonstrated benefit in a small number of studies but have not yet been replicated using the most rigorous study designs will therefore have insufficient or low strength of evidence to describe the body of research. Future research may find that the intervention is either effective or ineffective. Interventions that demonstrate consistent results from well-designed studies that minimize risk of bias will be assessed as high or moderate depending upon the likelihood that future research will alter the current evidence.

Methods for applying strength of evidence assessments are established in the EPC's Methods Guide for Effectiveness and Comparative Effectiveness Reviews14 and are based on consideration of four domains: risk of bias (low, medium, high), consistency (inconsistency not present, inconsistency present, unknown or not applicable), directness (direct, indirect), and precision (precise, imprecise).We assessed strength of evidence separately for each major intervention-outcome pair. We assigned an overall evidence grade to each key outcome for each comparison of interest based on the ratings for the individual four domains. Once we had established the maximum strength of evidence possible based upon these four domains we assessed the number of studies and range of study designs for a given intervention-outcome pair, and downgraded the rating when the cumulative evidence was not sufficient to justify the higher rating. The possible grades were:

- High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates.
- Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate.
- Insufficient: Evidence is either unavailable or does not permit a conclusion.

## Peer Review and Public Commentary

Experts in the fields of QI and health disparities and individuals representing stakeholder and user communities were invited to provide external peer review. AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments and revised the report as appropriate. A disposition of comments report will be available 3 months after the Agency posts the final report on the AHRQ website.