# Introduction

## Background

Health care disparities are the differences or gaps in care experienced by one population compared with another.1 Disparities have been noted in health outcomes including clinical outcomes and mortality, process measures in the health care system, and disease prevalence. By definition, a disparity in health care quality or health outcomes is not due to differences in health care needs or preferences of the patient, but to other factors.2

Disparities occur between identified populations, described by attributes such as race, ethnicity, language, sex, insurance status, socioeconomic status, and health literacy.2 These attributes and the disparities that may be associated with them are not mutually exclusive, and populations with disproportionately poor health outcomes often share multiple indicators of disparity.

Examples of health disparities include substantially higher rates of death due to coronary heart disease among Black men and women than their White counterparts. Rates of preventable hospitalizations are inversely related to income. Hypertension is substantially more prevalent among Black than other populations, and tobacco use is higher among minorities, particularly Native Americans.3

Nonetheless, despite well documented disparities in health and health care in the United States, little is known about what interventions might serve to reduce differences.1 Given the potential for quality improvement (QI) efforts in the health care setting to improve outcomes in general, considering whether these interventions could be fruitful in reducing disparities as well is a logical next step.

### Quality Improvement

QI is a multidisciplinary, systems-focused, data-driven method of understanding and improving the efficiency, effectiveness, and reliability of health processes and outcomes of health care. The QI process is designed to raise the standards of the delivery of preventive, diagnostic, therapeutic, and rehabilitative measures to maintain, restore or improve health outcomes of individuals and populations. The ongoing process of QI requires all four of the following elements: performance goals, performance measures, QI practices, and feedback and reporting.4

QI describes a wide range of initiatives aimed at improving quality in health care organizations and includes programmed approaches that build on models and tools first used in industry as many as 60 years ago. One of the earliest approaches was Plan, Do, Study, Act (PDSA), and other examples include Total Quality Management (TQM), Continuous Quality Improvement (CQI), Business Process Reengineering (BPR), rapid cycle change, lean thinking, and Six Sigma.5 Another model is Focus, Analyze, Develop, Execute/Evaluate (FADE).

For this report, we defined a QI intervention as a change process in health care systems, services, or suppliers for the purpose of increasing the likelihood of optimal clinical quality of care, measured by positive health outcomes for individuals and populations. An intervention could also be described as a strategy aimed at reducing the quality gap (the difference between health care processes or outcomes observed in practice and those potentially obtainable based on current evidence-based knowledge) for a group of patients representative of those encountered in routine practice.6 As a starting point, we borrowed the taxonomy of QI strategies described in the antecedent Closing the Quality Gap series.6 Examples of QI strategies that we expected to find in the literature are found in Table 1.

Table 1 Quality improvement strategies examples

QI Strategy | Examples
Patient education | - Classes; - Parent and family education; - Patient pamphlets; - Intensive education strategies promoting self-management of chronic conditions
Provider education | - Workshops and conferences; - Educational outreach visits (e.g., academic detailing); - Distribution of educational materials
Promotion of self-management | - Materials and devices to promote self-management
Audit and feedback | - Feedback of performance to individual providers; - Quality indicators and reports; - National/state quality report cards; - Publicly released performance data; - Benchmarking – provision of outcomes data from top performers for comparison with provider's own data
Facilitated relay of clinical data to providers | - Transmission of clinical data from outpatient specialty clinic to primary care provider by means other than medical record, (e.g., phone call or fax)
Patient reminder systems | - Postcards or calls to patients
Provider reminder systems | - Reminders in charts for providers; - Computer-based reminders for providers; - Computer-based decision support
Organizational change | - Case Management, Disease Management; - Total Quality Management, Cycles of Quality Improvement; - Multidisciplinary teams; - Change from paper to computer-based records; - Increased staffing; - Skill mix changes
Other | - Guideline adherence; - Care manager; - Collaborative care model

### Disparity

A health disparity is the difference between health care processes or outcomes observed in practice for a specific population, compared with another population. By definition, a disparity in health care quality or health outcomes is not due to differences in health care needs or preferences of the patient, but to other factors.2 Differences in health outcomes and their determinants between segments of the population are associated with certain social conditions, and demographic attributes.3,7

Disparities may be associated with attributes such as socioeconomic status (low income), minority group (race, ethnicity, culture, language), sex (women), age (children and elderly), access (insurance status), geography (inner-city or rural), education (health literacy), or disability. Numerous environmental or contextual differences, (e.g., resource availability, transportation, air pollution) may also contribute to inequitable health care quality. As noted in the Centers for Disease Control and Prevention Health Disparities and Inequalities Report,3 the terms health disparity, health inequality, and health inequity are sometimes used interchangeably and each may provide an important indicator of community health.

Consistent with extensive research and findings in previous reports, the 2010 National Healthcare Disparity Report (NHDR) found that disparities related to race, ethnicity, and socioeconomic status are pervasive in the American health care system.1 Within the scope of health care delivery, these disparities may be due to differences in access to care, provider biases, poor provider-patient communication, poor health literacy, or other factors. Three key themes emerged from the report:

1. Disparities are common and uninsurance is an important contributor.
2. Many disparities are not decreasing over time.
3. Some disparities merit particular attention, especially disparities related to care for cancer, heart failure, and pneumonia.

The report also included a charge to examine disparities in “priority populations,” which are groups with unique health care needs or issues that require special attention.1 The identification of priority populations has remained consistent across Institute of Medicine and Agency for Healthcare Research and Quality (AHRQ) and the Evidence-based Practice Center (EPC) Program documents from 2003 through 2010.^6^

### Approaches To Reducing Disparities

Despite what is known about disparities, it is not clear what strategies have the potential to effectively improve the quality of care and to reduce inequities for segments of the population. QI interventions have been successful at improving health outcomes generally and in a number of settings; it is possible that they could be adapted or targeted to narrow a health or health care gap. If they were implemented in either a targeted way (i.e., in locations with especially high disparities) or broadly, they could potentially affect disparities at the population level.

A prior systematic review and analysis conducted by Beach and colleagues in 2006 summarized controlled studies of interventions targeted at health care providers to improve health care quality or reduce disparities in care for racial or ethnic minorities. Twenty-seven studies met criteria for review. Almost all (n = 26) took place in the primary care setting, and most (n = 19) focused on improving provision of preventive services.8

Nonetheless, the report concluded that there was little evidence to promote the use of QI interventions specifically to reduce disparities. The particular difficulty in assessing the impact of any health care intervention on disparities is that research must show effectiveness across multiple planes. Evidence of the effectiveness of the intervention needs to be demonstrated using a non-intervention comparison group, and at the same time, a disparity in outcome must be narrowed in the intervention group, but not in the comparison group. Thus, for a QI intervention to be effective for reduction of disparity both intervention effectiveness and disparity reduction effectiveness must be demonstrated; the intervention would be more effective for disadvantaged groups or individuals than for advantaged groups. A judgment of effectiveness in reducing disparities is therefore not possible when the intervention is targeted only at disadvantaged individuals or groups.9 While extraordinarily important, research that demonstrates a change in both effectiveness outcomes and disparity between at least two groups is thus complicated and rare.

## Scope and Key Questions

### Scope of This Report

The objective of this review was to assess the effectiveness of QI interventions in reducing disparities in health and health care.

### Key Questions

Key Question 1 (KQ 1). What evidence is available about the effectiveness of quality improvement strategies to reduce differences in health outcomes associated with selected disparities in patients with key conditions?

Key Question 2 (KQ 2). What evidence is available about the harms related to quality improvement strategies to reduce differences in health outcomes associated with selected disparities in patients with key conditions?

### Analytic Framework

We developed the analytic framework (Figure 1) based on clinical expertise and refined it with input from our TEP members. The analytic framework outlines the review of the available evidence on the effectiveness of QI strategies in the reduction of disparities in health outcomes and other measures of health care delivery for selected conditions and groups.

Figure 1 Analytic framework

Abbreviations: KQ = Key Question, QI = quality improvement

^1^ Disparities include: race or ethnicity, socioeconomic status, insurance status, sex, sexual orientation, health literacy/numeracy, and language barrier. ^2^ Selected conditions include: asthma, cardiovascular disease (including congestive heart failure, coronary heart disease, and hypertension); cancer (specifically colorectal cancer and breast cancer); cystic fibrosis; depression; diabetes; end stage renal disease; pneumonia (including pneumococcal vaccination); and pregnancy. ^3^ Taxonomy of quality improvement strategies: patient education; provider education; promotion of self-management; audit and feedback; facilitated relay of clinical data to providers; organizational change; patient reminder systems; and provider reminder systems. ^4^ Settings include those in which QI interventions were tested: hospitals, provider offices, and/or health care clinics. ^5^ Inclusion of a target and referent group is required to demonstrate a disparity.

Figure 1 is an analytic framework representing the project topic (i.e., established disparity in health care quality for select conditions); the intervention of interest (i.e., quality improvement [QI] strategy implemented in a health care setting); the outcome of interest (i.e., health care process or clinical outcome); and the associated observed change in disparity. A small box for key question 1: “What evidence is available about the effectiveness of QI strategies to reduce differences in health outcomes associated with selected disparities in patients with key conditions?” is situated between the intervention box and the outcome box. Harms of the intervention are represented within an oval with an attached box for key question 2: “What evidence is available about the harms related to QI strategies to reduce differences in health outcomes associated with selected disparities in patients with key conditions?” There are five footnotes within the figure. Footnote one states: Disparities include: race or ethnicity, socioeconomic status, insurance status, sex, sexual orientation, health literacy/numeracy, and language barrier. Footnote two states: Selected conditions include: asthma, cardiovascular disease (including congestive heart failure, coronary heart disease, and hypertension); cancer (specifically colorectal cancer and breast cancer); cystic fibrosis; depression; diabetes; end stage renal disease; pneumonia (including pneumococcal vaccination); and pregnancy. Footnote three states: Taxonomy of quality improvement strategies: patient education; provider education; promotion of self-management; audit and feedback; facilitated relay of clinical data to providers; organizational change; patient reminder systems; and provider reminder systems. Footnote four states: Settings include those in which QI interventions were tested: hospitals, provider offices, and/or health care clinics. Footnote five states: Inclusion of a target and referent group is required to demonstrate a disparity.

We explicitly defined eligibility criteria using a PICOTS (population, intervention, comparator, outcome, timing, and setting) structure (Table 2). Broadly, we sought studies that described a QI intervention and measured potential changes in the inequity of care between patient groups with pre-specified clinical conditions.

To measure potential changes in disparity between patient groups, studies had to include a target and referent population (e.g., for income disparity studies, they should include data for low and high income groups). We included studies that reported outcomes in terms of health care processes, individual health outcomes, and/or adverse outcomes or harms resulting from a QI intervention.

### Uses of This Report

This evidence report addresses the KQs using the methods described to conduct a systematic review of published literature. We anticipate that the report will primarily be of value to researchers interested in studying disparities and to funders developing RFAs for this type of research. It may also be of value to policymakers and health systems leaders as they consider the potential impact of QI interventions focused on addressing disparities in health care.