# Technical Expert Panel

Scott Cook, Ph.D.

Deputy Director, Finding Answers:

Disparities Research for Change

Center for Health and the Social Sciences

The University of Chicago

Chicago, IL

Romana Hasnain-Wynia, Ph.D.

Director, Center for Healthcare Equity

Northwestern University

Chicago, IL

Charles Homer, M.D., M.P.H., CEO

National Initiative for Children's Healthcare Quality (NICHQ)

Associate Professor, Department of Society, Human Development and Health

Harvard University School of Public Health

Cambridge, MA

Kathleen Lohr, Ph.D.

Distinguished Fellow

RTI International

Research Triangle Park, NC

Wesley Petersen, Ph.D., M.Ed.

Assistant Professor of Oncology

Professional Associate in Research

Behavioral Health Research, Department of Psychiatry and Psychology

Mayo Clinic College of Medicine

Rochester, MN

Selwyn Rogers, Jr., M.D., M.P.H.

Division Chief, Trauma, Burns and Surgical Critical Care

Brigham and Women's Hospital

Boston, MA