# Discussion

## Review of Main Findings

Disparities in health care access, utilization and outcomes are a known challenge to improving quality of care across the United States. Disparities have been measured in a wide range of clinical conditions including: cancer, diabetes, end stage renal disease, cardiovascular disease, HIV and AIDS, maternal and child health, mental health and substance abuse, and respiratory diseases.1 Given the potential for quality improvement (QI) strategies to improve health care in clinical settings, interest has developed in whether they might be used to reduce disparities, potentially by being particularly effective at improving outcomes in individuals and groups affected by disparities. A review of effectiveness of QI interventions to reduce disparities has the potential to provide a basis for policy and health care program decision making when choices about how to best serve a disadvantaged population are made.

QI activities that are implemented across a large population provide a degree of efficiency and sustainability. However, even in the face of positive outcomes, disparities remain, as improvements in care affect all segments of the population—the “rising tide raises all boats.”41 Conversely, it is theoretically possible that QI interventions could worsen quality of care for a disadvantaged population relative to an advantaged one.

Although substantial research has examined ways to improve the health of specific populations known to have disproportionate rates of poor outcomes, little research has focused on measuring a decrease in disparity between two groups. Rather, disparities research generally measures an increase in appropriate care in a disadvantaged group under the assumption that an improvement in outcomes in that group should bring their outcomes closer in line to those of the group to whom they are implicitly compared. This is not always the case. For example, although survival has improved for premature infants overall in the United States, including among racial minorities, the gap between survival for White and Black babies has continued to increase.42 Thus, research may focus on changing outcomes in one group, but if improvements are seen in all groups, disparities will remain. The purpose of this review was specifically to identify the potential for QI interventions to close the gap between measured outcomes in two groups of individuals to identify interventions that might be specifically targeted to situations where there is a disparity.

Methodologic challenges in this literature, including heterogeneity in the study populations, target clinical conditions, and interventions have made synthesis and interpretation challenging. No two studies used the same QI intervention to study disparity in the same health outcome. The standard approach to assessing the strength of an overall body of literature involves assessing a number of factors, including the risk of bias in individual studies, consistency of the overall literature, and precision of available estimates. The resulting strength of evidence score reflects the degree to which we expect the observed effects to be stable and not altered with future research. For this particular review, the measure of effect was a change in a disparity between two groups in a health outcome, rather than a change in the health outcome itself. The strength of the evidence would nonetheless be assessed for each health outcome and each intervention. Thus, as the results could not be combined quantitatively, and no two studies evaluated the same intervention and outcomes, it is not possible to consider the strength of the evidence (confidence in a given effect) to be other than insufficient at this time.

Nonetheless, 19 papers qualified for our review, reflecting results from 14 studies, and these studies do provide information on the potential role of some QI interventions in reducing disparities in health and health care, pending additional research. Studies were conducted to improve care in cancer screening, cardiovascular disease, depression, and diabetes care, using a number of different QI models (Table 10). Most interventions included some elements of patient education (12/14) and promotion of self-management (10/14). Most (11/12) involved at least two QI components. One included language concordance as an additional component.20

Table 10 Included studies' quality improvement strategies

Author, Year Clinical Condition(s) | Patient Education | Provider Education | Promotion of Self-Management | Audit and Feedback | Facilitated Relay of Clinical Data to Providers | Patient Reminder System | Provider Reminder System | Organizational Change | Other
Arean et al., 2007;^18^ Arean et al., 2005^17^ Depression | • | • | • | | • | | | | •^a^
Bao et al., 2011^24^ Depression | • | • | • | | | | • | | •^a^
Barr et al., 2001^19^ Cancer: breast cancer screening | | | | | | •
Beach et al., 2007^20^ Cancer: CRC and breast cancer screening | • | | • | | | •
Bosworth et al., 2011^21^ Cardiovascular disease: hypertension | • | | •
Coberley et al., 2007^32^ Diabetes | • | | • | | | | | •^b^
Connett and Stamler, 1984^22^ Cardiovascular disease: coronary artery disease and hypertension | • | | •
Ferreira et al., 2005^23^ Cancer: CRC screening | • | • | | •
Lasser et al., 2011^26^ Cancer: CRC screening | • | | • | | | •
Mahotiere et al., 2006^31^ Diabetes | • | • | • | • | | | | | •^c^
Olomu et al., 2010^33^ Cardiovascular disease: coronary artery disease | • | • | • | | | | | | •^d^
Miranda et al., 2003;^15^ Miranda et al., 2004;^34^ Wells et al., 2007;^28^ Wells et al., 2004;^29^ Sherbourne et al., 2004^30^ Depression | • | • | • | • | • | | | | •^a^
Sequist et al., 2010^16^ Diabetes | | • | | •
Siddiqui et al., 2011^25^ Cancer: CRC screening | • | • | | | | •
Counts | 12 | 8 | 10 | 4 | 2 | 4 | 1 | 1 | 5

Notes:

a Collaborative care;

b Disease Management;

c Community intervention;

d Guideline adherence

Abbreviation: CRC = colorectal cancer.

Although the strength of the evidence (our confidence that future studies will not change observe estimates of effect) is uniformly insufficient at this point in time, this is partly due to the substantial heterogeneity in research clinical targets, disparity targets and interventions. Additional research is needed to confirm currently observed effects in individual studies, and provide new information on approaches in the health system to reducing disparities in health and health care. Therefore, we present the evidence in two ways, by clinical target and by disparity target, to describe areas where there may be promising suggestions for additional research.

## Effects on Disparities

Included studies addressed disparities by race or ethnicity (Table 11), insurance (Table 12), language (Table 13), health literacy (Table 14), socioeconomic status (Table 15), and sex (Table 16).

Table 11 Summary of effects on disparities in health outcomes associated with race or ethnicity

Author, Year Study Design Clinical Condition(s) | QI Intervention Characteristic(s) | Effect on Health Disparity
Arean et al., 2005^17^ RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Other (collaborative care model); - Facilitated relay of clinical data to provider | - No disparity in depression severity existed by race or income at baseline.; - The intervention was effective in all racial subgroups with no interaction by race and no amplified effect in any group.; - In subgroup analysis, the intervention was associated with greater use of psychotherapy but not pharmacotherapy within the Black population
Bao et al., 2011^24^ RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Other (collaborative care model); - Provider reminder system | - At baseline within the usual care group, 22% of minorities had adequate antidepressant use, compared to 39% of White patients.; - The intervention had no effect on this disparity and ethnic minorities did not receive greater benefit from intervention compared with White patients during any time period.
Bosworth et al., 2011^21^ RCT Cardiovascular disease: hypertension | - Patient education; - Promotion of self-management | - The race by time by treatment group effect model suggested differential intervention effects on BP over time for White participants vs. nonwhite participants for both SBP (p=0.08) and DBP (p=0.01).; - The combination of home BP monitoring and tailored behavioral intervention was most effective in nonwhite participants at 24 months (p=0.04).
Coberley et al., 2007^32^ Retrospective cohort Diabetes | - Patient education; - Promotion of self-management; - Organizational change (disease management) | - Initial racial disparity in HbA1c testing between the health disparity zone (HDZ) group and non-HDZ group was 12%.; - Disparity was not significantly reduced after 12 months (p=0.06).; - Within the HDZ zone (high prevalence of diabetes), testing increased by15% among Black participants but not among White participants, resulting in a reduction in disparity in this subgroup analysis.
Connett and Stamler, 1984^22^ RCT Cardiovascular disease: coronary artery disease and hypertension | - Patient education; - Promotion of self-management | - At baseline, Black participants had higher rates of smoking than White participants (68.7% vs. 63%; p<.001).; - Both racial groups experienced significant reductions in smoking of close to 50% in the intervention group and more than 35% in the usual care group.; - The baseline disparity persisted in the intervention group but was apparently reduced in the usual care group.; - A statistically significant but clinically insignificant disparity in DBP and SBP by race was present at baseline.; - Blood pressures were reduced in both the intervention and control groups, with greater change observed in the intervention group.; - The small disparity observed at baseline was further reduced at followup in the intervention group but not the control group.
Lasser et al., 2011^26^ RCT Cancer: CRC screening | - Patient education; - Promotion of self-management; - Patient reminder system | - No disparity in CRC screening rates at baseline by race or ethnicity.; - The intervention was more effective in White and Black individuals relative to those of other or unknown race.
Mahotiere et al., 2006^31^ Prospective cohort Diabetes | - Patient education; - Provider education; - Promotion of self-management; - Audit and feedback; - Other (community intervention) | - The disparity in biennial lipid profile testing at baseline was 19%.; - The biennial lipid profile testing rate improved by 26.2 percent in African-American beneficiaries with diabetes in the intervention areas following implementation of the QI program.; - The disparity in performance of biennial lipid profile between African-American Medicare fee-for-service beneficiaries and White Medicare fee-for-service beneficiaries reduced to 9.2% following implementation of the QI program.; - An analysis of the direct impact of the selected interventions on reducing the disparity in this uncontrolled database analysis was not feasible.
Miranda et al., 2003^15^; Miranda et al., 2004^34^; Wells et al., 2007^28^; Wells et al., 2004^29^ Cluster RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Audit and feedback; - Other (collaborative care model); - Facilitated relay of clinical data to provider | - The intervention was associated with decreases in probable depressive disorder among minorities but not White patients at 12 months. (Latino p=0.02; African-American p=0.01).; - At 12 months among intervention recipients, the baseline disparity increased (6.7% to 7.7%) between Latino and White patients, and decreased between African-American and White patients (9.2% to 6.7%).; - Although a statistically significant interaction was seen between intervention and ethnicity at 6 months when minorities were grouped and contrasted with White patients, no such interaction persisted at 12 months.; - The overall effect of the intervention on depression status was not significant at five and nine years, but an interaction with race was seen in the overall model of effectiveness. The intervention was associated with improvements in the Mental Health Inventory among minorities (p=0.008) but not among White patients (p=0.59).; - In subanalysis at five years, QI–Therapy but not QI–Meds was effective within the minority population.
Olomu et al., 2010^33^ Retrospective cohort (historic controls) Cardiovascular disease: coronary artery disease | - Patient education; - Provider education; - Promotion of self-management; - Other (guideline adherence) | - The American College of Cardiology's Acute Myocardial Infarction (AMI) Guidelines Applied in Practice (GAP) strategy was associated with increased inpatient use of beta-blockers among nonwhite patients.; - Racial disparities in use of cardiac catheterization and percutaneous coronary intervention appeared after implementation of the GAP QI strategy despite overall improvements in care.; - The admission tool and inpatient aspirin were more often used post-GAP vs. pre-GAP in both White and nonwhite patients.
Sequist et al., 2010^16^ Cluster RCT Diabetes | - Provider education; - Audit and feedback | - Disparities were present at baseline in HbA1c levels, BP control, and LDL level.; - The intervention showed no effect overall in either racial group.; - The intervention did not reduce the disparity.
Siddiqui et al., 2011 25 RCT Cancer: CRC screening | - Patient education; - Promotion of self-management; - Patient reminder system | - No disparity in CRC screening rates at baseline by race or ethnicity.; - No statistically significant difference in screening rates between Whites and African-Americans in the control group.; - When intervention groups were combined, the screening rate was significantly higher in Whites compared to African-Americans.

Abbreviations: BP = blood pressure; CRC = colorectal cancer; DBP = diastolic blood pressure; GAP = American College of Cardiology's AMI Guidelines Applied in Practice; HbA1c = hemoglobin A1c; HDZ = health disparity zone; LDL = low density lipoprotein; QI = quality improvement; RCT = randomized controlled trial; SBP = systolic blood pressure.

Table 12 Summary of effects on disparities in health outcomes associated with insurance status

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Barr et al., 2001^19^ RCT Cancer: breast cancer screening | - Patient reminder system | - No disparity was observed at baseline.; - The intervention was successful in both groups.; - Reminder interventions improved likelihood of screening mammography in both commercially insured women (p=0.001) and women covered by Medicare (p=0.01) with no difference in improvement between groups.
Lasser et al., 2011^26^ RCT Cancer: CRC screening | - Patient education; - Promotion of self-management; - Patient reminder system | - No disparity in CRC screening rates at baseline by race or ethnicity.; - The intervention increased screening rates in both the private and public insurance groups compared to individuals in the usual care group.; - The intervention was associated with a better screening rate for the privately insured group compared to publicly insured group.

Abbreviations: CRC = colorectal cancer; QI = quality improvement; RCT = randomized controlled trial.

Table 13 Summary of effects on disparities in health outcomes associated with language barrier

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Beach et al., 2007^20^ RCT Cancer: CRC and breast cancer screening | - Patient education; - Promotion of self-management; - Patient reminder system | - At baseline, Spanish speakers were more likely to be up to date on breast cancer screening.; - The intervention was effective at increasing rates of breast cancer screening overall, with greater effect among Spanish speakers.; - Nonetheless, the difference between observed effects for breast cancer screening in the two language groups was not significant.; - No disparity in CRC screening rate was measured at baseline.; - The intervention was associated with increases in CRC screening in both groups, with neither group associated with a greater effect of the intervention.; - Therefore, although there was no evidence that the intervention might reduce known disparities, the intervention was effective at increasing CRC screening for both groups.
Lasser et al., 2011^26^ RCT Cancer: CRC screening | - Patient education; - Promotion of self-management; - Patient reminder system | - No disparity was measured at baseline; - English speaking participants had a similar incidence of CRC screening during 1 year of followup in the intervention group as compared with usual care.; - Intervention was particularly beneficial for non-English language participants

Abbreviations: CRC = colorectal cancer; QI = quality improvement; RCT = randomized controlled trial.

Table 14 Summary of effects on disparities in health outcomes associated with health literacy

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Ferreira et al., 2005^23^ RCT Cancer: CRC screening | - Patient education; - Provider education; - Audit and feedback | - Patients with limited health literacy were significantly more likely to be screened for CRC when treated at the VA clinic implementing the QI strategy as compared with patients treated at the usual care clinic (55.7% vs. 30.0%, p=0.002).; - Patients with adequate health literacy were equally likely to pursue CRC screening when treated at the VA clinic implementing the QI strategy as compared with the patients treated at the usual care clinic (39.0% vs. 36.0%, p=0.65).; - Although the effect of the intervention on disparity was not measured directly, the intervention improved the incidence of up-to-date CRC screening among those with limited health literacy only and not among those with higher health literacy, suggesting that it might be a useful tool for reducing literacy related disparity.

Abbreviations: CRC = colorectal cancer; QI = quality improvement; RCT = randomized controlled trial; VA = Veterans Affairs.

Table 15 Summary of effects on disparities in health outcomes associated with socioeconomic status

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Disparity Target
Arean et al., 2007^18^ RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Facilitated relay of clinical data to provider; - Other (collaborative care model) | - Both low income and high/middle income populations experienced a very small benefit from the collaborative care intervention [fewer depression symptoms (high/middle income adjusted OR -0.41, 95% CI -0.49 to -0.33; low income adjusted OR -0.39, 95% CI, -0.5 to -0.27; comparator: usual care)], but no disparities in depressive symptoms had existed at baseline.
Bao et al., 2011^24^ RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Provider reminder system; - Other (collaborative care model) | - No disparity in depressive symptoms was present at baseline.; - At 24 months, participants with no college education had a greater reduction in depression than participants with college.

Abbreviations: OR = odds ratio; QI = quality improvement; RCT = randomized controlled trial.

Table 16 Summary of effects on disparities in health outcomes associated with sex

Author, Year Study Design Clinical Condition | QI Intervention Characteristic(s) | Effect on Health Disparity
Sherbourne et al., 2004^30^ Cluster RCT Depression | - Patient education; - Provider education; - Promotion of self-management; - Audit and feedback; - Facilitated relay of clinical data to provider; - Other (collaborative care model) | - Women had higher rates of appropriate depression care compared with men at 2 years (p= 0.0001).; - QI–Meds and QI–Therapy decreased “probable unmet need” disparity gap between men and women (from 10% to 1% (QI–Meds) and to 3% (QI–Therapy) at 24 months).

Abbreviations: QI = quality improvement; RCT = randomized controlled trial.

Table 11 summarizes results of studies addressing disparities in health outcomes associated with race or ethnicity. One disease management and patient education program32 was associated with a reduction in disparity between Black and White patients in HbA1c testing when it was targeted in a health disparity zone (HDZ) with a high prevalence of diabetes. Other interventions did not demonstrate a significant reduction in disparity, but an amplified effect was seen in nonwhite (presumably disadvantaged) population, including an additional patient education program for reduction in blood pressures,21 and a complex collaborative care model aimed at providers of patients with depression.15,28,29,34 In the latter study, the intervention was more effective in the short term among minorities, although the interaction was no longer significant after 1 year, and the intervention was not effective overall at five and nine years.

Two studies (Table 12) examined a difference in outcomes associated with insurance status.19,26 In both studies, the intervention was equally successful at increasing cancer screening in publicly and privately insured participants. In the first,19 a patient reminder system for breast cancer screening improved mammography rates in all women. In the second study,26 language-concordant assistance by a patient navigator who promoted self-management strategies, patient education, and reminders was associated with significantly increased colorectal cancer screening rates among both privately insured and publicly insured participants compared to usual care, but seemed to be most effective in the privately insured group.

Two studies examined the effects of QI strategies on disparities associated with language (Table 13). Both of them studied language concordance, in which strategies are provided in the native or preferred language of the participant (e.g., in Spanish for native Spanish speakers). One study examined the degree to which a language concordant intervention increased cancer screening (breast and colorectal) among English and Spanish speaking patients. For breast cancer screening, Spanish speakers were more likely to be up to date at baseline than English speakers (OR 1.46; 95% CI: 1.16 – 1.84). The intervention was associated with increased rates of screening overall, with greater effect in the Spanish speaking group (OR 1.85; 95% CI: 1.38, 2.47) than the English speaking group (OR 1.18; 95% CI: 0.82, 1.71). However, the overall multivariate analysis failed to confirm these results and providing the intervention in Spanish to Spanish speakers did not make it any more effective in this group. For colorectal screening, there was no difference in up to date status at baseline, the intervention was again effective overall, and there was no language-by-intervention effect.

A second study included language-concordant assistance by a patient navigator promoting self-management strategies, and providing patient education and reminders to facilitate adherence to colorectal cancer screening for individuals speaking English as their primary language and individuals speaking a language other than English. The patient navigator intervention was associated with increased CRC screening among individuals speaking languages other than English as their primary language (28.9 percent vs. 18.9 percent, p=0.04), but not among patients for whom English was their primary language (26.8 percent vs. 21.4 percent, p=0.35)26 These studies combined may suggest that targeted language concordant interventions could warrant further examination, with results suggesting a significantly different effect for non-English speakers and English speakers in one study, and a clinically, but not statistically different effect in the other.

In one health literacy study focusing on improving provider-patient communication in the VA system, colorectal cancer screening was increased among individuals with limited health literacy (55.7 percent vs. 30 percent; p=.002) but not among individuals with adequate health literacy (39 percent vs. 36 percent; p=.65) in the 20 percent subsample that underwent literacy assessment. The intervention itself included a workshop and feedback sessions for providers and educational materials for patients that included a video (Table 14).

In the two studies that assessed differences in effect by socioeconomic status, no effect was seen by income, but individuals with less education experienced greater benefits of collaborative care for depression than did those with higher education (Table 15).

One analysis examined the degree to which a collaborative care model for depression could reduce known disparities in accessing care and in outcomes by sex (Table 16). Women had higher rates of appropriate depression care compared with men at 2 years (p= 0.0001). A medication focused intervention and a therapy focused intervention decreased a disparity gap between men and women in probable unmet need from 10 percent to 1 percent (QI–Meds) and 3 percent (QI–Therapy) at 24 months.

In sum, there are individual studies that suggest benefits in particular subgroups known to suffer from disparities in health and health care. By far, the largest proportion of the literature focused on the ability of QI interventions to reduce racial disparities, with some suggestions that targeted programs could have some greater effects among racial minorities in both diabetes32 and hypertension.21 However, consistent findings from a rich body of literature are lacking to guide QI efforts specifically to reduce disparities.

Based on the limited evidence qualified for inclusion in this report, several strategies are worthy of future study, and possibly wider implementation. These strategies include the collaborative care model15,17,18,28,29,34 and the role of targeted patient education,21,26,32 which is accommodating of recipients' language and literacy levels. The collaborative care model emphasizes the coordination of care by multiple clinical providers, usually by a care manager, and interventions that reflect literacy and language needs of participants have included both the preparation of materials in multiple languages, and materials that reflect the complexity of medical or health care information and the need to make it accessible to a range of patients. A common thread is the emphasis on adapting interventions to the needs of disadvantaged populations and to individuals within them. Sufficient data are not available to support universal implementation of these strategies, but the strategies may be suitable for implementation if an appropriate plan is in place to monitor their effectiveness.

## Applicability

Given the insufficient strength of evidence health systems or clinicians wishing to replicate any of these interventions should carefully assess whether the interventions apply or must be modified to suit their particular patient population, clinical setting, and available resources. Discussions of implementation are likely to be in the context of specific clinical conditions, given the degree to which the health system is structured in this way. Therefore, we summarize the available literature and its likely applicability by clinical focus below.

### Cancer

#### Summary

Five RCTs with subgroup analyses explored the effects of various QI strategies on health care disparities in cancer screening, including one examining breast cancer screening,19 three studies assessing screening for colorectal cancer,23,25,26 and one assessing both breast and colorectal cancer screening.20. Disparities that served as the focus of these analyses included insurance status,19 health literacy,23 and language.20 The QI strategies included provision of mail or telephone reminders to patients,19 education and feedback for clinicians,23 and language–concordant telephone support calls from prevention care managers to patients.20 All three RCTs took place in study settings including one large group–model health maintenance organization (HMO),19 two Department of Veterans Affairs (VA) clinics,23 and 11 community health centers.20 All studies employed an internal, “usual care” comparison group. A language-concordant intervention,20 as compared with usual care, was more effective in increasing breast cancer screening among Spanish-speaking women than in English-speaking women, but the observed difference between the two groups (English and Spanish speaking) was not significant. The language-concordant intervention did not have a similar effect on colorectal cancer (CRC) screening.20 A health-literacy targeted strategy, as compared with usual care, facilitated CRC screening among those with limited health literacy more effectively than among those with high health literacy.23 A reminder intervention for breast cancer screening had no differential effect on mammography disparities by insurance status.19

#### Applicability

Studies included patients cared for at community clinics in New York City, men treated at two VA clinics in Chicago, and women enrolled in a large group model HMO in the northeastern United States. These settings were appropriate for cancer screening interventions, as the bulk of cancer screening recommendations focus on the clinic setting. However, it is uncertain how well the results of these studies generalize to other populations or settings.

The tested interventions varied substantially, ranging from patient reminders to provider education with audit and feedback. These interventions could be replicated, though they generally required significant organizational resources to develop and implement and may not be feasible in other settings. Barriers to care may also differ in other settings, and the interventions likely would need to be adapted to the needs of the target population. In each study, usual care served as the comparator, and this too, may differ in other practice settings. Thus, the marginal benefit of each intervention likely would be different in different settings.

Study outcomes consisted only of short-term process measures—receipt of cancer screening during followup. No long-term outcomes or clinical outcomes, such as diagnosis of malignancies, were reported. Thus the long-term clinical impact of such interventions is unclear.

### Cardiovascular Disease

#### Summary

One post hoc analysis of an RCT22 and one retrospective cohort study33 explored the effects of various QI strategies on racial health care disparities in coronary artery disease. The RCT addressed reduction of risk factors for coronary artery disease,22 while the retrospective cohort examined management of acute myocardial infarction (AMI).33 QI strategies included patient education and facilitation of self–management22 and a multifactorial provider– and systems–focused strategy.33 Both studies were collaborations of academic and community health centers.22,33 The studies each employed an internal “usual care” comparison group.

One study of cardiovascular risk factor modification showed no meaningful reduction in health disparities seen in smoking rates, although both Black and White participants had substantially lower rates of smoking after intervention.22 The other study of AMI treatment reduced disparities in one aspect of treatment, which exacerbated disparities in other areas.33 The strength of evidence was insufficient.

Two post hoc analyses of RCTs explored the effects of various QI strategies on racial health care disparities in hypertension.21,22 The RCTs addressed management of hypertension21 and reduction of risk factors for coronary artery disease (CAD) including hypertension.22 QI strategies were patient education21 and facilitation of self–management.21,22 The studies took place in university clinics21 and multicenter collaborations of academic and community health centers.22 The studies each employed an internal “usual care” comparison group.

One study had no significant intervention effect on a clinically insignificant disparity in blood pressure measures present at baseline after patient education and promotion of self management.22 In the second study, however, a home-based self-management strategy, including home blood pressure monitoring and tailored self-management strategies were more effective in the Black population than in the White population, although the study design precludes a clear causal effect by the intervention. 21

#### Applicability

Studies of CAD risk factor control included men with CAD risk factors at clinical centers in 18 U.S. cities, and patients with hypertension cared for at two university-affiliated clinics in North Carolina. A study involving treatment of acute myocardial infarction (AMI) included patients hospitalized at academic and community hospitals in Michigan. The study involving men only has limited applicability to women, as patterns of CAD risk factors differ by sex. Moreover, its enrollment occurred between 1973 and 1975, limiting applicability to present day practice. The results of the other two studies are applicable to patients in academic primary care practices, or academic or community hospitals, respectively.

The interventions for CAD risk factor control included intensive patient education and self-management, along with medication titration in one study. The intervention for AMI treatment involved provider education, practice feedback, and implementation of a toolkit. These all required significant institutional resources and the CAD risk factor interventions in particular may not be feasible in routine clinical practice. The AMI treatment initiative, though requiring institutional commitment, has already been disseminated extensively around the United States as a professional society initiative (American College of Cardiology Guidelines Applied in Practice), and thus, its replication is confirmed to be feasible. In each of these studies, usual care served as the comparator. As this varies across practice settings, the effect of the interventions may differ in other environments.

For studies of cardiovascular risk factor control, outcomes consisted of intermediate clinical variables (hypertension, cholesterol, smoking, weight). Outcome assessment in the AMI treatment study was extensive but focused on measures of process and proximal utilization (e.g., prescription of evidence-based medications, use of cardiac catheterization).

### Depression

#### Summary

The three studies that evaluated the effect of QI interventions on disparities in depression outcomes focused on racial disparities but included analyses on sex,30 income,18 and educational status.24 All three studies used a collaborative care model, which involved collaboration among multiple clinical providers to provide a coordinated set of interventions .The clinical model in all three studies included a dedicated mental health coordinator (nurse or case manager), creation of mental health teams (composed of primary provider, facility nurses, and psychiatrists), evidence-based pharmacotherapy and psychotherapy, extensive provider education, and longitudinal patient followup to evaluate clinical status and adherence. Each intervention was designed to address known barriers to the receipt of quality mental health care.

The collaborative care models were all associated with improvements in mental health outcomes, including depression scores, severity and functioning, but none specifically demonstrated a reduction in disparity caused by the intervention. In part, this was because few disparities were measurable at baseline, and what the studies did show is that there was no significant difference in the effect in groups defined by income, race or education. Nonetheless, there were some notable differences in effectiveness that might inform future research. For example, the Prevention of Suicide in Primary Care Elderly: Collaborative Trial (PROSPECT) intervention had a greater effect on clinical outcomes in the less educated group, 24 and the effect of the Partners in Care (PIC) intervention was amplified in minorities on some measures.28 Although no change in disparity was associated with the interventions, improvements did occur across the board, and no harms were reported in any of the studies. However, because we selected only those studies that could have demonstrated a change in disparity, this review does not include even a small proportion of the overall literature on collaborative care, so it is possible that these studies are anomalies in terms of overall effectiveness.

#### Applicability

Two of the three studies focused on elderly patients in primary care. One included a range of ages in adulthood. All included both men and women and were racially diverse. Nonetheless, these patient groups may represent a small proportion of the individuals who struggle with depression because of the limited range of health care settings represented in these studies. It is unclear whether the observed results apply to patient populations who receive their primary and mental health care outside of a managed care system, or to individuals who do not receive regular medical care. Additionally, given the settings in which the study took place, they also may not apply to vulnerable populations receiving care through public health systems.

The interventions were all intensive in terms of demand on resources and required strong communication between care providers. In the PIC study, enrolled practiced committed to an intervention cost-sharing arrangement, with the understanding that the long-term implementation would fall on the organization of practice itself. The degree to which this is likely to be feasible is unclear.

All studies compared the intervention to usual care, although usual care was not ever completely described and therefore would be expected to vary.

Generally speaking, outcomes were appropriate and reflected those that would and could be used in practice. They included changes in depressive symptoms, incidence of probably depressive disorder, mental health related quality of life, functional impairment, and receipt of appropriate depression care.

All studies were conducted in primary care practices associated with larger health care organizations. It is unclear whether results would therefore apply to other settings, including individual practices without the resources of a larger organization, or assisted living facilities (pertinent because of the focus on the elderly population).

### Diabetes

#### Summary

Three good quality studies could be used to assess the impact of QI interventions on disparities in diabetes outcomes. One was a randomized controlled trial (RCT),16 one was a prospective cohort,31 and one was a retrospective cohort study.32 None reported critically important clinical outcomes of diabetes, such as death, hypoglycemic coma, adverse drug event, cardiovascular complications, retinopathy progression, nephropathy progression, neurologic complications, or hospitalization for a complication of diabetes. Rather, they reported on surrogate clinical outcomes, clinical risk factors for diabetes comorbidities, and process measures. In two of three studies of diabetes, disparities were reduced in one or more outcomes over the course of the study in at least one subgroup, but the study designs were such that the reduction could not be be shown to be caused by the intervention. 31,32

In one study of a patient reminder system, racial disparities were reduced when HbA1c testing increased substantially among Black participants, relative to no change among White participants. In a broad, systems level program in New York State, a disparity of 19 percent in biennial lipid testing between African-American beneficiaries and White Medicare recipients was reduced to 9.2 percent after intervention of multifaceted QI program. However, the intervention was multifaceted and widespread, and the authors note that they cannot attribute the change to any specific components of the intervention.

#### Applicability

Studies included people cared for by primary care clinicians in ambulatory health centers in eastern Massachusetts, diabetes disease management program members living in socioeconomically disparate areas throughout the United States and Medicare patients in New York State. Therefore, the results may or may not be applicable to other populations in other regions.

Interventions evaluated included cultural competency training for clinicians and race-stratified performance reports with recommendations for Black diabetic patients, patient telephone reminders in Health Disparity Zones, defined as one with diabetes prevalence above the national average for minorities, and Medicare New York State Quality Improvement Organization (IPRO) multifaceted provider and community interventions. The interventions may not be available in other regions and settings, since they required significant programmatic and implementation resources. The usual care comparators described in these studies may not be applicable to other settings and regions.

Studies reported surrogate clinical outcomes (i.e., HbA1c control), clinical risk factors for diabetes comorbidities (i.e., blood pressure and lipid control), and process measures (i.e., HbA1c and low density lipoprotein measurements). Duration of studies was generally 1 year. No studies reported any critically important clinical outcomes of diabetes such as death or microvascular and/or macrovascular complications. Results from surrogate outcomes may not apply to important long-term clinical outcomes in people with diabetes.

Studies were conducted in ambulatory health centers in eastern Massachusetts, in diabetes disease management programs across the United States, and in New York State. As much of diabetes care is delivered in primary care ambulatory settings, the evidence would be applicable. However, specialty clinic settings were not reported and the evidence may not apply.

## Gaps in the Literature

A sufficient body of methodologically appropriate research to assess the effects of QI intervention on disparity outcomes currently is not available in the literature. Our assessment is consistent with at least one prior review from 2006,^8^ despite several additional years of QI research. Although researchers have focused on the role of QI for improving care in specific populations, there is a fundamental lack of research focused specifically on reducing gaps in the availability, accessibility, and quality of health care between any two populations.43 Authors of studies in this review have attempted to address the question by conducting post hoc analyses of RCTs intended to study the effectiveness of QI interventions; however, in doing so they have broken what randomization existed and have been unable to make the necessary comparison to tie observed improvements to the intervention conclusively.

Our review specifically sought studies that could measure a potential change in disparity. Other types of studies, such as those that only included only underserved individuals, might provide valuable information to policymakers and clinicians hoping to improve care in those populations, but would not have been included in this review.

## Limitations

One of the challenges to studying the degree to which QI interventions can be found to address disparities is the substantial breadth and heterogeneity of clinical conditions of interest, populations of people with the clinical conditions, QI intervention strategies, comparator, important clinical outcomes, surrogate outcomes, and disparities of interest. Compounding this heterogeneity is poor indexing of QI strategies in the medical literature databases. For example, the subject term “Quality Improvement” was only added to PubMed in 2011; before this time, myriad subject terms were employed to describe the various strategies employed in the QI literature, understandably leading to tremendous variability in how similar studies are categorized in the database. This is partially due to a lack of consistency or agreement on what constitutes a QI intervention – what is available in the literature is often not clearly identified as such and may be multifaceted and thus difficult to evaluate or compare to other intervention studies. Many QI interventions also include non-QI components, such as broader public health initiatives; thus, the potential impact of the QI intervention may be masked or difficult to isolate.

A further challenge to studying changes in disparities is the poor documentation of those disparities, and the fact that any two populations may represent multiple and overlapping disparities. In the studies that we were able to find that could have empirically assessed a disparity change, many were unable to demonstrate any existing disparity at baseline, which may be a reflection of the complexity of identifying and measuring disparities using single characteristics. Future studies will require much broader populations to include enough individuals from diverse background to capture and assess disparities over time empirically.

Finally, the degree to which publication bias may exist is unknown but potentially important for this literature. Many QI interventions are programmatic interventions in health care systems, not necessarily designed as research. Decisions about whether to publish the results of such interventions could, therefore, be based on the degree to which they were perceived to be successful and potentially useful to other industry colleagues and systems. It is possible that other interventions have been performed and remain unpublished.

## Future Research

Calls for the study of QI strategies to address disparities are not new.6 In order to advance this field, research must be specifically designed to assess the relevant contrasts in disparities and not rely on post hoc analyses of interventions designed to improve the health and health care of all participating individuals. In part, this is complicated by a lack of detailed evidence about the root causes of disparities.

To determine if a QI intervention is effective for reduction of a disparity, the research protocol needs to establish the baseline health outcomes for the health condition of interest for at least two groups, and this baseline data must include the report of disparity. The research protocol must be designed to produce a report of the same health outcome measures after the QI intervention for the same groups, and that post-intervention analysis must include data about the disparity. In this way, two levels of effectiveness are measured simultaneously—that for the intervention overall and that for the reduction of disparity.

For intervention effectiveness to be established there must be a statistically significant improvement in the health outcomes for an intervention group, compared with a control group. For reduction of disparity effectiveness to be established, there must be a statistically significant reduction of the disparity measured after the intervention, compared with the baseline disparity; complex sample size calculations must be performed to determine that the study will be adequately powered for both QI intervention effectiveness versus control, and for QI intervention effectiveness for reduction of disparity. A potentially effective intervention for reducing inequities may be one that is equally effective across the socioeconomic spectrum, but that may reduce health inequalities simply because the prevalence of health problems among the disadvantaged is greater. It may also be the case that an intervention is more effective in a disparity group because it addresses their particular needs, but also benefits the non-disparity group (e.g., a disease management program that pays attention to issues of health literacy may provide greater benefits to patients with low health literacy). Nonetheless, the vast majority of studies purported to address disparities study only one group—the disadvantaged group—thus eliminating the studies' own ability to actually measure an actual change in disparity.

Even with well-designed studies, the basis for believing that a QI intervention designed to improve health care overall would reduce a disparity is the assumption that it would have an amplified effect in a disadvantaged group, thus accelerating their health care improvement to the point that the gap decreases. This assumption has not been adequately studied in any health care condition or in relation to any disparity, and this foundational research is necessary to establish the basis for continuing research on QI interventions with the expectation that they will affect disparities.

Nonetheless, QI interventions that demonstrate improvements across all populations do not necessarily do so at the expense of disadvantaged groups; they simply do not demonstrate an ability to accelerate change in one group versus another to the point that a gap is closed. Therefore, it is unclear whether QI interventions are potentially fruitful or appropriate for the purpose of reducing health care outcome disparities, despite their known effectiveness at improving health and health care across disparity groups.

Nonetheless, research should be conducted on the collaborative care model and the role of targeted patient education, which is accommodating of recipients' language and literacy levels. As previously noted, sufficient data are not available to support universal implementation of these strategies, but the strategies may be suitable for implementation if an appropriate plan is in place to monitor their effectiveness. In particular, it will be important in studying these and other QI interventions to ensure capture on data reflecting organizational adherence to interventions, something notably missing from the current literature.

Furthermore, data on patient characteristics known to be associated with disparity should be collected regularly such that any observed changes in disparity can be measured. Future studies should provide data in such a way that both the overall effectiveness and a change in disparity can be assessed statistically.

## Conclusions

The literature on QI interventions generally and their ability to improve health and health care is large. Whether those interventions are effective at reducing disparities remains unclear. This report should not be construed to assess the general effectiveness of QI in the health care setting; rather, QI has not been shown specifically to reduce known disparities in health care or health outcomes. In a few instances, some increased effect is seen in disadvantaged populations; these studies should be replicated and the interventions studied further as having potential to address disparities. Specific examples that warrant additional study include increasing our understanding of the collaborative care model in improving depression outcomes, and the role of targeted patient education, including ensuring that interventions are provided in the primary language of the patients.