# Excluded Papers

Table L-1 Excluded papers: exclusion code, exclusion reason, and count

Exclusion code | Exclusion reason | Count
X-1 | Not original research (e.g. review articles, systematic reviews, editorials, commentaries, letters to editor, etc.) | 763
X-2 | Does not include an intervention | 2,880
X-3 | Does not include individuals receiving health care within the U.S. | 1, 123
X-4 | The number of participants enrolled is less than 50 per group | 2,758
X-5 | Does not address a pre-specified condition^*^ | 669
X-6 | Does not include individuals from a target population with selected characteristics known to be associated with health disparities^†^ | 1,937
X-7 | Does not address a quality improvement strategy or intervention (i.e. a systematic process designed to improve the quality of care) | 534
X-8 | Intervention does not originate from or occur within a health care setting (i.e. hospital, clinic, or provider office) | 59
X-9 | Does not include a qualifying referent group^‡^ | 863
X-10 | Does not addresses an outcome of interest (i.e. health outcome, process outcome, harm, or unanticipated adverse effect) | 92
X-11 | Does not include a control group for the intervention | 19
X-12 | Not a qualifying study design | 8
X-13 | Unable to obtain | 7

Notes:

* Included: asthma; colorectal cancer (including screening); breast cancer (including screening); cardiovascular disease (including congestive heart failure, coronary artery disease, and hypertension); cystic fibrosis; depression (major depressive disorder only); diabetes mellitus; end stage renal disease; pregnancy; pneumonia (including pneumococcal vaccination); and pregnancy.

† Included: race or ethnicity, socioeconomic status, insurance status, sex, sexual orientation, health literacy/numeracy, and language barrier.

‡ A qualifying referent group was from either an internal (i.e., within study referent group) or external (i.e., data from a referent group not included in the study) source and had to provide adequate data (i.e. baseline characteristics and post-intervention outcome data) to facilitate an actual measure of disparity. Data from external referent groups needed to have been collected within four years of the enrollment of the target group and be from a source that was at the state or local level.

1 A study of women's awareness and use of mammograms. J Ky Med Assoc. Sep. 1987;85(9):553-5. X-2, X-4. [pmid: 3668368].
2 Hypoglycemia and employment/licensure. Diabetes Care. May. 1990;13(5):535. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 2190777].
3 Testimony of the American Dietetic Association: non-insulin-dependent diabetes mellitus--an unrelenting but undeserved threat to the health of minorities. J Am Diet Assoc. Jun. 1992;92(6):671-2. X-1, X-2, X-3, X-4, X-6. [pmid: 1607556].
4 The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. Mar. 4. 1992;267(9):1213-20. X-6. [pmid: 1586398].
5 SSI (Supplemental Security Income) for premature infants. Continuum. Jul-Aug. 1995;15(4):17-8. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10145060].
6 Setting the standards for asthma care. Bus Health. Jul. 1995;13(7 Suppl D):27-31. X-1, X-2, X-3, X-4, X-6. [pmid: 10144994].
7 A survey of treatment routines and educational level of health care providers in the initial phase of suspected acute myocardial infarction in Sweden in 1994. Swedish Working Group on Early Heart Attack Care. Eur J Emerg Med. Sep. 1996;3(3):149-56. X-2, X-3, X-4, X-6. [pmid: 9023493].
8 Pediatric asthma DM programs help kids breathe easier. Healthc Demand Dis Manag. Jan. 1997;3(1):1-7. X-1, X-6, X-7, X-9. [pmid: 10174584].
9 Outcome data on Medicare patients with pneumonia. Connecticut Nursing News. 1997;70(9):10-1. X-2.
10 Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. The Trials of Hypertension Prevention Collaborative Research Group. Arch Intern Med. Mar. 24. 1997;157(6):657-67. X-6. [pmid: 9080920].
11 Tools help pinpoint cap rates, forecast changes in utilization. Capitation Manag Rep. Nov. 1998;5(11):174-6. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10338921].
12 Community health initiative uses casefinding, intervention to boost prevention and revenues. Healthc Demand Dis Manag. Oct. 1998;4(10):151-4. X-1, X-6, X-7, X-9. [pmid: 10338756].
13 Disease management program improves diabetes outcomes, curbs hospital costs, utilization. Health Care Cost Reengineering Rep. Mar. 1998;3(3):42-5. X-1, X-2, X-3, X-4, X-6. [pmid: 10178787].
14 Target individual needs to boost diabetic compliance. Hosp Case Manag. Feb. 1998;6(2):35-9. X-1, X-6, X-7, X-9. [pmid: 10177974].
15 Big changes for diabetes management. Is your MCO missing the boat?. Manag Care Strateg. Feb. 21. 1998;6(2):16-2. X-1, X-2, X-3, X-4, X-6. [pmid: 10177093].
16 Quality compass ‘99: slow, but steady improvements. Med Manag Netw. Sep. 1999;7(9):5-7. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10558153].
17 From the Centers for Disease Control and Prevention. Patients' reports of counseling on mammography screening by health-care providers--North Carolina, 1997. JAMA. Jul. 14. 1999;282(2):124-5. X-6, X-7, X-9. [pmid: 10411182].
18 Patients' reports of counseling on mammography screening by health-care providers--North Carolina, 1997. MMWR Morb Mortal Wkly Rep. May. 7. 1999;48(17):356-8. X-2, X-4. [pmid: 10363960].
19 Cutting RNs a false economy?. Hosp Peer Rev. Feb. 1999;24(2):29-30. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10345889].
20 Innovative breast cancer education programs for African-Americans. Oncology (Williston Park). Mar. 1999;13(3):298. 303. X-1, X-6, X-7, X-9. [pmid: 10204152].
21 Medicare program; expanded coverage for outpatient diabetes self-management training and diabetes outcome measurements. Health Care Financing Administration (HCFA), HHS. Final rule. Fed Regist. Dec. 29. 2000;65(251):83130-54. X-1, X-2, X-3, X-4, X-6. [pmid: 11503741].
22 The Diabetes Prevention Program: baseline characteristics of the randomized cohort. The Diabetes Prevention Program Research Group. Diabetes Care. Nov. 2000;23(11):1619-29. X-2, X-4. [pmid: 11092283].
23 Health plans bear down on quality, HEDIS scores improve dramatically. Manag Care. Oct. 2001;10(10):34-5. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11688109].
24 Report highlights gaps in care for older asthmatics. Dis Manag Advis. Sep. 2001;7(9):141-3. 29. X-1, X-2, X-3, X-4, X-6. [pmid: 11584649].
25 Managed care outlook. ‘Quality of care’ in eye of beholder. Manag Care. Jun. 2001;10(6):64. X-1, X-2, X-3, X-4, X-6. [pmid: 11474636].
26 Health plan incentives and quality improvement: do employers support them?. Manag Care Interface. Jun. 2001;(Suppl):3. 6. X-1, X-2, X-3, X-4, X-6. [pmid: 11428230].
27 Are we missing the grade on report cards?. Manag Care Interface. Jun. 2001;(Suppl):2. 4. X-1, X-2, X-3, X-4, X-6. [pmid: 11428229].
28 2002 HEDIS data mark big changes for high-performing physicians. Capitation Rates Data. Oct. 2002;7(10):116-8. X-1, X-2, X-3, X-4, X-6. [pmid: 12412317].
29 Diverse approaches to asthma DM succeed in Medicaid populations. Dis Manag Advis. May. 2002;8(5):71-7. 65. X-1, X-2, X-3, X-4, X-6. [pmid: 12048765].
30 Developing a CRI pre-screening program for African-Americans. Nephrol News Issues. Apr. 2002;16(5):28. X-1, X-7, X-9. [pmid: 11962148].
31 Use of intermittent or continuous interstitial fluid glucose monitoring in patients with diabetes mellitus. TEC Bull (Online). Nov. 6. 2003;20(3):38-42. X-13. [pmid: 15043083].
32 Lay educators shore up diabetes DM efforts in Hispanic communities. Dis Manag Advis. Aug. 2003;9(8):107-10. 5. X-1, X-6, X-7, X-9. [pmid: 14556558].
33 Health promoters make diabetes educators more efficient. Perform Improv Advis. Aug. 2003;7(8):114-6. 05. X-1, X-6, X-7, X-9. [pmid: 12971011].
34 A laser-like focus on diabetes pays off for multi-plan coalition in NM. Dis Manag Advis. Feb. 2003;9(2):21-5. 17. X-1, X-2, X-4. [pmid: 12658951].
35 Training patients to become experts. Nurs Times. Feb 23-Mar 3. 2003;99(8):44-5. X-1, X-2, X-4. [pmid: 12656025].
36 Intensive approach pays off in diabetics with low literacy skills. Dis Manag Advis. Dec. 2004;10(12):133-7. X-1, X-6, X-7, X-9. [pmid: 15673127].
37 Knowledge about preconception care in French women with type 1 diabetes. Diabetes Metab. Nov. 2005;31(5):443-7. X-2, X-3, X-4, X-6. [pmid: 16357787].
38 New depression programs are designed with the employer in mind. Dis Manag Advis. Jun. 2005;11(6):65-9. 1. X-1, X-2. [pmid: 16060295].
39 Initiative shines spotlight on real-world models for diabetes care in diverse populations. Dis Manag Advis. Dec. 2006;12(12):133-6. X-1, X-6, X-7, X-9. [pmid: 17225629].
40 Summaries for patients. Relationship of insurance type with the care of acute coronary syndromes. Ann Intern Med. Nov. 21. 2006;145(10):I47. X-1, X-6, X-7, X-9. [pmid: 17116915].
41 For the patient. Diabetes education and personal doctors team up for better care for persons with diabetes. Ethn Dis. Autumn. 2006;16(4):1015. X-1, X-2, X-3, X-4, X-6. [pmid: 17063585].
42 For the patient. Preparing diabetes education materials for targeted groups. Ethn Dis. Autumn. 2006;16(4):1011-2. X-1, X-2, X-3, X-4, X-6. [pmid: 17063582].
43 For the patient. Managing and treating diabetes. Ethn Dis. Winter. 2006;16(1):321-2. X-1, X-2, X-3, X-4, X-6. [pmid: 16602156].
44 Summaries for patients. Can providing support to dementia caregivers improve their quality of life?. Ann Intern Med. Nov. 21. 2006;145(10):I39. X-1, X-2, X-4, X-5. [pmid: 17116914].
45 Discharge planning advisor. Project targets diabetes in Latino community. Hosp Peer Rev. Oct. 2007;32(10):139-41. X-1, X-6, X-7, X-9. [pmid: 17957883].
46 Project targets diabetes in Latino community. Hosp Case Manag. Oct. 2007;15(10):155-7. X-1, X-6, X-7, X-9. [pmid: 17955894].
47 Program aims to leverage the skills of community pharmacists to boost diabetes care. Dis Manag Advis. Jun. 2007;13(6):71-2. 61. X-1, X-2, X-4, X-6. [pmid: 17595921].
48 For the patient. Breast-conserving surgery and radiation therapy: do the two go hand-in-hand as recommended?. Ethn Dis. Winter. 2007;17(1):173-4. X-1, X-6, X-7, X-9. [pmid: 17278287].
49 AADE position statement. Cultural sensitivity and diabetes education: recommendations for diabetes educators. Diabetes Educ. Jan-Feb. 2007;33(1):41-4. X-1, X-2, X-4. [pmid: 17272791].
50 Hypoglycemia and employment/licensure. Diabetes Care. Jan. Suppl 1. 2007;30:S85. X-14. [pmid: 17192383].
51 Practice notes: strategies in health education. Program: Talk It Up Texas! A depression awareness program for Mexican American adolescents. Health Education & Behavior. 2007;34(3):417-8. X-1, X-2, X-4.
52 Self-monitoring of blood glucose in type 2 diabetes: an inter-country comparison. Diabetes Res Clin Pract. Dec. 2008;82(3):e15-8. X-2. [pmid: 18995920].
53 Summaries for patients. Association of numeracy and diabetes control. Ann Intern Med. May. 20. 2008;148(10):I53. X-1, X-2, X-3, X-4, X-6. [pmid: 18490670].
54 Medicare and Medicaid programs; conditions for coverage for end-stage renal disease facilities. Final rule. Fed Regist. Apr. 15. 2008;73(73):20369-484. X-1, X-2, X-3, X-4, X-6. [pmid: 18464351].
55 A lifesaving education. Ethn Dis. Winter. 2008;18(1):108. X-1, X-7, X-9. [pmid: 18447111].
56 Hypoglycemia and employment/licensure. Diabetes Care. Jan. Suppl 1. 2008;31:S94. X-1, X-6, X-7, X-9. [pmid: 18165342].
57 For the patient. Fit body and soul: a diabetes prevention program in African American churches. Ethn Dis. Spring. 2009;19(2):219. X-1, X-6, X-7, X-9. [pmid: 19537237].
58 TRICARE; diabetic education. Final rule. Fed Regist. Aug. 6. 2010;75(151):47458-60. X-1, X-2, X-4. [pmid: 20695037].
59 Vital signs: breast cancer screening among women aged 50-74 years - United States, 2008. MMWR Morb Mortal Wkly Rep. Jul. 9. 2010;59(26):813-6. X-2, X-4. [pmid: 20613705].
60 Vital signs: asthma prevalence, disease characteristics, and self-management education: United States, 2001--2009. MMWR Morb Mortal Wkly Rep. May. 6. 2011;60(17):547-52. X-2, X-4, X-6. [pmid: 21544044].
61 Abdel Gawwad ES, El-Herishi S. Asthma education for school staff in Riyadh city: effectiveness of pamphlets as an educational tool. J Egypt Public Health Assoc. 2007;82(1-2):147-71. X-3, X-6. [pmid: 18217329].
62 Abdelhamid AS, Maisey S, Steel N. Predictors of the quality of care for asthma in general practice: An observational study. Family Practice. Apr. 2010;27(2):186-91. X-2, X-3. [pmid: 20026552].
63 Abdel-Kader K, Dew MA, Bhatnagar M, et al. Numeracy Skills in CKD: Correlates and Outcomes. Clinical Journal of the American Society of Nephrology. Sep. 2010;5(9):1566-73. X-2. [pmid: 20507954].
64 Abdullah L, Margolis S, Townsend T. Primary health care patients' knowledge about diabetes in the United Arab Emirates. East Mediterr Health J. Jul-Sep. 2001;7(4-5):662-70. X-2, X-3, X-6. [pmid: 15332764].
65 Abercrombie EL, Greenbaum LA, Baxter DH, et al. Effect of intensified diet education on serum phosphorus and knowledge of pediatric peritoneal dialysis patients. J Ren Nutr. May. 2010;20(3):193-8. X-4, X-6. [pmid: 20303791].
66 Abhyankar P, Bekker HL, Summers BA, et al. Why values elicitation techniques enable people to make informed decisions about cancer trial participation. Health Expect. Mar. Suppl 1. 2011;14:20-32. X-3, X-4, X-5, X-6. [pmid: 20629765].
67 Abood DA, Coster DC, Mullis AK, et al. Evaluation of a “loss-framed” minimal intervention to increase mammography utilization among medically un- and underinsured women. Cancer Detect Prev. 2002;26(5):394-400. X-9. [pmid: 12518870].
68 Abrams LS, Dornig K, Curran L. Barriers to service use for postpartum depression symptoms among low-income ethnic minority mothers in the United States. Qual Health Res. Apr. 2009;19(4):535-51. X-2, X-4. [pmid: 19299758].
69 Abrams RC, Lachs M, McAvay G, et al. Predictors of self-neglect in community-dwelling elders. Am J Psychiatry. Oct. 2002;159(10):1724-30. X-2, X-4, X-5, X-6. [pmid: 12359679].
70 Abreo K, Allon M, Asif A, et al. Which direction is right for vascular access surveillance? A debate. Nephrol News Issues. Jun. 2010;24(7):30. 2. 4. X-1, X-2, X-4. [pmid: 20617629].
71 Absetz P, Valve R, Oldenburg B, et al. Type 2 diabetes prevention in the “real world”: one-year results of the GOAL Implementation Trial. Diabetes Care. Oct. 2007;30(10):2465-70. X-3, X-6. [pmid: 17586741].
72 Abu-Rayya HM. Psychological traits of mixed-ethnic Arab-European adolescents in Israel. Internet Journal of Mental Health. 2005;2(2):16p. X-2, X-3, X-5.
73 Acik Y, Bulut HY, Gulbayrak C, et al. Effectiveness of a diabetes education and intervention program on blood glucose control for patients with type 2 diabetes in a Turkish community. Southeast Asian J Trop Med Public Health. Dec. 2004;35(4):1012-8. X-3, X-4, X-5, X-6. [pmid: 15916107].
74 Adams A, Receveur O, Mundt M, et al. Healthy lifestyle indicators in children (grades 4 to 6) from the Kahnawake Schools Diabetes Prevention Project. Canadian Journal of Diabetes. 2005;29(4):403-9. X-2, X-3.
75 Adams AS, Mah C, Soumerai SB, et al. Barriers to self-monitoring of blood glucose among adults with diabetes in an HMO: a cross sectional study. BMC Health Serv Res. Mar. 19. 2003;3(1):6. X-2. [pmid: 12659642].
76 Adams AS, Trinacty CM, Zhang F, et al. Medication adherence and racial differences in A1C control. Diabetes Care. May. 2008;31(5):916-21. X-2. [pmid: 18235050].
77 Adams EF, Lee AJ, Pritchard CW, et al. What stops us from healing the healers: a survey of help-seeking behaviour, stigmatisation and depression within the medical profession. Int J Soc Psychiatry. Jul. 2010;56(4):359-70. X-2, X-3, X-4, X-6. [pmid: 19617278].
78 Adams ML. The African American Breast Cancer Outreach Project: Partnering With Communities. Family & Community Health: The Journal of Health Promotion & Maintenance. Jan-Mar. 2007;30(1,Suppl):S85-S94. X-1, X-2, X-4. [pmid: 17159636].
79 Adams RJ, Smith BJ, Ruffin RE. Factors associated with hospital admissions and repeat emergency department visits for adults with asthma. Thorax. Jul. 2000;55(7):566-73. X-2, X-4. [pmid: 10856316].
80 Adams RJ, Smith BJ, Ruffin RE. Patient preferences for autonomy in decision making in asthma management. Thorax. Feb. 2001;56(2):126-32. X-2, X-4. [pmid: 11209101].
81 Adams RJ, Weiss ST, Fuhlbrigge A. How and by whom care is delivered influences anti-inflammatory use in asthma: Results of a national population survey. J Allergy Clin Immunol. Aug. 2003;112(2):445-50. X-6, X-7, X-9. [pmid: 12897755].
82 Adderley-Kelly B, Green PM. Breast cancer education, self-efficacy, and screening in older African American women. J Natl Black Nurses Assoc. Spring-Summer. 1997;9(1):45-57. X-2, X-4. [pmid: 9384102].
83 Adib SM, Sabbah MA, Hlais S, et al. Research in action: mammography utilization following breast cancer awareness campaigns in Lebanon 2002-05. East Mediterr Health J. Jan-Feb. 2009;15(1):6-18. X-2, X-3, X-4. [pmid: 19469422].
84 Adolfsson ET, Rosenblad A, Wikblad K. The Swedish National Survey of the Quality and Organization of Diabetes Care in Primary Healthcare—Swed-QOP. Primary Care Diabetes. Jul. 2010;4(2):91-7. X-2, X-3, X-4. [pmid: 20434973].
85 Afable-Munsuz A, Braveman P. Pregnancy intention and preterm birth: Differential associations among a diverse population of women. Perspectives on Sexual and Reproductive Health. Jun. 2008;40(2):66-73. X-2. [pmid: 18577138].
86 Afshar A, Afshar N. Long-term follow-up evaluation of bilateral total hand loss. J Hand Surg Am. Oct. 2007;32(8):1148-53. X-2, X-4, X-5, X-6. [pmid: 17923294].
87 Agabiti N, Ancona C, Forastiere F, et al. Evaluating outcomes of hospital care following coronary artery bypass surgery in Rome, Italy. Eur J Cardiothorac Surg. Apr. 2003;23(4):599-606. discussion 7-8. X-2, X-3, X-6. [pmid: 12694783].
88 Agban H, Elley CR, Kenealy T, et al. Trends in the management of risk of diabetes complications in different ethnic groups in New Zealand primary care. Prim Care Diabetes. Dec. 2008;2(4):181-6. X-2, X-3. [pmid: 18829410].
89 Agho AO, Mosley BW, Rivers PA, et al. Utilization of mammography services among elderly rural and urban African American women. Health Education Journal. 2007;66(3):245-61. X-9.
90 Agosti V, Stewart JW. Hypomania with and without Dysphoria: comparison of comorbidity and clinical characteristics of respondents from a national community sample. J Affect Disord. May. 2008;108(1-2):177-82. X-2, X-5. [pmid: 17963847].
91 Aguado O, Morcillo C, Delas J, et al. Long-term implications of a single home-based educational intervention in patients with heart failure. Heart Lung. Nov-Dec. 2010;39(6 Suppl):S14-22. X-4, X-6. [pmid: 20598745].
92 Aguilar MM. Humanizing the teaching-learning environment for Vietnamese clients with ESRD. ANNA J. Apr. 1986;13(2):61-4. 79. X-1, X-6, X-7, X-9. [pmid: 3634601].
93 Aguilera N, Marrufo GM. Can better infrastructure and quality reduce hospital infant mortality rates in Mexico?. Health Policy. Feb. 2007;80(2):239-52. X-2, X-3, X-6. [pmid: 16632069].
94 Agurs-Collins T, Smoot D, Afful J, et al. Legume intake and reduced colorectal adenoma risk in African-Americans. J Natl Black Nurses Assoc. Dec. 2006;17(2):6-12. X-2, X-7, X-8. [pmid: 17410754].
95 Agurs-Collins TD, Kumanyika SK, Ten Have TR, et al. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. Oct. 1997;20(10):1503-11. X-4. [pmid: 9314625].
96 Ahlers-Schmidt CR, Golbeck AL, Paschal AM, et al. Breast cancer counts: numeracy in breast cancer information on the Web. J Cancer Educ. Summer. 2006;21(2):95-8. X-2, X-3, X-4, X-6. [pmid: 17020522].
97 Ahluwalia HK, Miller CE, Pickard SP, et al. Prevalence and correlates of preventive care among adults with diabetes in Kansas. Diabetes Care. Apr. 2000;23(4):484-9. X-2, X-4. [pmid: 10857939].
98 Ahluwalia JS, McNagny SE, Kanuru NK. A randomized trial to improve follow-up care in severe uncontrolled hypertensives at an inner-city walk-in clinic. J Health Care Poor Underserved. Nov. 1996;7(4):377-89. X-9. [pmid: 8908893].
99 Ahluwalia JS, McNagny SE, Rask KJ. Correlates of controlled hypertension in indigent, inner-city hypertensive patients. J Gen Intern Med. Jan. 1997;12(1):7-14. X-2, X-4. [pmid: 9034941].
100 Ahmad F, Stewart DE. Predictors of clinical breast examination among South Asian immigrant women. J Immigr Health. Jul. 2004;6(3):119-26. X-2, X-3, X-4. [pmid: 15269515].
101 Ahmed A, Weaver MT, Allman RM, et al. Quality of Care of Nursing Home Residents Hospitalized With Heart Failure. Journal of the American Geriatrics Society. Nov. 2002;50(11):1831-6. X-2. [pmid: 12410902].
102 Ahmed F, Elbasha EE, Thompson BL, et al. Cost-benefit analysis of a new HEDIS performance measure for pneumococcal vaccination. Med Decis Making. Sep-Oct. 2002;22(5 Suppl):S58-66. X-2, X-3, X-4, X-6. [pmid: 12369232].
103 Akamatsu K, Saito A, Wada T, et al. Analysis of comprehensive geriatric assessment of elderly residents in a social welfare home for the aged compared with those in a residential care home in an urban are in Japan. Geriatrics & Gerontology International. 2005;5(1):53-8. X-3.
104 Akbar DH, Ahmed MM, Algamdi AA. Cardiovascular risk factors in Saudi Arabian and non-Saudi Arabian diabetic patients in Saudi Arabia. East Mediterr Health J. Sep-Nov. 2003;9(5-6):884-92. X-2, X-3, X-6. [pmid: 16450518].
105 Akerman MJ, Sinert R. A successful effort to improve asthma care outcome in an inner-city emergency department. J Asthma. May. 1999;36(3):295-303. X-6, X-9. [pmid: 10350227].
106 Akin S, Can G, Durna Z, et al. The quality of life and self-efficacy of Turkish breast cancer patients undergoing chemotherapy. Eur J Oncol Nurs. Dec. 2008;12(5):449-56. X-2, X-3, X-6. [pmid: 18842460].
107 Aktan-Collan K, Mecklin JP, Jarvinen H, et al. Predictive genetic testing for hereditary non-polyposis colorectal cancer: uptake and long-term satisfaction. Int J Cancer. Jan. 20. 2000;89(1):44-50. X-2, X-3, X-4, X-6. [pmid: 10719730].
108 Al Hamarneh YN, Crealey GE, McElnay JC. Coronary heart disease: health knowledge and behaviour. Int J Clin Pharm. Feb. 2011;33(1):111-23. X-2, X-3, X-4, X-6. [pmid: 21365403].
109 Al Zabadi H, El Sharif N. Risk factors for asthma severity among emergency rooms attendees, Palestine. Pulm Pharmacol Ther. Jun. 2009;22(3):208-13. X-2, X-3, X-6. [pmid: 19138752].
110 Al-Adsani AM, Moussa MA, Al-Jasem LI, et al. The level and determinants of diabetes knowledge in Kuwaiti adults with type 2 diabetes. Diabetes Metab. Apr. 2009;35(2):121-8. X-2, X-3, X-6. [pmid: 19250850].
111 Albano MG, Crozet C, d'Ivernois JF. Analysis of the 2004-2007 literature on therapeutic patient education in diabetes: results and trends. Acta Diabetol. Dec. 2008;45(4):211-9. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18633570].
112 Albarran NB, Ballesteros MN, Morales GG, et al. Dietary behavior and type 2 diabetes care. Patient Educ Couns. May. 2006;61(2):191-9. X-3, X-4. [pmid: 15905066].
113 Albert NM. Promoting self-care in heart failure state of clinical practice based on the perspectives of healthcare systems and providers. Journal of Cardiovascular Nursing. May-Jun. 2008;23(3):277-84. X-1, X-2, X-4. [pmid: 18437070].
114 Albert NM, Trochelman K, Meyer KH, et al. Characteristics Associated with Racial Disparities in Illness Beliefs of Patients with Heart Failure. Behavioral Medicine. Win. 2009;35(4):112-25. X-2. [pmid: 19933058].
115 Alberti H, Boudriga N, Nabli M. Primary care management of diabetes in a low/middle income country: a multi-method, qualitative study of barriers and facilitators to care. BMC Fam Pract. 2007;8:63. X-2, X-3, X-4, X-6. [pmid: 17996084].
116 Alberti H, Boudriga N, Nabli M. “Damm sokkor”: factors associated with the quality of care of patients with diabetes: a study in primary care in Tunisia. Diabetes Care. Aug. 2007;30(8):2013-8. X-2, X-3, X-6. [pmid: 17507697].
117 Aldana S, Barlow M, Smith R, et al. A worksite diabetes prevention program: two-year impact on employee health. AAOHN J. Sep. 2006;54(9):389-95. X-2, X-4, X-6. [pmid: 17001837].
118 Alderman AK, McMahon L Jr., Wilkins EG. The national utilization of immediate and early delayed breast reconstruction and the effect of sociodemographic factors. Plast Reconstr Surg. Feb. 2003;111(2):695-703. discussion 4-5. X-2. [pmid: 12560690].
119 Alegria M, Frank R, McGuire T. Managed care and systems cost-effectiveness: treatment for depression. Med Care. Dec. 2005;43(12):1225-33. X-2. [pmid: 16299434].
120 Alexander GK, Uz SW, Hinton I, et al. Culture brokerage strategies in diabetes education. Public Health Nurs. Sep-Oct. 2008;25(5):461-70. X-1, X-7, X-9. [pmid: 18816363].
121 Alexander J, Divin-Cosgrove C, Faner ML, et al. Increasing the knowledge base of asthmatics and their families through asthma clubs along the southwest border. J Am Acad Nurse Pract. Jul. 2000;12(7):260-6. X-7, X-9. [pmid: 11930464].
122 Alexander KP, Roe MT, Chen AY, et al. Evolution in cardiovascular care for elderly patients with non-ST-segment elevation acute coronary syndromes: results from the CRUSADE National Quality Improvement Initiative. J Am Coll Cardiol. Oct. 18. 2005;46(8):1479-87. X-6. [pmid: 16226171].
123 Alexandraki I, Mooradian AD. Barriers Related to Mammography Use for Breast Cancer Screening Among Minority Women. Journal of the National Medical Association. Mar. 2010;102(3):206-18. X-1, X-2, X-4. [pmid: 20355350].
124 Alkadry MG, Wilson C, Nicholson D. Stroke awareness among rural residents: the case of West Virginia. Soc Work Health Care. 2005;42(2):73-92. X-2, X-4, X-5, X-6. [pmid: 16390837].
125 Al-Lawati JA, Barakat NM, Al-Lawati AM, et al. Optimal cut-points for body mass index, waist circumference and waist-to-hip ratio using the Framingham coronary heart disease risk score in an Arab population of the Middle East. Diab Vasc Dis Res. Nov. 2008;5(4):304-9. X-2, X-3, X-6. [pmid: 18958841].
126 Allen C, LeCaire T, Palta M, et al. Risk factors for frequent and severe hypoglycemia in type 1 diabetes. Diabetes Care. Nov. 2001;24(11):1878-81. X-2, X-4, X-6. [pmid: 11679450].
127 Allen J, Annells M, Nunn R, et al. Evaluation of effectiveness and satisfaction outcomes of a mental health screening and referral clinical pathway for community nursing care. J Psychiatr Ment Health Nurs. Jun. 2011;18(5):375-85. X-3, X-5, X-6. [pmid: 21539682].
128 Allen JD, Shelton RC, Harden E, et al. Follow-up of abnormal screening mammograms among low-income ethnically diverse women: Findings from a qualitative study. Patient Education and Counseling. Aug. 2008;72(2):283-92. X-2. [pmid: 18490127].
129 Allen MC. Preterm outcomes research: A critical component of neonatal intensive care. Mental Retardation and Developmental Disabilities Research Reviews. 2002;8(4):221-33. X-1, X-2, X-4, X-5. [pmid: 12454898].
130 Allen NA, Fain JA, Braun B, et al. Continuous glucose monitoring in non-insulin-using individuals with type 2 diabetes: acceptability, feasibility, and teaching opportunities. Diabetes Technol Ther. Mar. 2009;11(3):151-8. X-2, X-4, X-6. [pmid: 19216684].
131 Allen-Ramey FC, Diette GB, McDonald RC, et al. Methods aimed at improving asthma care and outcomes management: a case study. Disease Management & Health Outcomes. 2002;10(8):495-503. X-2.
132 Allgar VL, Neal RD, Ali N, et al. Urgent GP referrals for suspected lung, colorectal, prostate and ovarian cancer. Br J Gen Pract. May. 2006;56(526):355-62. X-2, X-3, X-6. [pmid: 16638251].
133 Allison JT. Enhancing care, one community at a time. Hosp Health Netw. May. 2011;85(5):52. X-1, X-7, X-9. [pmid: 21682242].
134 Allison MA, Crane LA, Beaty BL, et al. School-based health centers: improving access and quality of care for low-income adolescents. Pediatrics. Oct. 2007;120(4):e887-94. X-2, X-5. [pmid: 17846146].
135 Allsworth JE, Toppa R, Palin NC, et al. For the patient. Many nursing home patients do not receive diabetes medicine. Ethn Dis. Spring. 2005;15(2):351. X-1, X-2, X-3, X-4. [pmid: 15825983].
136 Allsworth JE, Toppa R, Palin NC, et al. Racial and ethnic disparities in the pharmacologic management of diabetes mellitus among long-term care facility residents. Ethn Dis. Spring. 2005;15(2):205-12. X-2, X-4. [pmid: 15825966].
137 Almendarez IS, Boysun M, Clark K. Thunder and Lightning and Rain: a Latino/Hispanic diabetes media awareness campaign. Fam Community Health. Apr-Jun. 2004;27(2):114-22. X-7, X-9. [pmid: 15596978].
138 Alnasir FA, Skerman JH. Schoolteachers' knowledge of common health problems in Bahrain. East Mediterr Health J. Jul-Sep. 2004;10(4-5):537-46. X-2, X-3, X-4, X-6. [pmid: 16335644].
139 Alnigenis MNY, Bradley JD, Wallick J, et al. Massage therapy in the management of fibromyalgia: a pilot study. Journal of Musculoskeletal Pain. 2001;9(2):55-67. X-4, X-5.
140 Alonso A, Beunza JJ, Delgado-Rodriguez M, et al. Validation of self reported diagnosis of hypertension in a cohort of university graduates in Spain. BMC Public Health. 2005;5:94. X-2, X-3, X-4, X-6. [pmid: 16156889].
141 Al-Saeedi M, Elzubier AG, Bahnassi AA, et al. Patterns of belief and use of traditional remedies by diabetic patients in Mecca, Saudi Arabia. East Mediterr Health J. Jan-Mar. 2003;9(1-2):99-107. X-2, X-3, X-6. [pmid: 15562738].
142 Al-Safi SA, Alkofahi AS, El-Eid HS. Public response to chest pain in Jordan. Eur J Cardiovasc Nurs. Jun. 2005;4(2):139-44. X-2, X-3, X-6. [pmid: 15904884].
143 Al-Shadli AM, Bener A, Brebner J, et al. Asthma diagnosis and management in adults: is the risk of underdiagnosis and undertreatment related to patients' education levels?. J Asthma. Apr. 2001;38(2):121-6. X-2, X-3, X-4, X-6. [pmid: 11321681].
144 Alshamsan R, Majeed A, Vamos EP, et al. Ethnic differences in diabetes management in patients with and without comorbid medical conditions: a cross-sectional study. Diabetes Care. Mar. 2011;34(3):655-7. X-2, X-3, X-4. [pmid: 21282346].
145 Alshamsan R, Millett C, Majeed A, et al. Has pay for performance improved the management of diabetes in the United Kingdom?. Primary Care Diabetes. Jul. 2010;4(2):73-8. X-1, X-2, X-3, X-4, X-6. [pmid: 20363200].
146 Alt PS, Schatell D. How to make the new conditions for coverage work in your dialysis clinic: Teaching self-management: new conditions emphasize patient participation in care. Nephrol News Issues. Jun. 8. 40. 2009;23(7):36-1. X-1, X-2, X-4. [pmid: 19585808].
147 Alter DA, Austin PC, Naylor CD, et al. Factoring socioeconomic status into cardiac performance profiling for hospitals: does it matter?. Med Care. Jan. 2002;40(1):60-7. X-2, X-3, X-4. [pmid: 11748427].
148 Alter DA, Austin PC, Tu JV. Community factors, hospital characteristics and inter-regional outcome variations following acute myocardial infarction in Canada. Can J Cardiol. Mar. 2005;21(3):247-55. X-2, X-3, X-6. [pmid: 15776114].
149 Alter DA, Khaykin Y, Austin PC, et al. Processes and outcomes of care for diabetic acute myocardial infarction patients in Ontario: do physicians undertreat?. Diabetes Care. May. 2003;26(5):1427-34. X-2, X-3, X-6. [pmid: 12716800].
150 Alter DA, Venkatesh V, Chong A. Evaluating the performance of the Global Registry of Acute Coronary Events risk-adjustment index across socioeconomic strata among patients discharged from the hospital after acute myocardial infarction. Am Heart J. Feb. 2006;151(2):323-31. X-2, X-6. [pmid: 16442894].
151 Altimiras J, Borras JM, Mendez E, et al. Knowledge of medication in hospitalized chronic respiratory patients. Pharm Weekbl Sci. Aug. 21. 1992;14(4):174-9. X-2, X-3, X-4, X-5. [pmid: 1437495].
152 Altıok M, Yılmaz M. Opinions of Individuals Who have had Myocardial Infarction About Sex. Sexuality & Disability. 2011;29(3):263-73. X-6, X-7, X-9.
153 Alto WA, Albu RE, Irabo G. An alternative to unattended delivery--a training programme for village midwives in Papua New Guinea. Soc Sci Med. 1991;32(5):613-8. X-3, X-4. [pmid: 2017729].
154 Alzate MM. Welfare recipients' quality of life: lessons from the United Nations' Human Development Index for the US Welfare Policy. European Journal of Social Work. 2006;9(1):85-101. X-2.
155 Amaral S, Hwang W, Fivush B, et al. Serum albumin level and risk for mortality and hospitalization in adolescents on hemodialysis. Clin J Am Soc Nephrol. May. 2008;3(3):759-67. X-2. [pmid: 18287254].
156 Amaya H, Petersen J. Introduction: Breast cancer and the perils of health literacy. International Journal of Qualitative Studies in Education. Special Issue: Constructing Breast Cancer: Discourses and Practices. Jul-Aug. 2004;17(4):467-71. X-1, X-2, X-4.
157 Ambriz EH, Woodard LD, Kressin NR, et al. Use of smoking cessation interventions and aspirin for secondary prevention: are there racial disparities?. Am J Med Qual. Jul-Aug. 2004;19(4):166-71. X-7, X-9. [pmid: 15368781].
158 Ambrosino JM, Fennie K, Whittemore R, et al. Short-term effects of coping skills training in school-age children with type 1 diabetes. Pediatr Diabetes. Jun. 2008;9(3 Pt 2):74-82. X-4, X-6. [pmid: 18540868].
159 Amirehsani KA. Mexican Americans with type 2 diabetes in an emerging Latino community: Evaluation of health disparity factors and interventions. Home Health Care Management & Practice. Dec. 2010;22(7):470-8. X-1, X-2, X-4.
160 Ammerman AS, Devellis BM, Haines PS, et al. Nutrition education for cardiovascular-disease prevention among low income populations- description and pilot evaluation of a physician-based model. Patient Education and Counseling. Feb. 1992;19(1):5-18. X-1, X-2, X-4. [pmid: 1298949].
161 Amoako E, Skelly AH. Managing uncertainty in diabetes: an intervention for older African American women. Ethn Dis. Summer. 2007;17(3):515-21. X-4, X-10. [pmid: 17985507].
162 Amoako E, Skelly AH, Rossen EK. Outcomes of an intervention to reduce uncertainty among African American women with diabetes. West J Nurs Res. Dec. 2008;30(8):928-42. X-4. [pmid: 18596303].
163 Amthauer H, Gaglio B, Glasgow RE, et al. Lessons learned: patient recruitment strategies for a type 2 diabetes intervention in a primary care setting [corrected]. Diabetes Educ. Jul-Aug. 2003;29(4):673-81. X-2, X-7. [pmid: 13677178].
164 Anand SS, Razak F, Vuksan V, et al. Diagnostic strategies to detect glucose intolerance in a multiethnic population. Diabetes Care. Feb. 2003;26(2):290-6. X-2, X-3. [pmid: 12547851].
165 Anarella J, Roohan P, Balistreri E, et al. A survey of Medicaid recipients with asthma: perceptions of self-management, access, and care. Chest. Apr. 2004;125(4):1359-67. X-2. [pmid: 15078746].
166 Andersen JR, Sognen E, Natvig GK. Diet quality in 116 Norwegian men and women with coronary heart disease. Eur J Cardiovasc Nurs. Sep. 2006;5(3):244-50. X-2, X-3, X-4, X-6. [pmid: 16376153].
167 Anderson BJ, Wolf FM, Burkhart MT, et al. Effects of peer-group intervention on metabolic control of adolescents with IDDM. Randomized outpatient study. Diabetes Care. Mar. 1989;12(3):179-83. X-6, X-9. [pmid: 2649330].
168 Anderson BO, Yip CH, Smith RA, et al. Guideline implementation for breast healthcare in low-income and middle-income countries: overview of the Breast Health Global Initiative Global Summit 2007. Cancer. Oct. 15. 2008;113(8 Suppl):2221-43. X-1, X-2, X-3, X-4. [pmid: 18816619].
169 Anderson DR, Christison-Lagay J, Procter-Gray E. Self-management goal setting in a community health center: the impact of goal attainment on diabetes outcomes. Diabetes Spectrum. 2010;23(2):97-105. X-6, X-7, X-9.
170 Anderson DR, Christison-Lagay J, Villagra V, et al. Managing the space between visits: a randomized trial of disease management for diabetes in a community health center. J Gen Intern Med. Oct. 2010;25(10):1116-22. X-4. [pmid: 20556536].
171 Anderson RM, Arnold MS, Donnelly MB, et al. Continuing education needs of dietitians who are diabetes educators. J Am Diet Assoc. May. 1992;92(5):607-9. X-1, X-2, X-4, X-5, X-6. [pmid: 1573146].
172 Anderson RM, Barr PA, Edwards GJ, et al. Using focus groups to identify psychosocial issues of urban black individuals with diabetes. Diabetes Educ. Jan-Feb. 1996;22(1):28-33. X-2, X-4. [pmid: 8697953].
173 Anderson RM, Fitzgerald JT, Funnell MM, et al. Evaluation of an activated patient diabetes education newsletter. Diabetes Educ. Jan-Feb. 1994;20(1):29-34. X-6, X-10. [pmid: 8137701].
174 Anderson RM, Funnell MM, Arnold MS, et al. Assessing the cultural relevance of an education program for urban African Americans with diabetes. Diabetes Educ. Mar-Apr. 2000;26(2):280-9. X-6, X-7, X-9. [pmid: 10865593].
175 Anderson RM, Funnell MM, Nwankwo R, et al. Evaluating a problem-based empowerment program for African Americans with diabetes: results of a randomized controlled trial. Ethn Dis. Autumn. 2005;15(4):671-8. X-9. [pmid: 16259492].
176 Anderson RM, Goddard CE, Garcia R, et al. Using focus groups to identify diabetes care and education issues for Latinos with diabetes. Diabetes Educ. Sep-Oct. 1998;24(5):618-25. X-2, X-4. [pmid: 9830959].
177 Anderson RM, Musch DC, Nwankwo RB, et al. Personalized follow-up increases return rate at urban eye disease screening clinics for African Americans with diabetes: results of a randomized trial. Ethn Dis. Winter. 2003;13(1):40-6. X-9. [pmid: 12723011].
178 Anderson RT, Balkrishnan R, Camacho F, et al. Patient-centered outcomes of diabetes self-care. Associations with satisfaction and general health in a community clinic setting. N C Med J. Mar-Apr. 2003;64(2):58-65. X-2. [pmid: 12774734].
179 Anderson-Loftin W, Barnett S, Sullivan P, et al. Culturally competent dietary education for southern rural African Americans with diabetes. Diabetes Educ. Mar-Apr. 2002;28(2):245-57. X-4. [pmid: 11924302].
180 Andersson P, Sjoberg RL, Ohrvik J, et al. Knowledge about cardiovascular risk factors among obese individuals. Eur J Cardiovasc Nurs. Dec. 2006;5(4):275-9. X-2, X-3, X-5, X-6. [pmid: 16616876].
181 Andrade WC, Camargos P, Lasmar L, et al. A pediatric asthma management program in a low-income setting resulting in reduced use of health service for acute asthma. Allergy. Nov. 2010;65(11):1472-7. X-2, X-3, X-4. [pmid: 20557301].
182 Andrews D, Popiel A, Margolis SA, et al. Improving diabetic patients' outcomes in family medicine in the United Arab Emirates. East Mediterr Health J. Jul-Sep. 2002;8(4-5):566-73. X-2, X-6. [pmid: 15603039].
183 Andrulis DP. Reducing racial and ethnic disparities in disease management to improve health outcomes. Disease Management & Health Outcomes. 2003;11(12):789-800. X-1, X-2, X-4.
184 Angus J, Evans S, Lapum J, et al. “Sneaky disease”: the body and health knowledge for people at risk for coronary heart disease in Ontario, Canada. Soc Sci Med. May. 2005;60(9):2117-28. X-2, X-3, X-4, X-6. [pmid: 15743659].
185 Ani C, Bazargan M, Hindman D, et al. Comorbid chronic illness and the diagnosis and treatment of depression in safety net primary care settings. J Am Board Fam Med. Mar-Apr. 2009;22(2):123-35. X-2, X-6. [pmid: 19264935].
186 Anne Kelsey L, Joel E, Kathryn L, et al. Reducing Asthma Disparities by Addressing Environmental Inequities: A Case Study of Regional Asthma Management and Prevention's Advocacy Efforts. Family and Community Health. 2011;34(1S):S54. X-7, X-10. [pmid: 21160331].
187 Ansa VO, Oyo-Ita A, Essien OE. Perception of ischaemic heart disease, knowledge of and attitude to reduction of its risk factors. East Afr Med J. Jul. 2007;84(7):318-23. X-2, X-3, X-6. [pmid: 17886425].
188 Ansell D, Grabler P, Whitman S, et al. A community effort to reduce the black/white breast cancer mortality disparity in Chicago. Cancer Causes Control. Nov. 2009;20(9):1681-8. X-2, X-4. [pmid: 19688184].
189 Ansell D, Lacey L, Whitman S, et al. A nurse-delivered intervention to reduce barriers to breast and cervical cancer screening in Chicago inner city clinics. Public Health Rep. Jan-Feb. 1994;109(1):104-11. X-7, X-9. [pmid: 8303003].
190 Antoniassi Villela. A representaÃ§Ã£o da sexualidade por idosas e a educaÃ§Ã£o para a saÃºde. Revista Eletrônica de Enfermagem. 2010;12(4):622-9. X-2, X-3, X-4, X-5, X-6.
191 Apostolopoulou E, Veldekis D. Excess nursing workload and extra cost attributable to ventilator associated pneumonia in intensive care unit. ICUs & Nursing Web Journal. 2004;(20):8p. X-2, X-5.
192 Appel LJ, Champagne CM, Harsha DW, et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. Apr. 23-30. 2003;289(16):2083-93. X-6, X-7, X-9. [pmid: 12709466].
193 Appel LJ, Espeland MA, Easter L, et al. Effects of reduced sodium intake on hypertension control in older individuals: results from the Trial of Nonpharmacologic Interventions in the Elderly (TONE). Arch Intern Med. Mar. 12. 2001;161(5):685-93. X-6, X-9. [pmid: 11231700].
194 Appiah AP, Ganthier R Jr., Watkins N. Delayed diagnosis of diabetic retinopathy in black and Hispanic patients with diabetes mellitus. Ann Ophthalmol. Apr. 1991;23(4):156-8. X-2, X-4. [pmid: 2064260].
195 Applegate BW, Ames SC, Mehan DJ Jr., et al. Maximizing medication adherence in low-income hypertensives: a pilot study. J La State Med Soc. Jul. 2000;152(7):349-56. X-9. [pmid: 10986847].
196 Appleton S, Garcia-Minaur S, Porteous M, et al. The development of a psychoeducational intervention for women living with an increased risk of breast cancer. Patient Educ Couns. Oct. 2004;55(1):99-104. X-1, X-2, X-4, X-6. [pmid: 15476996].
197 Appleton SL, Adams RJ, Wilson DH, et al. Spirometric criteria for asthma: adding further evidence to the debate. J Allergy Clin Immunol. Nov. 2005;116(5):976-82. X-2, X-3, X-6. [pmid: 16275363].
198 Apte DV. A plan to prevent adolescent pregnancy and reduce infant mortality. Public Health Rep. Jan-Feb. 1987;102(1):80-6. X-1, X-2, X-3, X-4, X-6. [pmid: 3101128].
199 Apter AJ. Advances in adult asthma diagnosis and treatment and health outcomes, education, delivery, and quality in 2008. Journal of Allergy and Clinical Immunology. Jan. 2009;123(1):35-40. X-1, X-2, X-4, X-6. [pmid: 19130925].
200 Apter AJ, Cheng J, Small D, et al. Asthma numeracy skill and health literacy. J Asthma. Nov. 2006;43(9):705-10. X-2. [pmid: 17092853].
201 Apter AJ, Reisine ST, Affleck G, et al. Adherence with twice-daily dosing of inhaled steroids. Socioeconomic and health-belief differences. Am J Respir Crit Care Med. Jun. 1998;157(6 Pt 1):1810-7. X-2, X-4. [pmid: 9620910].
202 Apter AJ, Van Hoof TJ, Sherwin TE, et al. Assessing the quality of asthma care provided to Medicaid patients enrolled in managed care organizations in Connecticut. Ann Allergy Asthma Immunol. Feb. 2001;86(2):211-8. X-2, X-4. [pmid: 11258692].
203 Apter AJ, Wang X, Bogen D, et al. Linking numeracy and asthma-related quality of life. Patient Educ Couns. Jun. 2009;75(3):386-91. X-2. [pmid: 19217741].
204 Apter AJ, Wang XM, Bogen DK, et al. Problem solving to improve adherence and asthma outcomes in urban adults with moderate or severe asthma: A randomized controlled trial. Journal of Allergy and Clinical Immunology. Sep. 2011;128(3):516-U122. X-4, X-6, X-9. [pmid: 21704360].
205 Aragones A, Schwartz MD, Shah NR, et al. A randomized controlled trial of a multilevel intervention to increase colorectal cancer screening among Latino immigrants in a primary care facility. J Gen Intern Med. Jun. 2010;25(6):564-7. X-4. [pmid: 20213208].
206 Aragones A, Schwartz MD, Shah NR, et al. A randomized controlled trial of a multilevel intervention to increase colorectal cancer screening among Latinos immigrants in a primary care facility. Journal of General Internal Medicine. Jun. 2010;25(6):564-7. X-14. [pmid: 20213208].
207 Arber S, McKinlay J, Adams A, et al. Influence of patient characteristics on doctors' questioning and lifestyle advice for coronary heart disease: a UK/US video experiment. Br J Gen Pract. Sep. 2004;54(506):673-8. X-2, X-4. [pmid: 15353053].
208 Arber S, McKinlay J, Adams A, et al. Patient characteristics and inequalities in doctors' diagnostic and management strategies relating to CHD: a video-simulation experiment. Soc Sci Med. Jan. 2006;62(1):103-15. X-2, X-3, X-4, X-6. [pmid: 16002197].
209 Arcury TA, Bell RA, Snively BM, et al. Complementary and alternative medicine use as health self-management: rural older adults with diabetes. J Gerontol B Psychol Sci Soc Sci. Mar. 2006;61(2):S62-70. X-2, X-5, X-6. [pmid: 16497962].
210 Arcury TA, Skelly AH, Gesler WM, et al. Diabetes beliefs among low-income, white residents of a rural North Carolina community. J Rural Health. Fall. 2005;21(4):337-45. X-2, X-4. [pmid: 16294657].
211 Ard JD, Rosati R, Oddone EZ. Culturally-sensitive weight loss program produces significant reduction in weight, blood pressure, and cholesterol in eight weeks. J Natl Med Assoc. Nov. 2000;92(11):515-23. X-4, X-5. [pmid: 11152083].
212 Ardena GJ, Paz-Pacheco E, Jimeno CA, et al. Knowledge, attitudes and practices of persons with type 2 diabetes in a rural community: phase I of the community-based Diabetes Self-Management Education (DSME) Program in San Juan, Batangas, Philippines. Diabetes Res Clin Pract. Nov. 2010;90(2):160-6. X-2, X-3, X-4, X-6. [pmid: 20828851].
213 Ardron M, MacFarlane I, Robinson C. Educational achievements, employment and social class of insulin-dependent diabetics: a survey of a young adult clinic in Liverpool. Diabet Med. Nov-Dec. 1987;4(6):546-8. X-2, X-3, X-4. [pmid: 2962812].
214 Armstrong K, Berlin M, Schwartz JS, et al. Barriers to influenza immunization in a low-income urban population. American Journal of Preventive Medicine. Jan. 2001;20(1):21-5. X-2, X-5. [pmid: 11137770].
215 Arnetz JE, Winblad U, Hoglund AT, et al. Is patient involvement during hospitalization for acute myocardial infarction associated with post-discharge treatment outcome? An exploratory study. Health Expect. Sep. 2010;13(3):298-311. X-2, X-3, X-4, X-6. [pmid: 20579120].
216 Arnold LB, Usery JB, Finch CK, et al. Inadequate documentation of asthma management in hospitalized adult patients. South Med J. May. 2009;102(5):510-4. X-2, X-4. [pmid: 19373150].
217 Aronson RA. A work in progress. WMJ. Apr. 2000;99(2):18-24. X-1, X-6, X-7, X-9. [pmid: 10843019].
218 Arora S, Marzec K, Gates C, et al. Diabetes knowledge in predominantly Latino patients and family caregivers in an urban emergency department. Ethn Dis. Winter. 2011;21(1):1-6. X-2, X-4. [pmid: 21462722].
219 Arshad S, Williams KP, Mabiso A, et al. Evaluating the knowledge of breast cancer screening and prevention among Arab-American women in Michigan. J Cancer Educ. Mar. 2011;26(1):135-8. X-2, X-4. [pmid: 20443095].
220 Arslanian-Engoren C. Patient cues that predict nurses' triage decisions for acute coronary syndromes. Appl Nurs Res. May. 2005;18(2):82-9. X-2, X-4. [pmid: 15991105].
221 Arslanian-Engoren C, Hagerty B, Antonakos CL, et al. The feasibility and utility of the aid to cardiac triage intervention to improve nurses' cardiac triage decisions. Heart Lung. May-Jun. 2010;39(3):201-7. X-4. [pmid: 20457340].
222 Artinian NT. Best practice. Perceived benefits and barriers of eating heart healthy. MEDSURG Nursing. 2001;10(3):129-38. X-1, X-2, X-4.
223 Artinian NT, Harden JK, Kronenberg MW, et al. Pilot study of a Web-based compliance monitoring device for patients with congestive heart failure. Heart Lung. Jul-Aug. 2003;32(4):226-33. X-4, X-6. [pmid: 12891162].
224 Artinian NT, Magnan M, Christian W, et al. What do patients know about their heart failure?. Appl Nurs Res. Nov. 2002;15(4):200-8. X-2, X-4. [pmid: 12444578].
225 Artinian NT, Washington OG, Templin TN. Effects of home telemonitoring and community-based monitoring on blood pressure control in urban African Americans: a pilot study. Heart Lung. May-Jun. 2001;30(3):191-9. X-4. [pmid: 11343005].
226 226. Aruda MM. Diagnosing and tracking pregnant teens: development of a quality improvement project. Women's Health Care: A Practical Journal for Nurse Practitioners. 2007;6(9):25. X-1.
227 Asarnow JR, Jaycox LH, Duan N, et al. Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial. JAMA. Jan. 19. 2005;293(3):311-9. X-6. [pmid: 15657324].
228 Asarnow JR, Jaycox LH, Tang L, et al. Long-term benefits of short-term quality improvement interventions for depressed youths in primary care. Am J Psychiatry. Sep. 2009;166(9):1002-10. X-6. [pmid: 19651711].
229 Asch SM, Baker DW, Keesey JW, et al. Does the collaborative model improve care for chronic heart failure?. Med Care. Jul. 2005;43(7):667-75. X-6, X-9. [pmid: 15970781].
230 Ashiabi GS. African American and non-Hispanic white children's health: integrating alternative explanations. Ethnicity & Health. 2008;13(5):375-98. X-2, X-5. [pmid: 18850366].
231 Ashing-Giwa K. Quality of life and psychosocial outcomes in long-term survivors of breast cancer: a focus on African-American women. Journal of Psychosocial Oncology. 1999;17(3/4):47-62. X-2.
232 Ashing-Giwa K, Ganz P. Effect of timed incentives on subject participation in a study of long-term breast cancer survivors: Are there ethnic differences?. Journal of the National Medical Association. Nov. 2000;92(11):528-32. X-7. [pmid: 11152085].
233 Ashing-Giwa KT, Kagawa-Singer M, Padilla GV, et al. The impact of cervical cancer and dysplasia: A qualitative, multiethnic study. Psycho-Oncology. Oct. 2004;13(10):709-28. X-2, X-5. [pmid: 15386644].
234 Ashing-Giwa KT, Padilla G, Tejero J, et al. Understanding the breast cancer experience of women: A qualitative study of African American, Asian American, Latina and Caucasian cancer survivors. Psycho-Oncology. Jun. 2004;13(6):408-28. X-2. [pmid: 15188447].
235 Ashing-Giwa KT, Padilla GV, Bohorquez DE, et al. Understanding the breast cancer experience of Latina women. Journal of Psychosocial Oncology. 2006;24(3):19-52. X-2. [pmid: 17088240].
236 Ashok M, Griffin P, Halpern M. Impact of clinical and non-clinical factors on the choice of HER2 test for breast cancer. Cancer Invest. Aug. 2010;28(7):735-42. X-2. [pmid: 20590449].
237 Ashton CM, Houston TK, Williams JH, et al. A stories-based interactive DVD intended to help people with hypertension achieve blood pressure control through improved communication with their doctors. Patient Educ Couns. May. 2010;79(2):245-50. X-2, X-4. [pmid: 19833472].
238 Ashworth A, Chopra M, McCoy D, et al. WHO guidelines for management of severe malnutrition in rural South African hospitals: effect on case fatality and the influence of operational factors. Lancet. Apr. 3. 2004;363(9415):1110-5. X-3, X-5. [pmid: 15064029].
239 239. Ashworth M, Lloyd D, Smith RS, et al. Social deprivation and statin prescribing: a cross-sectional analysis using data from the new UK general practitioner ‘Quality and Outcomes Framework’. J Public Health (Oxf). Mar. 2007;29(1):40-7. X-2, X-3, X-4. [pmid: 17071815].
240 Aspinall PJ, Hashem F. Are our data on teenage pregnancy across ethnic groups in England fit for the purpose of policy formulation, implementation, and monitoring?. Critical Public Health. 2010;20(1):47-70. X-1, X-2, X-3.
241 Aspray TJ, Nesbit K, Cassidy TP, et al. Rapid assessment methods used for health-equity audit: diabetes mellitus among frail British care-home residents. Public Health. Nov. 2006;120(11):1042-51. X-3, X-6. [pmid: 16938318].
242 Astagneau P, Lang T, Delarocque E, et al. Arterial hypertension in urban Africa: an epidemiological study on a representative sample of Dakar inhabitants in Senegal. J Hypertens. Sep. 1992;10(9):1095-101. X-2, X-3, X-4. [pmid: 1328370].
243 Astin F, Jones K. Heart disease attributions of patients prior to elective percutaneous transluminal coronary angioplasty. J Cardiovasc Nurs. Jan-Feb. 2004;19(1):41-7. X-2. [pmid: 14994781].
244 Atak N, Arslan U. A pilot project to develop and assess a health education programme for type 2 diabetes mellitus patients. Health Education Journal. 2005;64(4):339-46. X-2, X-3, X-6.
245 Atallah A, Kelly-Irving M, Zouini N, et al. Controlling arterial hypertension in the French West Indies: a separate strategy for women?. Eur J Public Health. Dec. 2010;20(6):665-70. X-2, X-3, X-4. [pmid: 20047934].
246 Attar MA, Hanrahan K, Lang SW, et al. Pregnant mothers out of the perinatal regionalization's reach. J Perinatol. Apr. 2006;26(4):210-4. X-2, X-3, X-6. [pmid: 16554850].
247 Audrain J, Rimer B, Cella D, et al. Genetic counseling and testing for breast-ovarian cancer susceptibility: what do women want?. J Clin Oncol. Jan. 1998;16(1):133-8. X-2, X-4, X-6. [pmid: 9440734].
248 Ausili E, Tabacco F, Focarelli B, et al. Multidimensional study on quality of life in children with type 1 diabetes. Eur Rev Med Pharmacol Sci. Jul-Aug. 2007;11(4):249-55. X-2, X-4, X-6. [pmid: 17876960].
249 Austin S, Martin MY, Levine RS, et al. Breast cancer screening interventions in selected counties across US regions. Cancer Causes Control. Dec. 2010;21(12):2165-72. X-2, X-4. [pmid: 20820899].
250 Austin SA, Claiborne N. Faith wellness collaboration: a community-based approach to address type II diabetes disparities in an African-American community. Soc Work Health Care. 2011;50(5):360-75. X-8. [pmid: 21614729].
251 Avci IA, Okanli A, Karabulutlu E, et al. Women's marital adjustment and hopelessness levels after mastectomy. Eur J Oncol Nurs. Sep. 2009;13(4):299-303. X-2, X-3, X-4. [pmid: 19520606].
252 Avis NE, Colvin A. Disentangling cultural issues in quality of life data. Menopause-the Journal of the North American Menopause Society. Jul-Aug. 2007;14(4):708-16. X-2, X-4, X-5, X-6. [pmid: 17327811].
253 Avis NE, Smith KW, Link CL, et al. Increasing mammography screening among women over age 50 with a videotape intervention. Prev Med. Sep. 2004;39(3):498-506. X-6, X-7, X-9. [pmid: 15313089].
254 Avis-Williams A, Khoury A, Lisovicz N, et al. Knowledge, attitudes, and practices of underserved women in rural south toward breast cancer prevention and detection. Family & Community Health: The Journal of Health Promotion & Maintenance. Jul-Sep. 2009;32(3):238-46. X-2. [pmid: 19525705].
255 Awad A, Al-Rabiy S, Abahussain E. Self-medication practices among diabetic patients in Kuwait. Med Princ Pract. 2008;17(4):315-20. X-2, X-3. [pmid: 18523400].
256 Axon RN, Williams MV. Hospital readmission as an accountability measure. JAMA. Feb. 2. 2011;305(5):504-5. X-1, X-2, X-4, X-5, X-6. [pmid: 21285430].
257 Ayanian JZ, Weissman JS, Chasan-Taber S, et al. Quality of care by race and gender for congestive heart failure and pneumonia. Medical Care. Dec. 1999;37(12):1260-9. X-2. [pmid: 10599607].
258 Ayers BN, Myers LB. Understanding of stroke and coronary heart disease in the UK: An exploratory study. Psychology, Health & Medicine. Aug. 2010;15(4):474-7. X-2, X-3. [pmid: 20677085].
259 Ayotte BJ, Allaire JC, Bosworth H. The Associations of Patient Demographic Characteristics and Health Information Recall: The Mediating Role of Health Literacy. Aging Neuropsychology and Cognition. Jul. 2009;16(4):419-32. X-2. [pmid: 19424920].
260 Ayotte BJ, Trivedi R, Bosworth HB. Racial differences in hypertension knowledge: effects of differential item functioning. Ethn Dis. Winter. 2009;19(1):23-7. X-2, X-4. [pmid: 19341159].
261 Ayyagari P, Grossman D, Sloan F. Education and health: evidence on adults with diabetes. Int J Health Care Finance Econ. Mar. 2011;11(1):35-54. X-2, X-4, X-6. [pmid: 21213044].
262 Aziz NA, Norzila MZ, Hamid MZ, et al. Skills amongst parents of children with asthma: a pilot interventional study in primary care setting. Med J Malaysia. Dec. 2006;61(5):534-9. X-6. [pmid: 17623952].
263 Aziz Z, Iqbal J, Akram M. Effect of social class disparities on disease stage, quality of treatment and survival outcomes in breast cancer patients from developing countries. Breast J. Jul-Aug. 2008;14(4):372-5. X-2, X-3. [pmid: 18540953].
264 Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. Feb. 2009;36(1):113-26. X-9. [pmid: 19188371].
265 Bachar JJ, Lefler LJ, Reed L, et al. Cherokee Choices: a diabetes prevention program for American Indians. Prev Chronic Dis. Jul. 2006;3(3):A103. X-8, X-9, X-10. [pmid: 16776864].
266 Bachmann MO, Eachus J, Hopper CD, et al. Socio-economic inequalities in diabetes complications, control, attitudes and health service use: a cross-sectional study. Diabet Med. Nov. 2003;20(11):921-9. X-2, X-3. [pmid: 14632718].
267 Baggs JG, Karch AM. Sexual counseling of women with coronary heart disease. Heart Lung. Mar. 1987;16(2):154-9. X-6, X-7, X-9. [pmid: 3643916].
268 Bahru Y, Abdulkadir J. Assessment of diabetes education in the teaching hospital, Addis Ababa, Ethiopia. Diabet Med. Nov. 1993;10(9):870-3. X-2, X-3. [pmid: 8281736].
269 Bai YL, Chiou CP, Chang YY. Self-care behaviour and related factors in older people with Type 2 diabetes. J Clin Nurs. Dec. 2009;18(23):3308-15. X-2, X-3, X-6. [pmid: 19930088].
270 Bailey BJ. Using change theory to help the diabetic. Diabetes Educ. Fall. 1983;9(3):37-9. 56. X-1, X-6, X-7, X-9. [pmid: 6557913].
271 Bailey EJ, Erwin DO, Belin P. Using cultural beliefs and patterns to improve mammography utilization among African-American women: the Witness Project. J Natl Med Assoc. Mar. 2000;92(3):136-42. X-2, X-4. [pmid: 10745644].
272 Bailie K, Dobie I, Kirk S, et al. Survival after breast cancer treatment: the impact of provider volume. J Eval Clin Pract. Oct. 2007;13(5):749-57. X-2. [pmid: 17824868].
273 Bailit JL, Love TE. The role of race in cesarean delivery rate case mix adjustment. Am J Obstet Gynecol. Jan. 2008;198(1):69 e1-5. X-2. [pmid: 17905177].
274 Bain NS, Campbell NC, Ritchie LD, et al. Striking the right balance in colorectal cancer care--a qualitative study of rural and urban patients. Fam Pract. Aug. 2002;19(4):369-74. X-2, X-3, X-4, X-6. [pmid: 12110557].
275 Bainbridge KE, Cowie CC, Rust KF, et al. Mitigating case mix factors by choice of glycemic control performance measure threshold. Diabetes Care. Sep. 2008;31(9):1754-60. X-2, X-6. [pmid: 18509211].
276 Bains SS, Egede LE. Associations between health literacy, diabetes knowledge, self-care behaviors, and glycemic control in a low income population with type 2 diabetes. Diabetes Technol Ther. Mar. 2011;13(3):335-41. X-2, X-4. [pmid: 21299402].
277 Bakemeier RF, Krebs LU, Murphy JR, et al. Attitudes of Colorado health professionals toward breast and cervical cancer screening in Hispanic women. J Natl Cancer Inst Monogr. 1995;(18):95-100. X-2, X-3, X-4. [pmid: 8562228].
278 Baker AM, Russell JM, Campbell JK. Variance in treatment compliance and costs by antidepressant class: analysis in an HMO setting. Formulary. 2001;36(3):204-10. X-2, X-6.
279 Baker D, Middleton E, Campbell S. The impact of chronic disease management in primary care on inequality in asthma severity. J Public Health Med. Sep. 2003;25(3):258-60. X-1, X-6, X-7, X-9. [pmid: 14575205].
280 Baker DW, Parker RM, Williams MV, et al. Health literacy and the risk of hospital admission. Journal of General Internal Medicine. Dec. 1998;13(12):791-8. X-2, X-4, X-5. [pmid: 9844076].
281 Baker LK, Denyes MJ. Predictors of self-care in adolescents with cystic fibrosis: a test of Orem's theories of self-care and self-care deficit. J Pediatr Nurs. Feb. 2008;23(1):37-48. X-2. [pmid: 18207046].
282 Bakhai A, Iniguez A, Ferrieres J, et al. Treatment patterns in acute coronary syndrome patients in the United Kingdom undergoing PCI. EuroIntervention. Mar. 2011;6(8):992-6. X-2, X-3, X-4, X-6. [pmid: 21330248].
283 Bakken S, Grullon-Figueboa L, Izquierdo R, et al. Development, validation, and use of English and Spanish versions of the Telemedicine Satisfaction and Usefulness Questionnaire. Journal of the American Medical Informatics Association. Nov-Dec. 2006;13(6):660-7. X-2, X-4, X-6. [pmid: 16929036].
284 Bakker IM, Terluin B, van Marwijk HW, et al. Effectiveness of a Minimal Intervention for Stress-related mental disorders with Sick leave (MISS); study protocol of a cluster randomised controlled trial in general practice [ISRCTN43779641]. BMC Public Health. 2006;6:124. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 16674806].
285 Bakker IM, van Marwijk HW, Terluin B, et al. Training GP's to use a minimal intervention for stress-related mental disorders with sick leave (MISS): Effects on performance: Results of the MISS project; a cluster-randomised controlled trial [ISRCTN43779641]. Patient Educ Couns. Feb. 2010;78(2):206-11. X-3, X-4, X-5, X-6. [pmid: 19647973].
286 Balamurugan A, Ohsfeldt R, Hughes T, et al. Diabetes self-management education program for medicaid recipients: A continuous quality improvement process. The Diabetes Educator. Nov-Dec. 2006;32(6):893-900. X-9. [pmid: 17102156].
287 Balbuena FR, Aranda AB, Figueras A. Self-medication in older urban mexicans : an observational, descriptive, cross-sectional study. Drugs Aging. 2009;26(1):51-60. X-2, X-3, X-5. [pmid: 19102514].
288 Balcazar HG, Byrd TL, Ortiz M, et al. A randomized community intervention to improve hypertension control among Mexican Americans: using the promotoras de salud community outreach model. J Health Care Poor Underserved. 2009;20(4):1079-94. X-4. [pmid: 20168020].
289 Baldwin DM, Williams-Brown S. Uncovering homeless African-American women's knowledge of breast cancer and their use of breast cancer screening services. J Natl Black Nurses Assoc. Jul. 2005;16(1):24-30. X-2, X-4. [pmid: 16255312].
290 Bali RK, Gibbons MC. Exploring the link between populomics and knowledge management: patient-oriented case exemplars. Stud Health Technol Inform. 2010;156:138-49. X-1, X-2. [pmid: 20543349].
291 Balieiro HM, Osugue RK, Rangel SP, et al. Clinical and demographic profile and quality indicators for heart failure in a rural area. Arq Bras Cardiol. Dec. 2009;93(6):637-42. 87. 91. X-2, X-3, X-6. [pmid: 20379645].
292 Ballard DJ, Strogatz DS, Wagner EH, et al. Hypertension control in a rural southern community: medical care process and dropping out. Am J Prev Med. May-Jun. 1988;4(3):133-9. X-2, X-4. [pmid: 3395499].
293 Balsam L, Attia AM, Sharma NP. Achieving KDOQI Guidelines for Hematocrit in HIV-Infected Hemodialysis Patients. Ren Fail. 2009;31(3):189-91. X-6, X-7, X-9. [pmid: 19288322].
294 Banerjee D, Perry M, Tran D, et al. Self-reported Health, Functional Status and Chronic Disease in Community Dwelling Older Adults: Untangling the Role of Demographics. Journal of Community Health. Apr. 2010;35(2):135-41. X-2, X-4. [pmid: 20033835].
295 Banister NA, Jastrow ST, Hodges V, et al. Diabetes self-management training program in a community clinic improves patient outcomes at modest cost. J Am Diet Assoc. May. 2004;104(5):807-10. X-6, X-9. [pmid: 15127069].
296 Banning M. Perceptions of breast health awareness in Black British women. Eur J Oncol Nurs. Apr. 2011;15(2):173-7. X-2, X-3, X-4. [pmid: 20855234].
297 Bansal M, Shrivastava S, Mehrotra R, et al. Time-trends in prevalence and awareness of cardiovascular risk factors in an asymptomatic North Indian urban population. J Assoc Physicians India. Aug. 2009;57:568-73. X-2, X-3, X-6. [pmid: 20209717].
298 Bansil P, Keenan NL, Zlot AI, et al. Health-related information on the Web: results from the HealthStyles Survey, 2002-2003. Prev Chronic Dis. Apr. 2006;3(2):A36. X-2, X-4, X-6. [pmid: 16539777].
299 Bao Y, Fox SA, Escarce JJ. Socioeconomic and racial/ethnic differences in the discussion of cancer screening: “between-” versus “within-” physician differences. Health Serv Res. Jun. 2007;42(3 Pt 1):950-70. X-2. [pmid: 17489898].
300 Baptist AP, Talreja N, Clark NM. Asthma education for older adults: results from the National Asthma Survey. J Asthma. Mar. 2011;48(2):133-8. X-2, X-6. [pmid: 21128881].
301 Baradaran HR, Knill-Jones RP, Wallia S, et al. A controlled trial of the effectiveness of a diabetes education programme in a multi-ethnic community in Glasgow [ISRCTN28317455]. BMC Public Health. 2006;6:134. X-3. [pmid: 16709243].
302 Barbee EL. Healing time: the blues and African-American women. Health Care Women Int. Jan-Feb. 1994;15(1):53-60. X-2, X-4, X-5. [pmid: 8169169].
303 Barbot O, Platt R, Marchese C. Using preprinted rescue medication order forms and health information technology to monitor and improve the quality of care for students with asthma in New York City public schools. J Sch Health. Aug. 2006;76(6):329-32. X-6, X-9. [pmid: 16918865].
304 Barceló A, Cafiero E, de Boer M, et al. Using collaborative learning to improve diabetes care and outcomes: The VIDA project. Primary Care Diabetes. Oct. 2010;4(3):145-53. X-3, X-6. [pmid: 20478753].
305 Barnato AE, Llewellyn-Thomas HA, Peters EM, et al. Comunication and decision making in cancer care: Setting research priorities for decision Support/Patients' decision aids. Medical Decision Making. Sep-Oct. 2007;27(5):626-34. X-1, X- 2, X-4, X-5, X-6. [pmid: 17873249].
306 Barnato AE, Lucas FL, Staiger D, et al. Hospital-level racial disparities in acute myocardial infarction treatment and outcomes. Med Care. Apr. 2005;43(4):308-19. X-2. [pmid: 15778634].
307 Barner JC, Mason HL, Murray MD. Assessment of asthma patients' willingness to pay for and give time to an asthma self-management program. Clin Ther. May. 1999;21(5):878-94. X-2, X-4. [pmid: 10397382].
308 Barnes LP. The illiterate client: strategies in patient teaching. MCN Am J Matern Child Nurs. May-Jun. 1992;17(3):127. X-1, X-2. [pmid: 1625537].
309 Barnhart JM, Cohen O, Kramer HM, et al. Awareness of heart attack symptoms and lifesaving actions among New York City area residents. J Urban Health. Jun. 2005;82(2):207-15. X-2. [pmid: 15888639].
310 Barr B, Leichter SB, Taylor L. Bedside capillary glucose monitoring in the general hospital. Diabetes Care. May-Jun. 1984;7(3):261-4. X-2, X-4, X-5. [pmid: 6734395].
311 Barr JK, Kelvey-Albert M, Curry M, et al. Reducing disparities in utilization of mamography: reaching dually eligible women in Connecticut. J Health Hum Serv Adm. Winter. 2003;26(3):298-335. X-9. [pmid: 15704636].
312 Barratt AL, Cockburn J, Redman S, et al. Mammographic screening: results from the 1996 National Breast Health Survey. Med J Aust. Nov. 17. 1997;167(10):521-4. X-2, X-3, X-4. [pmid: 9397038].
313 Barros AJ, Matijasevich A, Santos IS, et al. Neonatal mortality: description and effect of hospital of birth after risk adjustment. Rev Saude Publica. Feb. 2008;42(1):1-9. X-2, X-3, X-6. [pmid: 17992353].
314 Barry CD, Lange B, King B. Women alive: gathering underserved women upstream for a comprehensive breast health program. Southern Online Journal of Nursing Research. 2011;11(1):13p. X-4.
315 Barta L, Molnar M, Madacsy L, et al. The position of the diabetic child in society. Acta Paediatr Hung. 1983;24(1):79-83. X-2, X-3, X-4. [pmid: 6613578].
316 Bartholomew LK, Gold RS, Parcel GS, et al. Watch, Discover, Think, and Act: Evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. Patient Education and Counseling. Feb. 2000;39(2-3):269-80. X-1, X-4, X-6, X-7, X-9. [pmid: 11040726].
317 Bartholomew LK, Shegog R, Parcel GS, et al. Watch, Discover, Think, and Act: A model for patient education program development. Patient Education and Counseling. Feb. 2000;39(2-3):253-68. X-1, X-2, X-4. [pmid: 11040725].
318 Bartholomew LK, Sockrider M, Abramson SL, et al. Partners in school asthma management: evaluation of a self-management program for children with asthma. J Sch Health. Aug. 2006;76(6):283-90. X-6, X-7, X-9. [pmid: 16918856].
319 Bartle-Haring S. Living in the context of poverty and trajectories of breast cancer worry, knowledge, and perceived risk after a breast cancer risk education session. Womens Health Issues. Nov-Dec. 2010;20(6):406-13. X-6, X-7, X-9. [pmid: 20688528].
320 Bartle-Haring S, Toviessi P, Katafiasz H. Predicting the use of individualized risk assessment for breast cancer. Women's Health Issues. Mar-Apr. 2008;18(2):100-9. X-2. [pmid: 18319147].
321 Bartter T, Pratter MR. Asthma: better outcome at lower cost? The role of the expert in the care system. Chest. Dec. 1996;110(6):1589-96. X-1, X-2, X-4, X-6. [pmid: 8989082].
322 Baskin LB, Wians FH Jr., Elder F. Preconception and prenatal screening for cystic fibrosis. MLO Med Lab Obs. Oct. 2002;34(10):8-12. quiz 4, 6. X-1, X-6, X-7, X-9. [pmid: 12385171].
323 Battacharyya M. Coronary heart disease prevention in Kolkata, India. Journal of the Royal Society for the Promotion of Health. 2003;123(4):222-8. X-2, X-3, X-4, X-6. [pmid: 14669497].
324 Battleman DS, Callahan MA, Silber S, et al. Dedicated asthma center improves the quality of care and resource utilization for pediatric asthma: a multicenter study. Acad Emerg Med. Jul. 2001;8(7):709-15. X-2, X-3, X-4, X-6. [pmid: 11435185].
325 Batts ML, Gary TL, Huss K, et al. Patient priorities and needs for diabetes care among urban African American adults. Diabetes Educ. May-Jun. 2001;27(3):405-12. X-9, X-10. [pmid: 11912801].
326 Batty GD, Lewars H, Emslie C, et al. Internationally recognized guidelines for ‘sensible’ alcohol consumption: is exceeding them actually detrimental to health and social circumstances? Evidence from a population-based cohort study. J Public Health (Oxf). Sep. 2009;31(3):360-5. X-2, X-3, X-5, X-6. [pmid: 19574275].
327 Baty BJ, Kinney AY, Ellis SM. Developing culturally sensitive cancer genetics communication aids for African Americans. Am J Med Genet A. Apr. 15. 2003;118A(2):146-55. X-2, X-4. [pmid: 12655495].
328 Bauer AM, Chen CN, Alegria M. English Language Proficiency and Mental Health Service Use Among Latino and Asian Americans With Mental Disorders. Medical Care. Dec. 2010;48(12):1097-104. X-2, X-4. [pmid: 21063226].
329 Baumann LC, Opio CK, Otim M, et al. Self-care beliefs and behaviors in Ugandan adults with type 2 diabetes. Diabetes Educ. Mar-Apr. 2010;36(2):293-300. X-2, X-3, X-6. [pmid: 20067944].
330 Baumeister H, Morar V. The impact of clinical significance criteria on subthreshold depression prevalence rates. Acta Psychiatr Scand. Dec. 2008;118(6):443-50. X-2, X-3, X-5, X-6. [pmid: 19032704].
331 Baxter JD, Samnaliev M, Clark RE. The quality of asthma care among adults with substance-related disorders and adults with mental illness. Psychiatric Services. Jan. 2009;60(1):43-9. X-2, X-6. [pmid: 19114569].
332 Bayliss EA, Ellis JL, Steiner JF. Barriers to self-management and quality-of-life outcomes in seniors with multimorbidities. Ann Fam Med. Sep-Oct. 2007;5(5):395-402. X-2, X-6. [pmid: 17893380].
333 Baylor C, Yorkston K, Bamer A, et al. Variables Associated With Communicative Participation in People With Multiple Sclerosis: A Regression Analysis. American Journal of Speech-Language Pathology. May. 2010;19(2):143-53. X-2, X-5, X-6. [pmid: 19948761].
334 Bazalo G, Weiss R, Clark N, et al. Effect of drug therapy on HEDIS measurements of HbA1c control in diabetes patients. Manag Care. Feb. 2009;18(2):40-4. X-2, X-6. [pmid: 19264026].
335 Bazargan M, Ani C, Bazargan-Hejazi S, et al. Colorectal cancer screening among underserved minority population: discrepancy between physicians' recommended, scheduled, and completed tests. Patient Educ Couns. Aug. 2009;76(2):240-7. X-2. [pmid: 19150198].
336 Bazargan M, Ani CO, Hindman DW, et al. Correlates of complementary and alternative medicine utilization in depressed, underserved african american and Hispanic patients in primary care settings. J Altern Complement Med. Jun. 2008;14(5):537-44. X-2. [pmid: 18537468].
337 Bazargan-Hejazi S, Bazargan M, Hardin E, et al. Alcohol use and adherence to prescribed therapy among under-served Latino and African-American patients using emergency department services. Ethn Dis. Spring. 2005;15(2):267-75. X-2, X-5. [pmid: 15825973].
338 Beach MC, Cooper LA, Robinson KA, et al. Strategies for improving minority healthcare quality. Evid Rep Technol Assess (Summ). Jan. 2004;(90):1-8. X-1, X-2, X-4, X-5. [pmid: 15164678].
339 Beach SRH, Katz J, Kim S, et al. Prospective effects of marital satisfaction on depressive symptoms in established marriages: a dyadic model. Journal of Social & Personal Relationships. 2003;20(3):355-71. X-2, X-6.
340 Beacom AM, Newman SJ. Communicating Health Information to Disadvantaged Populations. Family & Community Health. Apr-Jun. 2010;33(2):152-62. X-1, X-2, X-4. [pmid: 20216358].
341 Bean D, Cundy T, Petrie KJ. Ethnic differences in illness perceptions, self-efficacy and diabetes self-care. Psychology & Health. 2007;22(7):787-811. X-2.
342 Beanlands H, Horsburgh ME, Fox S, et al. Caregiving by family and friends of adults receiving dialysis. Nephrol Nurs J. Nov-Dec. 2005;32(6):621-31. X-2, X-4, X-6. [pmid: 16425810].
343 Beard E, Clark M, Hurel S, et al. Do people with diabetes understand their clinical marker of long-term glycemic control (HbA1c levels) and does this predict diabetes self-care behaviours and HbA1c?. Patient Educ Couns. Aug. 2010;80(2):227-32. X-2, X-3. [pmid: 20036098].
344 Beatty WW. Cognitive dysfunction in multiple sclerosis: natural history and impact on productive living. Italian Journal of Neurological Sciences. 1998;19(6):S381-S7. X-1, X-2, X-4, X-5, X-6.
345 Beausoleil JL, Zalneraitis EL, Gregorio DI, et al. The influence of education and experience on ethical attitudes in neonatal intensive care. Med Decis Making. Oct-Dec. 1994;14(4):403-8. X-2, X-3, X-4, X-5, X-6. [pmid: 7808215].
346 Beaver K, Luker K. Readability of patient information booklets for women with breast cancer. Patient Educ Couns. Jun. 1997;31(2):95-102. X-2, X-3, X-4. [pmid: 9216350].
347 Beaver K, Witham G. Information needs of the informal carers of women treated for breast cancer. Eur J Oncol Nurs. Feb. 2007;11(1):16-25. X-2, X-3, X-6. [pmid: 16781890].
348 Becker C, Whetstone L, Glascoff M, et al. Evaluation of the reliability and validity of an adult version of the Salutogenic Wellness Promotion Scale (SWPS). American Journal of Health Education. 2008;39(6):322-8. X-2, X-3, X-4, X-5, X-6.
349 Becker DM, Gomez EB, Kaiser DL, et al. Improving preventive care at a medical clinic: how can the patient help?. Am J Prev Med. Nov-Dec. 1989;5(6):353-9. X-6. [pmid: 2597431].
350 Becker DM, Yanek LR, Johnson WR Jr., et al. Impact of a community-based multiple risk factor intervention on cardiovascular risk in black families with a history of premature coronary disease. Circulation. Mar. 15. 2005;111(10):1298-304. X-7, X-9. [pmid: 15769772].
351 Becker H, Bester M, Reyneke N, et al. Nutrition related knowledge and practices of hypertensive adults attending hypertensive clinics at Day Hospitals in the Cape Metropole. Curationis. May. 2004;27(2):63-9. X-2, X-3, X-6. [pmid: 15974021].
352 Beckham S, Bradley S, Washburn A, et al. Diabetes management: utilizing community health workers in a Hawaiian/Samoan population. J Health Care Poor Underserved. May. 2008;19(2):416-27. X-9. [pmid: 18469413].
353 Beckie TM, Beckstead JW. Predicting cardiac rehabilitation attendance in a gender-tailored randomized clinical trial. J Cardiopulm Rehabil Prev. May-Jun. 2010;30(3):147-56. X-9. [pmid: 20216324].
354 Beeber LS, Holditch-Davis D, Belyea MJ, et al. In-home intervention for depressive symptoms with low-income mothers of infants and toddlers in the United States. Health Care Women Int. Jun-Jul. 2004;25(6):561-80. X-4. [pmid: 15354622].
355 Beets MW, Mitchell E. Effects of yoga on stress, depression, and health-related quality of life in a nonclinical, bi-ethnic sample of adolescents: a pilot study. Hispanic Health Care International. 2010;8(1):47-53. X-4, X-5, X-7, X-9, X-10.
356 Beisecker AE, Hayes J, Ashworth JK, et al. Providing information about breast cancer via public forums. Cancer Detect Prev. 1997;21(4):370-9. X-2, X-4, X-6. [pmid: 9232329].
357 Bell JA, Patel B, Malasanos T. Knowledge improvement with web-based diabetes education program: brainfood. Diabetes Technol Ther. Aug. 2006;8(4):444-8. X-2, X-10. [pmid: 16939369].
358 Bell ME, Goodman LA, Dutton MA. The dynamics of staying and leaving: implications for battered women's emotional well-being and experiences of violence at the end of a year. Journal of Family Violence. 2007;22(6):413-28. X-2, X-5.
359 Bell PD, Hudson S. Equity in the diagnosis of chest pain: race and gender. Am J Health Behav. Jan-Feb. 2001;25(1):60-71. X-2, X-4. [pmid: 11289730].
360 Bell RA, Andrews JS, Arcury TA, et al. Depressive symptoms and diabetes self-management among rural older adults. Am J Health Behav. Jan-Feb. 2010;34(1):36-44. X-6, X-7, X-9. [pmid: 19663750].
361 Bell RA, Arcury TA, Stafford JM, et al. Ethnic and sex differences in ownership of preventive health equipment among rural older adults with diabetes. J Rural Health. Autumn. 2007;23(4):332-8. X-2. [pmid: 17868240].
362 Bell RA, Camacho F, Duren-Winfield VT, et al. Improving diabetes care among low-income North Carolinians: Project IDEAL. N C Med J. Mar-Apr. 2005;66(2):96-102. X-6, X-9. [pmid: 15952458].
363 Bell RA, Camacho F, Goonan K, et al. Quality of diabetes care among low-income patients in North Carolina. Am J Prev Med. Aug. 2001;21(2):124-31. X-2, X-4. [pmid: 11457632].
364 Bell RA, Paterniti DA, Azari R, et al. Encouraging patients with depressive symptoms to seek care: a mixed methods approach to message development. Patient Educ Couns. Feb. 2010;78(2):198-205. X-2. [pmid: 19674862].
365 Bell RA, Smith SL, Arcury TA, et al. Prevalence and correlates of depressive symptoms among rural older African Americans, Native Americans, and whites with diabetes. Diabetes Care. Apr. 2005;28(4):823-9. X-2. [pmid: 15793180].
366 Bell RA, Stafford JM, Arcury TA, et al. Complementary and Alternative Medicine Use and Diabetes Self-Management Among Rural Older Adults. Complementary Health Practice Review. Apr. 2006;11(2):95-106. X-2. [pmid: 19756166].
367 Bell RA, Suerken CK, Grzywacz JG, et al. CAM use among older adults age 65 or older with hypertension in the United States: general use and disease treatment. J Altern Complement Med. Nov. 2006;12(9):903-9. X-2, X-6. [pmid: 17109582].
368 Bell RA, Suerken CK, Grzywacz JG, et al. Complementary and alternative medicine use among adults with diabetes in the United States. Altern Ther Health Med. Sep-Oct. 2006;12(5):16-22. X-2, X-6. [pmid: 17017751].
369 Bell TS, Branston LK, Newcombe RG, et al. Interventions to improve uptake of breast screening in inner city Cardiff general practices with ethnic minority lists. Ethn Health. Nov. 1999;4(4):277-84. X-3. [pmid: 10705564].
370 Belle SH, Burgio L, Burns R, et al. Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial. Ann Intern Med. Nov. 21. 2006;145(10):727-38. X-7. [pmid: 17116917].
371 Belloch A, Perpina M, Pascual LM, et al. The Revised Asthma Problem Behavior Checklist: adaptation for use in Spanish asthmatic patients. J Asthma. 1997;34(1):31-41. X-2, X-4. [pmid: 9033438].
372 Benatar D, Bondmass M, Ghitelman J, et al. Outcomes of chronic heart failure. Arch Intern Med. Feb. 10. 2003;163(3):347-52. X-6, X-7. [pmid: 12578516].
373 Benavides-Vaello S, Brown SA. Evaluating guiding questions for an ethnographic study of Mexican American women with diabetes. Hispanic Health Care International. 2010;8(2):77-84. X-2, X-4.
374 Benavides-Vaello S, Garcia AA, Brown SA, et al. Using focus groups to plan and evaluate diabetes self-management interventions for Mexican Americans. Diabetes Educ. Mar-Apr. 42. 2004;30(2):238-4. 47. 50. passim. X-6, X-7, X-9. [pmid: 15095514].
375 Bender BG, Ellison MC, Gleason M, et al. Minimizing attrition in a long-term clinical trial of pediatric asthma. Ann Allergy Asthma Immunol. Aug. 2003;91(2):168-76. X-2. [pmid: 12952111].
376 Bender DE, McCann MF. The influence of maternal intergenerational education on health behaviors of women in peri-urban Bolivia. Soc Sci Med. May. 2000;50(9):1189-96. X-2, X-3, X-4, X-6. [pmid: 10728840].
377 Benjamin EM, Schneider MS, Hinchey KT. Implementing practice guidelines for diabetes care using problem-based learning. A prospective controlled trial using firm systems. Diabetes Care. Oct. 1999;22(10):1672-8. X-6, X-9. [pmid: 10526733].
378 Benkert R, Buchholz S, Poole M. Hypertension outcomes in an urban nurse-managed center. J Am Acad Nurse Pract. Feb. 2001;13(2):84-9. X-2, X-4. [pmid: 11930402].
379 Bennett H, Laird K, Margolius D, et al. The effectiveness of health coaching, home blood pressure monitoring, and home-titration in controlling hypertension among low-income patients: protocol for a randomized controlled trial. BMC Public Health. 2009;9:456. X-1. [pmid: 20003300].
380 Bennett IM, Marcus SC, Palmer SC, et al. Pregnancy-related discontinuation of antidepressants and depression care visits among Medicaid recipients. Psychiatr Serv. Apr. 2010;61(4):386-91. X-2. [pmid: 20360278].
381 Bennett L. The next steps. BMJ. Mar. 29. 2003;326(7391):S103. X-13. [pmid: 12663429].
382 Bennett SE, Lawrence RS, Fleischmann KH, et al. Profile of women practicing breast self-examination. JAMA. Jan. 28. 1983;249(4):488-91. X-2, X-4. [pmid: 6848849].
383 Benoit SR, Ji M, Fleming R, et al. Predictors of dropouts from a San Diego diabetes program: a case control study. Prev Chronic Dis. Oct. 2004;1(4):A10. X-2. [pmid: 15670442].
384 Benton J. Making schools safer and healthier for lesbian, gay, bisexual, and questioning students. The Journal of School Nursing. Oct. 2003;19(5):251-9. X-1, X-2, X-4, X-5. [pmid: 14498773].
385 Berardi D, Menchetti M, Cevenini N, et al. Increased recognition of depression in primary care. Comparison between primary-care physician and ICD-10 diagnosis of depression. Psychother Psychosom. 2005;74(4):225-30. X-2, X-3, X-6. [pmid: 15947512].
386 Berg GD, Wadhwa S. Diabetes disease management results in Hispanic Medicaid patients. J Health Care Poor Underserved. May. 2009;20(2):432-43. X-9. [pmid: 19395840].
387 Bergland JE, Heuer L, Lausch C. Diabetes lay educator case study: one woman's experience working with the Hispanic migrant and seasonal farmworkers. J Cult Divers. Fall. 2006;13(3):152-7. X-1, X-2, X-4. [pmid: 16989252].
388 Bergman J, Chi AC, Litwin MS. Quality of end-of-life care in low-income, uninsured men dying of prostate cancer. Cancer. May. 2010;116(9):2126-31. X-2, X-4, X-5. [pmid: 20198706].
389 Berikai P, Meyer PM, Kazlauskaite R, et al. Gain in patients' knowledge of diabetes management targets is associated with better glycemic control. Diabetes Care. Jun. 2007;30(6):1587-9. X-6, X-9. [pmid: 17372160].
390 Berlie HD, Herman WH, Brown MB, et al. Quality of diabetes care in Arab Americans. Diabetes Res Clin Pract. Feb. 2008;79(2):249-55. X-2. [pmid: 17949846].
391 Berlin I, Sachon CI, Grimaldi A. Identification of factors associated with impaired hypoglycaemia awareness in patients with type 1 and type 2 diabetes mellitus. Diabetes Metab. Jun. 2005;31(3 Pt 1):246-51. X-2, X-6. [pmid: 16142015].
392 Berlin LJ, Brooksgunn J, Spiker D, et al. EXAMINING OBSERVATIONAL MEASURES OF EMOTIONAL SUPPORT AND COGNITIVE STIMULATION IN BLACK-AND-WHITE MOTHERS OF PRESCHOOLERS. Journal of Family Issues. Sep. 1995;16(5):664-86. X-2, X-5.
393 Bermejo I, Kriston L, Berger M, et al. Patients' language proficiency and inpatient depression treatment in Baden-Württemberg (South Germany). Psychiatric Services. Apr. 2009;60(4):545-8. X-2, X-3. [pmid: 19339333].
394 Bernal H. Self-management of diabetes in a Puerto Rican population. Public Health Nurs. Mar. 1986;3(1):38-47. X-6, X-7, X-9. [pmid: 3515337].
395 Bernal H, Wooley S, Schensul JJ. The challenge of using Likert-type scales with low-literate ethnic populations. Nurs Res. May-Jun. 1997;46(3):179-81. X-6, X-7, X-9. [pmid: 9176508].
396 Bernal H, Woolley S, Schensul JJ, et al. Correlates of self-efficacy in diabetes self-care among Hispanic adults with diabetes. Diabetes Educ. Jul-Aug. 2000;26(4):673-80. X-2, X-4. [pmid: 11212851].
397 Bernhardt BA, Geller G, Strauss M, et al. Toward a model informed consent process for BRCA1 testing: a qualitative assessment of women's attitudes. J Genet Couns. Jun. 1997;6(2):207-22. X-2, X-4, X-6. [pmid: 11656642].
398 Berra K, Ma J, Klieman L, et al. Implementing cardiac risk-factor case management: lessons learned in a county health system. Crit Pathw Cardiol. Dec. 2007;6(4):173-9. X-1, X-6, X-9. [pmid: 18091408].
399 Berry J, Caplan L, Davis S, et al. A black-white comparison of the quality of stage-specific colon cancer treatment. Cancer. Feb. 1. 2010;116(3):713-22. X-2. [pmid: 19950126].
400 Bertolotti G, Carone M, Viaggi S, et al. Reliability of a questionnaire for evaluating the understanding of asthma. Monaldi Arch Chest Dis. Feb. 2001;56(1):11-6. X-2, X-4, X-6. [pmid: 11407201].
401 Bertorelli AM. Nutrition counseling: meeting the needs of ethnic clients with diabetes. Diabetes Educ. Jul-Aug. 1990;16(4):285-9. X-1, X-2, X-4. [pmid: 2357918].
402 Bertron P, Barnard ND, Mills M. Racial bias in federal nutrition policy, Part II: Weak guidelines take a disproportionate toll. J Natl Med Assoc. Apr. 1999;91(4):201-8. X-1, X-2, X-4, X-5. [pmid: 10333669].
403 Berz JP, Johnston K, Backus B, et al. The influence of black race on treatment and mortality for early-stage breast cancer. Med Care. Sep. 2009;47(9):986-92. X-2. [pmid: 19648837].
404 Betancourt JR, Green AR, Carrillo JE, et al. Defining cultural competence: A practical framework for addressing racial/ethnic disparities in health and health care. Public Health Reports. Jul-Aug. 2003;118(4):293-302. X-1, X-2, X-3, X-4, X-5. [pmid: 12815076].
405 Beune EJ, Haafkens JA, Agyemang C, et al. How Ghanaian, African-Surinamese and Dutch patients perceive and manage antihypertensive drug treatment: a qualitative study. J Hypertens. Apr. 2008;26(4):648-56. X-2, X-3, X-4. [pmid: 18327072].
406 Beune EJAJ, Haafkens JA, Bindels PJE. Barriers and enablers in the implementation of a provider-based intervention to stimulate culturally appropriate hypertension education. Patient Education and Counseling. Jan. 2011;82(1):74-80. X-2, X-3, X-6. [pmid: 20303232].
407 Bhagat K, Mazayi-Mupanemunda M. Compliance with medication in patients with heart failure in Zimbabwe. East Afr Med J. Jan. 2001;78(1):45-8. X-2, X-3, X-4, X-6. [pmid: 11320766].
408 Bhalla R, Yongue BG, Currie BP, et al. Improving primary percutaneous coronary intervention performance in an urban minority population using a quality improvement approach. Am J Med Qual. Sep-Oct. 2010;25(5):370-7. X-9, X-11. [pmid: 20484661].
409 Bhat AA, DeWalt DA, Zimmer CR, et al. The role of helplessness, outcome expectation for exercise and literacy in predicting disability and symptoms in older adults with arthritis. Patient Education and Counseling. Oct. 2010;81(1):73-8. X-2, X-5. [pmid: 20060257].
410 Bhatt DL, Roe MT, Peterson ED, et al. Utilization of early invasive management strategies for high-risk patients with non-ST-segment elevation acute coronary syndromes: results from the CRUSADE Quality Improvement Initiative. JAMA. Nov. 3. 2004;292(17):2096-104. X-6, X-7, X-9. [pmid: 15523070].
411 Bhattacharya N, Biswas R, Das MK, et al. A study of compliance status of diabetes mellitus patients. Indian J Public Health. Jan-Mar. 2005;49(1):34-5. X-2, X-3, X-6. [pmid: 15989161].
412 Bhutta ZA, Soofi S, Cousens S, et al. Improvement of perinatal and newborn care in rural Pakistan through community-based strategies: a cluster-randomised effectiveness trial. Lancet. Jan. 29. 2011;377(9763):403-12. X-3, X-5, X-6. [pmid: 21239052].
413 413. Bickell NA, LePar F, Wang JJ, et al. Lost opportunities: physicians' reasons and disparities in breast cancer treatment. J Clin Oncol. Jun. 20. 2007;25(18):2516-21. X-2. [pmid: 17577028].
414 Bickmore TW, Mitchell SE, Jack BW, et al. Response to a relational agent by hospital patients with depressive symptoms. Interacting with Computers. Jul. 2010;22(4):289-98. X-2, X-6. [pmid: 20628581].
415 Bielawska-Batorowicz E, Kossakowska-Petrycka K. Depressive mood in men after the birth of their offspring in relation to a partner's depression, social support, fathers' personality and prenatal expectations. Journal of Reproductive & Infant Psychology. 2006;24(1):21-9. X-2, X-6.
416 Bigby JA, Caine VA, Rice VM. Plenary session 2: Improving quality. Making a difference at the individual, business, and community levels. Ethn Dis. Spring. 2005;15(2 Suppl 2):S68-73. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15822843].
417 Biksey T, Zickmund S, Wu F. Disparities in risk communication: a pilot study of asthmatic children, their parents, and home environments. J Natl Med Assoc. May. 2011;103(5):388-91. X-2, X-4. [pmid: 21809787].
418 Bildt C, Alfredsson L, Michelsen H, et al. Occupational and nonoccupational risk indicators for incident and chronic low back pain in a sample of the Swedish general population during a 4-year period: an influence of depression?. International Journal of Behavioral Medicine. 2000;7(4):372-92. X-2, X-3, X-5, X-6.
419 Bird CE, Fremont AM, Bierman AS, et al. Does quality of care for cardiovascular disease and diabetes differ by gender for enrollees in managed care plans?. Womens Health Issues. May-Jun. 2007;17(3):131-8. X-2. [pmid: 17434752].
420 Bird JA, McPhee SJ, Ha NT, et al. Opening pathways to cancer screening for Vietnamese-American women: lay health workers hold a key. Prev Med. Nov-Dec. 1998;27(6):821-9. X-9. [pmid: 9922064].
421 421. Bird SM, Wiles JL, Okalik L, et al. Living with diabetes on Baffin Island: Inuit storytellers share their experiences. Can J Public Health. Jan-Feb. 2008;99(1):17-21. X-2, X-3, X-4. [pmid: 18435384].
422 Bishop C, Earp JA, Eng E, et al. Implementing a natural helper lay health advisor program: lessons learned from unplanned events. Health Promotion Practice. 2002;3(2):233-44. X-2, X-4, X-6.
423 Blackwell AD, Mellinger-Birdsong AK, Wu M, et al. Asthma management practices among children in Georgia. J Public Health Manag Pract. Jul-Aug. 2006;12(4):395-401. X-2, X-6. [pmid: 16775538].
424 Blaha MJ, Kusz KL, Drake W, et al. Hypertension prevalence awareness, treatment and control in North Nashville. Tenn Med. Apr. 2006;99(4):35-7. X-2. [pmid: 16704130].
425 Blais L, Beauchesne MF, Levesque S. Socioeconomic status and medication prescription patterns in pediatric asthma in Canada. J Adolesc Health. May. 2006;38(5):607 e9-16. X-2, X-3. [pmid: 16635775].
426 Blake SM, Kiely M, Gard CC, et al. Pregnancy intentions and happiness among pregnant black women at high risk for adverse infant health outcomes. Perspect Sex Reprod Health. Dec. 2007;39(4):194-205. X-2. [pmid: 18093036].
427 Blanc PD, Trupin L, Earnest G, et al. Alternative therapies among adults with a reported diagnosis of asthma or rhinosinusitis : data from a population-based survey. Chest. Nov. 2001;120(5):1461-7. X-2, X-4, X-6. [pmid: 11713120].
428 Blanch DC, Rudd RE, Wright E, et al. Predictors of refusal during a multi-step recruitment process for a randomized controlled trial of arthritis education. Patient Education and Counseling. Nov. 2008;73(2):280-5. X-2, X-5, X-6. [pmid: 18715740].
429 Blanchard MA, Rose LE, Taylor J, et al. Using a focus group to design a diabetes education program for an African American population. Diabetes Educ. Nov-Dec. 1999;25(6):917-24. X-2, X-4. [pmid: 10711073].
430 Blanson Henkemans OA, Rogers WA, Fisk AD, et al. Usability of an adaptive computer assistant that improves self-care and health literacy of older adults. Methods Inf Med. 2008;47(1):82-8. X-4. [pmid: 18213433].
431 Blecker S, Zhang Y, Ford DE, et al. Quality of care for heart failure among disabled Medicaid recipients with and without severe mental illness. General Hospital Psychiatry. May-Jun. 2010;32(3):255-61. X-2, X-6. [pmid: 20430228].
432 Blixen CE, Hammel JP, Murphy D, et al. Feasibility of a nurse-run asthma education program for urban African-Americans: a pilot study. J Asthma. Feb. 2001;38(1):23-32. X-4. [pmid: 11256551].
433 Bloch JR, Dawley K, Suplee PD. Application of the Kessner and Kotelchuck prenatal care adequacy indices in a preterm birth population. Public Health Nursing. Sep-Oct. 2009;26(5):449-59. X-2. [pmid: 19706128].
434 Blomkalns AL, Chen AY, Hochman JS, et al. Gender disparities in the diagnosis and treatment of non-ST-segment elevation acute coronary syndromes: large-scale observations from the CRUSADE (Can Rapid Risk Stratification of Unstable Angina Patients Suppress Adverse Outcomes With Early Implementation of the American College of Cardiology/American Heart Association Guidelines) National Quality Improvement Initiative. J Am Coll Cardiol. Mar. 15. 2005;45(6):832-7. X-2. [pmid: 15766815].
435 Blonk RWB, Brenninkmeijer V, Lagerveld SE, et al. Return to work: a comparison of two cognitive behavioural interventions in cases of work-related psychological complaints among the self-employed. Work & Stress. 2006;20(2):129-44. X-3, X-6.
436 Bloom JR, Stewart SL, D'Onofrio CN, et al. Addressing the needs of young breast cancer survivors at the 5 year milestone: can a short-term, low intensity intervention produce change?. J Cancer Surviv. Sep. 2008;2(3):190-204. X-6, X-7, X-9. [pmid: 18670888].
437 Bloom SS, Tsui AO, Plotkin M, et al. What husbands in northern India know about reproductive health: correlates of knowledge about pregnancy and maternal and sexual health. J Biosoc Sci. Apr. 2000;32(2):237-51. X-2, X-3, X-4, X-6. [pmid: 10765613].
438 Bloomberg GR, Banister C, Sterkel R, et al. Socioeconomic, family, and pediatric practice factors that affect level of asthma control. Pediatrics. Mar. 2009;123(3):829-35. X-7, X-9. [pmid: 19255010].
439 Bloomfield S, Calder JE, Chisholm V, et al. A project in diabetes education for children. Diabet Med. Feb. 1990;7(2):137-42. X-6, X-9. [pmid: 2137754].
440 Blumenthal DS, Smith SA, Majett CD, et al. A trial of 3 interventions to promote colorectal cancer screening in African Americans. Cancer. Feb. 15. 2010;116(4):922-9. X-9. [pmid: 20052732].
441 Blustein J, Valentine M, Mead H, et al. Race/Ethnicity and patient confidence to self-manage cardiovascular disease. Med Care. Sep. 2008;46(9):924-9. X-6, X-7, X-9. [pmid: 18725846].
442 Bluthenthal RN, Jones L, Fackler-Lowrie N, et al. Witness for Wellness: preliminary findings from a community-academic participatory research mental health initiative. Ethn Dis. Winter. 2006;16(1 Suppl 1):S18-34. X-9. [pmid: 16681126].
443 Bobay KL, Jerofke TA, Weiss ME, et al. Age-Related Differences in Perception of Quality of Discharge Teaching and Readiness for Hospital Discharge. Geriatric Nursing. May-Jun. 2010;31(3):178-87. X-2, X-5, X-6. [pmid: 20525522].
444 Bodurtha J, Quillin JM, Tracy KA, et al. Mammography screening after risk-tailored messages: the women improving screening through education and risk assessment (WISER) randomized, controlled trial. J Womens Health (Larchmt). Jan-Feb. 2009;18(1):41-7. X-6, X-9. [pmid: 19105686].
445 Boegner C, Fontbonne A, Gras Vidal MF, et al. Evaluation of a structured educational programme for type 2 diabetes patients seen in private practice. Diabetes Metab. Jun. 2008;34(3):243-9. X-2, X-3, X-6. [pmid: 18396086].
446 Boehmer U, Case P. Sexual minority women's interactions with breast cancer providers. Women Health. 2006;44(2):41-58. X-2, X-4. [pmid: 17255058].
447 Boersma K, Lindblom K. Stability and change in burnout profiles over time: a prospective study in the working population. Work & Stress. 2009;23(3):264-83. X-2, X-3, X-5, X-6.
448 Bogatz S, Colasanto R, Sweeney L. Defining the impact of high patient/staff ratios on dialysis social workers. Nephrol News Issues. Jan. 2005;19(2):55-60. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15717576].
449 Bohn J, Burrowes N, Pinkston L, et al. Diabetes care for Hispanic patients: honoring culture while promoting glycemic control. Adv Nurse Pract. Jan. 2010;18(1):46-8. X-1, X-6, X-7, X-9. [pmid: 20128205].
450 Boltri JM, Davis-Smith YM, Zayas LE, et al. Developing a church-based diabetes prevention program with African Americans: focus group findings. Diabetes Educ. Nov-Dec. 2006;32(6):901-9. X-2, X-4. [pmid: 17102157].
451 Bondmass MD. Improving outcomes for African Americans with chronic heart failure: a comparison of two home care management delivery methods. Home Health Care Management & Practice. 2007;20(1):8-20. X-9.
452 Bone LR, Mamon J, Levine DM, et al. Emergency department detection and follow-up of high blood pressure: use and effectiveness of community health workers. Am J Emerg Med. Jan. 1989;7(1):16-20. X-6, X-9. [pmid: 2914043].
453 Bonner S, Zimmerman BJ, Evans D, et al. An individualized intervention to improve asthma management among urban Latino and African-American families. J Asthma. Apr. 2002;39(2):167-79. X-9. [pmid: 11990232].
454 Bonomi AE, Boudreau DM, Fishman PA, et al. Quality of life valuations of mammography screening. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. Jun. 2008;17(5):801-14. X-2, X-6. [pmid: 18491217].
455 Boon HS, Olatunde F, Zick SM. Trends in complementary/alternative medicine use by breast cancer survivors: comparing survey data from 1998 and 2005. BMC Womens Health. 2007;7:4. X-2, X-4, X-6. [pmid: 17397542].
456 Boren SA, Wakefield BJ, Dohrmann M. Chronic heart failure consumer information: an exploratory study. AMIA Annu Symp Proc. 2008:884. X-2, X-4. [pmid: 18998896].
457 Borges WJ, Ostwald SK. Improving foot self-care behaviors with Pies Sanos. West J Nurs Res. Apr. 2008;30(3):325-41. discussion 42-9. X-7, X-9. [pmid: 17607055].
458 Borovoy A, Hine J. Managing the unmanageable: elderly Russian Jewish emigres and the biomedical culture of diabetes care. Med Anthropol Q. Mar. 2008;22(1):1-26. X-1, X-2, X-4, X-6. [pmid: 18610811].
459 Borras M, Sorolla C, Carrera D, et al. Patients with learning difficulties: outcome on peritoneal dialysis. Adv Perit Dial. 2006;22:116-8. X-2, X-9, X-10. [pmid: 16983953].
460 Borrayo EA. Where's Maria? A video to increase awareness about breast cancer and mammography screening among low-literacy Latinas. Prev Med. Jul. 2004;39(1):99-110. X-1, X-7, X-9. [pmid: 15207991].
461 Borrayo EA. Where's Maria? - A video to increase awareness about breast cancer and mammography screening among low-literacy Latinas. Preventive Medicine. Jul. 2004;39(1):99-110. X-14. [pmid: 15207991].
462 Borrayo EA. Using a community readiness model to help overcome breast health disparities among U.S. Latinas. Substance Use & Misuse. 2007;42(4):603-19. X-1, X-2, X-4. [pmid: 17558953].
463 Boryc K, Anastario MP, Dann G, et al. A Needs Assessment of Clients With HIV in a Home-Based Care Program in Guyana. Public Health Nursing. 2010;27(6):482-91. X-2, X-3, X-4, X-5, X-6. [pmid: 21087301].
464 Boscoe FP, Schrag D, Chen K, et al. Building capacity to assess cancer care in the Medicaid population in New York State. Health Services Research. Jun. 2011;46(3):805-20. X-1, X-2, X-6. [pmid: 21158856].
465 Bosworth HB, Olsen MK, Gentry P, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Education and Counseling. Apr. 2005;57(1):5-14. X-6, X-9. [pmid: 15797147].
466 Bosworth HB, Olsen MK, Grubber JM, et al. Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. Nov. 17. 2009;151(10):687-95. X-6, X-9. [pmid: 19920269].
467 Bosworth HB, Olsen MK, Neary A, et al. Take Control of Your Blood pressure (TCYB) study: A multifactorial tailored behavioral and educational intervention for achieving blood pressure control. Patient Education and Counseling. Mar. 2008;70(3):338-47. X-6, X-9. [pmid: 18164894].
468 Bosworth HB, Olsen MK, Oddone EZ. Improving blood pressure control by tailored feedback to patients and clinicians. Am Heart J. May. 2005;149(5):795-803. X-1, X-6, X-7, X-9. [pmid: 15894959].
469 Bosworth HB, Powers BJ, Olsen MK, et al. Home blood pressure management and improved blood pressure control: results from a randomized controlled trial. Arch Intern Med. Jul. 11. 2011;171(13):1173-80. X-6, X-9. [pmid: 21747013].
470 Botha KFH, Du Plessis WF, Van Rooyen JM, et al. Biopsychosocial determinants of self-management in culturally diverse South African patients with hypertension. Journal of Health Psychology. Sep. 2002;7(5):519-32. X-2, X-3. [pmid: 22113138].
471 Bott U, Jorgens V, Grusser M, et al. Predictors of glycaemic control in type 1 diabetic patients after participation in an intensified treatment and teaching programme. Diabet Med. May. 1994;11(4):362-71. X-2, X-4, X-9. [pmid: 8088108].
472 Bottle A, Gnani S, Saxena S, et al. Association between quality of primary care and hospitalization for coronary heart disease in England: national cross-sectional study. J Gen Intern Med. Feb. 2008;23(2):135-41. X-2, X-3, X-6. [pmid: 17924171].
473 Bottle A, Millett C, Xie Y, et al. Quality of primary care and hospital admissions for diabetes mellitus in England. J Ambul Care Manage. Jul-Sep. 2008;31(3):226-38. X-2, X-3, X-6. [pmid: 18574381].
474 Boudioni M, McPherson K, Moynihan C, et al. Do men with prostate or colorectal cancer seek different information and support from women with cancer?. Br J Cancer. Sep. 1. 2001;85(5):641-8. X-2, X-3, X-4. [pmid: 11531244].
475 Bougneres PF, Landais P, Mairesse AM, et al. Improvement of diabetic control and acceptability of a three-injection insulin regimen in diabetic adolescents. A multicenter controlled study. Diabetes Care. Jan. 1993;16(1):94-102. X-6, X-7. [pmid: 8422839].
476 Boulet LP, Belanger M, Lajoie P. Characteristics of subjects with a high frequency of emergency visits for asthma. Am J Emerg Med. Nov. 1996;14(7):623-8. X-2, X-4, X-6. [pmid: 8906757].
477 Boulter P. Diabetes as an opportunity for health plans to improve the quality of care for their members. Manag Care Interface. Suppl C. 2003:8-10. X-1, X-6, X-7, X-9. [pmid: 14569630].
478 Bounthavong M, Law AV. Identifying health-related quality of life (HRQL) domains for multiple chronic conditions (diabetes, hypertension and dyslipidemia): patient and provider perspectives. J Eval Clin Pract. Dec. 2008;14(6):1002-11. X-2, X-4, X-6. [pmid: 18759755].
479 Bourjolly JN, Kerson TS, Nuamah IF. A comparison of social functioning among Black and White women with breast cancer. Social Work in Health Care. 1999;28(3):1-20. X-2, X-4. [pmid: 10457978].
480 Bourque NM. Searching for the knowledge to heal: improving the links between medical research and the consumer. Can J Public Health. Nov-Dec. Suppl 2. 1996;87:S68-70. X-1, X-2, X-3, X-4, X-6. [pmid: 9002349].
481 Boutain DM. Collective knowledge sharing as a social justice strategy: the difference it made in a service project about preterm birth disparity. ANS Adv Nurs Sci. Apr-Jun. 2009;32(2):E68-80. X-1, X-2, X-7, X-8, X-10. [pmid: 19461223].
482 Boutin-Foster C, Ravenell JE, Greenfield VW, et al. Applying qualitative methods in developing a culturally tailored workbook for black patients with hypertension. Patient Educ Couns. Oct. 2009;77(1):144-7. X-2. [pmid: 19375264].
483 Bovier PA, Chamot E, Bouvier Gallacchi M, et al. Importance of patients' perceptions and general practitioners' recommendations in understanding missed opportunities for immunisations in Swiss adults. Vaccine. Sep. 14. 2001;19(32):4760-7. X-2, X-3, X-4, X-5, X-6. [pmid: 11535327].
484 Bowen DJ, Powers D, Greenlee H. Effects of breast cancer risk counseling for sexual minority women. Health Care Women Int. Jan. 2006;27(1):59-74. X-9. [pmid: 16338740].
485 Bowker SL, Mitchell CG, Majumdar SR, et al. Lack of insurance coverage for testing supplies is associated with poorer glycemic control in patients with type 2 diabetes. CMAJ. Jul. 6. 2004;171(1):39-43. X-2, X-3. [pmid: 15238494].
486 Boyde M, Tuckett A, Peters R, et al. Learning style and learning needs of heart failure patients (The Need2Know-HF patient study). Eur J Cardiovasc Nurs. Dec. 2009;8(5):316-22. X-2, X-6. [pmid: 19520614].
487 Brackbill RM, Siegel PZ, Ackermann SP. Self reported hypertension among unemployed people in the United States. BMJ. Mar. 4. 1995;310(6979):568. X-2, X-4. [pmid: 7888932].
488 Braddock A, Kapp-Simon K, Stein MT. Neurofibromatosis Type 1 in a 9-Year-Old Boy With Learning Problems, Emotional Outbursts, and Facial Disfigurement. Journal of Developmental and Behavioral Pediatrics. Jun. 2011;32(5):427-9. X-2, X-3, X-4, X-5, X-6. [pmid: 21558950].
489 Bradley EH, Carlson MDA, Gallo WT, et al. From Adversary to Partner: Have Quality Improvement Organizations Made the Transition?. Health Services Research. Apr. 2005;40(2):459-76. X-2, X-3, X-4, X-6. [pmid: 15762902].
490 Bradley EH, Herrin J, Mattera JA, et al. Hospital-level performance improvement: beta-blocker use after acute myocardial infarction. Med Care. Jun. 2004;42(6):591-9. X-2, X-6. [pmid: 15167327].
491 Bradley EH, Herrin J, Wang Y, et al. Racial and Ethnic Differences in Time to Acute Reperfusion Therapy for Patients Hospitalized with Myocardial Infarction. JAMA: Journal of the American Medical Association. Oct. 2004;292(13):1563-72. X-2. [pmid: 15467058].
492 Bradley HA, Puoane T. Prevention of hypertension and diabetes in an urban setting in South Africa: participatory action research with community health workers. Ethn Dis. Winter. 2007;17(1):49-54. X-2, X-3. [pmid: 17274209].
493 Bradley PK, Berry A, Lang C, et al. Getting ready: developing an educational intervention to prepare African American women for breast biopsy. ABNF J. Jan-Feb. 2006;17(1):15-9. X-2, X-3, X-4. [pmid: 16596896].
494 Bradley PK, Kash KM, Piccoli CW, et al. Preparing African American women for breast biopsy. Cancer Control. Nov. Suppl 2. 2005;12:100-2. X-7, X-9. [pmid: 16327759].
495 Braganza S, Sharif I, Ozuah PO. Documenting asthma severity: do we get it right?. J Asthma. Sep. 2003;40(6):661-5. X-2. [pmid: 14579997].
496 Braido F, Baiardini I, Menoni S, et al. Asthma management failure: a flaw in physicians' behavior or in patients' knowledge?. J Asthma. Apr. 2011;48(3):266-74. X-2, X-4, X-6. [pmid: 21381864].
497 Brand A, Walker DK, Hargreaves M, et al. Intermediate outcomes, strategies, and challenges of eight healthy start projects. Matern Child Health J. Sep. 2010;14(5):654-65. X-2, X-4, X-5, X-6. [pmid: 19011959].
498 Brant JM, Fallsdown D, Iverson ML. The evolution of a breast health program for Plains Indian women. Oncol Nurs Forum. May. 1999;26(4):731-9. X-9. [pmid: 10337651].
499 Braun KL, Fong M, Kaanoi ME, et al. Testing a culturally appropriate, theory-based intervention to improve colorectal cancer screening among Native Hawaiians. Prev Med. Jun. 2005;40(6):619-27. X-9. [pmid: 15850857].
500 Bray GA, Vollmer WM, Sacks FM, et al. A further subgroup analysis of the effects of the DASH diet and three dietary sodium levels on blood pressure: results of the DASH-Sodium Trial. Am J Cardiol. Jul. 15. 2004;94(2):222-7. X-7, X-9. [pmid: 15246908].
501 Bray P, Roupe M, Young S, et al. Feasibility and effectiveness of system redesign for diabetes care management in rural areas: the eastern North Carolina experience. Diabetes Educ. Sep-Oct. 2005;31(5):712-8. X-6, X-9. [pmid: 16203855].
502 Bray P, Thompson D, Wynn JD, et al. Confronting disparities in diabetes care: the clinical effectiveness of redesigning care management for minority patients in rural primary care practices. J Rural Health. Fall. 2005;21(4):317-21. X-6, X-7, X-9. [pmid: 16294654].
503 Breitkopf CR, Pearson HC, Breitkopf DM. Poor knowledge regarding the pap test among low-income women undergoing routine screening. Perspectives on Sexual and Reproductive Health. Jun. 2005;37(2):78-84. X-2, X-5. [pmid: 15961361].
504 Breland-Noble AM, Burriss A, Poole HK. Engaging depressed African American adolescents in treatment: lessons from the AAKOMA PROJECT. J Clin Psychol. Aug. 2010;66(8):868-79. X-4. [pmid: 20564682].
505 Brenes GA, McCall WV, Williamson JD, et al. Feasibility and acceptability of bibliotherapy and telephone sessions for the treatment of late-life anxiety disorders. Clinical Gerontologist. 2010;33(1):62-8. X-1, X-2, X-4, X-5, X-6. [pmid: 20661315].
506 Brenes GA, Paskett ED. Predictors of stage of adoption for colorectal cancer screening. Prev Med. Oct. 2000;31(4):410-6. X-2, X-4. [pmid: 11006067].
507 Brennan DT. Impact of prospective payment regulations: results of head nurse survey. ANNA J. Dec. 1984;11(7):49-52. X-2, X-5, X-6. [pmid: 6570439].
508 Breslin TM, Morris AM, Gu N, et al. Hospital factors and racial disparities in mortality after surgery for breast and colon cancer. J Clin Oncol. Aug. 20. 2009;27(24):3945-50. X-2. [pmid: 19470926].
509 Bresser PJ, Seynaeve C, Van Gool AR, et al. Satisfaction with prophylactic mastectomy and breast reconstruction in genetically predisposed women. Plast Reconstr Surg. May. 2006;117(6):1675-82. discussion 83-4. X-2, X-6. [pmid: 16651934].
510 Bressler B, Lo C, Amar J, et al. Prospective evaluation of screening colonoscopy: who is being screened?. Gastrointest Endosc. Dec. 2004;60(6):921-6. X-2, X-3. [pmid: 15605007].
511 Bressler J, Ansell D, Parker J, et al. Breast cancer screening in an urban public hospital. Five-year results. Cancer. Dec. 15. 1993;72(12):3636-40. X-2, X-4. [pmid: 8252479].
512 Brewer-Lowry AN, Arcury TA, Bell RA, et al. Differentiating approaches to diabetes self-management of multi-ethnic rural older adults at the extremes of glycemic control. Gerontologist. Oct. 2010;50(5):657-67. X-2, X-4. [pmid: 20110333].
513 Brick JC, Derr RL, Saudek CD. A randomized comparison of the terms estimated average glucose versus hemoglobin A1C. Diabetes Educ. Jul-Aug. 2009;35(4):596-602. X-4, X-7, X-9, X-10. [pmid: 19633166].
514 Briggs LM. Sexual healing: caring for patients recovering from myocardial infarction. Br J Nurs. Sep. 8-21. 1994;3(16):837-42. X-1, X-2, X-3, X-4, X-6. [pmid: 7950265].
515 Briscoe VJ, Pichert JW. Evaluation of a program to promote diabetes care via existing agencies in African American communities. ABNF J. Sep-Oct. 1999;10(5):111-5. X-4. [pmid: 10795176].
516 Brock TP, Williams DM, Beauchesne MF. Assessment of the readability and comprehensibility of a CFC-transition brochure. Ann Allergy Asthma Immunol. Feb. 2000;84(2):211-4. X-2, X-4, X-5, X-6. [pmid: 10719779].
517 Brod M, Christensen T, Thomsen TL, et al. The impact of non-severe hypoglycemic events on work productivity and diabetes management. Value Health. Jul-Aug. 2011;14(5):665-71. X-2, X-4. [pmid: 21839404].
518 Brody GH, Jack L Jr., Murry VM, et al. Heuristic model linking contextual processes to self-management in African American adults with type 2 diabetes. Diabetes Educ. Sep-Oct. 2001;27(5):685-93. X-1, X-2, X-4. [pmid: 12212018].
519 Brody GH, Kogan SM, Murry VM, et al. Psychological functioning, support for self-management, and glycemic control among rural African American adults with diabetes mellitus type 2. Health Psychol. Jan. 2008;27(1 Suppl):S83-90. X-2. [pmid: 18248109].
520 Brogan GX Jr., Peterson ED, Mulgund J, et al. Treatment disparities in the care of patients with and without diabetes presenting with non-ST-segment elevation acute coronary syndromes. Diabetes Care. Jan. 2006;29(1):9-14. X-2, X-6. [pmid: 16373888].
521 Bronte-Tinkew J, Moore KA, Matthews G, et al. Symptoms of major depression in a sample of fathers of infants: sociodemographic correlates and links to father involvement. Journal of Family Issues. 2007;28(1):61-99. X-2, X-6.
522 Brooten D, Youngblut JM, Royal S, et al. Outcomes of an asthma program: Healthy Children, Healthy Homes. Pediatr Nurs. Nov-Dec. 2008;34(6):448-55. X-4, X-8. [pmid: 19263751].
523 Brotanek JM, Grimes K, Flores G. Leave no asthmatic child behind: the cultural competency of asthma educational materials. Ethn Dis. Autumn. 2007;17(4):742-8. X-2, X-4. [pmid: 18072389].
524 Brotherstone H, Miles A, Robb KA, et al. The impact of illustrations on public understanding of the aim of cancer screening. Patient Education and Counseling. Nov. 2006;63(3):328-35. X-6, X-9. [pmid: 17011155].
525 Brough P, O'Driscoll M, Kalliath T. Evaluating the criterion validity of the Cybernetic Coping Scale: cross-lagged predictions of psychological strain, job and family satisfaction. Work & Stress. 2005;19(3):276-92. X-2, X-5, X-6.
526 Brouse CH, Basch CE, Wolf RL. The RESPECT approach to tailored telephone education. Health Education Journal. 2008;67(2):67-73. X-1, X-2, X-4, X-6.
527 Brouse CH, Basch CE, Wolf RL, et al. Barriers to colorectal cancer screening: an educational diagnosis. J Cancer Educ. Fall. 2004;19(3):170-3. X-2. [pmid: 15458873].
528 Brouse CH, Basch CE, Wolf RL, et al. Barriers to colorectal cancer screening with fecal occult blood testing in a predominantly minority urban population: a qualitative study. Am J Public Health. Aug. 2003;93(8):1268-71. X-2. [pmid: 12893609].
529 Brown A. Acute coronary syndromes in indigenous Australians: opportunities for improving outcomes across the continuum of care. Heart Lung Circ. May-Jun. 2010;19(5-6):325-36. X-2, X-3. [pmid: 20363187].
530 Brown AF, Gerzoff RB, Karter AJ, et al. Health behaviors and quality of care among Latinos with diabetes in managed care. Am J Public Health. Oct. 2003;93(10):1694-8. X-2. [pmid: 14534224].
531 Brown C, Schulberg HC, Sacco D, et al. Effectiveness of treatments for major depression in primary medical care practice: a post hoc analysis of outcomes for African American and white patients. J Affect Disord. May. 1999;53(2):185-92. X-2, X-7, X-9, X-10. [pmid: 10360414].
532 Brown CM. Exploring the role of religiosity in hypertension management among African Americans. J Health Care Poor Underserved. Feb. 2000;11(1):19-32. X-2, X-4. [pmid: 10778040].
533 Brown CP, Ross L, Lopez I, et al. Disparities in the receipt of cardiac revascularization procedures between blacks and whites: an analysis of secular trends. Ethn Dis. Spring. 2008;18(2 Suppl 2):S2-112-7. X-2. [pmid: 18646331].
534 Brown DJ, Metiko EB. Prevalence of hypertension in a sample of Black American adults using JNC 7 classifications. J Natl Black Nurses Assoc. Dec. 2005;16(2):1-5. X-2. [pmid: 16570640].
535 Brown DW, Haldeman GA, Croft JB, et al. Racial or ethnic differences in hospitalization for heart failure among elderly adults: Medicare, 1990 to 2000. Am Heart J. Sep. 2005;150(3):448-54. X-2. [pmid: 16169322].
536 Brown JB, Shye D, McFarland B. The paradox of guideline implementation: how AHCPR's depression guideline was adapted at Kaiser Permanente Northwest Region. Jt Comm J Qual Improv. Jan. 1995;21(1):5-21. X-1, X-2, X-4, X-6. [pmid: 7719400].
537 Brown JB, Shye D, McFarland BH, et al. Controlled trials of CQI and academic detailing to implement a clinical practice guideline for depression. Jt Comm J Qual Improv. Jan. 2000;26(1):39-54. X-1, X-2, X-4, X-6. [pmid: 10677821].
538 Brown JS, Elliott SA, Boardman J, et al. Meeting the unmet need for depression services with psycho-educational self-confidence workshops: preliminary report. Br J Psychiatry. Dec. 2004;185:511-5. X-2, X-3, X-6. [pmid: 15572743].
539 Brown JV, Avery E, Mobley C, et al. Asthma management by preschool children and their families: a developmental framework. J Asthma. 1996;33(5):299-311. X-2, X-4. [pmid: 8827937].
540 Brown JV, Bakeman R, Celano MP, et al. Home-based asthma education of young low-income children and their families. J Pediatr Psychol. Dec. 2002;27(8):677-88. X-4. [pmid: 12403858].
541 Brown JV, Demi AS, Celano MP, et al. A home visiting asthma education program: challenges to program implementation. Health Educ Behav. Feb. 2005;32(1):42-56. X-4. [pmid: 15642753].
542 Brown P, Zavestoski S, McCormick S, et al. Embodied health movements: New approaches to social movements in health. Sociology of Health & Illness. Jan. 2004;26(1):50-80. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15027990].
543 Brown R, Bratton SL, Cabana MD, et al. Physician asthma education program improves outcomes for children of low-income families. Chest. Aug. 2004;126(2):369-74. X-4. [pmid: 15302719].
544 Brown SA, Blozis SA, Kouzekanani K, et al. Dosage effects of diabetes self-management education for Mexican Americans: the Starr County Border Health Initiative. Diabetes Care. Mar. 2005;28(3):527-32. X-7, X-9. [pmid: 15735182].
545 Brown SA, Blozis SA, Kouzekanani K, et al. Health beliefs of Mexican Americans with type 2 diabetes: The Starr County border health initiative. Diabetes Educ. Mar-Apr. 2007;33(2):300-8. X-7, X-9. [pmid: 17426305].
546 Brown SA, Duchin SP, Villagomez ET. Diabetes education in a Mexican-American population: pilot testing of a research-based videotape. Diabetes Educ. Jan-Feb. 1992;18(1):47-51. X-4. [pmid: 1370266].
547 Brown SA, Garcia AA, Kouzekanani K, et al. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. Feb. 2002;25(2):259-68. X-9. [pmid: 11815493].
548 Brown SA, Garcia AA, Winter M, et al. Integrating education, group support, and case management for diabetic Hispanics. Ethn Dis. Winter. 2011;21(1):20-6. X-7, X-9. [pmid: 21462725].
549 Brown SA, Hanis CL. A community-based, culturally sensitive education and group-support intervention for Mexican Americans with NIDDM: a pilot study of efficacy. Diabetes Educ. May-Jun. 1995;21(3):203-10. X-9. [pmid: 7758387].
550 Brown SA, Hanis CL. Culturally competent diabetes education for Mexican Americans: the Starr County Study. Diabetes Educ. Mar-Apr. 1999;25(2):226-36. X-9. [pmid: 10531848].
551 Brown SA, Harrist RB, Villagomez ET, et al. Gender and treatment differences in knowledge, health beliefs, and metabolic control in Mexican Americans with type 2 diabetes. Diabetes Educ. May-Jun. 2000;26(3):425-38. X-7, X-9. [pmid: 11151290].
552 Brown SA, Upchurch SL, Garcia AA, et al. Symptom-related self-care of Mexican Americans with type 2 diabetes: preliminary findings of the Starr County Diabetes Education Study. Diabetes Educ. May-Jun. 1998;24(3):331-9. X-2, X-4. [pmid: 9677951].
553 Brown SM, Culver JO, Osann KE, et al. Health literacy, numeracy, and interpretation of graphical breast cancer risk estimates. Patient Educ Couns. Apr. 2011;83(1):92-8. X-2, X-4. [pmid: 20554149].
554 Brown Wright L, Gregoski MJ, Tingen MS, et al. Impact of Stress Reduction Interventions on Hostility and Ambulatory Systolic Blood Pressure in African American Adolescents. Journal of Black Psychology. 2011;37(2):210-33. X-7, X-9. [pmid: 22485058].
555 Browne JV, Talmi A. Family-based intervention to enhance infant-parent relationships in the neonatal intensive care unit. J Pediatr Psychol. Dec. 2005;30(8):667-77. X-4, X-5, X-6. [pmid: 16260436].
556 Brownhill S, Wilhelm K, Eliovson G, et al. ‘For men only’. A mental health prompt list in primary care. Aust Fam Physician. Jun. 2003;32(6):443-50. X-6, X-7, X-9. [pmid: 12833772].
557 Brownson CA, Hoerger TJ, Fisher EB, et al. Cost-effectiveness of diabetes self-management programs in community primary care settings. Diabetes Educ. Sep-Oct. 2009;35(5):761-9. X-2, X-6. [pmid: 19622716].
558 Brownstein JN, Cheal N, Ackermann SP, et al. Breast and cervical cancer screening in minority populations: a model for using lay health educators. J Cancer Educ. Winter. 1992;7(4):321-6. X-1, X-2, X-4. [pmid: 1305418].
559 Bruce DG, Davis WA, Cull CA, et al. Diabetes education and knowledge in patients with type 2 diabetes from the community: the Fremantle Diabetes Study. J Diabetes Complications. Mar-Apr. 2003;17(2):82-9. X-2, X-3. [pmid: 12614974].
560 Bruce IN, Gladman DD, Urowitz MB. Factors associated with refractory renal disease in patients with systemic lupus erythematosus: the role of patient nonadherence. Arthritis Care Res. Dec. 2000;13(6):406-8. X-2, X-5. [pmid: 14635317].
561 Brugge D, Rivera-Carrasco E, Zotter J, et al. Community-based participatory research in Boston's neighborhoods: A review of asthma case examples. Arch Environ Occup Health. Jan-Mar. 1. 2010;65(1):38-44. X-1, X-2. [pmid: 20147002].
562 Brunt MJ, Milbauer MJ, Ebner SA, et al. Health status and practices of urban Caribbean Latinos with diabetes mellitus. Ethn Dis. 1998;8(2):158-66. X-2, X-3, X-4. [pmid: 9681282].
563 Bruzzese JM, Markman LB, Appel D, et al. An evaluation of Open Airways for Schools: using college students as instructors. J Asthma. Jun. 2001;38(4):337-42. X-2, X-6, X-8. [pmid: 11456387].
564 Bruzzese JM, Sheares BJ, Vincent EJ, et al. Effects of a school-based intervention for urban adolescents with asthma. A controlled trial. Am J Respir Crit Care Med. Apr. 15. 2011;183(8):998-1006. X-7, X-8, X-9. [pmid: 21139088].
565 Bruzzese JM, Unikel L, Gallagher R, et al. Feasibility and impact of a school-based intervention for families of urban adolescents with asthma: results from a randomized pilot trial. Fam Process. Mar. 2008;47(1):95-113. X-4. [pmid: 18411832].
566 Bryant CA, Forthofer MS, McCormack-Brown K, et al. A social marketing approach to increasing breast cancer screening rates. Journal of Health Education. 2000;31(6):320-30. X-2, X-6.
567 Bryant PK. Congestive heart failure performance-improvement project: special needs for special patients. Lippincotts Case Manag. Jul-Aug. 2002;7(4):152-62. X-9. [pmid: 12151809].
568 Bryant RA, O'Donnell ML, Creamer M, et al. The psychiatric sequelae of traumatic injury. Am J Psychiatry. Mar. 2010;167(3):312-20. X-2, X-3, X-5, X-6. [pmid: 20048022].
569 Bryant-Stephens T, Kurian C, Guo R, et al. Impact of a household environmental intervention delivered by lay health workers on asthma symptom control in urban, disadvantaged children with asthma. Am J Public Health. Nov. Suppl 3. 2009;99:S657-65. X-9. [pmid: 19890172].
570 Buch HN, Barton DM, Varughese GI, et al. An assessment of the coverage of a district-wide diabetic retinopathy screening service. Diabet Med. Jul. 2005;22(7):840-1. X-2, X-3, X-6. [pmid: 15975096].
571 Buchholz SW, Artinian NT. Dimensions of physical activity in african american women. Health Care Women Int. Apr. 2009;30(4):308-23. X-2. [pmid: 19255885].
572 Buckhardt CS, Clark SR, Bennett RM. Long-term follow-up of fibromyalgia patients who completed a structured treatment program versus patients in routine treatment. Journal of Musculoskeletal Pain. 2005;13(1):5-14. X-2, X-5, X-6.
573 Buckley T, McKinley S, Gallagher R, et al. The effect of education and counselling on knowledge, attitudes and beliefs about responses to acute myocardial infarction symptoms. Eur J Cardiovasc Nurs. Jun. 2007;6(2):105-11. X-6, X-9. [pmid: 16839819].
574 Budden LM, Pierce PF, Hayes BA, et al. Australian women's prediagnostic decision-making styles, relating to treatment choices for early breast cancer treatment. Res Theory Nurs Pract. Summer. 2003;17(2):117-36. X-2, X-3, X-6. [pmid: 12880217].
575 Buelow JR, Zimmer AH, Mellor MJ, et al. Mammography screening for older minority women. Journal of Applied Gerontology. Jun. 1998;17(2):133-49. X-4, X-9.
576 Buford TA. Transfer of asthma management responsibility from parents to their school-age children. J Pediatr Nurs. Feb. 2004;19(1):3-12. X-2, X-4, X-6. [pmid: 14963865].
577 Buist A, Speelman C, Hayes B, et al. Impact of education on women with perinatal depression. Journal of Psychosomatic Obstetrics & Gynecology. Mar. 2007;28(1):49-54. X-2, X-6. [pmid: 17454513].
578 Bujnowska-Fedak MM, Puchala E, Steciwko A. The impact of telehome care on health status and quality of life among patients with diabetes in a primary care setting in Poland. Telemed J E Health. Apr. 2011;17(3):153-63. X-6, X-9. [pmid: 21375410].
579 Bunch AS. Tackling a new opponent. NFL star tells those with diabetes to “check your feet”. Healthplan. May-Jun. 2003;44(3):51-3. X-1, X-6, X-7, X-9. [pmid: 12808759].
580 Burack RC, Gimotty PA. Promoting screening mammography in inner-city settings. The sustained effectiveness of computerized reminders in a randomized controlled trial. Med Care. Sep. 1997;35(9):921-31. X-6, X-9. [pmid: 9298081].
581 Burack RC, Gimotty PA, George J, et al. The effect of patient and physician reminders on use of screening mammography in a health maintenance organization. Results of a randomized controlled trial. Cancer. Oct. 15. 1996;78(8):1708-21. X-4, X-6, X-9. [pmid: 8859184].
582 Burack RC, Gimotty PA, George J, et al. Promoting screening mammography in inner-city settings: a randomized controlled trial of computerized reminders as a component of a program to facilitate mammography. Med Care. Jun. 1994;32(6):609-24. X-6, X-9. [pmid: 8189778].
583 Burak L, Boone B. College women and breast cancer: knowledge, behavior, and beliefs regarding risk reduction. American Journal of Health Education. 2008;39(4):206-12. X-2, X-6.
584 Burckhardt CS, Clark SR, Bennett RM. Pain coping strategies and quality of life in women with fibromyalgia: does age make a difference?. Journal of Musculoskeletal Pain. 2001;9(2):5-18. X-2, X-5, X-6.
585 Burden M. Diabetes: new treatments and guidance. Nurs Times. Jan. 21-27. 2003;99(3):30-1. X-1, X-2, X-3, X-4, X-6. [pmid: 12617010].
586 Burden RW, Kumar RN, Phillips DL, et al. Hyperlipidemia in Native Americans: evaluation of lipid management through a cardiovascular risk reduction program. J Am Pharm Assoc (Wash). Jul-Aug. 2002;42(4):652-5. X-1, X-9. [pmid: 12150364].
587 Burgener SC, Twigg P, Popovich A. Measuring psychological well-being in cognitively impaired persons. Dementia. (14713012). 2005;4(4):463-85. X-2, X-5, X-6.
588 Burgess SW, Sly PD, Morawska A, et al. Assessing adherence and factors associated with adherence in young children with asthma. Respirology. Jun. 2008;13(4):559-63. X-6, X-7, X-9. [pmid: 18422868].
589 Burhansstipanov L, Krebs LU, Seals BF, et al. Native American breast cancer survivors' physical conditions and quality of life. Cancer. Mar. 15. 2010;116(6):1560-71. X-2. [pmid: 20120031].
590 Burke DJ. Diabetes education for the Native American population. Diabetes Educ. Mar-Apr. 2001;27(2):181-2. 7. 8. X-1, X-7, X-9. [pmid: 11913002].
591 Burke NJ, Jackson JC, Thai HC, et al. ‘Honoring tradition, accepting new ways’: development of a hepatitis B control intervention for Vietnamese immigrants. Ethnicity & Health. May. 2004;9(2):153-69. X-2, X-5. [pmid: 15223574].
592 Burkhart PV, Rayens MK. Self-concept and health locus of control: factors related to children's adherence to recommended asthma regimen. Pediatr Nurs. Sep-Oct. 2005;31(5):404-9. X-2, X-4, X-6. [pmid: 16295156].
593 Burkhart PV, Ward HJ. Children's Self-Reports of Characteristics of Their Asthma Episodes. Journal of Asthma. Dec. 2003;40(8):909-16. X-2, X-4, X-6. [pmid: 14736091].
594 Burnett CB, Steakley CS, Slack R, et al. Patterns of breast cancer screening among lesbians at increased risk for breast cancer. Women Health. 1999;29(4):35-55. X-2, X-4. [pmid: 10608668].
595 Burnett J, Coverdale JH, Pickens S, et al. What is the association between self-neglect, depressive symptoms and untreated medical conditions?. J Elder Abuse Negl. 2006;18(4):25-34. X-2, X-6. [pmid: 17972657].
596 Burns B. Special issues for younger Medicare beneficiaries with disabilities. Issue Brief Cent Medicare Educ. 2003;4(2):1-8. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12675050].
597 Burns D, Skelly AH. African American women with type 2 diabetes: meeting the daily challenges of self care. Journal of Multicultural Nursing & Health (JMCNH). 2005;11(3):6-10. X-2, X-4.
598 Bursac Z, Campbell JE. Prevalence of current cigarette smoking among American Indians in Oklahoma: a comparison. J Okla State Med Assoc. Mar. 2002;95(3):155-8. X-2, X-4, X-5. [pmid: 11921864].
599 Bursac Z, Campbell JE. From risky behaviors to chronic outcomes: current status and Healthy People 2010 goals for American Indians in Oklahoma. J Okla State Med Assoc. Dec. 2003;96(12):569-73. X-2, X-4. [pmid: 14965026].
600 Bursch B, Schwankovsky L, Gilbert J, et al. Construction and validation of four childhood asthma self-management scales: parent barriers, child and parent self-efficacy, and parent belief in treatment efficacy. J Asthma. 1999;36(1):115-28. X-2, X-4, X-6. [pmid: 10077141].
601 Burton MV, Parker RW. Satisfaction of breast cancer patients with their medical and psychological care. Journal of Psychosocial Oncology. 1994;12(1/2):41-63. X-2, X-6.
602 Burton WN, Connerty CM, Schultz AB, et al. Bank One's worksite-based asthma disease management program. J Occup Environ Med. Feb. 2001;43(2):75-82. X-8, X-9. [pmid: 11227636].
603 Busch AB, Huskamp HA, Normand SLT, et al. The Impact of Parity on Major Depression Treatment Quality in the Federal Employees' Health Benefits Program After Parity Implementation. Medical Care. Jun. 2006;44(6):506-12. X-2, X-6. [pmid: 16707998].
604 Bushnell FK. Self-care teaching for congestive heart failure patients. J Gerontol Nurs. Oct. 1992;18(10):27-32. X-2, X-4. [pmid: 1479155].
605 Busse WW, Morgan WJ, Gergen PJ, et al. Randomized trial of omalizumab (anti-IgE) for asthma in inner-city children. N Engl J Med. Mar. 17. 2011;364(11):1005-15. X-7, X-9. [pmid: 21410369].
606 Bussell G, Marlow N. The dietary beliefs and attitudes of women who have had a low-birthweight baby: a retrospective preconception study. Journal of Human Nutrition & Dietetics. 2000;13(1):29-39. X-2, X-4, X-6.
607 Butler SG, Hill LJ, Harrison J, et al. Is there a difference in airway clearance practices between children with non cystic fibrosis bronchiectasis and cystic fibrosis?. New Zealand Journal of Physiotherapy. 2008;36(3):112-7. X-2, X-3, X-4, X-6.
608 Butterfoss FD, Kelly C, Taylor-Fishwick J. Health planning that magnifies the community's voice: allies against asthma. Health Educ Behav. Feb. 2005;32(1):113-28. X-1, X-6, X-7, X-9. [pmid: 15642758].
609 Butz A, Kub J, Donithan M, et al. Influence of caregiver and provider communication on symptom days and medication use for inner-city children with asthma. J Asthma. May. 2010;47(4):478-85. X-9. [pmid: 20528605].
610 Butz AM, Eggleston P, Huss K, et al. Children with asthma and nebulizer use: parental asthma self-care practices and beliefs. J Asthma. Oct. 2001;38(7):565-73. X-2, X-4. [pmid: 11714079].
611 Butz AM, Huss K, Mudd K, et al. Asthma management practices at home in young inner-city children. J Asthma. Jun. 2004;41(4):433-44. X-2, X-4. [pmid: 15281329].
612 Butz AM, Malveaux FJ, Eggleston P, et al. Use of community health workers with inner-city children who have asthma. Clinical Pediatrics. 1994;33(3):135-41. X-9. [pmid: 8194287].
613 Butz AM, Walker J, Land CL, et al. Improving asthma communication in high-risk children. J Asthma. Nov. 2007;44(9):739-45. X-2. [pmid: 17994404].
614 Buxeda MV. The use of audiocassette recordings for patient education. Bol Asoc Med P R. Nov. 1990;82(11):487-90. X-3, X-5. [pmid: 1706181].
615 Byczkowski TL, Munafo JK, Britto MT. Variation in use of Internet-based patient portals by parents of children with chronic disease. Arch Pediatr Adolesc Med. May. 2011;165(5):405-11. X-6, X-7, X-9. [pmid: 21536954].
616 Bynum JP, Fisher ES, Song Y, et al. Measuring racial disparities in the quality of ambulatory diabetes care. Med Care. Dec. 2010;48(12):1057-63. X-2. [pmid: 21063231].
617 Bynum JPW, Fisher ES, Song Y, et al. Measuring racial disparities in the quality of ambulatory diabetes care. Medical Care. Dec. 2010;48(12):1057-63. X-2, X-4. [pmid: 21063231].
618 Byrne M, Murphy AW, Walsh JC, et al. A cross-sectional study of secondary cardiac care in general practice: impact of personal and practice characteristics. Fam Pract. Jun. 2006;23(3):295-302. X-2, X-6. [pmid: 16585129].
619 Byrne S, Robles-Rodriguez E. Educational parties as a strategy to promote breast health awareness and screening in underserved female populations. Oncology Nursing Forum. Mar. 2009;36(2):145-8. X-1, X-6, X-7, X-9. [pmid: 19273403].
620 Cabana MD, Flores G. The role of clinical practice guidelines in enhancing quality and reducing racial/ethnic disparities in paediatrics. Paediatr Respir Rev. Mar. 2002;3(1):52-8. X-1, X-4, X-5. [pmid: 12065183].
621 Cabassa LJ, Hansen MC. A systematic review of depression treatments in primary care for Latino adults. Research on Social Work Practice. 2007;17(4):494-503. X-1, X-2, X-4.
622 Cabassa LJ, Hansen MC, Palinkas LA, et al. Azucar y nervios: explanatory models and treatment experiences of Hispanics with diabetes and depression. Soc Sci Med. Jun. 2008;66(12):2413-24. X-2, X-4. [pmid: 18339466].
623 Cabral AL, Carvalho WA, Chinen M, et al. Are International Asthma Guidelines effective for low-income Brazilian children with asthma?. Eur Respir J. Jul. 1998;12(1):35-40. X-3. [pmid: 9701411].
624 Cacho CP. Nocturnal dialysis in the inner city. ASAIO J. Sep-Oct. 2001;47(5):456-8. X-4, X-6, X-7, X-9, X-11. [pmid: 11575813].
625 Cagle CS, Appel S, Skelly AH, et al. Mid-life African-American women with type 2 diabetes: influence on work and the multicaregiver role. Ethn Dis. Fall. 2002;12(4):555-66. X-2, X-4. [pmid: 12477143].
626 Cairney J, Wade TJ. Single parent mothers and mental health care service use. Soc Psychiatry Psychiatr Epidemiol. May. 2002;37(5):236-42. X-2, X-3, X-5, X-6. [pmid: 12107716].
627 Caironi PV, Portoni L, Combi C, et al. HyperCare: a prototype of an active database for compliance with essential hypertension therapy guidelines. Proc AMIA Annu Fall Symp. 1997:288-92. X-1, X-2, X-3, X-6. [pmid: 9357634].
628 Calderon JL, Bazargan M, Sangasubana N, et al. A comparison of two educational methods on immigrant Latinas breast cancer knowledge and screening behaviors. J Health Care Poor Underserved. Aug. 2010;21(3 Suppl):76-90. X-9. [pmid: 20675947].
629 Calderon JL, Zadshir A, Norris K. Structure and content of chronic kidney disease information on the World Wide Web: barriers to public understanding of a pandemic. Nephrol News Issues. Oct. 8. 2004;18(11):76-9. 81. 4. X-2, X-4, X-6. [pmid: 15551616].
630 Calhoun D, Brod R, Kirlin K, et al. Effectiveness of motivational interviewing for improving self-care among Northern Plains Indians with type 2 diabetes. Diabetes Spectrum. 2010;23(2):107-14. X-9.
631 Caliskan D, Ozdemir O, Ocaktan E, et al. Evaluation of awareness of diabetes mellitus and associated factors in four health center areas. Patient Educ Couns. Jul. 2006;62(1):142-7. X-2, X-3, X-4. [pmid: 16139985].
632 Callender CO, Bey AS, Miles PV, et al. A national minority organ/tissue transplant education program: the first step in the evolution of a national minority strategy and minority transplant equity in the USA. Transplant Proc. Feb. 1995;27(1):1441-3. X-1, X-5. [pmid: 7878936].
633 Callender CO, Hall MB, Branch D. An assessment of the effectiveness of the Mottep model for increasing donation rates and preventing the need for transplantation--adult findings: program years 1998 and 1999. Semin Nephrol. Jul. 2001;21(4):419-28. X-5. [pmid: 11455531].
634 Calman N. Making health equality a reality: the Bronx takes action. Health Aff (Millwood). Mar-Apr. 2005;24(2):491-8. X-1, X-2, X-4, X-5. [pmid: 15757935].
635 Calman NS, Golub M, Ruddock C, et al. Separate and unequal care in New York City. J Health Care Law Policy. 2006;9(1):105-20. X-1, X-2, X-4, X-5, X-6. [pmid: 17165226].
636 Calnan MW, Moss S, Chamberlain J. Explaining attendance at a class teaching breast self-examination. Patient Educ Couns. 1984;6(2):83-90. X-2, X-4. [pmid: 10268101].
637 Calvin JE, Roe MT, Chen AY, et al. Insurance coverage and care of patients with non-ST-segment elevation acute coronary syndromes. Ann Intern Med. Nov. 21. 2006;145(10):739-48. X-2, X-4. [pmid: 17116918].
638 Calvocoressi L, Kasl SV, Lee CH, et al. A prospective study of perceived susceptibility to breast cancer and nonadherence to mammography screening guidelines in African American and White women ages 40 to 79 years. Cancer Epidemiol Biomarkers Prev. Dec. 2004;13(12):2096-105. X-2, X-4. [pmid: 15598767].
639 Calvocoressi L, Sun A, Kasl SV, et al. Mammography screening of women in their 40s: impact of changes in screening guidelines. Cancer. Feb. 1. 2008;112(3):473-80. X-6, X-7, X-9. [pmid: 18072258].
640 Calzone KA, Prindiville SA, Jourkiv O, et al. Randomized comparison of group versus individual genetic education and counseling for familial breast and/or ovarian cancer. J Clin Oncol. May. 20. 2005;23(15):3455-64. X-6, X-9, X-10. [pmid: 15908654].
641 Camacho F, Anderson RT, Bell RA, et al. Investigating correlates of health related quality of life in a low-income sample of patients with diabetes. Qual Life Res. Dec. 2002;11(8):783-96. X-2, X-4. [pmid: 12482162].
642 Cameron J, Worrall-Carter L, Page K, et al. Does cognitive impairment predict poor self-care in patients with heart failure?. Eur J Heart Fail. May. 2010;12(5):508-15. X-2, X-4, X-6. [pmid: 20354031].
643 Cameron KA, FranciS L, Wolf MS, et al. Investigating Hispanic/Latino perceptions about colorectal cancer screening: A community-based approach to effective message design. Patient Education and Counseling. Oct. 2007;68(2):145-52. X-2, X-4. [pmid: 17517486].
644 Campbell LV, Ashwell SM, Borkman M, et al. White coat hyperglycaemia: disparity between diabetes clinic and home blood glucose concentrations. BMJ. Nov. 14. 1992;305(6863):1194-6. X-2, X-4, X-6. [pmid: 1467722].
645 Campo Cascon J, Caparros Sanz R, Martin Bedia L, et al. Psychological evaluation of patients with an ostomy. World Council of Enterostomal Therapists Journal. 2003;23(3):8-12. X-2, X-3, X-4, X-5, X-6.
646 Canada RE, Turner B. Talking to patients about screening colonoscopy--where conversations fall short. J Fam Pract. Aug. 2007;56(8):E1-9. X-2, X-4, X-6. [pmid: 17669281].
647 Candib LM, Silva M, Cashman SB, et al. Creating open access to exercise for low-income patients through a community collaboration for quality improvement: if you build it, they will come. J Ambul Care Manage. Apr-Jun. 2008;31(2):142-50. X-8. [pmid: 18360175].
648 Canino G, McQuaid EL, Rand CS. Addressing asthma health disparities: a multilevel challenge. J Allergy Clin Immunol. Jun. 2009;123(6):1209-17. quiz 18-9. X-1, X-2, X-4. [pmid: 19447484].
649 Canino G, Vila D, Normand SL, et al. Reducing asthma health disparities in poor Puerto Rican children: the effectiveness of a culturally tailored family intervention. J Allergy Clin Immunol. Mar. 2008;121(3):665-70. X-7, X-9. [pmid: 18061648].
650 Canter DL, Atkins MD, McNeal CJ, et al. Risk factor treatment in veteran women at risk for cardiovascular disease. J Surg Res. Dec. 2009;157(2):175-80. X-2, X-4, X-6. [pmid: 19482299].
651 Cantwell R, Clutton-Brock T, Cooper G, et al. Saving Mothers' Lives: Reviewing maternal deaths to make motherhood safer: 2006-2008. The Eighth Report of the Confidential Enquiries into Maternal Deaths in the United Kingdom. BJOG. Mar. Suppl 1. 2011;118:1-203. X-2, X-3, X-4, X-6. [pmid: 21356004].
652 Caplan R, Siddarth P, Gurbani S, et al. Depression and anxiety disorders in pediatric epilepsy. Epilepsia. May. 2005;46(5):720-30. X-2, X-4, X-5, X-6. [pmid: 15857439].
653 Capriotti T, Kirby LG, Smeltzer SC. Unrecognized high blood pressure. A major public health issue for the workplace. AAOHN J. Jul. 2000;48(7):338-43. X-7, X-8, X-9, X-10. [pmid: 11261183].
654 Carbone ET, Lennon KM, Torres MI, et al. Testing the feasibility of an interactive learning styles measure for U.S. Latino adults with type 2 diabetes and low literacy. Int Q Community Health Educ. 2005;25(4):315-35. X-2, X-4. [pmid: 17686705].
655 Carbone ET, Lennon KM, Torres MI, et al. Testing the feasibility of an interactive learning styles measure for U.S. Latino Adults with type 2 diabetes and low literacy. International Quarterly of Community Health Education. 2006;25(4):315-35. X-2, X-4, X-7, X-10. [pmid: 17686705].
656 Carbone ET, Rosal MC, Torres MI, et al. Diabetes self-management: perspectives of Latino patients and their health care providers. Patient Educ Couns. May. 2007;66(2):202-10. X-2, X-4. [pmid: 17329060].
657 Carcillo JA, Diegel JE, Bartman BA, et al. Improved maternal and child health care access in a rural community. J Health Care Poor Underserved. 1995;6(1):23-40. X-3, X-9. [pmid: 7734633].
658 Cardarelli R, Kurian AK, Pandya V. Having a personal healthcare provider and receipt of adequate cervical and breast cancer screening. J Am Board Fam Med. Jan-Feb. 2010;23(1):75-81. X-2, X-4. [pmid: 20051545].
659 Carey KW. Refusing to follow orders: what's the cost of saying no?. Nurs Life. Jul-Aug. 1985;5(4):53-6. X-1, X-6, X-7, X-9. [pmid: 11650739].
660 Carlos RC, Fendrick AM, Patterson SK, et al. Associations in breast and colon cancer screening behavior in women. Acad Radiol. Apr. 2005;12(4):451-8. X-2, X-4, X-6. [pmid: 15831418].
661 Carlson B, Riegel B, Moser DK. Self-care abilities of patients with heart failure. Heart Lung. Sep-Oct. 2001;30(5):351-9. X-2, X-6. [pmid: 11604977].
662 Carlson BA, Neal D, Magwood G, et al. A community-based participatory health information needs assessment to help eliminate diabetes information disparities. Health Promot Pract. Jul. 2006;7(3 Suppl):213S-22S. X-7, X-8, X-9. [pmid: 16760247].
663 Carlson SA, Maynard LM, Fulton JE, et al. Physical activity advice to manage chronic conditions for adults with arthritis or hypertension, 2007. Prev Med. Aug-Sep. 2009;49(2-3):209-12. X-2, X-4. [pmid: 19573554].
664 Carolyn J, Patsy M, Khosrow H, et al. Efforts to Decrease Diabetes-Related Amputations in African Americans by the Racial and Ethnic Approaches to Community Health Charleston and Georgetown Diabetes Coalition. Family and Community Health. 2011;34(1S):S63. X-8. [pmid: 21160332].
665 Carr DS. Black/white differences in psychological adjustment to spousal loss among older adults. Research on Aging. 2004;26(6):591-622. X-2, X-4.
666 Carroll DL, Robinson E, Buselli E, et al. Activities of the APN to enhance unpartnered elders self-efficacy after myocardial infarction. Clin Nurse Spec. Mar. 2001;15(2):60-6. X-1, X-2, X-4, X-6. [pmid: 11855491].
667 Carter AW, Borchardt N, Cooney M, et al. Dual test diabetes screening project: screening for poor glycemic control in a large workplace population. Diabetes Technol Ther. Winter. 2000;2(4):529-36. X-7, X-9, X-10. [pmid: 11469615].
668 Carter BL. Implementing the new guidelines for hypertension: JNC 7, ADA, WHO-ISH. J Manag Care Pharm. Sep. 2004;10(5 Suppl A):S18-25. X-1, X-2, X-3, X-4. [pmid: 15369421].
669 Carter BS, Stahlman M. Reflections on neonatal intensive care in the U.S.: limited success or success with limits?. J Clin Ethics. Fall. 2001;12(3):215-22. X-1, X-2, X-4, X-5, X-6. [pmid: 11789064].
670 Carter EL, Nunlee-Bland G, Callender C. A patient-centric, provider-assisted diabetes telehealth self-management intervention for urban minorities. Perspect Health Inf Manag. 2011;8:1b. X-4. [pmid: 21307985].
671 Carter-Edwards L, Skelly AH, Cagle CS, et al. “They care but don't understand”: family support of African American women with type 2 diabetes. Diabetes Educ. May-Jun. 2004;30(3):493-501. X-2, X-4. [pmid: 15208847].
672 Carthron DL, Johnson TM, Hubbart TD, et al. “Give me some sugar!” the diabetes self-management activities of African-American primary caregiving grandmothers. J Nurs Scholarsh. Sep. 1. 2010;42(3):330-7. X-2, X-4. [pmid: 20738744].
673 Cartwright E, Schow D, Herrera S, et al. Using participatory research to build an effective type 2 diabetes intervention: the process of advocacy among female Hispanic farmworkers and their families in Southeast Idaho. Women Health. 2006;43(4):89-109. X-2, X-4. [pmid: 17135090].
674 Caruso A, Bongiorno L, Vallini L, et al. Breast cancer and distress resulting from Magnetic Resonance Imaging (MRI): the impact of a psychological intervention of emotional and informative support. J Exp Clin Cancer Res. Dec. 2006;25(4):499-505. X-3. [pmid: 17310840].
675 Casarez RL, Engebretson JC, Ostwald SK. Spiritual practices in self-management of diabetes in African Americans. Holist Nurs Pract. Jul-Aug. 2010;24(4):227-37. X-2, X-4. [pmid: 20588132].
676 Case C, Johantgen M, Steiner C. Outpatient mastectomy: clinical, payer, and geographic influences. Health Serv Res. Oct. 2001;36(5):869-84. X-2. [pmid: 11666108].
677 Case S, Jernigan V, Gardner A, et al. Content and frequency of writing on diabetes bulletin boards: does race make a difference?. J Med Internet Res. 2009;11(2):e22. X-2, X-4. [pmid: 19632975].
678 Caserta MS, Lund DA. Toward the development of an inventory of daily widowed life (IDWL): guided by the dual process model of coping with bereavement. Death Stud. Jul. 2007;31(6):505-35. X-2, X-4, X-5, X-6. [pmid: 17726825].
679 Casey P, Birbeck G, McDonagh C, et al. Personality disorder, depression and functioning: results from the ODIN study. J Affect Disord. Oct. 15. 2004;82(2):277-83. X-2, X-3, X-4. [pmid: 15488258].
680 Castellanos DC, Connell C, Lee J. Factors affecting weight gain and dietary intake in latino males residing in mississippi: a preliminary study. Hispanic Health Care International. 2011;9(2):91-8. X-7, X-9.
681 Castillo A, Giachello A, Bates R, et al. Community-based Diabetes Education for Latinos: The Diabetes Empowerment Education Program. Diabetes Educ. Jul-Aug. 2010;36(4):586-94. X-4, X-8. [pmid: 20538970].
682 Castillo C, Salvatierra V, Mejias MC, et al. Treatment of children suffering from severe malnutrition in an area of Santiago, Chile. Bull Pan Am Health Organ. 1983;17(4):387-95. X-3, X-5. [pmid: 6421352].
683 Castro CM, Wilson C, Wang F, et al. Babel babble: physicians' use of unclarified medical jargon with patients. Am J Health Behav. Sep-Oct. Suppl 1. 2007;31:S85-95. X-2, X-4. [pmid: 17931142].
684 Cathcart J, Baillargeon A, Pokorski R. Critical illness risk for type 2 diabetes. J Insur Med. 2006;38(4):271-5. X-2, X-4. [pmid: 17323754].
685 Cavanaugh K, Huizinga MM, Wallston KA, et al. Association of numeracy and diabetes control. Ann Intern Med. May. 20. 2008;148(10):737-46. X-2, X-4. [pmid: 18490687].
686 Cavanaugh K, Wallston KA, Gebretsadik T, et al. Addressing literacy and numeracy to improve diabetes care: two randomized controlled trials. Diabetes Care. Dec. 2009;32(12):2149-55. X-9. [pmid: 19741187].
687 Cavanaugh KL, White RO, Rothman RL. Exploring disease management programs for diabetes mellitus - Proposal of a novel hybrid model. Disease Management & Health Outcomes. 2007;15(2):73-81. X-1, X-2, X-4.
688 Cavanaugh KL, Wingard RL, Hakim RM, et al. Low health literacy associates with increased mortality in ESRD. J Am Soc Nephrol. Nov. 2010;21(11):1979-85. X-2, X-4. [pmid: 20671215].
689 Cazap E, Buzaid A, Garbino C, et al. Breast cancer in Latin America: experts perceptions compared with medical care standards. Breast. Feb. 2010;19(1):50-4. X-2, X-3, X-4, X-6. [pmid: 19945878].
690 Ceballos RM, Coronado GD, Thompson B. Having a diagnosis of diabetes is not associated with general diabetes knowledge in rural Hispanics. J Rural Health. Fall. 2010;26(4):342-51. X-2, X-4. [pmid: 21029169].
691 Ceber E, Soyer MT, Ciceklioglu M, et al. Breast cancer risk assessment and risk perception on nurses and midwives in Bornova Health District in Turkey. Cancer Nurs. May-Jun. 2006;29(3):244-9. X-2, X-3, X-4, X-5. [pmid: 16783126].
692 Cebul RD. Using electronic medical records to measure and improve performance. Trans Am Clin Climatol Assoc. 2008;119:65-75. discussion -6. X-1, X-6, X-7, X-9. [pmid: 18596863].
693 Celano M, Geller RJ, Phillips KM, et al. Treatment adherence among low-income children with asthma. J Pediatr Psychol. Dec. 1998;23(6):345-9. X-6, X-7, X-9. [pmid: 9824922].
694 Celentano DD, Holtzman D. Breast self-examination competency: an analysis of self-reported practice and associated characteristics. Am J Public Health. Nov. 1983;73(11):1321-3. X-2, X-4, X-6. [pmid: 6625042].
695 Celik HH, Klinge II, Weijden TT, et al. Gender sensitivity among general practitioners: results of a training programme. BMC Med Educ. 2008;8:36. X-9. [pmid: 18582361].
696 696. Celik SS, Celik Y, Agirbas I, et al. Verbal and physical abuse against nurses in Turkey. Int Nurs Rev. Dec. 2007;54(4):359-66. X-2, X-3, X-4, X-5, X-6. [pmid: 17958665].
697 Cella D, Hernandez L, Bonomi AE, et al. Spanish language translation and initial validation of the functional assessment of cancer therapy quality-of-life instrument. Medical Care. Sep. 1998;36(9):1407-18. X-1, X-6, X-7, X-9. [pmid: 9749663].
698 Cernin PA, Lysack C, Lichtenberg PA. A Comparison of Self-Rated and Objectively Measured Successful Aging Constructs in an Urban Sample of African American Older Adults. Clinical Gerontologist. 2011;34(2):89-102. X-2, X-4, X-5. [pmid: 21796228].
699 Cersosimo E, Musi N. Improving Treatment in Hispanic/Latino Patients. American Journal of Medicine. Oct. 2011;124(10):S16-S21. X-1, X-2, X-4. [pmid: 21939794].
700 Chabra A, Chavez GF, Taylor D. Hospital use by pediatric patients: implications for change. Am J Prev Med. Nov-Dec. 1997;13(6 Suppl):30-7. X-2. [pmid: 9455591].
701 Chai SM, Tan KL, Wong JL, et al. Asthma knowledge among adult asthmatic outpatients in a tertiary care hospital. Asian Pac J Allergy Immunol. Jun-Sep. 2004;22(2-3):81-9. X-2, X-4. [pmid: 15565943].
702 Chaix B, Lindström M, Merlo J, et al. Neighbourhood social interactions and risk of acute myocardial infarction. Journal of Epidemiology and Community Health. Jan. 2008;62(1):62-8. X-2, X-3, X-4. [pmid: 18079335].
703 Chambers CV, Balaban DJ, Carlson BL, et al. Microcomputer-generated reminders. Improving the compliance of primary care physicians with mammography screening guidelines. J Fam Pract. Sep. 1989;29(3):273-80. X-6. [pmid: 2769192].
704 Chambers K. Asthma education and outcomes for women of childbearing age. Case Manager. Nov-Dec. 2003;14(6):58-61. X-1, X-6, X-7, X-9. [pmid: 14618151].
705 Champion VL, Skinner CS, Menon U, et al. Comparisons of tailored mammography interventions at two months postintervention. Ann Behav Med. Summer. 2002;24(3):211-8. X-7, X-9. [pmid: 12173678].
706 Champion VL, Springston JK, Zollinger TW, et al. Comparison of three interventions to increase mammography screening in low income African American women. Cancer Detect Prev. 2006;30(6):535-44. X-9, X-10. [pmid: 17110056].
707 Chan AD, Reid GJ, Farvolden P, et al. Learning needs of patients with congestive heart failure. Can J Cardiol. Mar. 31. 2003;19(4):413-7. X-2, X-3, X-4, X-6. [pmid: 12704489].
708 Chan I, Kong P, Leung P, et al. Cognitive-behavioral group program for Chinese heterosexual HIV-infected men in Hong Kong. Patient Educ Couns. Jan. 2005;56(1):78-84. X-3, X-4, X-5, X-6. [pmid: 15590226].
709 Chan JC, Gagliardino JJ, Baik SH, et al. Multifaceted determinants for achieving glycemic control: the International Diabetes Management Practice Study (IDMPS). Diabetes Care. Feb. 2009;32(2):227-33. X-2, X-3, X-4. [pmid: 19033410].
710 Chan KS, Keeler E, Schonlau M, et al. How do ethnicity and primary language spoken at home affect management practices and outcomes in children and adolescents with asthma?. Archives of Pediatrics & Adolescent Medicine. Mar. 2005;159(3):283-9. X-2, X-4. [pmid: 15753274].
711 Chan PS, Oetgen WJ, Buchanan D, et al. Cardiac performance measure compliance in outpatients: the American College of Cardiology and National Cardiovascular Data Registry's PINNACLE (Practice Innovation And Clinical Excellence) program. J Am Coll Cardiol. Jun. 29. 2010;56(1):8-14. X-2, X-4. [pmid: 20620710].
712 Chan YM, Molassiotis A. The relationship between diabetes knowledge and compliance among Chinese with non-insulin dependent diabetes mellitus in Hong Kong. J Adv Nurs. Aug. 1999;30(2):431-8. X-2, X-3, X-6. [pmid: 10457246].
713 Chandra A, Compton S, Sochor M, et al. Untreated hypercholesterolemia in an emergency department chest pain observation unit population. Acad Emerg Med. Jul. 2002;9(7):699-702. X-2, X-4. [pmid: 12093710].
714 Chaney D, Coates V, Shevlin M. Running a complex educational intervention for adolescents with type 1 diabetes -- lessons learnt. Journal of Diabetes Nursing. 2010;14(10):370. X-2, X-3, X-4, X-6.
715 Chang AB, Taylor B, Masters IB, et al. Indigenous healthcare worker involvement for Indigenous adults and children with asthma. Cochrane Database Syst Rev. 2007;(4):CD006344. X-1, X-6, X-7, X-9. [pmid: 17943904].
716 Chang AM, Walsh KM, Shofer FS, et al. Relationship between cocaine use and coronary artery disease in patients with symptoms consistent with an acute coronary syndrome. Academic Emergency Medicine. 2011;18(1):1-9. X-2, X-4, X-6. [pmid: 21182565].
717 Chang C. Increasing mental health literacy via narrative advertising. Journal of Health Communication. Jan. 2008;13(1):37-55. X-1, X-6, X-7, X-9. [pmid: 18307135].
718 Chang CH, Sharp LK, Kimmel LG, et al. A 6-item brief measure for assessing perceived control of asthma in culturally diverse patients. Ann Allergy Asthma Immunol. Aug. 2007;99(2):130-5. X-2, X-4. [pmid: 17718100].
719 Chang HY, Chiou CJ, Lin MC, et al. A population study of the self-care behaviors and their associated factors of diabetes in Taiwan: results from the 2001 National Health Interview Survey in Taiwan. Prev Med. Mar. 2005;40(3):344-8. X-2, X-3, X-4, X-6. [pmid: 15533549].
720 Chang RR, Chen AY, Rodriguez S, et al. Changes in the newborn delivery practice and neonatal outcomes as financing changed in Los Angeles County and Orange County, California. Managed Care Interface. 2005;18(10):53. X-2, X-4. [pmid: 16265936].
721 Chang VW, Asch DA, Werner RM. Quality of care among obese patients. JAMA: Journal of the American Medical Association. Apr. 2010;303(13):1274-81. X-2, X-5, X-6. [pmid: 20371786].
722 Charbonneau A, Rosen AK, Ash AS, et al. Measuring the quality of depression care in a large integrated health system. Medical Care. May. 2003;41(5):669-80. X-2, X-4. [pmid: 12719691].
723 Chartier K. PRONJ looks to reduce racial disparities in diabetes care. Nephrol News Issues. May. 2004;18(6):20-2. X-1, X-6, X-7, X-9. [pmid: 15160415].
724 Chartier M, Stoep AV, McCauley E, et al. Passive versus active parental permission: implications for the ability of school-based depression screening to reach youth at risk. J Sch Health. Mar. 2008;78(3):157-64. quiz 84-6. X-2, X-4, X-6, X-9, X-10. [pmid: 18307611].
725 Chase HP, Crews KR, Garg S, et al. Outpatient management vs in-hospital management of children with new-onset diabetes. Clin Pediatr (Phila). Aug. 1992;31(8):450-6. X-2, X-4, X-6. [pmid: 1643761].
726 Chatkin JM, Blanco DC, Scaglia N, et al. Impact of a low-cost and simple intervention in enhancing treatment adherence in a Brazilian asthma sample. J Asthma. May. 2006;43(4):263-6. X-2, X-6. [pmid: 16809238].
727 Chaudhry SI, Herrin J, Phillips C, et al. Racial disparities in health literacy and access to care among patients with heart failure. J Card Fail. Feb. 2011;17(2):122-7. X-2, X-4. [pmid: 21300301].
728 Chaveepojnkamjorn W, Pichainarong N, Schelp FP, et al. A randomized controlled trial to improve the quality of life of type 2 diabetic patients using a self-help group program. Southeast Asian J Trop Med Public Health. Jan. 2009;40(1):169-76. X-3, X-6. [pmid: 19323050].
729 Chaves N, Weeramanthri T, Mak D, et al. Diabetes audit can aid practice development in a range of indigenous health care settings. Aust J Rural Health. Oct. 2001;9(5):251-3. X-3. [pmid: 11736850].
730 Chee YK, Dennis MP, Gitlin LN. Provider assessment of interactions with dementia caregivers: evaluation and application of the Therapeutic Engagement Index. Clinical Gerontologist. 2005;28(4):43-59. X-2, X-5, X-6.
731 Chen H, Parker G, Kua J, et al. Mental health literacy in Singapore: a comparative survey of psychiatrists and primary health professionals. Ann Acad Med Singapore. Jul. 2000;29(4):467-73. X-2, X-3, X-4, X-6. [pmid: 11056777].
732 Chen J, Rizzo J. Racial and ethnic disparities in use of psychotherapy: evidence from U.S. national survey data. Psychiatr Serv. Apr. 2010;61(4):364-72. X-2, X-4. [pmid: 20360275].
733 Chen JY, Diamant A, Pourat N, et al. Racial/Ethnic Disparities in the Use of Preventive Services Among the Elderly. American Journal of Preventive Medicine. Dec. 2005;29(5):388-95. X-2, X-4. [pmid: 16376701].
734 Chen JY, Diamant AL, Thind A, et al. Determinants of breast cancer knowledge among newly diagnosed, low-income, medically underserved women with breast cancer. Cancer. Mar. 1. 2008;112(5):1153-61. X-2, X-4. [pmid: 18189306].
735 Chen SL, Tsai JC, Lee WL. The impact of illness perception on adherence to therapeutic regimens of patients with hypertension in Taiwan. J Clin Nurs. Aug. 2009;18(15):2234-44. X-2, X-3, X-4. [pmid: 19583655].
736 Chen WT. Predictors of breast examination practices of Chinese immigrants. Cancer Nurs. Jan-Feb. 2009;32(1):64-72. X-2, X-4. [pmid: 19104203].
737 Chen X, White MC, Peipins LA, et al. Increase in screening for colorectal cancer in older Americans: results from a national survey. J Am Geriatr Soc. Aug. 2008;56(8):1511-6. X-2, X-4. [pmid: 18662217].
738 Cheng WS. Adapting a quality of life scale for those with a colostomy in Hong Kong: a preliminary study. World Council of Enterostomal Therapists Journal. 2001;21(3):21. X-2, X-3, X-4, X-5, X-6.
739 Chenot JF, Leonhardt C, Keller S, et al. The impact of specialist care for low back pain on health service utilization in primary care patients: a prospective cohort study. Eur J Pain. Apr. 2008;12(3):275-83. X-2, X-3, X-4, X-5, X-6. [pmid: 17681811].
740 Cheraghali AM, Nikfar S, Behmanesh Y, et al. Evaluation of availability, accessibility and prescribing pattern of medicines in the Islamic Republic of Iran. East Mediterr Health J. May. 2004;10(3):406-15. X-2, X-3, X-5, X-6. [pmid: 16212218].
741 Cherry JC, Moffatt TP, Rodriguez C, et al. Diabetes disease management program for an indigent population empowered by telemedicine technology. Diabetes Technol Ther. 2002;4(6):783-91. X-4, X-9. [pmid: 12685802].
742 Chesla CA, Fisher L, Skaff MM, et al. Family predictors of disease management over one year in Latino and European American patients with type 2 diabetes. Fam Process. Fall. 2003;42(3):375-90. X-2, X-4. [pmid: 14606201].
743 Chesney MA, Chambers DB, Taylor JM, et al. Coping effectiveness training for men living with HIV: results from a randomized clinical trial testing a group-based intervention. Psychosom Med. Nov-Dec. 2003;65(6):1038-46. X-5, X-6. [pmid: 14645783].
744 Chevalier A, Bonenfant S, Picot MC, et al. Occupational factors of anxiety and depressive disorders in the French National Electricity and Gas Company. The Anxiety-Depression Group. J Occup Environ Med. Nov. 1996;38(11):1098-107. X-2, X-3, X-6. [pmid: 8941899].
745 Chiang LC, Huang JL, Chao SY. A comparison, by quantitative and qualitative methods, between the self-management behaviors of parents with asthmatic children in two hospitals. J Nurs Res. Jun. 2005;13(2):85-96. X-2, X-3, X-4. [pmid: 15986310].
746 Chiang ZK, Tai TY. The impact of knowledge to diabetes mellitus on insulin-treated diabetics. Taiwan Yi Xue Hui Za Zhi. May. 1984;83(5):461-9. X-3, X-6. [pmid: 6381641].
747 Chiaranai C, Salyer J, Best A. Self-care and quality in life in patients with heart failure. Thai Journal of Nursing Research. 2009;13(4):302-17. X-2, X-4, X-6.
748 Chiba Y, Shimoyama K, Suzuki Y. Recognition and behaviour of caregiver managers related to oral care in the community. Gerodontology. Jun. 2009;26(2):112-21. X-2, X-4, X-5, X-6. [pmid: 19490133].
749 Chie WC, Chang KJ. Factors related to tumor size of breast cancer at treatment in Taiwan. Prev Med. Jan. 1994;23(1):91-7. X-2, X-3, X-4, X-6. [pmid: 8016039].
750 Chih AH, Jan CF, Shu SG, et al. Self-efficacy affects blood sugar control among adolescents with type I diabetes mellitus. J Formos Med Assoc. Jul. 2010;109(7):503-10. X-2, X-3, X-4. [pmid: 20654789].
751 Chilton L, Hu J, Wallace DC. Health-Promoting Lifestyle and Diabetes Knowledge in Hispanic American Adults. Home Health Care Management & Practice. Aug. 2006;18(5):378-85. X-2, X-4.
752 Chin MH, Cook S, Drum ML, et al. Improving diabetes care in midwest community health centers with the health disparities collaborative. Diabetes Care. Jan. 2004;27(1):2-8. X-6, X-9. [pmid: 14693957].
753 Chin MH, Cook S, Jin L, et al. Barriers to providing diabetes care in community health centers. Diabetes Care. Feb. 2001;24(2):268-74. X-2, X-4, X-6. [pmid: 11213877].
754 Chin MH, Drum ML, Guillen M, et al. Improving and sustaining diabetes care in community health centers with the health disparities collaboratives. Med Care. Dec. 2007;45(12):1135-43. X-9. [pmid: 18007163].
755 Chin MH, Drum ML, Jin L, et al. Variation in treatment preferences and care goals among older patients with diabetes and their physicians. Med Care. Mar. 2008;46(3):275-86. X-2, X-4, X-6. [pmid: 18388842].
756 Chin MH, Polonsky TS, Thomas VD, et al. Developing a conceptual framework for understanding illness and attitudes in older, urban African Americans with diabetes. Diabetes Educ. May-Jun. 2000;26(3):439-49. X-2, X-4. [pmid: 11151291].
757 Chinouya M, O'Keefe E. Zimbabwean cultural traditions in England: Ubunto-Hunhu as a human rights tool. Diversity in Health & Social Care. 2006;3(2):89-98. X-1, X-2, X-3, X-4, X-5, X-6.
758 Chisholm MA, Mulloy LL, Jagadeesan M, et al. Effect of clinical pharmacy services on the blood pressure of African-American renal transplant patients. Ethn Dis. Summer. 2002;12(3):392-7. X-4. [pmid: 12148711].
759 Chisolm DJ, Johnson LD, McAlearney AS. What Makes Teens Start Using and Keep Using Health Information Web Sites? A Mixed Model Analysis of Teens with Chronic Illnesses. Telemedicine and E-Health. Jun. 2011;17(5):324-8. X-2, X-4, X-5, X-6. [pmid: 21495853].
760 Chiu CJ, Wray LA. Gender differences in functional limitations in adults living with type 2 diabetes: biobehavioral and psychosocial mediators. Ann Behav Med. Feb. 2011;41(1):71-82. X-2, X-4. [pmid: 20827519].
761 Chlebowy DO, Garvin BJ. Social support, self-efficacy, and outcome expectations: Impact on self-care behaviors and glycemic control in Caucasian and African American adults with type 2 diabetes. The Diabetes Educator. Sep-Oct. 2006;32(5):777-86. X-6, X-7, X-9. [pmid: 16971711].
762 Chlebowy DO, Hood S, LaJoie AS. Facilitators and barriers to self-management of type 2 diabetes among urban African American adults: focus group findings. Diabetes Educ. Nov-Dec. 2010;36(6):897-905. X-2, X-4. [pmid: 20974906].
763 Choi H, Marks N. Transition to caregiving, marital disagreement, and psychological well-being: a prospective U.S. National Study. Journal of Family Issues. 2006;27(12):1701-22. X-2, X-4, X-5, X-6.
764 Choi J, Bakken S. Comparison of primary care expert and computer-interpretable depression screening guideline recommendations. AMIA Annu Symp Proc. 2006:887. X-2, X-4, X-6. [pmid: 17238506].
765 Choi P, Szumacher E, Adams L, et al. Are we addressing patients' needs in radiation oncology practice? Results of patients' satisfaction pilot survey. Canadian Journal of Medical Radiation Technology. 2006;37(3):7-11. X-2, X-4, X-5, X-6.
766 Choi S, Lee JA, Rush E. Ethnic and language disparities in diabetes care among California residents. Ethn Dis. Spring. 2011;21(2):183-9. X-2, X-4. [pmid: 21749022].
767 Chomba E, McClure EM, Wright LL, et al. Effect of WHO newborn care training on neonatal mortality by education. Ambul Pediatr. Sep-Oct. 2008;8(5):300-4. X-2, X-3, X-4. [pmid: 18922503].
768 Chou AF, Brown AF, Jensen RE, et al. Gender and racial disparities in the management of diabetes mellitus among Medicare patients. Womens Health Issues. May-Jun. 2007;17(3):150-61. X-2, X-4. [pmid: 17475506].
769 Chowdhury EK, El Arifeen S, Rahman M, et al. Care at first-level facilities for children with severe pneumonia in Bangladesh: a cohort study. Lancet. Sep. 6. 2008;372(9641):822-30. X-2, X-3, X-4, X-5. [pmid: 18715634].
770 Choy DK, Tong M, Ko F, et al. Evaluation of the efficacy of a hospital-based asthma education programme in patients of low socioeconomic status in Hong Kong. Clin Exp Allergy. Jan. 1999;29(1):84-90. X-3, X-6. [pmid: 10051706].
771 Christian AH, Mochari HY, Mosca LJ. Coronary heart disease in ethnically diverse women: risk perception and communication. Mayo Clin Proc. Dec. 2005;80(12):1593-9. X-7, X-9, X-10. [pmid: 16342652].
772 Christie J, Itzkowitz S, Lihau-Nkanza I, et al. A randomized controlled trial using patient navigation to increase colonoscopy screening among low-income minorities. J Natl Med Assoc. Mar. 2008;100(3):278-84. X-4. [pmid: 18390020].
773 Christie J, Jandorf L, Itzkowitz S, et al. Sociodemographic correlates of stage of adoption for colorectal cancer screening in African Americans. Ethn Dis. Summer. 2009;19(3):323-9. X-2, X-4. [pmid: 19769016].
774 Christie J, Smith GR, Williamson GM, et al. Quality of informal care is multidimensional. Rehabil Psychol. May. 2009;54(2):173-81. X-2, X-4, X-6. [pmid: 19469607].
775 Chuang HT, Atkinson M. AIDS knowledge and high-risk behaviour in the chronic mentally ill. Can J Psychiatry. Jun. 1996;41(5):269-72. X-2, X-3, X-4, X-5, X-6. [pmid: 8793145].
776 Chugg K, Barton C, Antic R, et al. The impact of alexithymia on asthma patient management and communication with health care providers: a pilot study. J Asthma. Mar. 2009;46(2):126-9. X-2, X-3, X-4, X-6. [pmid: 19253116].
777 Chun KM, Chesla CA, Kwan CM. “So We Adapt Step by Step”: Acculturation experiences affecting diabetes management and perceived health for Chinese American immigrants. Social Science & Medicine. 2011;72(2):256-64. X-2, X-4. [pmid: 21147509].
778 Chung B, Jones L, Dixon EL, et al. Using a community partnered participatory research approach to implement a randomized controlled trial: planning community partners in care. J Health Care Poor Underserved. Aug. 2010;21(3):780-95. X-1, X-6, X-7, X-9. [pmid: 20693725].
779 Chung H, Mahler JC, Kakuma T. Racial differences in treatment of psychiatric inpatients. Psychiatr Serv. Jun. 1995;46(6):586-91. X-2, X-4, X-5. [pmid: 7641000].
780 Chung LK, Cimprich B, Janz NK, et al. Breast cancer survivorship program: testing for cross-cultural relevance. Cancer Nurs. May-Jun. 2009;32(3):236-45. X-2, X-4. [pmid: 19295427].
781 Chunuan SK, Kala S. The effect of stress on childbirth outcomes. Thai Journal of Nursing Research. 2004. Jan-Mar. 2004;8(1):1-13. X-2, X-3, X-4, X-6.
782 Churilla JR, Ford ES. Comparing physical activity patterns of hypertensive and nonhypertensive US adults. Am J Hypertens. Sep. 2010;23(9):987-93. X-2, X-4, X-6. [pmid: 20431526].
783 Ciampa PJ, Osborn CY, Peterson NB, et al. Patient numeracy, perceptions of provider communication, and colorectal cancer screening utilization. J Health Commun. Suppl 3. 2010;15:157-68. X-2, X-4. [pmid: 21154091].
784 Cipher DJ, Clifford PA, Roper KD. The effectiveness of geropsychological treatment in improving pain, depression, behavioral disturbances, functional disability, and health care utilization in long-term care. Clinical Gerontologist. 2007;30(3):23-40. X-4, X-5, X-6.
785 Claes E, Denayer L, Evers-Kiebooms G, et al. Predictive testing for hereditary non-polyposis colorectal cancer: motivation, illness representations and short-term psychological impact. Patient Educ Couns. Nov. 2004;55(2):265-74. X-2, X-4, X-6. [pmid: 15530764].
786 Clancy CM, Lawrence W. Is outcomes research on cancer ready for prime time?. Medical Care. Jun. 2002;40(Suppl6):III-92-III-100. X-1, X-2, X-4, X-6. [pmid: 12064764].
787 Clancy DE, Cope DW, Magruder KM, et al. Evaluating group visits in an uninsured or inadequately insured patient population with uncontrolled type 2 diabetes. Diabetes Educ. Mar-Apr. 2003;29(2):292-302. X-7. [pmid: 12728756].
788 Clancy DE, Cope DW, Magruder KM, et al. Evaluating concordance to American Diabetes Association standards of care for type 2 diabetes through group visits in an uninsured or inadequately insured patient population. Diabetes Care. Jul. 2003;26(7):2032-6. X-7, X-9. [pmid: 12832308].
789 Clark CR, Baril N, Kunicki M, et al. Addressing social determinants of health to improve access to early breast cancer detection: Results of the Boston REACH 2010 Breast and Cervical Cancer Coalition Women's Health Demonstration Project. Journal of Women's Health. May. 2009;18(5):677-90. X-7, X-9. [pmid: 19445616].
790 Clark CR, Baril N, Kunicki M, et al. Mammography use among Black women: the role of electronic medical records. J Womens Health (Larchmt). Aug. 2009;18(8):1153-62. X-2, X-4. [pmid: 19630545].
791 Clark DO, Tu WZ, Weiner M, et al. Correlates of health-related quality of life among lower-income, urban adults with congestive heart failure. Heart & Lung. Nov-Dec. 2003;32(6):391-401. X-2, X-4. [pmid: 14652531].
792 Clark J. Constructing expertise: inequality and the consequences of information-seeking by breast cancer patients. Illness, Crisis & Loss. 2005;13(2):169-85. X-2, X-4.
793 Clark JC, Lan VM. Heart failure patient learning needs after hospital discharge. Appl Nurs Res. Aug. 2004;17(3):150-7. X-2, X-4. [pmid: 15343548].
794 Clark L, Vincent D, Zimmer L, et al. Cultural values and political economic contexts of diabetes among low-income Mexican Americans. J Transcult Nurs. Oct. 2009;20(4):382-94. X-2, X-4, X-5. [pmid: 19376966].
795 Clark NM, Dodge JA, Shah S, et al. A current picture of asthma diagnosis, severity, and control in a low-income minority preteen population. J Asthma. Mar. 2010;47(2):150-5. X-2, X-4. [pmid: 20170321].
796 Clark NM, Feldman CH, Evans D, et al. The impact of health education on frequency and cost of health care use by low income children with asthma. J Allergy Clin Immunol. Jul. 1986;78(1 Pt 1):108-15. X-6, X-9. [pmid: 3088085].
797 Clark NM, Feldman CH, Evans D, et al. Changes in children's school performance as a result of education for family management of asthma. J Sch Health. Apr. 1984;54(4):143-5. X-6, X-7, X-10. [pmid: 6562287].
798 Clark NM, Gong ZM, Wang SJ, et al. A randomized trial of a self-regulation intervention for women with asthma. Chest. Jul. 2007;132(1):88-97. X-7, X-9. [pmid: 17505047].
799 Clark NM, Gong ZM, Wang SJ, et al. From the female perspective: Long-term effects on quality of life of a program for women with asthma. Gend Med. Apr. 2010;7(2):125-36. X-6, X-9. [pmid: 20435275].
800 Clark NM, Levison MJ, Evans D, et al. Communication within low income families and the management of asthma. Patient Educ Couns. Apr. 1990;15(2):191-210. X-2, X-4. [pmid: 2290752].
801 Clark NM, Shah S, Dodge JA, et al. An evaluation of asthma interventions for preteen students. J Sch Health. Feb. 2010;80(2):80-7. X-8, X-10. [pmid: 20236406].
802 Clark RE, Weir S, Ouellette RA, et al. Beyond health plans: Behavioral health disorders and quality of diabetes and asthma care for Medicaid beneficiaries. Medical Care. May. 2009;47(5):545-52. X-2, X-4, X-6. [pmid: 19319000].
803 Claudio L, Stingone JA. Primary household language and asthma care among Latino children. Journal of Health Care for the Poor and Underserved. Aug. 2009;20(3):766-79. X-2, X-4. [pmid: 19648704].
804 Clauser SB, Wagner EH, Bowles EJA, et al. Improving modern cancer care through information technology. American Journal of Preventive Medicine. May. 2011;40(5, Suppl 2):S198-S207. X-1, X-2, X-4, X-5, X-6. [pmid: 21521595].
805 Clauson KA, Zeng-Treitler Q, Kandula S. Readability of patient and health care professional targeted dietary supplement leaflets used for diabetes and chronic fatigue syndrome. J Altern Complement Med. Jan. 2010;16(1):119-24. X-2, X-4, X-6. [pmid: 20064017].
806 Clay KS, Talley C, Young KB. Exploring spiritual well-being among survivors of colorectal and lung cancer. Journal of Religion & Spirituality in Social Work. 2010. Jan-Mar. 2010;29(1):14-32. X-2, X-4. [pmid: 20625520].
807 Clayman ML, Pandit AU, Bergeron AR, et al. Ask, understand, remember: a brief measure of patient communication self-efficacy within clinical encounters. J Health Commun. Suppl 2. 2010;15:72-9. X-2, X-4. [pmid: 20845194].
808 Clayton LH. TEMPtEd: development and psychometric properties of a tool to evaluate material used in patient education. J Adv Nurs. Oct. 2009;65(10):2229-38. X-2, X-4, X-5, X-6. [pmid: 19686403].
809 Clegg-Lamptey JN, Dakubo JC, Attobra YN. Psychosocial aspects of breast cancer treatment in Accra, Ghana. East Afr Med J. Jul. 2009;86(7):348-53. X-2, X-3, X-4. [pmid: 20499785].
810 Cleghorn GD, Nguyen M, Roberts B, et al. Practice-based interventions to improve health care for Latinos with diabetes. Ethn Dis. Summer. 2004;14(3 Suppl 1):S117-21. X-6, X-9. [pmid: 15682780].
811 Cleveland WH, Marable KG. Renal failure and donation for transplantation in the African-American community. J Med Assoc Ga. Apr. 1998;87(2):101-3. X-13. [pmid: 16259252].
812 Clever SL, Ford DE, Rubenstein LV, et al. Primary care patients' involvement in decision-making is associated with improvement in depression. Med Care. May. 2006;44(5):398-405. X-6, X-7, X-9. [pmid: 16641657].
813 Clingerman E. Type 2 diabetes among migrant and seasonal farmworkers. Hispanic Health Care International. 2008;6(2):97-106. X-2, X-4.
814 Cloutier MM, Hall CB, Wakefield DB, et al. Use of asthma guidelines by primary care providers to reduce hospitalizations and emergency department visits in poor, minority, urban children. J Pediatr. May. 2005;146(5):591-7. X-2, X-4, X-9. [pmid: 15870660].
815 Coady MH, Galea S, Blaney S, et al. Project VIVA: A multilevel community-based intervention to increase influenza vaccination rates among hard-to-reach populations in New York City. American Journal of Public Health. Jul. 2008;98(7):1314-21. X-5, X-6. [pmid: 18511725].
816 Cochran CR, Gorospe EC. Physician satisfaction in a cancer prevention program for low-income women in Nevada. ScientificWorldJournal. 2007;7:177-86. X-2, X-4, X-6. [pmid: 17334609].
817 Coffey LP. Care for children. Healthplan. May-Jun. 1996;37(3):86-93. X-1, X-6, X-7, X-9. [pmid: 10162272].
818 Coffman MJ. Effects of tangible social support and depression on diabetes self-efficacy. J Gerontol Nurs. Apr. 2008;34(4):32-9. X-2, X-4. [pmid: 18429377].
819 Coggin C, Shaw-Perry M. Breast cancer survivorship: expressed needs of black women. J Psychosoc Oncol. 2006;24(4):107-22. X-2, X-4. [pmid: 17182479].
820 Cohen M, Azaiza F. Increasing breast examinations among arab women using a tailored culture-based intervention. Behav Med. Jul-Sep. 2010;36(3):92-9. X-3, X-4. [pmid: 20801757].
821 Cohen MG, Fonarow GC, Peterson ED, et al. Racial and ethnic differences in the treatment of acute myocardial infarction: findings from the Get With the Guidelines-Coronary Artery Disease program. Circulation. Jun. 1. 2010;121(21):2294-301. X-6, X-7, X-9, X-10. [pmid: 20479153].
822 Cohen MG, Roe MT, Mulgund J, et al. Clinical characteristics, process of care, and outcomes of Hispanic patients presenting with non-ST-segment elevation acute coronary syndromes: results from Can Rapid risk stratification of Unstable angina patients Suppress ADverse outcomes with Early implementation of the ACC/AHA Guidelines (CRUSADE). Am Heart J. Jul. 2006;152(1):110-7. X-2. [pmid: 16824839].
823 Cohen SJ, Meister JS, deZapien JG. Special action groups for policy change and infrastructure support to foster healthier communities on the Arizona-Mexico border. Public Health Rep. Jan-Feb. 2004;119(1):40-7. X-1, X-2, X-4, X-9, X-10. [pmid: 15147648].
824 Cole DA, Jordan AE. Competence and memory: integrating psychosocial and cognitive correlates of child depression. Child Dev. Apr. 1995;66(2):459-73. X-2, X-4, X-6. [pmid: 7750377].
825 Cole N. Depression awareness: Community-based approach. Australian Psychologist. Jun. 2007;42(2):161-6. X-1, X-6, X-7, X-9.
826 Coleman CL, Holzemer WL, Eller LS, et al. Gender differences in use of prayer as a self-care strategy for managing symptoms in African Americans living with HIV/AIDS. J Assoc Nurses AIDS Care. Jul-Aug. 2006;17(4):16-23. X-2, X-4, X-5. [pmid: 16849085].
827 Coleman EA, Coon S, Mohrmann C, et al. Developing and testing lay literature about breast cancer screening for African American women. Clin J Oncol Nurs. Jan-Feb. 2003;7(1):66-71. X-2, X-4, X-9. [pmid: 12629937].
828 Coleman K, Reiter KL, Fulwiler D. The impact of pay-for-performance on diabetes care in a large network of community health centers. J Health Care Poor Underserved. Nov. 2007;18(4):966-83. X-7. [pmid: 17982218].
829 Coleman KJ, Clark AY, Shordon M, et al. Teen peer educators and diabetes knowledge of low-income fifth grade students. J Community Health. Feb. 2011;36(1):23-6. X-4, X-7, X-8, X-9, X-10. [pmid: 20496001].
830 Coleman KJ, Ocana LL, Walker C, et al. Outcomes from a culturally tailored diabetes prevention program in Hispanic families from a low-income school: Horton Hawks Stay Healthy (HHSH). Diabetes Educ. Sep-Oct. 2010;36(5):784-92. X-8, X-10. [pmid: 20651100].
831 Coleman MP, Forman D, Bryant H, et al. Cancer survival in Australia, Canada, Denmark, Norway, Sweden, and the UK, 1995-2007 (the International Cancer Benchmarking Partnership): an analysis of population-based cancer registry data. Lancet. Jan. 8. 2011;377(9760):127-38. X-2, X-3, X-4, X-6. [pmid: 21183212].
832 Coleman MT, Lott JA, Sharma S. Use of continuous quality improvement to identify barriers in the management of hypertension. Am J Med Qual. Mar-Apr. 2000;15(2):72-7. X-2, X-7, X-9, X-10. [pmid: 10763221].
833 Colen BD. Proceedings of the Workshop on Inherited Breast Cancer in Jewish Women: Ethical, Legal, and Social Implications. Law Med News. Summer. 1996;2(1):1-4. X-1, X-2, X-3, X-4, X-6. [pmid: 11654468].
834 Collie-Akers V, Schultz JA, Carson V, et al. Evaluating mobilization strategies with neighborhood and faith organizations to reduce risk for health disparities. Health Promot Pract. Apr. 2009;10(2 Suppl):118S-27S. X-7, X-8, X-10. [pmid: 19454758].
835 Collie-Akers VL, Fawcett SB, Schultz JA, et al. Analyzing a community-based coalition's efforts to reduce health disparities and the risk for chronic disease in Kansas City, Missouri. Prev Chronic Dis. Jul. 2007;4(3):A66. X-2, X-4. [pmid: 17572970].
836 Collier J, Pattison H, Watson A, et al. Parental information needs in chronic renal failure and diabetes mellitus. Eur J Pediatr. Jan. 2001;160(1):31-6. X-2. [pmid: 11195015].
837 Collins MM, O'Sullivan T, Harkins V, et al. Quality of life and quality of care in patients with diabetes experiencing different models of care. Diabetes Care. Apr. 2009;32(4):603-5. X-2, X-4. [pmid: 19171727].
838 Collins-McNeil J, Holston EC, Edwards CL, et al. Depressive symptoms, cardiovascular risk, and diabetes self-care strategies in African American women with type 2 diabetes. Arch Psychiatr Nurs. Aug. 2007;21(4):201-9. X-2, X-4. [pmid: 17673112].
839 Coltin KL, Beck A. The HEDIS antidepressant measure. Behav Healthc Tomorrow. Jun. 1999;8(3):40-1. 7. X-1, X-6, X-7, X-9. [pmid: 10537652].
840 Comellas M, Walker EA, Movsas S, et al. Training community health promoters to implement diabetes self-management support programs for urban minority adults. Diabetes Educ. Jan-Feb. 2010;36(1):141-51. X-4. [pmid: 19966071].
841 Commander MJ, O'Dell SM, Surtees PG, et al. Characteristics of patients and patterns of psychiatric service use in ethnic minorities. Int J Soc Psychiatry. Sep. 2003;49(3):216-24. X-2, X-3, X-4. [pmid: 14626364].
842 Compean-Ortiz LG, Gallegos EC, Gonzalez-Gonzalez JG, et al. Cognitive performance associated with self-care activities in Mexican adults with type 2 diabetes. Diabetes Educ. Mar-Apr. 2010;36(2):268-75. X-2, X-4. [pmid: 20179249].
843 Concepcion D. How to make the new conditions for coverage work in your dialysis clinic. Water treatment, dialysate prep. Nephrol News Issues. Jan. 2009;23(1):34. 6. X-1, X-2, X-3, X-4, X-6. [pmid: 19235356].
844 844. Concepcion DB. A model of career advancement for dialysis technicians. Nephrol News Issues. Apr. 2008;22(4):44. 6. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18488820].
845 Condon JV, Miller KM, Le AH, et al. Acute myocardial infarction and race, sex, and insurance types: unequal processes of care. Health Care Manager. 2008;27(3):212-22. X-2, X-4. [pmid: 18695400].
846 Cone MM, Shoop KM, Rea JD, et al. Ethnicity influences lymph node resection in colon cancer. J Gastrointest Surg. Nov. 2010;14(11):1752-7. X-2, X-4. [pmid: 20714936].
847 Conerly R. Communicating cancer control messages to low-literate and diverse audiences. Journal of Psychosocial Oncology. Special Issue: Psychosocial factors that influence participation in colorectal cancer screening. 2001;19(3-4):147-59. X-1, X-2, X-3, X-4, X-6.
848 Conroy S, Marks MN. Maternal psychological vulnerability and early infant care in a sample of materially disadvantaged women. Journal of Reproductive & Infant Psychology. 2003;21(1):5-22. X-2, X-4, X-5.
849 Conway SP, Pond MN, Watson A, et al. Knowledge of adult patients with cystic fibrosis about their illness. Thorax. Jan. 1996;51(1):34-8. X-2, X-4, X-6. [pmid: 8658366].
850 Cook A, Grothaus CT, Gutierrez CE, et al. Closing the gap “Disparity in Native Hawaiian cardiac care”. Hawaii Med J. May. 2010;69(5 Suppl 2):7-10. X-4, X-9. [pmid: 20544602].
851 Cooksey C, Lanza AP. Examining diabetes health benefits in health plans of large employers. J Public Health Manag Pract. Nov. 2003;(Suppl):S30-5. X-2, X-4. [pmid: 14677328].
852 Coonrod BA, Betschart J, Harris MI. Frequency and determinants of diabetes patient education among adults in the U.S. population. Diabetes Care. Aug. 1994;17(8):852-8. X-2, X-4. [pmid: 7956630].
853 Cooper C, Bebbington P, McManus S, et al. The treatment of Common Mental Disorders across age groups: results from the 2007 Adult Psychiatric Morbidity Survey. J Affect Disord. Dec. 2010;127(1-3):96-101. X-2, X-4. [pmid: 20466432].
854 Cooper CP, Gelb CA, Jameson H, et al. Developing English and Spanish television public service announcements to promote colorectal cancer screening. Health Promot Pract. Oct. 2005;6(4):385-93. X-1, X-2, X-4. [pmid: 16210680].
855 Cooper CP, Saraiya M, McLean TA, et al. Report from the CDC. Pap test intervals used by physicians serving low-income women through the National Breast and Cervical Cancer Early Detection Program. J Womens Health (Larchmt). Oct. 2005;14(8):670-8. X-2, X-4, X-5. [pmid: 16232098].
856 Cooper LA, Gonzales JJ, Gallo JJ, et al. The Acceptability of Treatment for Depression Among African-American, Hispanic, and White Primary Care Patients. Medical Care. Apr. 2003;41(4):479-89. X-2, X-4. [pmid: 12665712].
857 Cooper PJ, Landman M, Tomlinson M, et al. Impact of a mother-infant intervention in an indigent peri-urban South African context: pilot study. Br J Psychiatry. Jan. 2002;180:76-81. X-3, X-4, X-6. [pmid: 11772856].
858 Cooper PJ, Tomlinson M, Swartz L, et al. Improving quality of mother-infant relationship and infant attachment in socioeconomically deprived community in South Africa: randomised controlled trial [corrected]. [published erratum appears in BMJ 2009 Jun 6;338:1370]. BMJ: British Medical Journal. 2009;338(7701):997. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19366752].
859 Coppieters Y, Piette D. Targeting pupils at risk of occupational asthma. Patient Educ Couns. Oct. 2004;55(1):136-41. X-2, X-3, X-4, X-6. [pmid: 15477001].
860 Corbett CF. Research-based practice implications for patients with diabetes. Part I: Diabetes knowledge. Home Healthc Nurse. Aug. 1999;17(8):511-8. X-1, X-2, X-4. [pmid: 10745775].
861 Cordasco KM, Asch SM, Bell DS, et al. A Low-Literacy Medication Education Tool for Safety-Net Hospital Patients. American Journal of Preventive Medicine. Dec. 2009;37(6):S209-S16. X-9. [pmid: 19896021].
862 Corey-Lisle PK, Birnbaum HG, Greenberg PE, et al. Identification of a claims data “signature” and economic consequences for treatment-resistant depression. J Clin Psychiatry. Aug. 2002;63(8):717-26. X-2, X-4, X-6. [pmid: 12197453].
863 Corkery E, Palmer C, Foley ME, et al. Effect of a bicultural community health worker on completion of diabetes education in a Hispanic population. Diabetes Care. Mar. 1997;20(3):254-7. X-4. [pmid: 9051367].
864 Corney R, Everett H, Howells A, et al. The care of patients undergoing surgery for gynaecological cancer: the need for information, emotional support and counselling. J Adv Nurs. Jun. 1992;17(6):667-71. X-2, X-4, X-6. [pmid: 1607497].
865 Coronado GD, Thompson B, Tejeda S, et al. Sociodemographic factors and self-management practices related to type 2 diabetes among Hispanics and non-Hispanic whites in a rural setting. J Rural Health. Winter. 2007;23(1):49-54. X-2, X-4. [pmid: 17300478].
866 Correa-de-Araujo R, McDermott K, Moy E. Gender differences across racial and ethnic groups in the quality of care for diabetes. Womens Health Issues. Mar-Apr. 2006;16(2):56-65. X-2, X-4. [pmid: 16638522].
867 Correa-de-Araujo R, Stevens B, Moy E, et al. Gender Differences Across Racial and Ethnic Groups in the Quality of Care for Acute Myocardial Infarction and Heart Failure Associated with Comorbidities. Women's Health Issues. Mar-Apr. 2006;16(2):44-55. X-2. [pmid: 16638521].
868 Corrigan M, Cupples ME, Stevenson M. Quitting and restarting smoking: cohort study of patients with angina in primary care. BMJ. Apr. 27. 2002;324(7344):1016-7. X-6, X-7, X-9. [pmid: 11976245].
869 Cortes T, Lee A, Boal J, et al. Using focus groups to identify asthma care and education issues for elderly urban-dwelling minority individuals. Appl Nurs Res. Aug. 2004;17(3):207-12. X-2, X-4. [pmid: 15343555].
870 Cortina S, Repaske DR, Hood KK. Sociodemographic and psychosocial factors associated with continuous subcutaneous insulin infusion in adolescents with type 1 diabetes. Pediatr Diabetes. Aug. 2010;11(5):337-44. X-2, X-4. [pmid: 19761529].
871 Corvera-Tindel T, Doering LV, Roper J, et al. Emotional functioning drives quality of life in men with heart failure. Progress in Cardiovascular Nursing. 2009;24(1):2-11. X-2, X-6. [pmid: 19261137].
872 Cosby JL, Houlden RL. Health beliefs toward diabetes mellitus in two Ontario First Nation populations. Canadian Journal of Diabetes Care. 1996;20(2):12-9. X-2, X-3, X-4.
873 Costantini L, Beanlands H, McCay E, et al. The self-management experience of people with mild to moderate chronic kidney disease. Nephrol Nurs J. Mar-Apr. 2008;35(2):147-55. quiz 56. X-1, X-2, X-4. [pmid: 18472683].
874 Cote I, Moisan J, Chabot I, et al. Health-related quality of life in hypertension: impact of a pharmacy intervention programme. J Clin Pharm Ther. Aug. 2005;30(4):355-62. X-3, X-4. [pmid: 15985049].
875 Coughlin SS, Thompson T. Physician recommendation for colorectal cancer screening by race, ethnicity, and health insurance status among men and women in the United States, 2000. Health Promot Pract. Oct. 2005;6(4):369-78. X-2, X-4. [pmid: 16210678].
876 Coups EJ, Hay J, Ford JS. Awareness of the role of physical activity in colon cancer prevention. Patient Educ Couns. Aug. 2008;72(2):246-51. X-2, X-4. [pmid: 18455355].
877 Courtenay-Quirk C, Horvath KJ, Ding H, et al. Perceptions of HIV-related websites among persons recently diagnosed with HIV. AIDS Patient Care STDS. Feb. 2010;24(2):105-15. X-2, X-4, X-5, X-6. [pmid: 20064028].
878 Coventry JA, Weston MS, Collins PM. Emergency room encounters of pediatric patients with asthma: cost comparisons with other treatment settings. J Ambul Care Manage. Apr. 1996;19(2):9-21. X-2, X-4, X-6. [pmid: 10156661].
879 Cowell JM, McNaughton D, Ailey S, et al. Clinical trial outcomes of the Mexican American Problem Solving Program (MAPS). Hispanic Health Care International. 2009;7(4):178-89. X-7, X-9. [pmid: 20877438].
880 Cowie CC, Harris MI. Ambulatory medical care for non-Hispanic whites, African-Americans, and Mexican-Americans with NIDDM in the U.S. Diabetes Care. Feb. 1997;20(2):142-7. X-2. [pmid: 9118761].
881 Cowley C, Daws L, Ellis B. Health informatics and modernisation: bridging the gap. Inform Prim Care. 2003;11(4):207-14. X-1, X-2, X-3, X-4. [pmid: 14980060].
882 Cox N, Bowmer C, Ring A. Health literacy and the provision of information to women with breast cancer. Clin Oncol (R Coll Radiol). Apr. 2011;23(3):223-7. X-2, X-4, X-6. [pmid: 21186100].
883 Cox RH, Carpenter JP, Bruce FA, et al. Characteristics of low-income African-American and Caucasian adults that are important in self-management of type 2 diabetes. J Community Health. Apr. 2004;29(2):155-70. X-2, X-4. [pmid: 15065734].
884 Coyle YM, Aragaki CC, Hynan LS, et al. Effectiveness of Acute Asthma Care Among Inner-city Adults. Arch Intern Med. Jul. 14. 2003;163(13):1591-6. X-7, X-9. [pmid: 12860583].
885 Craig BM, Kraus CK, Chewning BA, et al. Quality of care for older adults with chronic obstructive pulmonary disease and asthma based on comparisons to practice guidelines and smoking status. BMC Health Serv Res. 2008;8:144. X-2, X-4, X-6. [pmid: 18611245].
886 Cram P, Rosenthal GE, Vaughan-Sarrazin MS. Cardiac revascularization in specialty and general hospitals. N Engl J Med. Apr. 7. 2005;352(14):1454-62. X-2. [pmid: 15814881].
887 Cramer JA, Pugh MJ. The influence of insulin use on glycemic control: How well do adults follow prescriptions for insulin?. Diabetes Care. Jan. 2005;28(1):78-83. X-2, X-4. [pmid: 15616237].
888 Cramer JS, Sibley RF, Bartlett DP, et al. An adaptation of the diabetes prevention program for use with high-risk, minority patients with type 2 diabetes. Diabetes Educ. May-Jun. 2007;33(3):503-8. X-6, X-9. [pmid: 17570881].
889 Crane LA, Leakey TA, Ehrsam G, et al. Effectiveness and cost-effectiveness of multiple outcalls to promote mammography among low-income women. Cancer Epidemiol Biomarkers Prev. Sep. 2000;9(9):923-31. X-9. [pmid: 11008910].
890 Crane PB. I want to know: exploring how older women acquire health knowledge after a myocardial infarction. J Women Aging. 2001;13(4):3-20. X-2, X-4. [pmid: 11876432].
891 Crane PB, Oles KS, Kennedy-Malone L. Beta-blocker medication usage in older women after myocardial infarction. J Am Acad Nurse Pract. Oct. 2006;18(10):463-70. X-2, X-4, X-6. [pmid: 16999711].
892 Cranston RD, Darragh TM, Holly EA, et al. Self-collected versus clinician-collected anal cytology specimens to diagnose anal intraepithelial neoplasia in HIV-positive men. J Acquir Immune Defic Syndr. Aug. 1. 2004;36(4):915-20. X-2, X-4, X-5, X-6. [pmid: 15220697].
893 Crawford P, Maxey R, Dacosta K. Community outreach: a call for community action. J Natl Med Assoc. Aug. 2002;94(8 Suppl):63S-71S. X-1, X-2, X-4, X-5, X-6. [pmid: 12152914].
894 Creamer P, Hochberg MC. The relationship between psychosocial variables and pain reporting in osteoarthritis of the knee. Arthritis Care Res. Feb. 1998;11(1):60-5. X-1, X-2, X-4, X-5, X-6. [pmid: 9534495].
895 Creer TL, Marion RJ, Creer PP. Asthma problem behavior checklist: parental perceptions of the behavior of asthmatic children. J Asthma. 1983;20(2):97-104. X-6, X-7, X-9. [pmid: 6853434].
896 Cress RD, Zaslavsky AM, West DW, et al. Completeness of information on adjuvant therapies for colorectal cancer in population-based cancer registries. Med Care. Sep. 2003;41(9):1006-12. X-2, X-4, X-6. [pmid: 12972840].
897 Crilly MA, Bundred PE. Gender inequalities in the management of angina pectoris: cross-sectional survey in primary care. Scott Med J. Nov. 2005;50(4):154-8. X-2, X-4. [pmid: 16374978].
898 Cristancho S, Garces DM, Peters KE, et al. Listening to rural Hispanic immigrants in the midwest: A community-based participatory assessment of major barriers to health care access and use. Qualitative Health Research. May. 2008;18(5):633-46. X-2, X-4, X-5. [pmid: 18420537].
899 Cromwell J, McCall NT, Burton J, et al. Race/ethnic disparities in utilization of lifesaving technologies by Medicare ischemic heart disease beneficiaries. Med Care. Apr. 2005;43(4):330-7. X-2. [pmid: 15778636].
900 Cromwell SL, Adams MM. Exercise, self-efficacy, and exercise behavior in hypertensive older African-Americans. J Natl Black Nurses Assoc. Jul. 2006;17(1):17-21. X-1, X-2, X-4. [pmid: 17004422].
901 Cronin DP, Harlan LC, Potosky AL, et al. Patterns of care for adjuvant therapy in a random population-based sample of patients diagnosed with colorectal cancer. Am J Gastroenterol. Oct. 2006;101(10):2308-18. X-2, X-6. [pmid: 17032196].
902 Crown WH, Treglia M, Meneades L, et al. Long-term costs of treatment for depression: impact of drug selection and guideline adherence. Value Health. Jul-Aug. 2001;4(4):295-307. X-2, X-6. [pmid: 11705297].
903 Culhane-Pera K, Peterson KA, Crain AL, et al. Group visits for Hmong adults with type 2 diabetes mellitus: a pre-post analysis. J Health Care Poor Underserved. May. 2005;16(2):315-27. X-4. [pmid: 15937395].
904 Culica D, Walton JW, Harker K, et al. Effectiveness of a community health worker as sole diabetes educator: comparison of CoDE with similar culturally appropriate interventions. J Health Care Poor Underserved. Nov. 2008;19(4):1076-95. X-9. [pmid: 19029738].
905 Cunningham R. Perspectives. Indefinite results in ABMT (autologous bone marrow transplantation) trials add to challenges for practice standards, quality assurance in cancer care. Med Health. Apr. 19. suppl. 1999;53(16):1-4. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10387749].
906 Cupples ME, McKnight A, O'Neill C, et al. The effect of personal health education on the quality of life of patients with angina in general practice. Health Education Journal. 1996;55(1):75-83. X-3, X-6, X-9.
907 Cupples ME, Stewart MC, Percy A, et al. A RCT of peer-mentoring for first-time mothers in socially disadvantaged areas (the MOMENTS Study). Arch Dis Child. Mar. 2011;96(3):252-8. X-3, X-5, X-7, X-9. [pmid: 20522466].
908 Curbow B, Fogarty LA, McDonnell K, et al. Can a brief video intervention improve breast cancer clinical trial knowledge and beliefs?. Soc Sci Med. Jan. 2004;58(1):193-205. X-9, X-10. [pmid: 14572931].
909 Currie J, Grogger J. Medicaid expansions and welfare contractions: offsetting effects on prenatal care and infant health?. J Health Econ. Mar. 2002;21(2):313-35. X-1, X-2, X-4. [pmid: 11939244].
910 Cypress M, Ponder S. A summary of the certification examinations from 1994 and 1995. Diabetes Educ. Sep-Oct. 1997;23(5):529-32. X-6, X-7, X-9. [pmid: 9355368].
911 Dailey AB, Kasl SV, Holford TR, et al. Perceived racial discrimination and nonadherence to screening mammography guidelines: results from the race differences in the screening mammography process study. Am J Epidemiol. Jun. 1. 2007;165(11):1287-95. X-2, X-4. [pmid: 17351294].
912 Dailey AB, Kasl SV, Jones BA. Does gender discrimination impact regular mammography screening? Findings from the race differences in screening mammography study. J Womens Health (Larchmt). Mar. 2008;17(2):195-206. X-2, X-4. [pmid: 18321171].
913 Dalcin PT, Piovesan DM, Kang S, et al. Factors associated with emergency department visits due to acute asthma. Braz J Med Biol Res. Sep. 2004;37(9):1331-8. X-2, X-4, X-6. [pmid: 15334198].
914 Daley AJ, Crank H, Mutrie N, et al. Determinants of adherence to exercise in women treated for breast cancer. Eur J Oncol Nurs. Dec. 2007;11(5):392-9. X-4. [pmid: 17524796].
915 Daley MF, Steiner JF, Brayden RM, et al. Immunization registry-based recall for a new vaccine. Ambul Pediatr. Nov-Dec. 2002;2(6):438-43. X-7, X-9. [pmid: 12437389].
916 Dallo FJ, Weller SC. Effectiveness of diabetes mellitus screening recommendations. Proc Natl Acad Sci U S A. Sep. 2. 2003;100(18):10574-9. X-2, X-4. [pmid: 12925739].
917 Dalmida SG, Robertson B, Carrion MM, et al. Spirituality, religiousness, psychosocial factors, and maternal-infant outcomes in Latina mothers. Southern Online Journal of Nursing Research. 2010;10(3):12p. X-2, X-4.
918 Dalton AR, Alshamsan R, Majeed A, et al. Exclusion of patients from quality measurement of diabetes care in the UK pay-for-performance programme. Diabet Med. May. 2011;28(5):525-31. X-2, X-3, X-4. [pmid: 21294767].
919 Damkjae LH, Deltour I, Suppli NP, et al. Breast cancer and early retirement: Associations with disease characteristics, treatment, comorbidity, social position and participation in a six-day rehabilitation course in a register-based study in Denmark. Acta Oncol. Feb. 2011;50(2):274-81. X-2, X-3, X-4, X-6. [pmid: 21231788].
920 Damush TM, Plue L, Bakas T, et al. Barriers and facilitators to exercise among stroke survivors. Rehabil Nurs. Nov-Dec. 2007;32(6):253-60. 62. X-2, X-4, X-5. [pmid: 18065147].
921 Dang S, Remon N, Harris J, et al. Care coordination assisted by technology for multiethnic caregivers of persons with dementia: a pilot clinical demonstration project on caregiver burden and depression. J Telemed Telecare. 2008;14(8):443-7. X-4, X-5. [pmid: 19047456].
922 Dangelser G, Besson S, Gatina JH, et al. Amputations among diabetics in Reunion Island. Diabetes Metab. Dec. 2003;29(6):628-34. X-2, X-3, X-4, X-6. [pmid: 14707893].
923 Danhauer SC, Sorocco KH, Andrykowski MA. Accentuating the positive: recent “uplifts” reported by nursing home residents. Clinical Gerontologist. 2006;29(3):39-58. X-2, X-4, X-5, X-6.
924 Daniel DM, Norman J, Davis C, et al. A state-level application of the chronic illness breakthrough series: results from two collaboratives on diabetes in Washington State. Jt Comm J Qual Saf. Feb. 2004;30(2):69-79. X-6. [pmid: 14986337].
925 Daniels A, Biesma R, Otten J, et al. Ambivalence of primary health care professionals towards the South African guidelines for hypertension and diabetes. S Afr Med J. Dec. 2000;90(12):1206-11. X-2, X-3, X-4, X-6. [pmid: 11234651].
926 Daniels EC, Bacon J, Denisio S, et al. Translation squared: improving asthma care for high-disparity populations through a safety net practice-based research network. J Asthma. Jul-Aug. 2005;42(6):499-505. X-9. [pmid: 16293546].
927 Daniels N, Sabin JE. Last chance therapies and managed care. Pluralism, fair procedures, and legitimacy. Hastings Cent Rep. Mar-Apr. 1998;28(2):27-41. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 9589291].
928 Darling CM, Nelson CP, Fife RS. Improving breast health education for Hispanic women. J Am Med Womens Assoc. Summer. 228. 2004;59(3):171-9. X-9. [pmid: 15354369].
929 Darnell JS, Chang CH, Calhoun EA. Knowledge about breast cancer and participation in a faith-based breast cancer program and other predictors of mammography screening among African American women and Latinas. Health Promot Pract. Jul. 2006;7(3 Suppl):201S-12S. X-7, X-8, X-10. [pmid: 16760248].
930 Dashiff C, Bartolucci A, Wallander J, et al. The relationship of family structure, maternal employment, and family conflict with self-care adherence of adolescents with type 1 diabetes. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2005;23(1):66-79. X-2, X-4, X-6.
931 Das-Munshi J, Stewart R, Ismail K, et al. Diabetes, common mental disorders, and disability: findings from the UK National Psychiatric Morbidity Survey. Psychosom Med. Jul-Aug. 2007;69(6):543-50. X-2, X-3, X-4, X-6. [pmid: 17636148].
932 Daumit GL, Hermann JA, Powe NR. Relation of gender and health insurance to cardiovascular procedure use in persons with progression of chronic renal disease. Med Care. Apr. 2000;38(4):354-65. X-2, X-4. [pmid: 10752967].
933 Davidson B, Vogel V, Wickerham L. Oncologist-patient discussion of adjuvant hormonal therapy in breast cancer: results of a linguistic study focusing on adherence and persistence to therapy. J Support Oncol. Mar. 2007;5(3):139-43. X-2, X-4, X-6. [pmid: 17410813].
934 Davidson JRT, Crawford C, Ives JA, et al. Homeopathic Treatments in Psychiatry: A Systematic Review of Randomized Placebo-Controlled Studies. Journal of Clinical Psychiatry. Jun. 2011;72(6):795-805. X-1, X-2, X-6. [pmid: 21733480].
935 Davidson P, Digiacomo M, Zecchin R, et al. A cardiac rehabilitation program to improve psychosocial outcomes of women with heart disease. J Womens Health (Larchmt). Jan-Feb. 2008;17(1):123-34. X-4, X-6. [pmid: 18240989].
936 Davies JA, Damani P, Margetts BM. Intervening to change the diets of low-income women. Proc Nutr Soc. May. 2009;68(2):210-5. X-3. [pmid: 19245742].
937 Davies TJ, Bunn WB 3rd, Fromer L, et al. A focus on the asthma HEDIS measure and its implications for clinical practice. Manag Care Interface. Feb. 2006;19(2):29-36. X-1, X-2, X-3, X-4, X-6. [pmid: 16529078].
938 Davis BH, Pope C, Mason PR, et al. “It's a Wild Thing, Waiting to Get Me”: Stance Analysis of African Americans With Diabetes. Diabetes Educator. May-Jun. 2011;37(3):409-18. X-2, X-4. [pmid: 21515541].
939 Davis C, Emerson JS, Husaini BA. Breast cancer screening among African American women: adherence to current recommendations. J Health Care Poor Underserved. May. 2005;16(2):308-14. X-2, X-4. [pmid: 15937394].
940 Davis KL, O'Toole ML, Brownson CA, et al. Teaching how, not what: The contributions of community health workers to diabetes self-management. The Diabetes Educator. Jan. 2007;33(Suppl6):208S-15S. X-2, X-4, X-6. [pmid: 17620403].
941 Davis LE, Lee J, Garg R, et al. Asthma in New York City. J Asthma. 2003;40(Suppl):55-61. X-1, X-6, X-7, X-9. [pmid: 12817930].
942 Davis LM, Wells KB, Rogers WH, et al. Effects of Medicare's prospective payment system on service use by depressed elderly inpatients. Psychiatric Services. Nov. 1995;46(11):1178-84. X-2, X-4, X-6. [pmid: 8564509].
943 Davis MS, Miller CK. Educational needs regarding the glycemic index in diabetes management. Topics in Clinical Nutrition. 2006. Jan-Mar. 2006;21(1):17-25. X-2, X-4, X-6.
944 Davis RE, Peterson KE, Rothschild SK, et al. Pushing the envelope for cultural appropriateness: does evidence support cultural tailoring in type 2 diabetes interventions for Mexican American adults?. Diabetes Educ. Mar-Apr. 2011;37(2):227-38. X-2, X-4, X-10. [pmid: 21343599].
945 Davis RM, Hitch AD, Nichols M, et al. A collaborative approach to the recruitment and retention of minority patients with diabetes in rural community health centers. Contemp Clin Trials. Jan. 2009;30(1):63-70. X-7, X-10. [pmid: 18824135].
946 Davis SK, Liu Y, Gibbons GH. Disparities in trends of hospitalization for potentially preventable chronic conditions among African Americans during the 1990s: implications and benchmarks. Am J Public Health. Mar. 2003;93(3):447-55. X-2, X-4. [pmid: 12604494].
947 Davis SW, Diaz-Mendez M, Garcia MT. Barriers to Seeking Cancer Information Among Spanish-Speaking Cancer Survivors. Journal of Cancer Education. 2009;24(3):167-71. X-2, X-4. [pmid: 19526401].
948 Davis TC, Berkel HJ, Arnold CL, et al. Intervention to increase mammography utilization in a public hospital. J Gen Intern Med. Apr. 1998;13(4):230-3. X-4, X-9. [pmid: 9565385].
949 Davis TC, Dolan NC, Ferreira MR, et al. The role of inadequate health literacy skills in colorectal cancer screening. Cancer Investigation. 2001;19(2):193-200. X-2, X-4. [pmid: 11296623].
950 Davis TC, Williams MV, Marin E, et al. Health literacy and cancer communication. Ca-a Cancer Journal for Clinicians. May-Jun. 2002;52(3):134-49. X-1, X-2, X-3, X-4. [pmid: 12018928].
951 Davis TM, Brown SG, Jacobs IG, et al. Determinants of severe hypoglycemia complicating type 2 diabetes: the Fremantle diabetes study. J Clin Endocrinol Metab. May. 2010;95(5):2240-7. X-2, X-3, X-4, X-6. [pmid: 20305006].
952 Davis-Smith YM, Boltri JM, Seale JP, et al. Implementing a diabetes prevention program in a rural African-American church. J Natl Med Assoc. Apr. 2007;99(4):440-6. X-4. [pmid: 17444435].
953 Day MA, Thorn BE. The relationship of demographic and psychosocial variables to pain-related outcomes in a rural chronic pain population. Pain. Nov. 2010;151(2):467-74. X-2, X-4, X-5. [pmid: 20817401].
954 de Alba Garcia JG, Rocha AL, Lopez I, et al. “Diabetes is my companion”: lifestyle and self-management among good and poor control Mexican diabetic patients. Soc Sci Med. Jun. 2007;64(11):2223-35. X-2, X-3, X-4, X-6. [pmid: 17383785].
955 de Albuquerque Citero V, de Araujo Andreoli PB, Nogueira-Martins LA, et al. New potential clinical indicators of consultation-liaison psychiatry's effectiveness in Brazilian general hospitals. Psychosomatics. Jan-Feb. 2008;49(1):29-38. X-2, X-3, X-4, X-5X-6. [pmid: 18212173].
956 de Almeida A, Salvador BC, Barbosa L, et al. PESO AO NASCER E VARIÃVEIS MATERNAS NO ÃMBITO DA PROMOÃÃO DA SAÃDE. Revista de Atenção Primária à Saúde. 2011. Jan-Mar. 2011;14(1):67-74. X-2, X-3, X-6.
957 de Brantes F. The quality of health care: an employer's perspective. Manag Care. Oct. 2003;12(10 Suppl):17-22. discussion 3-5. X-1, X-6, X-7, X-9. [pmid: 14606253].
958 De Clercq E, Van Casteren V, Jonckheer P, et al. Electronic Patient Record data as proxy of GPs' thoughts. Stud Health Technol Inform. 2008;141:103-10. X-2, X-3, X-4, X-5, X-6. [pmid: 18953130].
959 de Groene GJ, Pal TM, Beach J, et al. Workplace interventions for treatment of occupational asthma. Cochrane Database of Systematic Reviews. 2011;(5). X-1, X-6, X-7, X-9. [pmid: 21563151].
960 de Groot M, Welch G, Buckland GT 3rd, et al. Cultural orientation and diabetes self-care in low-income African Americans with type 2 diabetes mellitus. Ethn Dis. Winter. 2003;13(1):6-14. X-2, X-4. [pmid: 12723006].
961 de Jong JD, Westert GP, Noetscher CM, et al. Does managed care make a difference? Physicians' length of stay decisions under managed and non-managed care. BMC Health Serv Res. Feb. 9. 2004;4(1):3. X-2, X-4. [pmid: 15028122].
962 de Kok B, Hussein J, Jeffery P. Joining-up thinking: loss in childbearing from interdisciplinary perspectives. Introduction Soc Sci Med. Nov. 2010;71(10):1703-10. X-1, X-6, X-7, X-9. [pmid: 20943300].
963 de Koning JS, Klazinga N, Koudstaal PJ, et al. Deprivation and systematic stroke prevention in general practice: an audit among general practitioners in the Rotterdam region, The Netherlands. Eur J Public Health. Dec. 2003;13(4):340-6. X-2, X-3, X-4, X-5. [pmid: 14703321].
964 De Leo D, Diekstra RF, Lonnqvist J, et al. LEIPAD, an internationally applicable instrument to assess quality of life in the elderly. Behav Med. Spring. 1998;24(1):17-27. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 9575388].
965 de Oliveira MA, Bruno VF, Ballini LS, et al. Evaluation of an educational program for asthma control in adults. J Asthma. 1997;34(5):395-403. X-4. [pmid: 9350156].
966 de Oliveira MA, Faresin SM, Bruno VF, et al. Evaluation of an educational programme for socially deprived asthma patients. Eur Respir J. Oct. 1999;14(4):908-14. X-4. [pmid: 10573241].
967 de Peralta E, Patel K, Wan C, et al. Culturally competent diabetic education to lower hemoglobin A1c levels of diabetic patients: Esta mejor. Tex Med. Jun. 2005;101(6):54-6. X-7, X-9. [pmid: 17902280].
968 Dean JA, Wilson K. ‘Education? It is irrelevant to my job now. It makes me very depressed …’: exploring the health impacts of under/unemployment among highly skilled recent immigrants in Canada. Ethn Health. Apr. 2009;14(2):185-204. X-2, X-3, X-4, X-5. [pmid: 18949654].
969 DeBate R, Plescia M, Joyner D, et al. A qualitative assessment of Charlotte REACH: an ecological perspective for decreasing CVD and diabetes among African Americans. Ethn Dis. Summer. 2004;14(3 Suppl 1):S77-82. X-6, X-7, X-9. [pmid: 15682775].
970 DeBourcy AC, Lichtenberger S, Felton S, et al. Community-based preferences for stool cards versus colonoscopy in colorectal cancer screening. J Gen Intern Med. Feb. 2008;23(2):169-74. X-2, X-4. [pmid: 18157581].
971 DeBusk RF, Miller NH, Parker KM, et al. Care management for low-risk patients with heart failure: a randomized, controlled trial. Ann Intern Med. Oct. 19. 2004;141(8):606-13. X-6. [pmid: 15492340].
972 DeCoster VA. The emotions of adults with diabetes: a comparison across race. Soc Work Health Care. 2003;36(4):79-99. X-2, X-4. [pmid: 12836781].
973 DeCoster VA, Cummings S. Coping with Type 2 Diabetes: Do Race and Gender Matter?. Social Work in Health Care. 2004;40(2):37-53. X-2, X-4. [pmid: 15774362].
974 DeFrank JT, Rimer BK, Gierisch JM, et al. Impact of mailed and automated telephone reminders on receipt of repeat mammograms: a randomized controlled trial. Am J Prev Med. Jun. 2009;36(6):459-67. X-6, X-9. [pmid: 19362800].
975 DeGarmo DS, Forgatch MS. Efficacy of parent training for stepfathers: from playful spectator and polite stranger to effective stepfathering. Parenting: Science & Practice. 2007;7(4):331-55. X-5, X-6.
976 Degazon CE, Parker VG. Coping and psychosocial adaptation to Type 2 diabetes in older Blacks born in the Southern US and the Caribbean. Res Nurs Health. Apr. 2007;30(2):151-63. X-2, X-4. [pmid: 17380516].
977 Deglin JH, Deglin S. Hypertension: current trends and choices in pharmacotherapeutics. AACN Clin Issues Crit Care Nurs. May. 1992;3(2):507-26. X-1, X-2, X-3, X-4, X-6. [pmid: 1576044].
978 De-Graft Aikins A. Strengthening Quality and Continuity of Diabetes Care in Rural Ghana: A Critical Social Psychological Approach. Journal of Health Psychology. Mar. 2004;9(2):295-309. X-2, X-3, X-4, X-6. [pmid: 15018729].
979 Deitrick LM, Paxton HD, Rivera A, et al. Understanding the role of the promotora in a Latino diabetes education program. Qual Health Res. Mar. 2010;20(3):386-99. X-4. [pmid: 20133505].
980 del Pino A, Gaos MT, Dorta R, et al. Modification of coronary-prone behaviors in coronary patients of low socio-economic status. Span J Psychol. May. 2005;8(1):68-78. X-4, X-6. [pmid: 15875459].
981 Delamater AM, Bubb J, Davis SG, et al. Randomized prospective study of self-management training with newly diagnosed diabetic children. Diabetes Care. May. 1990;13(5):492-8. X-4, X-6. [pmid: 2351027].
982 Delaney C, Apostolidis B, Lachapelle L, et al. Home care nurses' knowledge of evidence-based education topics for management of heart failure. Heart & Lung. 2011;40(4):285-92. X-2, X-3, X-4, X-6. [pmid: 21429581].
983 Delgadillo AT, Grossman M, Santoyo-Olsson J, et al. Description of an academic community partnership lifestyle program for lower income minority adults at risk for diabetes. Diabetes Educ. Jul-Aug. 2010;36(4):640-50. X-1, X-6, X-7, X-9. [pmid: 20576836].
984 Delvaux I, van Tongerloo A, Messiaen L, et al. Carrier screening for cystic fibrosis in a prenatal setting. Genet Test. Summer. 2001;5(2):117-25. X-2, X-3, X-4, X-6. [pmid: 11551097].
985 Demi AS, Brown JV, Jones KD. Promoting asthma self-management skills in young children through a home-based nursing intervention: a pilot study. American Journal for Nurse Practitioners. 1998;2(10):15. X-4, X-9.
986 Denham SA. Diabetes: A family matter. Journal of Family Nursing. Aug. 2009;15(3):400-1. X-1, X-2, X-3, X-4, X-6. [pmid: 19622843].
987 Denham SA, Remsberg K, Wood L. Diabetes education in the Appalachian region: providers' views. Rural and Remote Health. Apr-Jun. 2010;10(2). X-2, X-4. [pmid: 20560683].
988 Dennison BA, Jenkins PL, Pearson TA. Challenges to implementing the current pediatric cholesterol screening guidelines into practice. Pediatrics. Sep. 1994;94(3):296-302. X-2, X-4, X-5, X-6. [pmid: 8065853].
989 Dennison CR, McEntee ML, Samuel L, et al. Adequate Health Literacy Is Associated With Higher Heart Failure Knowledge and Self-care Confidence in Hospitalized Patients. Journal of Cardiovascular Nursing. Sep-Oct. 2011;26(5):359-67. X-2, X-4. [pmid: 21099698].
990 Dennison CR, Post WS, Kim MT, et al. Underserved urban african american men: hypertension trial outcomes and mortality during 5 years. Am J Hypertens. Feb. 2007;20(2):164-71. X-9. [pmid: 17261462].
991 Dent OF, Goulston KJ, Tennant CC, et al. Rectal bleeding. Patient delay in presentation. Dis Colon Rectum. Oct. 1990;33(10):851-7. X-2, X-4, X-5, X-6. [pmid: 2209274].
992 DePue JD, McQuaid EL, Koinis-Mitchell D, et al. Providence school asthma partnership: school-based asthma program for inner-city families. J Asthma. Jul-Aug. 2007;44(6):449-53. X-7, X-9. [pmid: 17654131].
993 DePue JD, Rosen RK, Batts-Turner M, et al. Cultural translation of interventions: diabetes care in American Samoa. Am J Public Health. Nov. 2010;100(11):2085-93. X-1, X-6, X-7, X-9. [pmid: 20864729].
994 D'Eramo-Melkus G, Spollett G, Jefferson V, et al. A culturally competent intervention of education and care for black women with type 2 diabetes. Appl Nurs Res. Feb. 2004;17(1):10-20. X-4. [pmid: 14991551].
995 Derose KP, Hawes-Dawson J, Fox SA, et al. Dealing with diversity: recruiting churches and women for a randomized trial of mammography promotion. Health Educ Behav. Oct. 2000;27(5):632-48. X-2, X-4. [pmid: 11009131].
996 Desai AA, Bolus R, Nissenson A, et al. Is there “cherry picking” in the ESRD Program? Perceptions from a Dialysis Provider Survey. Clin J Am Soc Nephrol. Apr. 2009;4(4):772-7. X-2, X-3, X-4, X-6. [pmid: 19339407].
997 Desai J, Solberg L, Clark C, et al. Improving diabetes care and outcomes: the secondary benefits of a public health-managed care research collaboration. Journal of Public Health Management & Practice. 2003:S36-43. X-1, X-6, X-9. [pmid: 14677329].
998 DeSanto-Madeya S, Bauer-Wu S, Gross A. Activities of daily living in women with advanced breast cancer. Oncol Nurs Forum. Jul. 2007;34(4):841-6. X-2, X-4, X-6. [pmid: 17723984].
999 Desplenter FA, Laekeman GM, Simoens SR. Constraints and perspectives of pharmacists counseling patients with depression at hospital discharge. Int J Clin Pharm. Feb. 2011;33(1):101-10. X-2, X-3, X-4. [pmid: 21365402].
1000 Deswal A, Petersen NJ, Souchek J, et al. Impact of race on health care utilization and outcomes in veterans with congestive heart failure. J Am Coll Cardiol. Mar. 3. 2004;43(5):778-84. X-2, X-4. [pmid: 14998616].
1001 Deswal A, Petersen NJ, Urbauer DL, et al. Racial variations in quality of care and outcomes in an ambulatory heart failure cohort. Am Heart J. Aug. 2006;152(2):348-54. X-2, X-4. [pmid: 16875921].
1002 Detaille SI, Haafkens JA, Hoekstra JB, et al. What employees with diabetes mellitus need to cope at work: views of employees and health professionals. Patient Educ Couns. Dec. 2006;64(1-3):183-90. X-2, X-4, X-6. [pmid: 16469470].
1003 Detprapon M, Sirapo-ngam Y, Mishel MH, et al. Testing of uncertainty in illness theory to predict quality of life among Thais with head and neck cancer. Thai Journal of Nursing Research. 2009. Jan-Mar. 2009;13(1):1-14. X-2, X-3, X-4, X-5, X-6.
1004 Deuster L, Christopher S, Donovan J, et al. A Method to Quantify Residents' Jargon Use During Counseling of Standardized Patients About Cancer Screening. Journal of General Internal Medicine. Dec. 2008;23(12):1947-52. X-2, X-4, X-6. [pmid: 18670828].
1005 DeVon HA, Rankin SH, Paul SM, et al. The Know & Go! program improves knowledge for patients with coronary heart disease in pilot testing. Heart & Lung. 2010;39(6):S23-33. X-4, X-6. [pmid: 21092829].
1006 DeVore AD, Sorrentino M, Arnsdorf MF, et al. Predictors of hypertension control in a diverse general cardiology practice. J Clin Hypertens (Greenwich). Aug. 2010;12(8):570-7. X-2, X-4. [pmid: 20695933].
1007 DeWalt DA, Boone RS, Pignone MP. Literacy and its relationship with self-efficacy, trust, and participation in medical decision making. American Journal of Health Behavior. Sep-Oct. 2007;31:S27-S35. X-2, X-4, X-5. [pmid: 17931133].
1008 DeWalt DA, Broucksou KA, Hawk V, et al. Comparison of a one-time educational intervention to a teach-to-goal educational intervention for self-management of heart failure: design of a randomized controlled trial. BMC Health Serv Res. 2009;9:99. X-1, X-2, X-4. [pmid: 19519904].
1009 DeWalt DA, Davis TC, Wallace AS, et al. Goal setting in diabetes self-management: Taking the baby steps to success. Patient Education and Counseling. Nov. 2009;77(2):218-23. X-6, X-7, X-9. [pmid: 19359123].
1010 DeWalt DA, Malone RM, Bryant ME, et al. A heart failure self-management program for patients of all literacy levels: a randomized, controlled trial [ISRCTN11535170]. BMC Health Serv Res. 2006;6:30. X-4. [pmid: 16533388].
1011 DeWalt DA, Pignone M, Malone R, et al. Development and pilot testing of a disease management program for low literacy patients with heart failure. Patient Educ Couns. Oct. 2004;55(1):78-86. X-4. [pmid: 15476993].
1012 Deziel S, Bodin S. How to make the new Conditions for Coverage work in your dialysis clinic. Patient assessment. Nephrol News Issues. Dec. 2008;22(13):38. 40. 2. X-1, X-2, X-3, X-4, X-6. [pmid: 19149316].
1013 Di Battista AM, Hart TA, Greco L, et al. Type 1 diabetes among adolescents: reduced diabetes self-care caused by social fear and fear of hypoglycemia. Diabetes Educ. May-Jun. 2009;35(3):465-75. X-2, X-4, X-6. [pmid: 19321802].
1014 Di Bisceglie AM, Mzamane DV. Continuous peritoneal dialysis in a developing population--problems seen at Baragwanath Hospital. S Afr Med J. Mar. 12. 1983;63(11):405-6. X-2, X-3, X-4, X-6. [pmid: 6828946].
1015 Diaa MA, el-Gewely M. Life style of adult diabetics of patients attending outpatient clinics. J Egypt Public Health Assoc. 2003;78(1-2):165-89. X-2, X-3, X-4, X-6. [pmid: 17219917].
1016 Diamond F. Kaiser's asthma outcomes will take your breath away. Manag Care. Mar. 2005;14(3):57-8. X-1, X-2, X-3, X-4, X-6. [pmid: 15825612].
1017 Diaz H, Herring P, Montgomery S. Type 2 diabetes as a portal for community and university collaboration: one county's experience. Public Health Rep. Jul-Aug. 2006;121(4):479-82. X-9. [pmid: 16827451].
1018 Diaz T, Sturm T, Matte T, et al. Medication use among children with asthma in East Harlem. Pediatrics. Jun. 2000;105(6):1188-93. X-2, X-4. [pmid: 10835056].
1019 Dibble SL, Roberts SA. Improving cancer screening among lesbians over 50: results of a pilot study. Oncol Nurs Forum. Jul-Aug. 2003;30(4):E71-9. X-4. [pmid: 12861329].
1020 Dibble SL, Vanoni JM, Miaskowski C. Women's attitudes toward breast cancer screening procedures: differences by ethnicity. Womens Health Issues. Jan-Feb. 1997;7(1):47-54. X-6, X-7, X-9. [pmid: 9009861].
1021 DiCastro M, Frydman M, Friedman I, et al. Genetic counseling in hereditary breast/ovarian cancer in Israel: psychosocial impact and retention of genetic information. Am J Med Genet. Aug. 1. 2002;111(2):147-51. X-2, X-3, X-4, X-6. [pmid: 12210341].
1022 Dickerson JE, Garratt CJ, Brown MJ. Management of hypertension in general practice: agreements with and variations from the British Hypertension Society guidelines. J Hum Hypertens. Oct. 1995;9(10):835-9. X-2, X-3, X-4, X-6. [pmid: 8576900].
1023 Dickey LL, Petitti D. A patient-held minirecord to promote adult preventive care. J Fam Pract. Apr. 1992;34(4):457-63. X-6. [pmid: 1556540].
1024 Diefenbach GJ, Robison JT, Tolin DF, et al. Late-life anxiety disorders among Puerto Rican primary care patients: impact on well-being, functioning, and service utilization. J Anxiety Disord. 2004;18(6):841-58. X-2, X-4, X-5. [pmid: 15474856].
1025 Dietrich AJ, Tobin JN, Cassells A, et al. Telephone care management to improve cancer screening among low-income women: a randomized, controlled trial. Ann Intern Med. Apr. 18. 2006;144(8):563-71. X-9. [pmid: 16618953].
1026 Dietrich AJ, Tobin JN, Cassells A, et al. Translation of an efficacious cancer-screening intervention to women enrolled in a Medicaid managed care organization. Ann Fam Med. Jul-Aug. 2007;5(4):320-7. X-9. [pmid: 17664498].
1027 Dietrich AJ, Tobin JN, Sox CH, et al. Cancer early-detection services in community health centers for the underserved. A randomized controlled trial. Arch Fam Med. Jul-Aug. 1998;7(4):320-7. discussion 8. X-5, X-9. [pmid: 9682685].
1028 Dietrich S, Mergl R, Freudenberg P, et al. Impact of a campaign on the public's attitudes towards depression. Health Educ Res. Feb. 2010;25(1):135-50. X-3, X-4, X-6. [pmid: 19752000].
1029 Diette GB, Krishnan JA, Dominici F, et al. Asthma in older patients: factors associated with hospitalization. Arch Intern Med. May. 27. 2002;162(10):1123-32. X-2, X-4. [pmid: 12020182].
1030 Diette GB, Rand C. The contributing role of health-care communication to health disparities for minority patients with asthma. Chest. Nov. 2007;132(5):802S-9S. X-1, X-2, X-3, X-4. [pmid: 17998344].
1031 DiIorio C, Shafer PO, Letz R, et al. Behavioral, social, and affective factors associated with self-efficacy for self-management among people with epilepsy. Epilepsy Behav. Aug. 2006;9(1):158-63. X-2, X-4, X-5, X-6. [pmid: 16798100].
1032 Din-Dzietham R, Porterfield DS, Cohen SJ, et al. Quality care improvement program in a community-based participatory research project: example of Project DIRECT. J Natl Med Assoc. Oct. 2004;96(10):1310-21. X-6, X-9. [pmid: 15540882].
1033 Diniz NMF, Lopes RLM, Rodrigues AD, et al. Women who were burned by their husbands or partners. Acta Paulista de Enfermagem. 2007;20(3):321-5. X-2, X-4, X-5, X-6.
1034 Dittbrenner H. Diabetes: working with the newly diagnosed patient. Caring. May. 5. 1997;16(5):52-61. X-1, X-2, X-3, X-4, X-6. [pmid: 10168695].
1035 Diwan S. Limited English proficiency, social network characteristics, and depressive symptoms among older immigrants. Journals of Gerontology Series B: Psychological Sciences & Social Sciences. 2008;63B(3):S184-91. X-2, X-4. [pmid: 18559693].
1036 Dixon EL, Flaskerud JH. Community tailored responses to depression care. Issues Ment Health Nurs. Sep. 2010;31(9):611-3. X-1, X-6, X-7, X-9. [pmid: 20701424].
1037 Dixon LB, Ernst ND. Choose a diet that is low in saturated fat and cholesterol and moderate in total fat: subtle changes to a familiar message. J Nutr. Feb. 2001;131(2S-1):510S-26S. X-1, X-6, X-7, X-9. [pmid: 11160582].
1038 Dogan S, Ekiz S, Yucel L, et al. Relation of demographic, clinic and biochemical parameters to peritonitis in peritoneal dialysis. J Ren Care. Mar. 2008;34(1):5-8. X-2, X-4, X-6. [pmid: 18336516].
1039 Dogan SK, Ay S, Oztuna D, et al. The utility of the Faces Pain Scale in the assessment of shoulder pain in Turkish stroke patients: its relation with quality of life and psychologic status. International Journal of Rehabilitation Research. 2010;33(4):363-7. X-2, X-4, X-5, X-6. [pmid: 20651601].
1040 Dohan D, Levintova M. Barriers beyond words: Cancer, culture, and translation in a community of Russian speakers. Journal of General Internal Medicine. Nov. 2007;22:300-5. X-2, X-4. [pmid: 17957415].
1041 Dolan NC, McDermott MM, Morrow M, et al. Impact of same-day screening mammography availability: results of a controlled clinical trial. Arch Intern Med. Feb. 22. 1999;159(4):393-8. X-6. [pmid: 10030314].
1042 Dolan SM. Prenatal genetic testing. Pediatr Ann. Aug. 2009;38(8):426-30. X-1, X-6, X-7, X-9. [pmid: 19711880].
1043 Donahue KL, D'Onofrio BM, Bates JE, et al. Early Exposure to Parents' Relationship Instability: Implications for Sexual Behavior and Depression in Adolescence. Journal of Adolescent Health. 2010;47(6):547-54. X-2, X-4, X-5, X-6. [pmid: 21094431].
1044 Dong X, Simon MA, Odwazny R, et al. Depression and elder abuse and neglect among a community-dwelling Chinese elderly population. J Elder Abuse Negl. 2008;20(1):25-41. X-2, X-3, X-4, X-6. [pmid: 18551905].
1045 Donlan W, Lee JH. SCREENING FOR DEPRESSION AMONG INDIGENOUS MEXICAN MIGRANT FARMWORKERS USING THE PATIENT HEALTH QUESTIONNAIRE-9. Psychological Reports. Apr. 2010;106(2):419-32. X-2, X-4. [pmid: 20524542].
1046 Donovan KA, Small BJ, Andrykowski MA, et al. Cognitive functioning after adjuvant chemotherapy and/or radiotherapy for early-stage breast carcinoma. Cancer. Dec. 2005;104(11):2499-507. X-2, X-4, X-6. [pmid: 16247788].
1047 Doran A, Sullivan WR, Robertson C. Management of a long stay child in PICU: getting it right…………eventually!. Pediatric Intensive Care Nursing. 2010;11(1-2):4-8. X-1, X-2, X-3, X-4, X-5, X-6.
1048 Dorevitch S, Karandikar A, Washington GF, et al. Efficacy of an outdoor air pollution education program in a community at risk for asthma morbidity. J Asthma. Nov. 2008;45(9):839-44. X-6, X-7, X-9. [pmid: 18972306].
1049 Dorfman CS, Williams RM, Kassan EC, et al. The development of a web- and a print-based decision aid for prostate cancer screening. Bmc Medical Informatics and Decision Making. Mar. 2010:10. X-2, X-4, X-5, X-6. [pmid: 20178586].
1050 Dornhorst A, Rossi M. Risk and prevention of type 2 diabetes in women with gestational diabetes. Diabetes Care. Aug. Suppl 2. 1998;21:B43-9. X-1, X-2, X-3, X-4, X-6. [pmid: 9704226].
1051 Dougherty D, Meikle SF, Owens P, et al. Children's Health Care in the First National Healthcare Quality Report and National Healthcare Disparities Report. Med Care. Mar. 2005;43(3 Suppl):I58-63. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15746592].
1052 Douglas CY. Community-based screening interventions for colorectal cancer. Journal of Psychosocial Oncology. 2001;19(3-4):133-46. X-1, X-2, X-3, X-4, X-6.
1053 Douglas KA, Yen LE, Korda RJ, et al. Chronic disease management items in general practice: a population-based study of variation in claims by claimant characteristics. Med J Aust. Aug. 15. 2011;195(4):198-202. X-2, X-3, X-4. [pmid: 21843123].
1054 Downing NR, Williams JK, Paulsen JS. Building a Tool to Identify Risk for Lynch Syndrome Among Individuals Presenting for Screening Colonoscopy. Journal of Genetic Counseling. Aug. 2010;19(4):343-52. X-4, X-6. [pmid: 20309619].
1055 Downs SM, Biondich PG, Anand V, et al. Using Arden Syntax and adaptive turnaround documents to evaluate clinical guidelines. AMIA Annu Symp Proc. 2006:214-8. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17238334].
1056 Doyle J, Severance-Fonte T, Morandi-Matricaria E, et al. Improved blood pressure control among school bus drivers with hypertension. Popul Health Manag. Apr. 2010;13(2):97-103. X-6, X-9. [pmid: 20415620].
1057 Doyle W, Crawford MA, Srivastava A, et al. Interpregnancy nutrition intervention with mothers of low-birthweight babies living in an inner city area: a feasibility study. Journal of Human Nutrition & Dietetics. 1999;12(6):517-27. X-6, X-7, X-9.
1058 Draheim MD. Health care reform: AADE outlines the issues. Diabetes Educ. Sep-Oct. 2009;35(5):689-90. X-1, X-2, X-3, X-4. [pmid: 19783764].
1059 Drainoni ML, Houlihan B, Williams S, et al. Patterns of Internet use by persons with spinal cord injuries and relationship to health-related quality of life. Arch Phys Med Rehabil. Nov. 2004;85(11):1872-9. X-2, X-4, X-5, X-6. [pmid: 15520984].
1060 Drass JA, Feldman RH. Knowledge about hypoglycemia in young women with type I diabetes and their supportive others. Diabetes Educ. Jan-Feb. 1996;22(1):34-8. X-2, X-4, X-6. [pmid: 8697954].
1061 Dreyer G, Hull S, Aitken Z, et al. The effect of ethnicity on the prevalence of diabetes and associated chronic kidney disease. QJM. Apr. 2009;102(4):261-9. X-2, X-3, X-4. [pmid: 19147658].
1062 Driscoll A, Worrall-Carter L, McLennan S, et al. Heterogeneity of heart failure management programs in Australia. Eur J Cardiovasc Nurs. Mar. 2006;5(1):75-82. X-2, X-3, X-4, X-6. [pmid: 16216559].
1063 Druss BG, Rask K, Katon WJ. Major depression, depression treatment and quality of primary medical care. General Hospital Psychiatry. Jan-Feb. 2008;30(1):20-5. X-2, X-4, X-6. [pmid: 18164936].
1064 Du W, Mood D, Gadgeel S, et al. An educational video to increase clinical trials enrollment among breast cancer patients. Breast Cancer Res Treat. Sep. 2009;117(2):339-47. X-7, X-10. [pmid: 19152024].
1065 DuBard CA, Schmid D, Yow A, et al. Recommendation for and receipt of cancer screenings among medicaid recipients 50 years and older. Arch Intern Med. Oct. 13. 2008;168(18):2014-21. X-2, X-4. [pmid: 18852404].
1066 Dubay L, Joyce T, Kaestner R, et al. Changes in prenatal care timing and low birth weight by race and socioeconomic status: implications for the Medicaid expansions for pregnant women. Health Serv Res. Jun. 2001;36(2):373-98. X-2, X-4. [pmid: 11409818].
1067 Dubay LC, Kenney GM, Norton SA, et al. Local responses to expanded Medicaid coverage for pregnant women. Milbank Q. 1995;73(4):535-63. X-2, X-4. [pmid: 7491099].
1068 Dunbar VG, King EC, George CD, et al. Evolving demographics and disparities in an urban diabetes clinic: implications for diabetes education and treatment. Ethn Dis. Spring. 2005;15(2):173-8. X-2, X-4. [pmid: 15825961].
1069 Dunn K, Torres A, Tiscani J. Functional status outcomes in a quality of life study with Latinas. Journal of Multicultural Nursing & Health (JMCNH). 2004;10(2):39-47. X-2, X-4, X-5.
1070 Dunn KI, Goldney RD, Grande ED, et al. Quantification and examination of depression-related mental health literacy. J Eval Clin Pract. Aug. 2009;15(4):650-3. X-2, X-3, X-4. [pmid: 19522721].
1071 Dunn ME, Abulu J. Psychiatrists' role in teaching human sexuality to other medical specialties. Acad Psychiatry. Sep-Oct. 2010;34(5):381-5. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 20833911].
1072 Dunt DR, Rubinfeld AR, Feren P, et al. What patients know about their asthma. Community Health Stud. 1987;11(2):125-30. X-6, X-7, X-9. [pmid: 3621890].
1073 DuongTran P, Garcia K. An international study of health knowledge, behaviors, and cultural perceptions of young Mexican adults. Hispanic Health Care International. 2009;7(1):5-10. X-2, X-3, X-4, X-5.
1074 Duprez D, Van Helshoecht P, Van den Eynde W, et al. Prevalence of hypertension in the adult population of Belgium: report of a worksite study, Attention Hypertension. J Hum Hypertens. Jan. 2002;16(1):47-52. X-2, X-3, X-4, X-6. [pmid: 11840229].
1075 Duren-Winfield VT, Bell RA, Camacho F, et al. Partnership approaches to reducing socioeconomic disparities in diabetes care in North Carolina. Diabetes Educ. Jul-Aug. 2004;30(4):600. 2. 4. passim. X-1, X-6, X-7, X-9. [pmid: 15669778].
1076 Duru OK, Mangione CM, Steers NW, et al. The association between clinical care strategies and the attenuation of racial/ethnic disparities in diabetes care: the Translating Research Into Action for Diabetes (TRIAD) Study. Med Care. Dec. 2006;44(12):1121-8. X-11, X-12. [pmid: 17122717].
1077 Durvasula RS, Regan PC, Ureno O, et al. Frequency of cervical and breast cancer screening rates in a multi-ethnic female college sample. Psychol Rep. Oct. 2006;99(2):418-20. X-2, X-4, X-5. [pmid: 17153810].
1078 Dusheiko M, Doran T, Gravelle H, et al. Does higher quality of diabetes management in family practice reduce unplanned hospital admissions?. Health Serv Res. Feb. 2011;46(1 Pt 1):27-46. X-2, X-3, X-4, X-6. [pmid: 20880046].
1079 Dutton GR, Johnson J, Whitehead D, et al. Barriers to physical activity among predominantly low-income African-American patients with type 2 diabetes. Diabetes Care. May. 2005;28(5):1209-10. X-7, X-9. [pmid: 15855592].
1080 Dutton GR, Provost BC, Tan F, et al. A tailored print-based physical activity intervention for patients with type 2 diabetes. Prev Med. Oct. 2008;47(4):409-11. X-4, X-6, X-7, X-9. [pmid: 18652840].
1081 Dwight-Johnson M, Ell K, Lee PJ. Can collaborative care address the needs of low-income Latinas with comorbid depression and cancer? Results from a randomized pilot study. Psychosomatics. May-Jun. 2005;46(3):224-32. X-4. [pmid: 15883143].
1082 Dworkin SF, Huggins KH, Wilson L, et al. A randomized clinical trial using research diagnostic criteria for temporomandibular disorders-axis II to target clinic cases for a tailored self-care TMD treatment program. J Orofac Pain. Winter. 2002;16(1):48-63. X-5, X-6, X-7. [pmid: 11889659].
1083 Dyer KJ, Fearon KCH, Buckner K, et al. Diet and colorectal cancer risk: evaluation of a nutrition education leaflet. Health Education Journal. 2005;64(3):247-55. X-3, X-4, X-6.
1084 Eadie D, MacAskill S. Symptom awareness and cancer prevention: Exploratory findings from an at-risk population. Health Education. 2008;108(4):332-45. X-2, X-3, X-4.
1085 Eakin EG, Reeves MM, Lawler SP, et al. The Logan Healthy Living Program: a cluster randomized trial of a telephone-delivered physical activity and dietary behavior intervention for primary care patients with type 2 diabetes or hypertension from a socially disadvantaged community--rationale, design and recruitment. Contemp Clin Trials. May. 2008;29(3):439-54. X-1, X-3. [pmid: 18055274].
1086 Eamranond PP, Patel KV, Legedza ATR, et al. The association of language with prevalence of undiagnosed hypertension among older Mexican Americans. Ethnicity & Disease. Fal. 2007;17(4):699-706. X-2. [pmid: 18072382].
1087 Early KB, Shultz JA, Corbett C. Assessing diabetes dietary goals and self-management based on in-depth interviews with Latino and Caucasian clients with type 2 diabetes. J Transcult Nurs. Oct. 2009;20(4):371-81. X-2, X-4. [pmid: 19387093].
1088 Earp JA, Flax VL. What lay health advisors do: An evaluation of advisors' activities. Cancer Pract. Jan-Feb. 1999;7(1):16-21. X-2, X-4, X-6. [pmid: 9892999].
1089 Earp JA, Viadro CI, Vincus AA, et al. Lay health advisors: a strategy for getting the word out about breast cancer. Health Educ Behav. Aug. 1997;24(4):432-51. X-1, X-2, X-3, X-4, X-6. [pmid: 9247823].
1090 Easom AK. Nephrology APNs: who are we and what do we do? Survey results October 1999. Nephrol Nurs J. Apr. 2000;27(2):187-91. X-2, X-3, X-4, X-5, X-6. [pmid: 11111545].
1091 Ebeigbe PN, Gharoro EP. Obstetric complications, intervention rates and maternofetal outcome in teenage nullipara in Benin City, Nigeria. Trop Doct. Apr. 2007;37(2):79-83. X-2, X-3, X-4, X-6. [pmid: 17540084].
1092 Echeverry DM, Dike MR, Washington C, et al. The impact of using a low-literacy patient education tool on process measures of diabetes care in a minority population. J Natl Med Assoc. Nov. 2003;95(11):1074-81. X-6, X-9. [pmid: 14651374].
1093 Eckert KA, Kutek SM, Dunn KI, et al. Changes in depression-related mental health literacy in young men from rural and urban South Australia. Aust J Rural Health. Aug. 2010;18(4):153-8. X-2, X-3, X-4. [pmid: 20690911].
1094 Ecks S, Basu S. The unlicensed lives of antidepressants in India: generic drugs, unqualified practitioners, and floating prescriptions. Transcult Psychiatry. Mar. 2009;46(1):86-106. X-2, X-3, X-4, X-6. [pmid: 19293281].
1095 Eddy DM, Pawlson LG, Schaaf D, et al. The potential effects of HEDIS performance measures on the quality of care. Health Aff (Millwood). Sep-Oct. 2008;27(5):1429-41. X-2, X-4, X-6. [pmid: 18780934].
1096 Edgley A, Pilnick A, Clarke M. ‘The air still wasn't good … everywhere I went I was surrounded’: Lay perceptions of air quality and health. Health Sociology Review. 2011;20(1):97-108. X-2, X-3, X-4, X-5.
1097 Edington DW. Opportunities to improve care and manage costs for employees with chronic diseases. Manag Care Interface. Suppl C. 2003:5-7. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 14569629].
1098 Edwards BG, Palmer J. Effects of massage therapy on african americans with type 2 diabetes mellitus: a pilot study. Complementary Health Practice Review. 2010;15(3):149-55. X-4.
1099 Edwards BK, Brown ML, Wingo PA, et al. Annual report to the nation on the status of cancer, 1975-2002, featuring population-based trends in cancer treatment. J Natl Cancer Inst. Oct. 5. 2005;97(19):1407-27. X-2, X-4. [pmid: 16204691].
1100 Edwards JM, Carr BG. Improving patient outcomes from acute cardiovascular events through regionalized systems of care. Hosp Pract (Minneap). Nov. 2010;38(4):54-62. X-1, X-2, X-3, X-4, X-6. [pmid: 21068527].
1101 Egan BM, Lackland DT, Williams B, et al. Health care improvement and cost reduction opportunities in hypertensive Medicaid beneficiaries. J Clin Hypertens (Greenwich). Sep-Oct. 2001;3(5):279-82. 318. X-2, X-4. [pmid: 11588405].
1102 Egede LE, Bonadonna RJ. Diabetes self-management in African Americans: an exploration of the role of fatalism. Diabetes Educ. Jan-Feb. 2003;29(1):105-15. X-2, X-4. [pmid: 12632689].
1103 Egede LE, Ellis C. The effects of depression on diabetes knowledge, diabetes self-management, and perceived control in indigent patients with type 2 diabetes. Diabetes Technol Ther. Jun. 2008;10(3):213-9. X-2, X-4. [pmid: 18473696].
1104 Egede LE, Ellis C, Grubaugh AL. The effect of depression on self-care behaviors and quality of care in a national sample of adults with diabetes. General Hospital Psychiatry. Sep-Oct. 2009;31(5):422-7. X-2, X-4, X-6. [pmid: 19703635].
1105 Egede LE, Michel Y. Medical mistrust, diabetes self-management, and glycemic control in an indigent population with type 2 diabetes. Diabetes Care. Jan. 2006;29(1):131-2. X-7, X-9. [pmid: 16373908].
1106 Egede LE, Osborn CY. Role of motivation in the relationship between depression, self-care, and glycemic control in adults with type 2 diabetes. Diabetes Educ. Mar-Apr. 2010;36(2):276-83. X-2, X-4, X-6. [pmid: 20179250].
1107 Egede LE, Strom JL, Durkalski VL, et al. Rationale and design: telephone-delivered behavioral skills interventions for Blacks with Type 2 diabetes. Trials. 2010;11:35. X-1, X-4. [pmid: 20350322].
1108 Egger E. Diabetes increase may pose secondary revenue opportunities for hospitals. Health Care Strateg Manage. Nov. 2000;18(11):19-20. X-1, X-2, X-3, X-4, X-6. [pmid: 11148951].
1109 Eggleston PA, Malveaux FJ, Butz AM, et al. Medications used by children with asthma living in the inner city. Pediatrics. Mar. 1998;101(3 Pt 1):349-54. X-2, X-4. [pmid: 9480996].
1110 Egnew TR, Jones JM. Teaching psychosocial aspects of coronary care. J Fam Pract. Jan. 1984;18(1):107-13. X-1, X-2, X-3, X-4, X-6. [pmid: 6693837].
1111 Eiser AR, Ellis G. Viewpoint: Cultural competence and the African American experience with health care: The case for specific content in cross-cultural education. Academic Medicine. Feb. 2007;82(2):176-83. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17264697].
1112 Eiser C, Sykes J, Donohoe M, et al. Quality of life and metabolic control in the elderly following conversion to insulin. Psychology, Health & Medicine. 1997;2(2):161-8. X-2, X-4, X-6.
1113 Ekure EN, Ezeaka VC, Iroha E, et al. Prospective audit of perinatal mortality among inborn babies in a tertiary health center in Lagos, Nigeria. Niger J Clin Pract. Jan-Mar. 2011;14(1):88-94. X-2, X-3, X-4. [pmid: 21494000].
1114 Elahi M, Chetty G, Matata B. Ethnic differences in the management of coronary heart disease patients: lessons to be learned in indo-asians. Med Princ Pract. 2006;15(1):69-73. X-2, X-4. [pmid: 16340231].
1115 Elborn JS, Hodson M, Bertram C. Implementation of European standards of care for cystic fibrosis - provision of care. J Cyst Fibros. Sep. 2009;8(5):348-55. X-2, X-3, X-4, X-6. [pmid: 19703795].
1116 Elder JP, Candelaria JI, Woodruff SI, et al. Results of language for health: cardiovascular disease nutrition education for Latino English-as-a-second-language students. Health Educ Behav. Feb. 2000;27(1):50-63. X-7, X-9. [pmid: 10709792].
1117 El-Kak F, Chaaya M, Campbell O, et al. Patterns of antenatal care in low-versus high-risk pregnancies in Lebanon. East Mediterr Health J. May. 2004;10(3):268-76. X-2, X-3, X-4, X-6. [pmid: 16212201].
1118 Elkeles T, Kirschner W, Graf C, et al. Health care in and outside a DMP for type 2 diabetes mellitus in Germany–Results of an insurance customer survey focussing on differences in general education status. Journal of Public Health. Jun. 2009;17(3):205-16. X-2, X-3, X-4, X-6.
1119 Ell K, Katon W, Cabassa LJ, et al. Depression and diabetes among low-income Hispanics: design elements of a socioculturally adapted collaborative care model randomized controlled trial. Int J Psychiatry Med. 2009;39(2):113-32. X-1, X-2, X-4. [pmid: 19860071].
1120 Ell K, Lee P, Xie B. Depression care for low-income, minority, safety net clinic populations with comorbid illness. Research on Social Work Practice. 2010;20(5):467-75. X-1, X-6, X-7, X-9.
1121 Ell K, Padgett D, Vourlekis B, et al. Abnormal mammogram follow-up: a pilot study women with low income. Cancer Pract. May-Jun. 2002;10(3):130-8. X-9. [pmid: 11972567].
1122 Ell K, Vourlekis B, Lee PJ, et al. Patient navigation and case management following an abnormal mammogram: a randomized clinical trial. Prev Med. Jan. 2007;44(1):26-33. X-9. [pmid: 16962652].
1123 Ell K, Vourlekis B, Xie B, et al. Cancer treatment adherence among low-income women with breast or gynecologic cancer: a randomized controlled trial of patient navigation. Cancer. Oct. 1. 2009;115(19):4606-15. X-9. [pmid: 19551881].
1124 Ell K, Xie B, Quon B, et al. Randomized controlled trial of collaborative care management of depression among low-income patients with cancer. J Clin Oncol. Sep. 20. 2008;26(27):4488-96. X-7, X-9. [pmid: 18802161].
1125 Ell KO, Haywood LJ. Sociocultural factors in MI recovery: an exploratory study. Int J Psychiatry Med. 1985;15(2):157-75. X-2, X-4. [pmid: 4055253].
1126 Elliott V, Morgan S, Day S, et al. Parental health beliefs and compliance with prophylactic penicillin administration in children with sickle cell disease. J Pediatr Hematol Oncol. Feb. 2001;23(2):112-6. X-2, X-4, X-5, X-6. [pmid: 11216702].
1127 Ellis C, Devlin G, Elliott J, et al. ACS patients in New Zealand experience significant delays to access cardiac investigations and revascularisation treatment especially when admitted to non-interventional centres: results of the second comprehensive national audit of ACS patients. N Z Med J. Jul. 30. 2010;123(1319):44-60. X-2, X-3, X-4, X-6. [pmid: 20717177].
1128 Ellis DA, Frey MA, Naar-King S, et al. Use of multisystemic therapy to improve regimen adherence among adolescents with type 1 diabetes in chronic poor metabolic control: a randomized controlled trial. Diabetes Care. Jul. 2005;28(7):1604-10. X-6, X-7, X-9. [pmid: 15983308].
1129 El-Mallakh P. Doing my best: poverty and self-care among individuals with schizophrenia and diabetes mellitus. Arch Psychiatr Nurs. Feb. 2007;21(1):49-60. discussion 1-3. X-2, X-4, X-6. [pmid: 17258110].
1130 Elmer PJ, Obarzanek E, Vollmer WM, et al. Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Ann Intern Med. Apr. 4. 2006;144(7):485-95. X-6, X-7, X-9. [pmid: 16585662].
1131 Elmore JG, Nakano CY, Linden HM, et al. Racial Inequities in the Timing of Breast Cancer Detection, Diagnosis, and Initiation of Treatment. Medical Care. Feb. 2005;43(2):141-8. X-2, X-4. [pmid: 15655427].
1132 Elrayah-Eliadarous H, Yassin K, Eltom M, et al. Direct costs for care and glycaemic control in patients with type 2 diabetes in Sudan. Exp Clin Endocrinol Diabetes. Apr. 2010;118(4):220-5. X-2, X-3, X-4. [pmid: 20140852].
1133 Elshaw EB, Young EA, Saunders MJ, et al. Utilizing a 24-hour dietary recall and culturally specific diabetes education in Mexican Americans with diabetes. Diabetes Educ. May-Jun. 1994;20(3):228-35. X-9. [pmid: 7851238].
1134 el-Shazly M, Abdel-Fattah M, Scorpiglione N, et al. Risk factors for lower limb complications in diabetic patients. The Italian Study Group for the Implementation of the St. Vincent Declaration. J Diabetes Complications. Jan-Feb. 1998;12(1):10-7. X-2, X-3, X-4, X-6. [pmid: 9442809].
1135 El-Shazly M, Abdel-Fattah M, Zaki A, et al. Health care for diabetic patients in developing countries: a case from Egypt. Public Health. Jul. 2000;114(4):276-81. X-2, X-3, X-4, X-6. [pmid: 10962591].
1136 Embry DD. Behavioral vaccines and evidence-based kernels: Nonpharmaceutical approaches for the prevention of mental, emotional, and behavioral disorders. Psychiatric Clinics of North America. Mar. 2011;34(1):1-34. X-1, X-2, X-4, X-5, X-6. [pmid: 21333837].
1137 Emdad R, Belkic K, Theorell T, et al. What prevents professional drivers from following physicians' cardiologic advice?. Psychother Psychosom. Jul-Oct. 1998;67(4-5):226-40. X-4, X-6. [pmid: 9693350].
1138 Emerson JS, Reece MC, Levine RS, et al. Predictors of new screening for African American men participating in a prostate cancer educational program. Journal of Cancer Education. Oct. 2009;24(4):341-5. X-5. [pmid: 19838896].
1139 Emmanuel EN, Creedy DK, St John W, et al. Maternal role development: the impact of maternal distress and social support following childbirth. Midwifery. Apr. 2011;27(2):265-72. X-2, X-3, X-4, X-6. [pmid: 19656594].
1140 Emond SD, Reed CR, Graff LI, et al. Asthma education in the Emergency Department. On behalf of the MARC Investigators. Ann Emerg Med. Sep. 2000;36(3):204-11. X-2, X-3, X-4, X-6. [pmid: 10969221].
1141 Emtner M, Hedin A, Andersson M, et al. Impact of patient characteristics, education and knowledge on emergency room visits in patients with asthma and COPD: a descriptive and correlative study. BMC Pulm Med. 2009;9:43. X-2, X-4, X-6. [pmid: 19735571].
1142 Enarson PM, Enarson DA, Gie R. Management of asthma in children in low-income countries. Int J Tuberc Lung Dis. Nov. 2005;9(11):1204-9. X-1, X-2, X-3, X-4, X-6. [pmid: 16333925].
1143 Endres LK, Sharp LK, Haney E, et al. Health literacy and pregnancy preparedness in pregestational diabetes. Diabetes Care. Feb. 2004;27(2):331-4. X-2, X-4. [pmid: 14747209].
1144 Eng CM, Schechter C, Robinowitz J, et al. Prenatal genetic carrier testing using triple disease screening. JAMA. Oct. 15. 1997;278(15):1268-72. X-6, X-7, X-9. [pmid: 9333269].
1145 Eng E, Smith J. Natural helping functions of lay health advisors in breast cancer education. Breast Cancer Res Treat. Jul. 1995;35(1):23-9. X-2, X-4. [pmid: 7612900].
1146 Englander J, Bushnik T, Oggins J, et al. Fatigue after traumatic brain injury: Association with neuroendocrine, sleep, depression and other factors. Brain Injury. 2010;24(12):1379-88. X-2, X-3, X-4, X-5. [pmid: 20961172].
1147 English KC, Fairbanks J, Finster CE, et al. A socioecological approach to improving mammography rates in a tribal community. Health Educ Behav. Jun. 2008;35(3):396-409. X-7, X-9, X-10. [pmid: 17114330].
1148 Epstein SA, Hooper LM, Weinfurt KP, et al. Primary care physicians' evaluation and treatment of depression: Results of an experimental study using video vignettes. Medical Care Research and Review. Dec. 2008;65(6):674-95. X-2, X-3, X-4, X-6. [pmid: 18832109].
1149 Erasmus RT, Blanco Blanco E, Okesina AB, et al. Assessment of glycaemic control in stable type 2 black South African diabetics attending a peri-urban clinic. Postgrad Med J. Oct. 1999;75(888):603-6. X-2, X-3, X-4, X-6. [pmid: 10621901].
1150 Erci B. Psychometric evaluation of Self-Assessed Support Needs of women with breast cancer Scale. J Clin Nurs. Oct. 2007;16(10):1927-35. X-2, X-3, X-4, X-6. [pmid: 17880481].
1151 Erickson SR, Slaughter R, Halapy H. Pharmacists' ability to influence outcomes of hypertension therapy. Pharmacotherapy. Jan-Feb. 1997;17(1):140-7. X-6. [pmid: 9017775].
1152 Eriksson H, Tu SW, Musen M. Semantic clinical guideline documents. AMIA Annu Symp Proc. 2005:236-40. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 16779037].
1153 Erwin DO, Ivory J, Stayton C, et al. Replication and dissemination of a cancer education model for African American women. Cancer Control. Sep-Oct. 2003;10(5 Suppl):13-21. X-6, X-7, X-9. [pmid: 14581900].
1154 Erwin DO, Johnson VA, Feliciano-Libid L, et al. Incorporating cultural constructs and demographic diversity in the research and development of a Latina breast and cervical cancer education program. J Cancer Educ. Spring. 2005;20(1):39-44. X-2, X-4. [pmid: 15876181].
1155 Erwin DO, Johnson VA, Trevino M, et al. A comparison of African American and Latina social networks as indicators for culturally tailoring a breast and cervical cancer education intervention. Cancer. Jan. 15. 2007;109(2 Suppl):368-77. X-2, X-4. [pmid: 17173279].
1156 Erwin DO, Spatz TS, Stotts RC, et al. Increasing mammography practice by African American women. Cancer Pract. Mar-Apr. 1999;7(2):78-85. X-9. [pmid: 10352065].
1157 Erwin DO, Spatz TS, Stotts RC, et al. Increasing mammography and breast self-examination in African American women using the Witness Project model. J Cancer Educ. Winter. 1996;11(4):210-5. X-9. [pmid: 8989634].
1158 Erwin K, Carrico R, Glass P, et al. Asthma-how does it impact academic achievement and school budgets?. NASN Sch Nurse. Sep. 2010;25(5):202-4. X-1, X-2, X-3, X-4, X-6. [pmid: 20860196].
1159 Escobar JI, Cook B, Chen CN, et al. Whether medically unexplained or not, three or more concurrent somatic symptoms predict psychopathology and service use in community populations. J Psychosom Res. Jul. 2010;69(1):1-8. X-2, X-4. [pmid: 20630257].
1160 Eshah NF, Bond AE, Froelicher ES. The effects of a cardiovascular disease prevention program on knowledge and adoption of a heart healthy lifestyle in Jordanian working adults. Eur J Cardiovasc Nurs. Dec. 2010;9(4):244-53. X-3. [pmid: 20299286].
1161 Espinet LM, Osmick MJ, Ahmed T, et al. A cohort study of the impact of a national disease management program on HEDIS diabetes outcomes. Dis Manag. Apr. 2005;8(2):86-92. X-6, X-7, X-9. [pmid: 15815157].
1162 Espinoza-Palma T, Zamorano A, Arancibia F, et al. Effectiveness of asthma education with and without a self-management plan in hospitalized children. Journal of Asthma. Nov. 2009;46(9):906-10. X-3, X-6. [pmid: 19905916].
1163 Ethier KA, Ickovics JR, Fernandez MI, et al. The Perinatal Guidelines Evaluation Project HIV and Pregnancy Study: overview and cohort description. Public Health Rep. Mar-Apr. 2002;117(2):137-47. X-1, X-2, X-4. [pmid: 12356998].
1164 Ettner SL, Cadwell BL, Russell LB, et al. Investing time in health: do socioeconomically disadvantaged patients spend more or less extra time on diabetes self-care?. Health Econ. Jun. 2009;18(6):645-63. X-2, X-4. [pmid: 18709636].
1165 Etzioni DA, Ponce NA, Babey SH, et al. A population-based study of colorectal cancer test use: results from the 2001 California Health Interview Survey. Cancer. Dec. 1. 2004;101(11):2523-32. X-2, X-4. [pmid: 15505783].
1166 Etzioni DA, Yano EM, Rubenstein LV, et al. Measuring the quality of colorectal cancer screening: the importance of follow-up. Dis Colon Rectum. Jul. 2006;49(7):1002-10. X-2, X-4. [pmid: 16673056].
1167 Evangelista LS, Rasmusson KD, Laramee AS, et al. Health Literacy and the Patient With Heart Failure-Implications for Patient Care and Research: A Consensus Statement of the Heart Failure Society of America. Journal of Cardiac Failure. Jan. 2010;16(1):9-16. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 20123313].
1168 Evangelista LS, Shinnick MA. What do we know about adherence and self-care?. Journal of Cardiovascular Nursing. May-Jun. 2008;23(3):250-7. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18437067].
1169 Evans D, Clark NM, Feldman CH, et al. A school health education program for children with asthma aged 8-11 years. Health Educ Q. Fall. 1987;14(3):267-79. X-6, X-9. [pmid: 3654234].
1170 Evans D, Mellins R, Lobach K, et al. Improving care for minority children with asthma: professional education in public health clinics. Pediatrics. Feb. 1997;99(2):157-64. X-9. [pmid: 9024439].
1171 Evans JM, Newton RW, Ruta DA, et al. Frequency of blood glucose monitoring in relation to glycaemic control: observational study with diabetes database. BMJ. Jul. 10. 1999;319(7202):83-6. X-2, X-3, X-4, X-6. [pmid: 10398627].
1172 Ezenwaka CE, Dimgba A, Okali F, et al. Self-monitoring of blood glucose improved glycemic control and the 10-year coronary heart disease risk profile of female type 2 diabetes patients in Trinidad and Tobago. Niger J Clin Pract. Jan-Mar. 2011;14(1):1-5. X-3, X-4. [pmid: 21493982].
1173 Ezenwaka CE, Offiah NV. Patients' health education and diabetes control in a developing country. Acta Diabetol. Dec. 2003;40(4):173-5. X-2, X-3, X-4, X-6. [pmid: 14740276].
1174 Ezimokhai M, Joseph A, Bradley-Watson P. Audit of pregnancies complicated by diabetes from one center five years apart with selective versus universal screening. Ann N Y Acad Sci. Nov. 2006;1084:132-40. X-2, X-3, X-4. [pmid: 17151297].
1175 Fagerlin A, Dillard AJ, Smith DM, et al. Women's interest in taking tamoxifen and raloxifene for breast cancer prevention: response to a tailored decision aid. Breast Cancer Research and Treatment. Jun. 2011;127(3):681-8. X-4, X-6. [pmid: 21442198].
1176 Fagerlin A, Sepucha KR, Couper MP, et al. Patients' Knowledge about 9 Common Health Conditions: The DECISIONS Survey. Medical Decision Making. Sep-Oct. 2010;30:35S-52S. X-2, X-4, X-5. [pmid: 20881153].
1177 Fagerlin A, Ubel PA, Smith DM, et al. Making numbers matter: Present and future research in risk communication. American Journal of Health Behavior. Sep-Oct. 2007;31:S47-S56. X-1, X-2, X-4, X-5. [pmid: 17931136].
1178 Fain JA. Psychometric properties of the Spanish Version of the Diabetes Self-management Assessment Report Tool. Diabetes Educ. Sep-Oct. 2007;33(5):827-32. X-2, X-4. [pmid: 17925586].
1179 Fakhro AE, Fateha BE, al-Asheeri N, et al. Breast cancer: patient characteristics and survival analysis at Salmaniya medical complex, Bahrain. East Mediterr Health J. May. 1999;5(3):430-9. X-2, X-3, X-4, X-6. [pmid: 10793821].
1180 Falcao DM, Sales L, Leite JR, et al. Cognitive behavioral therapy for the treatment of fibromyalgia syndrome: a randomized controlled trial. Journal of Musculoskeletal Pain. 2008;16(3):133-40. X-5.
1181 Fallowfield L. Quality of life in the elderly woman with breast cancer treated with tamoxifen and surgery or tamoxifen alone. Journal of Women's Health. 1994;3(1):17-20. X-2, X-3, X-4, X-6.
1182 Famuyiwa OO. Important considerations in the care of diabetic patients in a developing country (Nigeria). Diabet Med. Dec. 1990;7(10):927-30. X-1, X-2, X-3, X-4. [pmid: 2149693].
1183 Famuyiwa OO, Edozien EM, Ukoli CO. Social, cultural and economic factors in the management of diabetes mellitus in Nigeria. Afr J Med Med Sci. Sep-Dec. 1985;14(3-4):145-54. X-2, X-3, X-4, X-6. [pmid: 3004173].
1184 Fang CY, Ma GX, Tan Y, et al. A multifaceted intervention to increase cervical cancer screening among underserved Korean women. Cancer Epidemiology Biomarkers & Prevention. Jun. 2007;16(6):1298-302. X-5. [pmid: 17548702].
1185 Fann JR, Jones AL, Dikmen SS, et al. Depression treatment preferences after traumatic brain injury. The Journal of Head Trauma Rehabilitation. Jul-Aug. 2009;24(4):272-8. X-2, X-4, X-6. [pmid: 19625866].
1186 Fardy PS, White RE, Clark LT, et al. Health promotion in minority adolescents: a Healthy People 2000 pilot study. J Cardiopulm Rehabil. Jan-Feb. 1995;15(1):65-72. X-4, X-5. [pmid: 8529088].
1187 Farley RL, Wade TD, Birchmore L. Factors influencing attendance at cardiac rehabilitation among coronary heart disease patients. Eur J Cardiovasc Nurs. Sep. 2003;2(3):205-12. X-2, X-4. [pmid: 14622628].
1188 Farmer SA, Kirkpatrick JN, Heidenreich PA, et al. Ethnic and racial disparities in cardiac resynchronization therapy. Heart Rhythm. Mar. 2009;6(3):325-31. X-2, X-4. [pmid: 19251206]. Farmer SA, Roter DL, Higginson IJ. Chest pain: communication of symptoms and history in a London emergency department. Patient Educ Couns. Oct. 2006;63(1-2):138-44. X-2, X-3, X-4. [pmid: 16242896].
1189 Farrell MH, Kuruvilla P. Assessment of parental understanding by pediatric residents during Counseling after newborn genetic screening. Archives of Pediatrics & Adolescent Medicine. Mar. 2008;162(3):199-204. X-2, X-4, X-5, X-6. [pmid: 18316655].
1190 Farrell MH, Kuruvilla P, Eskra KL, et al. A method to quantify and compare clinicians' assessments of patient understanding during counseling of standardized patients. Patient Educ Couns. Oct. 2009;77(1):128-35. X-2, X-3, X-4, X-5, X-6. [pmid: 19380210].
1191 Farris JR. When insurance is not enough: racial and ethnic disparities in immunizations for the Medicare population. Ethn Dis. Spring. 2005;15(2 Suppl 3):S3-7-S3-12. X-1, X-2, X-4, X-5. [pmid: 15945360].
1192 Fassaert T, Nielen M, Verheij R, et al. Quality of care for anxiety and depression in different ethnic groups by family practitioners in urban areas in the Netherlands. Gen Hosp Psychiatry. Jul-Aug. 2010;32(4):368-76. X-2, X-3, X-4. [pmid: 20633740].
1193 Fatoye FO, Mosaku SK, Komolafe MA, et al. Depressive symptoms and associated factors following cerebrovascular accident among Nigerians. Journal of Mental Health. 2009;18(3):224-32. X-2, X-3, X-4, X-5, X-6.
1194 Fayazi S, Asadizaker M, Shahrouz A. Comparison of quality of life between haemodialysis and renal transplant patients. CONNECT: The World of Critical Care Nursing. 2008;6(4):69-72. X-2, X-4, X-6.
1195 Feathers JT, Kieffer EC, Palmisano G, et al. The development, implementation, and process evaluation of the REACH Detroit Partnership's Diabetes Lifestyle Intervention. Diabetes Educ. May-Jun. 2007;33(3):509-20. X-7, X-9. [pmid: 17570882].
1196 Featherstone JJ, Goyder E. Is waist circumference a useful screening tool for diabetes mellitus in an overweight multi-ethnic population?. Quality in Primary Care. 2007;15(3):137-44. X-2, X-4, X-6.
1197 Fedder DO, Chang RJ, Curry S, et al. The effectiveness of a community health worker outreach program on healthcare utilization of west Baltimore City Medicaid patients with diabetes, with or without hypertension. Ethn Dis. Winter. 2003;13(1):22-7. X-4, X-7, X-8, X-10. [pmid: 12723008].
1198 Federman AD, Wisnivesky JP, Wolf MS, et al. Inadequate health literacy is associated with suboptimal health beliefs in older asthmatics. J Asthma. Aug. 2010;47(6):620-6. X-2, X-4. [pmid: 20636188].
1199 Feifer C, Ornstein SM. Strategies for increasing adherence to clinical guidelines and improving patient outcomes in small primary care practices. Jt Comm J Qual Saf. Aug. 2004;30(8):432-41. X-6. [pmid: 15357133].
1200 Feinberg E, Smith MV, Morales MJ, et al. Improving women's health during internatal periods: Developing an evidenced-based approach to addressing maternal depression in pediatric settings. Journal of Womens Health. Jul. 2006;15(6):692-703. X-1, X-6, X-7, X-9. [pmid: 16910901].
1201 Fekete E, Geaghan TR, Druley JA. Affective and behavioural reactions to positive and negative health-related social control in HIV+men. Psychol Health. Jun. 2009;24(5):501-15. X-2, X-4, X-5, X-6. [pmid: 20205008].
1202 Felder C, Uehlinger C, Baumann P, et al. Oral and intravenous methadone use: some clinical and pharmacokinetic aspects. Drug Alcohol Depend. Jun. 1. 1999;55(1-2):137-43. X-2, X-4, X-5, X-6. [pmid: 10402158].
1203 Felder E. Self-care agency and blood pressure control. J Hum Hypertens. Apr. 1990;4(2):124-6. X-2, X-4. [pmid: 2338682].
1204 Feldman PH, McDonald MV, Mongoven JM, et al. Home-based blood pressure interventions for blacks. Circ Cardiovasc Qual Outcomes. May. 2009;2(3):241-8. X-1, X-9. [pmid: 20031844].
1205 Felix-Aaron K, Moy E, Kang M, et al. Variation in quality of men's health care by race/ethnicity and social class. Med Care. Mar. 2005;43(3 Suppl):I72-81. X-2, X-4. [pmid: 15746594].
1206 Fennoy I. Contraception and the adolescent diabetic. Health Educ. Oct-Nov. 1989;20(6):21-3. 31. X-1, X-2, X-3, X-4, X-6. [pmid: 2516509].
1207 Fenton JJ, Tancredi DJ, Green P, et al. Persistent racial and ethnic disparities in up-to-date colorectal cancer testing in medicare enrollees. J Am Geriatr Soc. Mar. 2009;57(3):412-8. X-2, X-4. [pmid: 19175435].
1208 Fernandez A, Schillinger D, Warton EM, et al. Language Barriers, Physician-Patient Language Concordance, and Glycemic Control Among Insured Latinos with Diabetes: The Diabetes Study of Northern California (DISTANCE). Journal of General Internal Medicine. Feb. 2011;26(2):170-6. X-6, X-7, X-9. [pmid: 20878497].
1209 Fernandez ME, Gonzales A, Tortolero-Luna G, et al. Using intervention mapping to develop a breast and cervical cancer screening program for Hispanic farmworkers: Cultivando La Salud. Health Promot Pract. Oct. 2005;6(4):394-404. X-1, X-2. [pmid: 16210681].
1210 Fernandez RS, Davidson P, Griffiths R. Cardiac rehabilitation coordinators' perceptions of patient-related barriers to implementing cardiac evidence-based guidelines. J Cardiovasc Nurs. Sep-Oct. 2008;23(5):449-57. X-2, X-3, X-4, X-6. [pmid: 18728518].
1211 Fernandez S, Scales KL, Pineiro JM, et al. A senior center-based pilot trial of the effect of lifestyle intervention on blood pressure in minority elderly people with hypertension. J Am Geriatr Soc. Oct. 2008;56(10):1860-6. X-7, X-8, X-9. [pmid: 18721222].
1212 Feroze U, Noori N, Kovesdy CP, et al. Quality-of-life and mortality in hemodialysis patients: roles of race and nutritional status. Clin J Am Soc Nephrol. May. 2011;6(5):1100-11. X-2, X-4. [pmid: 21527646].
1213 Ferrante JM, Rovi S, Das K, et al. Family physicians expedite diagnosis of breast disease in urban minority women. J Am Board Fam Med. Jan-Feb. 2007;20(1):52-9. X-2, X-4. [pmid: 17204735].
1214 Ferrara A, Karter AJ, Ackerson LM, et al. Hormone replacement therapy is associated with better glycemic control in women with type 2 diabetes: The Northern California Kaiser Permanente Diabetes Registry. Diabetes Care. Jul. 2001;24(7):1144-50. X-2, X-4, X-6. [pmid: 11423493].
1215 Ferris TG, Crain EF, Oken E, et al. Insurance and quality of care for children with acute asthma. Ambul Pediatr. Sep-Oct. 2001;1(5):267-74. X-2, X-4. [pmid: 11888414].
1216 Fiddler M, Jackson J, Kapur N, et al. Childhood adversity and frequent medical consultations. Gen Hosp Psychiatry. Sep-Oct. 2004;26(5):367-77. X-2, X-4, X-5, X-6. [pmid: 15474636].
1217 Fiellin DA, O'Connor PG, Wang Y, et al. Quality of Care for Acute Myocardial Infarction in Elderly Patients with Alcohol-Related Diagnoses. Alcoholism: Clinical and Experimental Research. Jan. 2006;30(1):70-5. X-2, X-4, X-6. [pmid: 16433733].
1218 Figaro MK, Elasy T, BeLue R, et al. Exploring socioeconomic variations in diabetes control strategies: impact of outcome expectations. J Natl Med Assoc. Jan. 2009;101(1):18-23. X-2, X-4. [pmid: 19245068].
1219 Findley S, Irigoyen M, Sanchez M, et al. Community empowerment to reduce childhood immunization disparities in New York City. Ethn Dis. Summer. 2004;14(3 Suppl 1):S134-41. X-7. [pmid: 15682783].
1220 Findley SE, Irigoyen M, Sanchez M, et al. Community-based strategies to reduce childhood immunization disparities. Health Promot Pract. Jul. 2006;7(3 Suppl):191S-200S. X-7. [pmid: 16760249].
1221 Findley SE, Irigoyen M, See D, et al. Community-provider partnerships to reduce immunization disparities: field report from northern Manhattan. Am J Public Health. Jul. 2003;93(7):1041-4. X-4, X-6. [pmid: 12835176].
1222 Findley SE, Sanchez M, Mejia M, et al. REACH 2010: New York City: Effective strategies for integrating immunization promotion into community programs. Health Promotion Practice. Apr. 2009;10(2, Suppl):128S-37S. X-5, X-6, X-9. [pmid: 19454759].
1223 Fink JC, Armistead N, Turner M, et al. Hemodialysis adequacy in Network 5: disparity between states and the role of center effects. Am J Kidney Dis. Jan. 1999;33(1):97-104. X-2, X-4. [pmid: 9915273].
1224 Finkelstein FO, Story K, Firanek C, et al. Perceived knowledge among patients cared for by nephrologists about chronic kidney disease and end-stage renal disease therapies. Kidney Int. Nov. 2008;74(9):1178-84. X-2, X-4. [pmid: 18668024].
1225 Finkelstein J, Hripcsak G, Cabrera MR. Patients' acceptance of Internet-based home asthma telemonitoring. Proc AMIA Symp. 1998:336-40. X-4. [pmid: 9929237].
1226 Finlayson K, Edwards H, Courtney M. Relationships between preventive activities, psychosocial factors and recurrence of venous leg ulcers: a prospective study. Journal of Advanced Nursing. 2011;67(10):2180-90. X-2, X-4, X-5, X-6. [pmid: 21517938].
1227 Finucane ML, McMullen CK. Making diabetes self-management education culturally relevant for Filipino Americans in Hawaii. The Diabetes Educator. Sep-Oct. 2008;34(5):841-53. X-2, X-4. [pmid: 18832289].
1228 Firestone DN, Jimenez-Briceno L, Reimann JO, et al. Predictors of diabetes-specific knowledge and treatment satisfaction among Costa Ricans. Diabetes Educ. Mar-Apr. 2004;30(2):281-92. X-2, X-4. [pmid: 15095518].
1229 Fiscella K, Franks P. Should years of schooling be used to guide treatment of coronary risk factors?. Ann Fam Med. Sep-Oct. 2004;2(5):469-73. X-2, X-4. [pmid: 15506583].
1230 Fiscella K, Geiger HJ. Health information technology and quality improvement for community health centers. Health Aff (Millwood). Mar-Apr. 2006;25(2):405-12. X-1, X-2, X-4, X-5, X-6. [pmid: 16522580].
1231 Fiscella K, Holt K. Impact of primary care patient visits on racial and ethnic disparities in preventive care in the united states. Journal of the American Board of Family Medicine. Nov-Dec. 2007;20(6):587-97. X-2, X-4. [pmid: 17954867].
1232 Fiscella K, Ransom S, Jean-Pierre P, et al. Patient-Reported Outcome Measures Suitable to Assessment of Patient Navigation. Cancer. Aug. 2011;117(15):3603-17. X-1, X-2, X-4, X-5, X-6. [pmid: 21780095].
1233 Fiscella K, Yosha A, Hendren SK, et al. Get screened: a pragmatic randomized controlled trial to increase mammography and colorectal cancer screening in a large, safety net practice. BMC Health Serv Res. 2010;10:280. X-1, X-7, X-9. [pmid: 20863395].
1234 Fish J, Wilkinson S. Explaining lesbians' practice of breast self-examination: results from a UK survey of lesbian health. Health Education Journal. 2003;62(4):304-15. X-2, X-3, X-4.
1235 Fish L, Lung CL, Antileukotriene Working G. Adherence to asthma therapy. Annals of Allergy Asthma & Immunology. Jun. 2001;86(6):24-30. X-1, X-2, X-4, X-6. [pmid: 11426913].
1236 Fisher EB, Strunk RC, Highstein GR, et al. A randomized controlled evaluation of the effect of community health workers on hospitalization for asthma: the asthma coach. Arch Pediatr Adolesc Med. Mar. 2009;163(3):225-32. X-9. [pmid: 19255389].
1237 Fisher EB, Strunk RC, Sussman LK, et al. Community organization to reduce the need for acute care for asthma among African American children in low-income neighborhoods: the Neighborhood Asthma Coalition. Pediatrics. Jul. 2004;114(1):116-23. X-7, X-9. [pmid: 15231917].
1238 Fisher EB Jr., Sussman LK, Arfken C, et al. Targeting high risk groups. Neighborhood organization for pediatric asthma management in the Neighborhood Asthma Coalition. Chest. Oct. 1994;106(4 Suppl):248S-59S. X-1, X-7, X-9. [pmid: 7924552].
1239 Fisher L, Chesla CA, Chun KM, et al. Patient-appraised couple emotion management and disease management among Chinese American patients with type 2 diabetes. J Fam Psychol. Jun. 2004;18(2):302-10. X-2, X-4. [pmid: 15222837].
1240 Fisher L, Chesla CA, Skaff MA, et al. Disease management status: a typology of Latino and Euro-American patients with type 2 diabetes. Behav Med. Summer. 2000;26(2):53-66. X-1, X-2, X-4. [pmid: 11147290].
1241 Fisher L, Gudmundsdottir M, Gilliss C, et al. Resolving disease management problems in European-American and Latino couples with type 2 diabetes: the effects of ethnicity and patient gender. Fam Process. Winter. 2000;39(4):403-16. X-2, X-4. [pmid: 11143595].
1242 Fisher L, Skaff MM, Chesla CA, et al. Disease management advice provided to African-American and Chinese-American patients with type 2 diabetes. Diabetes Care. Sep. 2004;27(9):2249-50. X-7, X-9. [pmid: 15333495].
1243 Fisher M, Sloane P, Edwards L, et al. Continuity of care and hypertension control in a university-based practice. Ethn Dis. Autumn. 2007;17(4):693-8. X-2, X-4. [pmid: 18072381].
1244 Fitzgerald JT, Anderson RM, Funnell MM, et al. Differences in the impact of dietary restrictions on African Americans and Caucasians with NIDDM. Diabetes Educ. Jan-Feb. 1997;23(1):41-7. X-2, X-4. [pmid: 9052053].
1245 Fitzgerald JT, Anderson RM, Gruppen LD, et al. The reliability of the Diabetes Care Profile for African Americans. Eval Health Prof. Mar. 1998;21(1):52-65. X-2, X-4. [pmid: 10183339].
1246 Fitzgerald JT, Funnell MM, Hess GE, et al. The reliability and validity of a brief diabetes knowledge test. Diabetes Care. May. 1998;21(5):706-10. X-2, X-4, X-6. [pmid: 9589228].
1247 Fitzgerald JT, Gruppen LD, Anderson RM, et al. The influence of treatment modality and ethnicity on attitudes in type 2 diabetes. Diabetes Care. Mar. 2000;23(3):313-8. X-2, X-4. [pmid: 10868857].
1248 Fitzgibbon ML, Gapstur SM, Knight SJ. Results of Mujeres Felices por ser Saludables: a dietary/breast health randomized clinical trial for Latino women. Ann Behav Med. Oct. 2004;28(2):95-104. X-7, X-9. [pmid: 15454356].
1249 Fitzpatrick SB, Coughlin SS, Chamberlin J. A novel asthma camp intervention for childhood asthma among urban blacks. The Pediatric Lung Committee of the American Lung Association of the District of Columbia (ALADC) Washington, DC. J Natl Med Assoc. Mar. 1992;84(3):233-7. X-8, X-9. [pmid: 1578497].
1250 Fleming B, Silver A, Ocepek-Welikson K, et al. The relationship between organizational systems and clinical quality in diabetes care. Am J Manag Care. Dec. 2004;10(12):934-44. X-2, X-4. [pmid: 15617369].
1251 Fleming C, Simmons D, Leakehe L, et al. Ethnic differences in the perception of a video developed for a multiethnic diabetes prevention programme in south Auckland, New Zealand. Diabet Med. Aug. 1995;12(8):701-7. X-3. [pmid: 7587010].
1252 Flenady V, Middleton P, Smith GC, et al. Stillbirths: the way forward in high-income countries. Lancet. May. 14. 2011;377(9778):1703-17. X-1, X-2, X-3, X-4, X-6. [pmid: 21496907].
1253 Flessner MF, Wyatt SB, Akylbekova EL, et al. Prevalence and awareness of CKD among African Americans: the Jackson Heart Study. Am J Kidney Dis. Feb. 2009;53(2):238-47. X-2, X-4. [pmid: 19166799].
1254 Flores AM, Hodges LC, Brewer LH. Recovering shoulder function and quality of life after breast cancer surgery. Journal of the Section on Women's Health. 2004;28(3):7-14. X-2, X-4, X-6.
1255 Flores G, Bridon C, Torres S, et al. Improving asthma outcomes in minority children: a randomized, controlled trial of parent mentors. Pediatrics. Dec. 2009;124(6):1522-32. X-9. [pmid: 19948624].
1256 Flores G, Ngui E. Racial/ethnic disparities and patient safety. Pediatric Clinics of North America. Dec. 2006;53(6):1197. X-1, X-2, X-4, X-5. [pmid: 17126691].
1257 Flores G, Rabke-Verani J, Pine W, et al. The importance of cultural and linguistic issues in the emergency care of children. Pediatric Emergency Care. Aug. 2002;18(4):271-84. X-1, X-2, X-5. [pmid: 12187133].
1258 Flori YA, Desjeux JF, Reach G, et al. Characteristics of children and adolescents with insulin-dependent diabetes mellitus participating in a summer camp educational program. Diabete Metab. Jun. 1986;12(3):162-8. X-2, X-4, X-6. [pmid: 3525271].
1259 Flykt M, Kanninen K, Sinkkonen J, et al. Maternal depression and dyadic interaction: the role of maternal attachment style. Infant & Child Development. 2010;19(5):530-50. X-2, X-4, X-6.
1260 Flynn KJ, Powell LH, Mendes de Leon CF, et al. Increasing self-management skills in heart failure patients: a pilot study. Congest Heart Fail. Nov-Dec. 2005;11(6):297-302. X-4, X-6. [pmid: 16330904].
1261 Flynn L, Budd M, Modelski J. Enhancing resource utilization among pregnant adolescents. Public Health Nurs. Mar-Apr. 2008;25(2):140-8. X-6, X-7, X-9. [pmid: 18294182].
1262 Fogel J, Albert SM, Schnabel F, et al. Use of the Internet by women with breast cancer. J Med Internet Res. Apr-Nov. 2002;4(2):E9. X-2, X-4. [pmid: 12554556].
1263 Fogel J, Albert SM, Schnabel F, et al. Racial/ethnic differences and potential psychological benefits in use of the internet by women with breast cancer. Psychooncology. Mar. 2003;12(2):107-17. X-2, X-4. [pmid: 12619143].
1264 Folkvord S, Odegaard OA, Sundby J. Male infertility in Zimbabwe. Patient Educ Couns. Dec. 2005;59(3):239-43. X-2, X-3, X-4, X-5, X-6. [pmid: 16242296].
1265 Follick MJ, Gorkin L, Smith TW, et al. Quality of life post-myocardial infarction: effects of a transtelephonic coronary intervention system. Health Psychol. 1988;7(2):169-82. X-6, X-7, X-9. [pmid: 3371309].
1266 Fonnebo V, Sogaard AJ. The penetrating educational effect of a mass-media based fund-raising campaign “heart for life”. Scand J Soc Med. Sep. 1990;18(3):185-93. X-3, X-6. [pmid: 2237326].
1267 Fontana V, Castro T, Polynice A. Preferences of healthy inner city women and the surgical treatment of early stage breast cancer. Am Surg. Mar. 2007;73(3):215-21. X-2, X-4. [pmid: 17375774].
1268 Forbis SG, Aligne CA. Poor readability of written asthma management plans found in national guidelines. Pediatrics. Apr. 2002;109(4):e52. X-2, X-3, X-4. [pmid: 11927725].
1269 Ford ES, Harel Y, Heath G, et al. Test characteristics of self-reported hypertension among the Hispanic population: findings from the Hispanic Health and Nutrition Examination Survey. J Clin Epidemiol. 1990;43(2):159-65. X-2, X-4. [pmid: 2406376].
1270 Ford LA, Crabtree RD, Hubbell A. Crossing borders in health communication research: toward an ecological understanding of context, complexity, and consequences in community-based health education in the U.S.-Mexico borderlands. Health Commun. Oct. 2009;24(7):608-18. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 20183369].
1271 Ford ME, Edwards G, Rodriguez JL, et al. An empowerment-centered, church-based asthma education program for African American adults. Health Soc Work. Feb. 1996;21(1):70-5. X-1, X-9. [pmid: 8626161].
1272 Ford ME, Havstad SL, Tilley BC, et al. Health outcomes among African American and Caucasian adults following a randomized trial of an asthma education program. Ethn Health. Nov. 1997;2(4):329-39. X-6, X-9. [pmid: 9526696].
1273 Ford ME, Randolph V, Hopkins-Johnson L, et al. Design of a case management approach to enhance cancer screening trial retention among older African American men. J Aging Health. Nov. 2004;16(5 Suppl):39S-57S. X-7, X-9, X-10. [pmid: 15448286].
1274 Ford S, Mai F, Manson A, et al. Diabetes knowledge--are patients getting the message?. Int J Clin Pract. Oct. 2000;54(8):535-6. X-2, X-4. [pmid: 11198733].
1275 Forsander G, Malmodin B, Eklund C, et al. Relationship between dietary intake in children with diabetes mellitus type 1, their management at diagnosis, social factors, anthropometry and glycaemic control. Scandinavian Journal of Nutrition. 2003;47(2):75-84. X-2, X-3, X-4, X-6.
1276 Fort JG, McClellan L. REACH-Meharry community-campus partnership: developing culturally competent health care providers. J Health Care Poor Underserved. May. 2006;17(2 Suppl):78-87. X-1, X-2, X-4. [pmid: 16809876].
1277 Fortmann AL, Gallo LC, Philis-Tsimikas A. Glycemic control among Latinos with type 2 diabetes: the role of social-environmental support resources. Health Psychol. May. 2011;30(3):251-8. X-2, X-4. [pmid: 21553968].
1278 Fortmann AL, Gallo LC, Walker C, et al. Support for disease management, depression, self-care, and clinical indicators among Hispanics with type 2 diabetes in San Diego County, United States of America. Rev Panam Salud Publica. Sep. 2010;28(3):230-4. X-2, X-4. [pmid: 20963271].
1279 Foster PP, Williams JH, Estrada CA, et al. Recruitment of rural physicians in a diabetes internet intervention study: overcoming challenges and barriers. J Natl Med Assoc. Feb. 2010;102(2):101-7. X-2, X-3, X-4, X-10. [pmid: 20191922].
1280 Foster SM, Layton HS, Qualls SH, et al. Tailored caregiver therapy: consumer response to intervention. Clinical Gerontologist. 2009;32(2):177-97. X-2, X-4, X-5.
1281 Fouad M, Wynn T, Martin M, et al. Patient navigation pilot project: results from the Community Health Advisors in Action Program (CHAAP). Ethn Dis. Spring. 2010;20(2):155-61. X-9. [pmid: 20503896].
1282 Fouad MN, Nagy MC, Johnson RE, et al. The development of a community action plan to reduce breast and cervical cancer disparities between African-American and White women. Ethn Dis. Summer. 2004;14(3 Suppl 1):S53-60. X-2, X-4. [pmid: 15682772].
1283 Fouad MN, Partridge E, Dignan M, et al. A community-driven action plan to eliminate breast and cervical cancer disparity: successes and limitations. J Cancer Educ. Spring. 2006;21(1 Suppl):S91-100. X-1, X-6, X-7, X-9. [pmid: 17020510].
1284 Fowler BA. The influence of social support relationships on mammography screening in African-American women. J Natl Black Nurses Assoc. Jul. 2007;18(1):21-9. X-2, X-4. [pmid: 17679411].
1285 Fox J, Alabassi A, Black E, et al. Modelling clinical goals: a corpus of examples and a tentative ontology. Stud Health Technol Inform. 2004;101:31-45. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15537204].
1286 Fox P, Porter PG, Lob SH, et al. Improving asthma-related health outcomes among low-income, multiethnic, school-aged children: results of a demonstration project that combined continuous quality improvement and community health worker strategies. Pediatrics. Oct. 2007;120(4):e902-11. X-9. [pmid: 17908746].
1287 Fox SA, Klos DS, Worthen NJ, et al. Improving the adherence of urban women to mammography guidelines: strategies for radiologists. Radiology. Jan. 1990;174(1):203-6. X-1, X-2, X-4, X-6. [pmid: 2294548].
1288 Fox SA, Murata PJ, Stein JA. The impact of physician compliance on screening mammography for older women. Arch Intern Med. Jan. 1991;151(1):50-6. X-2, X-4, X-6. [pmid: 1985609].
1289 Fox SA, Stein JA, Sockloskie RJ, et al. Targeted mailed materials and the Medicare beneficiary: Increasing mammogram screening among the elderly. American Journal of Public Health. Jan. 2001;91(1):55-61. X-6, X-8, X-9. [pmid: 11189826].
1290 Francis L, Weiss BD, Senf JH, et al. Does literacy education improve symptoms of depression and self-efficacy in individuals with low literacy and depressive symptoms? A preliminary investigation. J Am Board Fam Med. Jan-Feb. 2007;20(1):23-7. X-2, X-4. [pmid: 17204731].
1291 Franks P, Clancy CM. Physician gender bias in clinical decisionmaking: screening for cancer in primary care. Med Care. Mar. 1993;31(3):213-8. X-2, X-4. [pmid: 8450679].
1292 Franz MJ. The Lenna Francis Cooper Memorial Lecture--The future of clinical dietetics: evidence, outcomes, and reimbursement. J Am Diet Assoc. Aug. 2003;103(8):977-81. X-1, X-2, X-3, X-4, X-6. [pmid: 12891145].
1293 Fraser W, Hatem-Asmar M, Krauss I, et al. Comparison of midwifery care to medical care in hospitals in the Quebec pilot projects study: clinical indicators. L'Equipe dEvaluation des Projets-Pilotes Sages-Femmes. Can J Public Health. Jan-Feb. 2000;91(1):I5-11. X-2, X-3, X-4, X-6. [pmid: 10765581].
1294 Frayne SM, Halanych JH, Miller DR, et al. Disparities in diabetes care: impact of mental illness. Arch Intern Med. Dec. 12-26. 2005;165(22):2631-8. X-2, X-4, X-6. [pmid: 16344421].
1295 Frayne SM, Skinner KM, Lin H, et al. Effect of patient gender on late-life depression management. J Womens Health (Larchmt). Oct. 2004;13(8):919-25. X-2, X-3, X-4. [pmid: 15671707].
1296 Fredericks S, Guruge S, Sidani S, et al. Patient demographics and learning needs: examination of relationship. Clin Nurs Res. Nov. 2009;18(4):307-22. X-2, X-4, X-6. [pmid: 19605606].
1297 Freeman HP, Muth BJ, Kerner JF. Expanding access to cancer screening and clinical follow-up among the medically underserved. Cancer Pract. Jan-Feb. 1995;3(1):19-30. X-4, X-9, X-10. [pmid: 7704057].
1298 Freeman J, Loewe R. Barriers to communication about diabetes mellitus. Patients' and physicians' different view of the disease. J Fam Pract. Jun. 2000;49(6):507-12. X-2, X-4. [pmid: 10923549].
1299 Fremont AM, Correa-de-Araujo R, Hayes SN. Gender disparities in managed care: It's time for action. Women's Health Issues. May-Jun. 2007;17(3):116-9. X-1, X-2, X-4, X-5. [pmid: 17512754].
1300 Frey MA, Ellis D, Templin T, et al. Diabetes management and metabolic control in school-age children with type 1 diabetes. Childrens Health Care. Fal. 2006;35(4):349-63. X-2, X-4.
1301 Freydberg N, Strain L, Tsuyuki RT, et al. “If he gives in, he will be gone…”: The influence of work and place on experiences, reactions and self-care of heart failure in rural Canada. Social Science & Medicine. Apr. 2010;70(7):1077-83. X-2, X-3, X-4, X-6. [pmid: 20117867].
1302 Friedemann-Sanchez G, Griffin JM, Partin MR. Gender differences in colorectal cancer screening barriers and information needs. Health Expect. Jun. 2007;10(2):148-60. X-2, X-4. [pmid: 17524008].
1303 Friedewald VE, Fonarow GC, Olshansky B, et al. The editor's roundtable: Implantable cardioverter-defibrillators in primary prevention of sudden cardiac death and disparity-related barriers to implementation. Am J Cardiol. Feb. 15. 2011;107(4):583-90. X-1, X-6, X-7, X-9. [pmid: 21295175].
1304 Friedman DB, Hoffman-Goetz L. An exploratory study of older adults' comprehension of printed cancer information: is readability a key factor?. J Health Commun. Jul-Aug. 2007;12(5):423-37. X-2, X-4. [pmid: 17710594].
1305 Friedman LC, Puryear LJ, Moore A, et al. Breast and colorectal cancer screening among low-income women with psychiatric disorders. Psychooncology. Sep. 2005;14(9):786-91. X-2, X-4. [pmid: 15690427].
1306 Friedman LC, Webb JA, Richards CS, et al. Psychological and behavioral factors associated with colorectal cancer screening among Ashkenazim. Prev Med. Aug. 1999;29(2):119-25. X-2, X-4. [pmid: 10446038].
1307 Friedman M, Borum ML. Colorectal cancer screening of African Americans by internal medicine resident physicians can be improved with focused educational efforts. J Natl Med Assoc. Sep. 2007;99(9):1010-2. X-9. [pmid: 17913110].
1308 Frijling BD, Lobo CM, Keus IM, et al. Perceptions of cardiovascular risk among patients with hypertension or diabetes. Patient Educ Couns. Jan. 2004;52(1):47-53. X-2, X-4, X-6. [pmid: 14729290].
1309 Frisco ML, Houle JN, Martin MA. Adolescent weight and depressive symptoms: For whom is weight a burden?. Social Science Quarterly. Dec. 2009;90(4):1019-38. X-2, X-4. [pmid: 23585698].
1310 Fritschi C, Quinn L, Penckofer S, et al. Continuous glucose monitoring: the experience of women with type 2 diabetes. Diabetes Educ. Mar-Apr. 2010;36(2):250-7. X-2, X-3, X-6. [pmid: 20016057].
1311 Froelicher ES, Kee LL, Newton KM, et al. Return to work, sexual activity, and other activities after acute myocardial infarction. Heart Lung. Sep-Oct. 1994;23(5):423-35. X-6, X-9. [pmid: 7989211].
1312 Frounfelker RL, Glover CM, Teachout A, et al. Access to supported employment for consumers with criminal justice involvement. Psychiatr Rehabil J. Summer. 2010;34(1):49-56. X-2, X-5, X-6. [pmid: 20615845].
1313 Ftohy EM, Abdel-Gawwad ES, Kamal MM, et al. Cognitive predictors of self-management behavior of asthmatic children and their families in Alexandria. J Egypt Public Health Assoc. 1999;74(3-4):439-61. X-2, X-3, X-4. [pmid: 17219878].
1314 Fu AZ, Qiu Y, Radican L, et al. Health care and productivity costs associated with diabetic patients with macrovascular comorbid conditions. Diabetes Care. Dec. 2009;32(12):2187-92. X-1, X-2, X-6. [pmid: 19729528].
1315 Fu CM, Parahoo K. Causes of depression: perceptions among people recovering from depression. J Adv Nurs. Jan. 2009;65(1):101-9. X-2, X-3, X-4, X-6. [pmid: 19032511].
1316 Fulwood R. Setting the agenda for research and education on coronary heart disease. J Health Care Poor Underserved. Aug. 1997;8(3):247-9. X-1, X-2, X-4. [pmid: 9253216].
1317 Funk KL, Elmer PJ, Stevens VJ, et al. PREMIER--a trial of lifestyle interventions for blood pressure control: intervention design and rationale. Health Promot Pract. Jul. 2008;9(3):271-80. X-1, X-2, X-4. [pmid: 16803935].
1318 Gabram SG, Lund MJ, Gardner J, et al. Effects of an outreach and internal navigation program on breast cancer diagnosis in an urban cancer center with a large African-American population. Cancer. Aug. 1. 2008;113(3):602-7. X-6, X-9. [pmid: 18613035].
1319 Gadzinowski J, Szymankiewicz M, Breborowicz G. International Perinatology/Neonatology--a global perspective. J Perinatol. May-Jun. 1998;18(3):211-5. X-1, X-3, X-6, X-7, X-9. [pmid: 9659652].
1320 Gaffney B, Kee F. Are the economically active more deserving?. Br Heart J. Apr. 1995;73(4):385-9. X-2, X-3. [pmid: 7756076].
1321 Gagliardi G, Pucciarelli S, Asteria CR, et al. A nationwide audit of the use of radiotherapy for rectal cancer in Italy. Tech Coloproctol. Sep. 2010;14(3):229-35. X-2, X-3, X-6. [pmid: 20632061].
1322 Galdeano LE, Rossi LA, Pelegrino FM. Content validation of the “deficient knowledge” nursing diagnosis. Acta Paulista de Enfermagem. 2008;21(4):549-55. X-2, X-3, X-5, X-6.
1323 Galesic M, Garcia-Retamero R, Gigerenzer G. Using icon arrays to communicate medical risks: overcoming low numeracy. Health Psychol. Mar. 2009;28(2):210-6. X-7, X-9. [pmid: 19290713].
1324 Gallagher R, Belshaw J, Kirkness A, et al. Sublingual nitroglycerin practices in patients with coronary artery disease in Australia. J Cardiovasc Nurs. Nov-Dec. 2010;25(6):480-6. X-2, X-3. [pmid: 20938250].
1325 Gallefoss F, Bakke PS, Wang IJ, et al. Smoking status, disease duration, and educational level in females, are related to asthma school participation. Eur Respir J. Jun. 2000;15(6):1022-5. X-2. [pmid: 10885419].
1326 Gallegos-Macias AR, Macias SR, Kaufman E, et al. Relationship between glycemic control, ethnicity and socioeconomic status in Hispanic and white non-Hispanic youths with type 1 diabetes mellitus. Pediatr Diabetes. Mar. 2003;4(1):19-23. X-2. [pmid: 14655519].
1327 Ganesan K, Teklehaimanot S, Akhtar AJ, et al. Racial differences in preventive practices of African-American and Hispanic women. Journal of the American Geriatrics Society. Apr. 2003;51(4):515-8. X-2. [pmid: 12657071].
1328 Gannon M, Qaseem A, Snow V. Community-based primary care: improving and assessing diabetes management. Am J Med Qual. Jan-Feb. 2010;25(1):6-12. X-6, X-9. [pmid: 19786594].
1329 Gansler T, Henley SJ, Stein K, et al. Sociodemographic determinants of cancer treatment health literacy. Cancer. Aug. 2005;104(3):653-60. X-2. [pmid: 15983986].
1330 Gany FM, Shah SM, Changrani J. New York City's immigrant minorities - Reducing cancer health disparities. Cancer. Oct. 2006;107(8):2071-81. X-1, X-2. [pmid: 16983657].
1331 Ganz PA, Greendale GA, Petersen L, et al. Managing menopausal symptoms in breast cancer survivors: results of a randomized controlled trial. J Natl Cancer Inst. Jul. 5. 2000;92(13):1054-64. X-6, X-9. [pmid: 10880548].
1332 Ganz PA, Kwan L, Stanton AL, et al. Quality of life at the end of primary treatment of breast cancer: first results from the moving beyond cancer randomized trial. J Natl Cancer Inst. Mar. 3. 2004;96(5):376-87. X-2, X-7. [pmid: 14996859].
1333 Garcia AA. Symptom prevalence and treatments among mexican americans with type 2 diabetes. Diabetes Educ. Jul-Aug. 2005;31(4):543-54. X-2. [pmid: 16100330].
1334 Garcia AA. The Diabetes Symptom Self-Care Inventory: development and psychometric testing with Mexican Americans. J Pain Symptom Manage. Apr. 2011;41(4):715-27. X-2, X-4. [pmid: 21276705].
1335 Garcia AA, Brown SA, Winchell M, et al. Using the Behavioral Checklist to document diabetes self-management behaviors in the Starr County Diabetes Education Study. Diabetes Educ. Sep-Oct. 2003;29(5):758-60. 62. 64. passim. X-6, X-7, X-9. [pmid: 14603867].
1336 Garcia AA, Villagomez ET, Brown SA, et al. The Starr County Diabetes Education Study: development of the Spanish-language diabetes knowledge questionnaire. Diabetes Care. Jan. 2001;24(1):16-21. X-2. [pmid: 11194219].
1337 Garcia CM, Saewyc EM. Perceptions of mental health among recently immigrated Mexican adolescents. Issues Ment Health Nurs. Jan. 2007;28(1):37-54. X-2, X-4. [pmid: 17130006].
1338 Garcia JA, Romano PS, Chan BK, et al. Sociodemographic factors and the assignment of do-not-resuscitate orders in patients with acute myocardial infarctions. Med Care. Jun. 2000;38(6):670-8. X-2. [pmid: 10843314].
1339 Garcia PC. International standard of quality in the pediatric intensive care unit: a model for pediatric intensive care units in South America. Crit Care Med. Sep. 1993;21(9 Suppl):S409-10. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 8365264].
1340 Garcia-Perez L, Perestelo-Perez L, Serrano-Aguilar P, et al. Effectiveness of a psychoeducative intervention in a summer camp for children with type 1 diabetes mellitus. Diabetes Educ. Mar-Apr. 2010;36(2):310-7. X-4. [pmid: 20185607].
1341 Garcia-Vera MP, Labrador FJ, Sanz J. Comparison of clinic, home self-measured, and work self-measured blood pressures. Behav Med. Spring. 1999;25(1):13-22. X-2, X-4. [pmid: 10209694].
1342 Gardner DF, Eastman BG, Mehl TD, et al. Effect of psychosocial factors on success in a program of self-glucose monitoring. Diabetes Res. Mar. 1985;2(2):89-93. X-2, X-4. [pmid: 4042533].
1343 Garg SK, Carter JA, Mullen L, et al. The clinical performance and ease of use of a blood glucose meter that uses a 10-test disk. Diabetes Technol Ther. Aug. 2004;6(4):495-502. X-2, X-6. [pmid: 15321005].
1344 Garner P, Heywood P, Baea M, et al. Infant mortality in a deprived area of Papua New Guinea: priorities for antenatal services and health education. P N G Med J. Mar. 1996;39(1):6-11. X-2, X-3. [pmid: 9522844].
1345 Garrett J, Fenwick JM, Taylor G, et al. Prospective controlled evaluation of the effect of a community based asthma education centre in a multiracial working class neighbourhood. Thorax. Oct. 1994;49(10):976-83. X-6, X-9. [pmid: 7974314].
1346 Garrett JE, Mulder J, Wong-Toi H. Reasons for racial differences in A & E attendance rates for asthma. N Z Med J. Mar. 22. 1989;102(864):121-4. X-2, X-3. [pmid: 2927806].
1347 Garrow D, Egede LE. National patterns and correlates of complementary and alternative medicine use in adults with diabetes. J Altern Complement Med. Nov. 2006;12(9):895-902. X-2. [pmid: 17109581].
1348 Garvin CC, Cheadle A, Chrisman N, et al. A community-based approach to diabetes control in multiple cultural groups. Ethn Dis. Summer. 2004;14(3 Suppl 1):S83-92. X-9, X-10. [pmid: 15682776].
1349 Gary TL, Batts-Turner M, Bone LR, et al. A randomized controlled trial of the effects of nurse case manager and community health worker team interventions in urban African-Americans with type 2 diabetes. Control Clin Trials. Feb. 2004;25(1):53-66. X-6, X-9. [pmid: 14980748].
1350 Gary TL, Bone LR, Hill MN, et al. Randomized controlled trial of the effects of nurse case manager and community health worker interventions on risk factors for diabetes-related complications in urban African Americans. Preventive Medicine: An International Journal Devoted to Practice and Theory. Jul. 2003;37(1):23-32. X-9.
1351 Gary TL, Crum RM, Cooper-Patrick L, et al. Depressive symptoms and metabolic control in African-Americans with type 2 diabetes. Diabetes Care. Jan. 2000;23(1):23-9. X-2. [pmid: 10857963].
1352 Gary TL, Hill-Briggs F, Batts-Turner M, et al. Translational research principles of an effectiveness trial for diabetes care in an urban African American population. Diabetes Educ. Nov-Dec. 2005;31(6):880-9. X-1, X-7, X-9. [pmid: 16288095].
1353 Gastal DA, Pinheiro RT, Vazquez DP. Self-efficacy scale for Brazilians with type 1 diabetes. Sao Paulo Med J. Mar. 1. 2007;125(2):96-101. X-2, X-3, X-6. [pmid: 17625707].
1354 Gattuso S, Fullagar S, Young I. Speaking of women's ‘nameless misery’: the everyday construction of depression in Australian women's magazines. Soc Sci Med. Oct. 2005;61(8):1640-8. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 16029771].
1355 Gayer D, Ganong L. Family structure and mothers' caregiving of children with cystic fibrosis. J Fam Nurs. Nov. 2006;12(4):390-412. X-2, X-6. [pmid: 17099117].
1356 Gaynes BN, West SL, Ford CA, et al. Screening for suicide risk in adults: A summary of the evidence for the US preventive services task force. Annals of Internal Medicine. May. 2004;140(10):822-35. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15148072].
1357 Gazmararian J, Baker D, Parker R, et al. A multivariate analysis of factors associated with depression: evaluating the role of health literacy as a potential contributor. Arch Intern Med. Nov. 27. 2000;160(21):3307-14. X-2. [pmid: 11088094].
1358 Gazmararian JA, Williams MV, Peel J, et al. Health literacy and knowledge of chronic disease. Patient Education and Counseling. Nov. 2003;51(3):267-75. X-2. [pmid: 14630383].
1359 Gazmararian JA, Ziemer DC, Barnes C. Perception of barriers to self-care management among diabetic patients. Diabetes Educ. Sep-Oct. 2009;35(5):778-88. X-2, X-4. [pmid: 19556552].
1360 Gee GC, Ryan A, Laflamme DJ, et al. Self-reported discrimination and mental health status among African descendants, Mexican Americans, and other Latinos in the New Hampshire REACH 2010 Initiative: the added dimension of immigration. Am J Public Health. Oct. 2006;96(10):1821-8. X-2, X-4, X-5. [pmid: 17008579].
1361 Gee L, Smith TL, Solomon M, et al. The clinical, psychosocial, and socioeconomic concerns of urban youth living with diabetes. Public Health Nurs. Jul-Aug. 2007;24(4):318-28. X-2, X-4. [pmid: 17553021].
1362 Geiger-Brown J, Muntaner C, Lipscomb J, et al. Demanding work schedules and mental health in nursing assistants working in nursing homes. Work & Stress. 2004;18(4):292-304. X-2, X-5, X-6.
1363 Gelfand DE, Parzuchowski J, Rivero-Perry M, et al. Work-site cancer screening: a Latino case study. Oncol Nurs Forum. May. 2000;27(4):659-66. X-9. [pmid: 10833694].
1364 Geller BM, Skelly JM, Dorwaldt AL, et al. Increasing patient/physician communications about colorectal cancer screening in rural primary care practices. Medical Care. Sep. 2008;46(9):S36-S43. X-6, X-9. [pmid: 18725831].
1365 Généreux M, Auger N, Goneau M, et al. Neighbourhood socioeconomic status, maternal education and adverse birth outcomes among mothers living near highways. Journal of Epidemiology and Community Health. Aug. 2008;62(8):695-700. X-2, X-3. [pmid: 18621954].
1366 Genev NM, Flack JR, Hoskins PL, et al. Diabetes education: whose priorities are met?. Diabet Med. Jun. 1992;9(5):475-9. X-2, X-3, X-6. [pmid: 1611837].
1367 Georg G, Seroussi B, Bouaud J. Does GEM-encoding clinical practice guidelines improve the quality of knowledge bases? A study with the rule-based formalism. AMIA Annu Symp Proc. 2003:254-8. X-2, X-3, X-4, X-5, X-6. [pmid: 14728173].
1368 Georg G, Seroussi B, Bouaud J. Interpretative framework of chronic disease management to guide textual guideline GEM-encoding. Stud Health Technol Inform. 2003;95:531-6. X-2, X-3, X-4. [pmid: 14664041].
1369 Georg G, Seroussi B, Bouaud J. Synthesis of elementary single-disease recommendations to support guideline-based therapeutic decision for complex polypathological patients. Stud Health Technol Inform. 2004;107(Pt 1):38-42. X-2, X-4. [pmid: 15360770].
1370 Georg G, Seroussi B, Bouaud J. Extending the GEM model to support knowledge extraction from textual guidelines. Int J Med Inform. Mar. 2005;74(2-4):79-87. X-2, X-3, X-4, X-6. [pmid: 15694612].
1371 George JT, Warriner DA, Anthony J, et al. Training tomorrow's doctors in diabetes: self-reported confidence levels, practice and perceived training needs of post-graduate trainee doctors in the UK. A multi-centre survey. BMC Med Educ. 2008;8:22. X-2, X-3, X-5, X-6. [pmid: 18419804].
1372 George M, Campbell J, Rand C. Self-management of acute asthma among low-income urban adults. J Asthma. Aug. 2009;46(6):618-24. X-2, X-4. [pmid: 19657906].
1373 Gerald LB, Redden D, Wittich AR, et al. Outcomes for a comprehensive school-based asthma management program. J Sch Health. Aug. 2006;76(6):291-6. X-8, X-9. [pmid: 16918857].
1374 Gerber B, Smith EV Jr., Girotti M, et al. Using Rasch measurement to investigate the cross-form equivalence and clinical utility of Spanish and English versions of a diabetes questionnaire: a pilot study. J Appl Meas. 2002;3(3):243-71. X-2, X-4. [pmid: 12147912].
1375 Gerber BS, Brodsky IG, Lawless KA, et al. Implementation and evaluation of a low-literacy diabetes education computer multimedia application. Diabetes Care. Jul. 2005;28(7):1574-80. X-6, X-7, X-9. [pmid: 15983303].
1376 Gerber BS, Cano AI, Caceres ML, et al. A Pharmacist and Health Promoter Team to Improve Medication Adherence Among Latinos with Diabetes. Annals of Pharmacotherapy. Jan. 2010;44(1):70-9. X-4. [pmid: 20028957].
1377 Gerber BS, Davis K, Wideman D, et al. Implementation of computer multimedia for diabetes prevention in African-American women. AMIA Annu Symp Proc. 2005:962. X-2, X-8, X-9, X-10. [pmid: 16779249].
1378 Gerber BS, Pagcatipunan M, Smith EV Jr., et al. The assessment of diabetes knowledge and self-efficacy in a diverse population using Rasch measurement. J Appl Meas. 2006;7(1):55-73. X-2. [pmid: 16385151].
1379 Gerber LM, Barron Y, Mongoven J, et al. Activation among chronically ill older adults with complex medical needs: challenges to supporting effective self-management. J Ambul Care Manage. Jul-Sep. 2011;34(3):292-303. X-2, X-4. [pmid: 21673530].
1380 Gerber Y, Goldbourt U, Drory Y. Interaction between income and education in predicting long-term survival after acute myocardial infarction. Eur J Cardiovasc Prev Rehabil. Oct. 2008;15(5):526-32. X-2, X-3. [pmid: 18622301].
1381 Gergen PJ, Goldstein RA. Does asthma education equal asthma intervention?. Int Arch Allergy Immunol. May-Jun. 1995;107(1-3):166-8. X-1, X-6, X-7, X-9. [pmid: 7613124].
1382 Gerin W, Tobin JN, Schwartz JE, et al. The medication Adherence and Blood Pressure Control (ABC) trial: a multi-site randomized controlled trial in a hypertensive, multicultural, economically disadvantaged population. Contemp Clin Trials. Jul. 2007;28(4):459-71. X-1, X-2. [pmid: 17287150].
1383 Gesler WM, Dougherty M, Arcury TA, et al. The importance of obtaining information from assessment of community service providers for a disease prevention program. Journal of Multicultural Nursing & Health (JMCNH). 2003;9(2):14-21. X-2, X-4.
1384 Gesler WM, Hayes M, Arcury TA, et al. Use of mapping technology in health intervention research. Nurs Outlook. May-Jun. 2004;52(3):142-6. X-6, X-7, X-9. [pmid: 15197363].
1385 Ghafari A, Sepehrvand N, Hatami S, et al. Effect of an educational program on awareness about peritoneal dialysis among patients on hemodialysis. Saudi J Kidney Dis Transpl. Jul. 2010;21(4):636-40. X-2, X-3, X-6. [pmid: 20587865].
1386 Ghisi GL, Durieux A, Manfroi WC, et al. Construction and validation of the CADE-Q for patient education in cardiac rehabilitation programs. Arq Bras Cardiol. Jun. 2010;94(6):813-22. X-2, X-3, X-4, X-5, X-6. [pmid: 20464275].
1387 Gholami P, Lew SQ, Klontz KC. Raw shellfish consumption among renal disease patients. A risk factor for severe Vibrio vulnificus infection. Am J Prev Med. Oct. 1998;15(3):243-5. X-6, X-7, X-9. [pmid: 9791643].
1388 Ghorob A, Vivas MM, De Vore D, et al. The effectiveness of peer health coaching in improving glycemic control among low-income patients with diabetes: protocol for a randomized controlled trial. BMC Public Health. 2011;11:208. X-1, X-2, X-4. [pmid: 21457567].
1389 Ghosh HA, Shaar A, Mashal J, et al. Diabetes control in 3 villages in Palestine: a community-based quality improvement intervention. J Ambul Care Manage. Jan-Mar. 2007;30(1):74-8. X-3. [pmid: 17170640].
1390 Giachello AL, Arrom JO, Davis M, et al. Reducing diabetes health disparities through community-based participatory action research: the Chicago Southeast Diabetes Community Action Coalition. Public Health Rep. Jul-Aug. 2003;118(4):309-23. X-10. [pmid: 12815078].
1391 Giannotti TE, Tate JP, Kelvey-Albert M, et al. Profiling variations in outpatient care for Medicare beneficiaries in Connecticut. Conn Med. Sep. 2006;70(8):509-14. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17089809].
1392 Giaramazidou T, Giovreki A, Morfakidou L, et al. A study of dietary knowledge and its religious relationship in patients receiving haemodialysis. EDTNA ERCA J. Oct-Dec. 2005;31(4):199-202. X-2, X-4, X-6. [pmid: 16551025].
1393 Giarratano G, Bustamante-Forest R, Carter C. A multicultural and multilingual outreach program for cervical and breast cancer screening. J Obstet Gynecol Neonatal Nurs. May-Jun. 2005;34(3):395-402. X-1, X-7, X-9. [pmid: 15890840].
1394 Gibson LM. A four-phase program to recruit African American women into breast cancer promotion programs. ABNF J. Jul-Aug. 2000;11(4):94-6. X-1, X-6, X-7, X-9. [pmid: 11760311].
1395 Gibson PG, Shah S, Mamoon HA. Peer-led asthma education for adolescents: impact evaluation. J Adolesc Health. Jan. 1998;22(1):66-72. X-7, X-8. [pmid: 9436069].
1396 Gifford AL, McPhee SJ, Fordham D. Preventive care among HIV-positive patients in a general medicine practice. Am J Prev Med. Jan-Feb. 1994;10(1):5-9. X-2, X-4, X-5. [pmid: 7909673].
1397 Gifford S, Zimmet P. A community approach to diabetes education in Australia--The Region 8 (Victoria) Diabetes Education and Control Program. Diabetes Res Clin Pract. May. 1986;2(2):105-12. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 3720500].
1398 Gijsbers B, Mesters I, Knottnerus JA, et al. Factors associated with the duration of exclusive breast-feeding in asthmatic families. Health Educ Res. Feb. 2008;23(1):158-69. X-3, X-5, X-6. [pmid: 17412718].
1399 Gilbertson HR, Brand-Miller JC, Thorburn AW, et al. The effect of flexible low glycemic index dietary advice versus measured carbohydrate exchange diets on glycemic control in children with type 1 diabetes. Diabetes Care. Jul. 2001;24(7):1137-43. X-7. [pmid: 11423492].
1400 Gilmer TP, O'Connor PJ, Rush WA, et al. Impact of office systems and improvement strategies on costs of care for adults with diabetes. Diabetes Care. Jun. 2006;29(6):1242-8. X-2. [pmid: 16732003].
1401 Gilmer TP, Roze S, Valentine WJ, et al. Cost-effectiveness of diabetes case management for low-income populations. Health Serv Res. Oct. 2007;42(5):1943-59. X-7, X-9. [pmid: 17850527].
1402 Gilmer TP, Walker C, Johnson ED, et al. Improving treatment of depression among Latinos with diabetes using project Dulce and IMPACT. Diabetes Care. Jul. 2008;31(7):1324-6. X-9. [pmid: 18356401].
1403 Gimpel N, Marcee A, Kennedy K, et al. Patient perceptions of a community-based care coordination system. Health Promot Pract. Mar. 2010;11(2):173-81. X-2, X-4, X-5. [pmid: 19131540].
1404 Ginde AA, Clark S, Goldstein JN, et al. Demographic disparities in numeracy among emergency department patients: evidence from two multicenter studies. Patient Educ Couns. Aug. 2008;72(2):350-6. X-2, X-5. [pmid: 18462915].
1405 Gines MD, Pinto LA, Gocka IT, et al. Relationship between chronic conditions and patient satisfaction with managed care. Journal for Healthcare Quality: Promoting Excellence in Healthcare. 2001;23(6):10-5. X-6, X-7, X-9.
1406 Ginsburg KR, Howe CJ, Jawad AF, et al. Parents' perceptions of factors that affect successful diabetes management for their children. Pediatrics. Nov. 2005;116(5):1095-104. X-2. [pmid: 16263995].
1407 Girdler SJ, Boldy DP, Dhaliwal SS, et al. Vision self-management for older adults: a randomised controlled trial. Br J Ophthalmol. Feb. 2010;94(2):223-8. X-6, X-7, X-9. [pmid: 20139291].
1408 Girois SB, Kumanyika SK, Morabia A, et al. A comparison of knowledge and attitudes about diet and health among 35- to 75-year-old adults in the United States and Geneva, Switzerland. Am J Public Health. Mar. 2001;91(3):418-24. X-2, X-5. [pmid: 11236407].
1409 Giroux J, Welty TK, Oliver FK, et al. Low national breast and cervical cancer-screening rates in American Indian and Alaska Native women with diabetes. J Am Board Fam Pract. Jul-Aug. 2000;13(4):239-45. X-2. [pmid: 10933287].
1410 Gitlin LN, Belle SH, Burgio LD, et al. Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. Sep. 2003;18(3):361-74. X-1, X-2, X-4, X-6. [pmid: 14518800].
1411 Giuffrida A, Gravelle H, Roland M. Measuring quality of care with routine data: avoiding confusion between performance indicators and health outcomes. BMJ. Jul. 10. 1999;319(7202):94-8. X-2, X-3. [pmid: 10398635].
1412 Given CW, Given BA, Coyle BW. Prediction of patient attrition from experimental behavioral interventions. Nurs Res. Sep-Oct. 1985;34(5):293-8. X-6, X-7, X-9. [pmid: 3900932].
1413 Glasgow RE. Interactive media for diabetes self-management: Issues in maximizing public health impact. Medical Decision Making. Nov-Dec. 2010;30(6):745-58. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 21183760].
1414 Glasgow RE, Christiansen SM, Kurz D, et al. Engagement in a Diabetes Self-management Website: Usage Patterns and Generalizability of Program Use. Journal of Medical Internet Research. Jan-Mar. 2011;13(1):70-83. X-6, X-9. [pmid: 21371992].
1415 Glasgow RE, Edwards LL, Whitesides H, et al. Reach and effectiveness of DVD and in-person diabetes self-management education. Chronic Illn. Dec. 2009;5(4):243-9. X-6, X-9. [pmid: 19933245].
1416 Glasgow RE, Fisher L, Skaff M, et al. Problem solving and diabetes self-management: investigation in a large, multiracial sample. Diabetes Care. Jan. 2007;30(1):33-7. X-2. [pmid: 17192329].
1417 Glasgow RE, Hampson SE, Strycker LA, et al. Personal-model beliefs and social-environmental barriers related to diabetes self-management. Diabetes Care. Apr. 1997;20(4):556-61. X-2, X-5, X-6. [pmid: 9096980].
1418 Glasgow RE, Kurz D, King D, et al. Outcomes of minimal and moderate support versions of an Internet-based diabetes self-management support program. Journal of General Internal Medicine. Dec. 2010;25(12):1315-22. X-6, X-9. [pmid: 20714820].
1419 Glasgow RE, La Chance PA, Toobert DJ, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Patient Educ Couns. Nov. 1997;32(3):175-84. X-6, X-9. [pmid: 9423499].
1420 Glasgow RE, Nelson CC, Strycker LA, et al. Using RE-AIM Metrics to Evaluate Diabetes Self-Management Support Interventions. American Journal of Preventive Medicine. Jan. 2006;30(1):67-73. X-6, X-9. [pmid: 16414426].
1421 Glasgow RE, Nutting PA, King DK, et al. Randomized effectiveness trial of a computer-assisted intervention to improve diabetes care. Diabetes Care. Jan. 2005;28(1):33-9. X-6, X-9. [pmid: 15616230].
1422 Glasgow RE, Perry JD, Toobert DJ, et al. Brief assessments of dietary behavior in field settings. Addict Behav. Mar-Apr. 1996;21(2):239-47. X-2, X-4, X-5, X-6. [pmid: 8730527].
1423 Glasgow RE, Strycker LA, Kurz D, et al. Recruitment for an internet-based diabetes self-management program: scientific and ethical implications. Ann Behav Med. Aug. 2010;40(1):40-8. X-2. [pmid: 20411443].
1424 Glasgow RE, Terborg JR, Hollis JF, et al. Modifying dietary and tobacco use patterns in the worksite: the Take Heart Project. Health Educ Q. Spring. 1994;21(1):69-82. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 8188494].
1425 Glasgow RE, Toobert DJ, Barrera M Jr., et al. Assessment of Problem-Solving: A Key to Successful Diabetes Self-Management. Journal of Behavioral Medicine. Oct. 2004;27(5):477-90. X-2, X-6. [pmid: 15675636].
1426 Glasgow RE, Whitesides H, Nelson CC, et al. Use of the Patient Assessment of Chronic Illness Care (PACIC) with diabetic patients: relationship to patient characteristics, receipt of care, and self-management. Diabetes Care. Nov. 2005;28(11):2655-61. X-2. [pmid: 16249535].
1427 Glauber JH. Does the HEDIS asthma measure go far enough?. Am J Manag Care. Jun. 2001;7(6):575-9. X-1, X-6, X-7, X-9. [pmid: 11439731].
1428 Glazer HR, Kirk LM, Bosler FE. Patient education pamphlets about prevention, detection, and treatment of breast cancer for low literacy women. Patient Educ Couns. Mar. 1996;27(2):185-9. X-2, X-4, X-6. [pmid: 8788348].
1429 Gleeson-Kreig J, Bernal H, Woolley S. The role of social support in the self-management of diabetes mellitus among a Hispanic population. Public Health Nurs. May-Jun. 2002;19(3):215-22. X-2. [pmid: 11967108].
1430 Glover S, Bellinger JD, Bae S, et al. Perceived health status and utilization of specialty care: Racial and ethnic disparities in patients with chronic diseases. Health Education Journal. Mar. 2010;69(1):95-106. X-2, X-3.
1431 Gnavi R, Migliardi A, Demaria M, et al. Statins prescribing for the secondary prevention of ischaemic heart disease in Torino, Italy. A case of ageism and social inequalities. Eur J Public Health. Oct. 2007;17(5):492-6. X-2, X-3, X-6. [pmid: 17303583].
1432 Gnavi R, Picariello R, la Karaghiosoff L, et al. Determinants of quality in diabetes care process: The population-based Torino Study. Diabetes Care. Nov. 2009;32(11):1986-92. X-2, X-3, X-6. [pmid: 19675196].
1433 Godard C, Chevalier A, Lecrubier Y, et al. APRAND programme: an intervention to prevent relapses of anxiety and depressive disorders. First results of a medical health promotion intervention in a population of employees. Eur Psychiatry. Oct. 2006;21(7):451-9. X-6, X-9. [pmid: 16675204].
1434 Godfrey CM, Harrison MB, Friedberg E, et al. The symptom of pain in individuals recently hospitalized for heart failure. J Cardiovasc Nurs. Sep-Oct. 2007;22(5):368-74. discussion 6-7. X-2. [pmid: 17724418].
1435 Godfrey JR, Wenger NK. Toward optimal health: Advances in the cardiovascular care of women. Journal of Women's Health. Apr. 2010;19(4):659-64. X-1, X-2, X-3, X-4, X-6. [pmid: 20187751].
1436 Goel MS, Gracia G, Baker DW. Development and pilot testing of a culturally sensitive multimedia program to improve breast cancer screening in Latina women. Patient Educ Couns. Jul. 2011;84(1):128-31. X-4, X-9. [pmid: 20638219].
1437 Goff VV. Depression: a decade of progress more to do. NHPF Issue Brief. Nov. 22. 2002;(786):1-14. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12463234].
1438 Gohar F, Greenfield SM, Beevers DG, et al. Self-care and adherence to medication: a survey in the hypertension outpatient clinic. BMC Complement Altern Med. 2008;8:4. X-2, X-3. [pmid: 18261219].
1439 Goksel O, Celik GE, Erkekol FO, et al. Triggers in adult asthma: are patients aware of triggers and doing right?. Allergol Immunopathol (Madr). May-Jun. 2009;37(3):122-8. X-2. [pmid: 19769844].
1440 Gold R, Yu K, Liang LJ, et al. Synchronous provider visit and self-management education improves glycemic control in Hispanic patients with long-standing type 2 diabetes. Diabetes Educ. Nov-Dec. 2008;34(6):990-5. X-4. [pmid: 18849465].
1441 Goldberg RW, Kreyenbuhl JA, Medoff DR, et al. Quality of diabetes care among adults with serious mental illness. Psychiatric Services. Apr. 2007;58(4):536-43. X-2, X-6. [pmid: 17412857].
1442 Golden AG, Corvea MH, Dang S, et al. Assessing advance directives in the homebound elderly. American Journal of Hospice & Palliative Medicine. Feb-Mar. 2009;26(1):13-7. X-2, X-5. [pmid: 18843136].
1443 Goldman DP, Smith JP. Can patient self-management help explain the SES health gradient?. Proc Natl Acad Sci U S A. Aug. 6. 2002;99(16):10929-34. X-6, X-7, X-9. [pmid: 12140364].
1444 Goldman LE, Handley M, Rundall TG, et al. Current and future directions in Medi-Cal chronic disease care management: A view from the top. American Journal of Managed Care. May. 2007;13(5):263-8. X-2, X-4. [pmid: 17488192].
1445 Goldman RE, Sanchez-Hernandez M, Ross-Degnan D, et al. Developing an automated speech-recognition telephone diabetes intervention. International Journal for Quality in Health Care. Aug. 2008;20(4):264-70. X-2, X-4. [pmid: 18492706].
1446 Goldney RD, Dunn KI, Dal Grande E, et al. Tracking depression-related mental health literacy across South Australia: a decade of change. Aust N Z J Psychiatry. May. 2009;43(5):476-83. X-2, X-3. [pmid: 19373710].
1447 Goldney RD, Fisher LJ. Have broad-based community and professional education programs influenced mental health literacy and treatment seeking of those with major depression and suicidal ideation?. Suicide Life Threat Behav. Apr. 2008;38(2):129-42. X-2, X-3. [pmid: 18444772].
1448 Goldney RD, Fisher LJ, Wilson DH. Mental health literacy: an impediment to the optimum treatment of major depression in the community. J Affect Disord. May. 2001;64(2-3):277-84. X-2. [pmid: 11313096].
1449 Goldney RD, Fisher LJ, Wilson DH, et al. Mental health literacy of those with major depression and suicidal ideation: an impediment to help seeking. Suicide Life Threat Behav. Winter. 2002;32(4):394-403. X-2, X-7, X-8. [pmid: 12501964].
1450 Goldney RD, Taylor AW, Bain MA. Depression and remoteness from health services in South Australia. Aust J Rural Health. Jun. 2007;15(3):201-10. X-2, X-3. [pmid: 17542794].
1451 Goldsmith DF, Sisneros GC. Cancer prevention strategies among California farmworkers: preliminary findings. J Rural Health. 1996;12(4 Suppl):343-8. X-9. [pmid: 10162865].
1452 Goldstein RB, Olfson M, Wickramaratne PJ, et al. Use of outpatient mental health services by depressed and anxious children as they grow up. Psychiatr Serv. Jul. 2006;57(7):966-75. X-2. [pmid: 16816281].
1453 Goldstone SE, Moshier E. Detection of oncogenic human papillomavirus impacts anal screening guidelines in men who have sex with men. Dis Colon Rectum. Aug. 2010;53(8):1135-42. X-2, X-5. [pmid: 20628276].
1454 Gollust SE, Lantz PM. Communicating population health: print news media coverage of type 2 diabetes. Soc Sci Med. Oct. 2009;69(7):1091-8. X-2, X-3, X-4. [pmid: 19666208].
1455 Golub RJ, McClellan JR, Herman SD, et al. Effectiveness of nuclear cardiology training guidelines: a comparison of trainees with experienced readers. J Nucl Cardiol. Mar-Apr. 1996;3(2):114-8. X-2, X-4, X-5, X-6. [pmid: 8799236].
1456 Gomes UA, Silva AA, Bettiol H, et al. Risk factors for the increasing caesarean section rate in Southeast Brazil: a comparison of two birth cohorts, 1978-1979 and 1994. Int J Epidemiol. Aug. 1999;28(4):687-94. X-2, X-3, X-6. [pmid: 10480697].
1457 Gomez SL, Tan S, Keegan TH, et al. Disparities in mammographic screening for Asian women in California: a cross-sectional analysis to identify meaningful groups for targeted intervention. BMC Cancer. 2007;7:201. X-2. [pmid: 17961259].
1458 Gondek MC. Post-MI sex: those unspoken fears. RN. May. 1983;46(5):60-3. X-1, X-6, X-7, X-9. [pmid: 6552022].
1459 Gonder-Frederick LA, Cox DJ, Ritterband LM. Diabetes and behavioral medicine: The second decade. Journal of Consulting and Clinical Psychology. Special Issue: Behavioral medicine and clinical health psychology. Jun. 2002;70(3):611-25. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12090372].
1460 Gonzalez HM, Vega WA, Tarraf W. Health Care Quality Perceptions among Foreign-Born Latinos and the Importance of Speaking the Same Language. Journal of the American Board of Family Medicine. Nov-Dec. 2010;23(6):745-52. X-2. [pmid: 21057070].
1461 Gonzalez S, Mlinarevich N, Michalski-Rimington AN, et al. The Latina Gestational Diabetes Mellitus Pilot Study: baseline data. Hispanic Health Care International. 2005;3(1):21-6. X-9.
1462 Goodson P, Gottlieb NH, Smith MM. Put prevention into practice. Evaluation of program initiation in nine Texas clinical sites. Am J Prev Med. Jul. 1999;17(1):73-8. X-2, X-4, X-5, X-6. [pmid: 10429756].
1463 Goodwin JS, Satish S, Anderson ET, et al. Effect of nurse case management on the treatment of older women with breast cancer. J Am Geriatr Soc. Sep. 2003;51(9):1252-9. X-6. [pmid: 12919237].
1464 Gopal RL, Beaver K, Barnett T, et al. A comparison of the information needs of women newly diagnosed with breast cancer in Malaysia and the United kingdom. Cancer Nurs. Mar-Apr. 2005;28(2):132-40. X-2, X-3, X-6. [pmid: 15815183].
1465 Gordon HS, Street RL Jr., Kelly PA, et al. Physician-patient communication following invasive procedures: an analysis of post-angiogram consultations. Soc Sci Med. Sep. 2005;61(5):1015-25. X-2. [pmid: 15955403].
1466 Gorin SS, Ashford AR, Lantigua R, et al. Effectiveness of academic detailing on breast cancer screening among primary care physicians in an underserved community. J Am Board Fam Med. Mar-Apr. 2006;19(2):110-21. X-9. [pmid: 16513899].
1467 Gorman BK, Chu M. Racial and ethnic differences in adult asthma prevalence, problems, and medical care. Ethnicity & Health. 2009;14(5):527-52. X-2. [pmid: 19533477].
1468 Gorter KJ, Tuytel GJ, de Leeuw RR, et al. Opinions of patients with type 2 diabetes about responsibility, setting targets and willingness to take medication. A cross-sectional survey. Patient Educ Couns. Jul. 2011;84(1):56-61. X-2, X-3, X-4, X-6. [pmid: 20655164].
1469 Gorter KJ, Wens J, Khunti K, et al. The European EUCCLID pilot study on care and complications in an unselected sample of people with type 2 diabetes in primary care. Primary Care Diabetes. Apr. 2010;4(1):17-23. X-2, X-3. [pmid: 20167551].
1470 Gottlieb NH, Huang PP, Blozis SA, et al. The impact of Put Prevention into Practice on selected clinical preventive services in five Texas sites. Am J Prev Med. Jul. 2001;21(1):35-40. X-4, X-6. [pmid: 11418255].
1471 Gotz I, Labenbacher I, Eichler I, et al. Health-independent lung transplantation information of parents of children with cystic fibrosis. Transplantation. Sep. 15. 1997;64(5):742-7. X-2, X-3, X-6. [pmid: 9311713].
1472 Goyder E, Carlisle J, Lawton J, et al. Informed choice and diabetes screening in primary care: qualitative study of patient and professional views in deprived areas of England. Prim Care Diabetes. May. 2009;3(2):85-90. X-2, X-3, X-4. [pmid: 19464976].
1473 Goyder E, Wild S, Fischbacher C, et al. Evaluating the impact of a national pilot screening programme for type 2 diabetes in deprived areas of England. Fam Pract. Oct. 2008;25(5):370-5. X-2, X-3. [pmid: 18765406].
1474 Goyder EC, Blank L, Ellis E, et al. Reducing inequalities in access to health care: developing a toolkit through action research. Qual Saf Health Care. Oct. 2005;14(5):336-9. X-3. [pmid: 16195566].
1475 Grace SL, Abbey SE, Bisaillon S, et al. Presentation, delay, and contraindication to thrombolytic treatment in females and males with myocardial infarction. Womens Health Issues. Nov-Dec. 2003;13(6):214-21. X-2, X-3. [pmid: 14675790].
1476 Grace SL, Gravely-Witte S, Brual J, et al. Contribution of patient and physician factors to cardiac rehabilitation enrollment: a prospective multilevel study. Eur J Cardiovasc Prev Rehabil. Oct. 2008;15(5):548-56. X-2, X-3. [pmid: 18830085].
1477 Graham CL, Ivey SL, Neuhauser L. From Hospital to Home: Assessing the Transitional Care Needs of Vulnerable Seniors. Gerontologist. Feb. 2009;49(1):23-33. X-2, X-5. [pmid: 19363001].
1478 Graling PR, Grant JM. Demographics and patient treatment choice in stage I breast cancer. AORN J. Sep. 1995;62(3):376-84. X-2. [pmid: 8534056].
1479 Gramling R, Anthony D, Simmons E, et al. Self-rated breast cancer risk among women reporting a first-degree family history of breast cancer on office screening questionnaires in routine medical care: The role of physician-delivered risk feedback. Genetics in Medicine. Oct. 2006;8(10):658-64. X-2. [pmid: 17079883].
1480 Grant BF, Harford TC. Comorbidity between DSM-IV alcohol use disorders and major depression: results of a national survey. Drug Alcohol Depend. Oct. 1995;39(3):197-206. X-2. [pmid: 8556968].
1481 Grant EN, Malone A, Lyttle CS, et al. Asthma morbidity and treatment in the Chicago metropolitan area: one decade after national guidelines. Ann Allergy Asthma Immunol. Jul. 2005;95(1):19-25. X-2, X-4. [pmid: 16095137].
1482 Grant R, Bowen SK, Neidell M, et al. Health care savings attributable to integrating guidelines-based asthma care in the pediatric medical home. J Health Care Poor Underserved. May. 2010;21(2 Suppl):82-92. X-2. [pmid: 20453378].
1483 Grant RW, Cagliero E, Chueh HC, et al. Internet use among primary care patients with type 2 diabetes: the generation and education gap. J Gen Intern Med. May. 2005;20(5):470-3. X-2. [pmid: 15963175].
1484 Graves KD, Huerta E, Cullen J, et al. Perceived risk of breast cancer among Latinas attending community clinics: risk comprehension and relationship with mammography adherence. Cancer Causes Control. Dec. 2008;19(10):1373-82. X-2, X-3. [pmid: 18704716].
1485 Gray J, Millett C, O'Sullivan C, et al. Association of age, sex and deprivation with quality indicators for diabetes: population-based cross sectional survey in primary care. J R Soc Med. Nov. 2006;99(11):576-81. X-2, X-3. [pmid: 17082303].
1486 Gray J, Millett C, Saxena S, et al. Ethnicity and quality of diabetes care in a health system with universal coverage: population-based cross-sectional survey in primary care. J Gen Intern Med. Sep. 2007;22(9):1317-20. X-2, X-3. [pmid: 17594128].
1487 Green AR, Peters-Lewis A, Percac-Lima S, et al. Barriers to screening colonoscopy for low-income latino and white patients in an urban community health center. Journal of General Internal Medicine. Jun. 2008;23(6):834-40. X-2, X-4. [pmid: 18350339].
1488 Green BB, Kaplan RC, Psaty BM. How do minor changes in the definition of blood pressure control affect the reported success of hypertension treatment?. Am J Manag Care. Mar. 2003;9(3):219-24. X-2. [pmid: 12643339].
1489 Green JA, Mor MK, Shields AM, et al. Prevalence and Demographic and Clinical Associations of Health Literacy in Patients on Maintenance Hemodialysis. Clinical Journal of the American Society of Nephrology. Jun. 2011;6(6):1354-60. X-2, X-4. [pmid: 21551025].
1490 Green JL, Gazmararian JA, Rask KJ, et al. Quality of diabetes care for underserved patients with and without mental illness: Site of care matters. Psychiatric Services. Dec. 2010;61(12):1204-10. X-2, X-6. [pmid: 21123404].
1491 Greenberg H, Fleischman J, Gouda HE, et al. Disparities in obstructive sleep apnea and its management between a minority-serving institution and a voluntary hospital. Sleep Breath. Dec. 2004;8(4):185-92. X-2, X-5. [pmid: 15611893].
1492 Greene BL, Miller JD, Brown TM, et al. Economic impact of the BP DownShift Program on blood pressure control among commercial driver license employees. J Occup Environ Med. May. 2009;51(5):542-53. X-2, X-4, X-5, X-8. [pmid: 19365286].
1493 Greene C, McClellan L, Gardner T, et al. Diabetes management among low-income African Americans: a description of a pilot strategy for empowerment. J Ambul Care Manage. Apr-Jun. 2006;29(2):162-6. X-7, X-9. [pmid: 16552325].
1494 Greene J, Yedidia MJ. Provider behaviors contributing to patient self-management of chronic illness among underserved populations. J Health Care Poor Underserved. Nov. 2005;16(4):808-24. X-2. [pmid: 16311500].
1495 Greene RA. Using the Ferrans and Powers Quality of Life Index of Dialysis: a comparison of quality of life in older and younger African Americans receiving hemodialysis. Topics in Geriatric Rehabilitation. 2005;21(3):230-2. X-2. [pmid: 14650370].
1496 Greenfield S, Kaplan SH, Kahn R, et al. Profiling care provided by different groups of physicians: effects of patient case-mix (bias) and physician-level clustering on quality assessment results. Ann Intern Med. Jan. 15. 2002;136(2):111-21. X-2. [pmid: 11790062].
1497 Greenglass ER, Burke RJ. Stress and the effects of hospital restructuring in nurses. Can J Nurs Res. Sep. 2001;33(2):93-108. X-2, X-3, X-5, X-6. [pmid: 11928340].
1498 Greenhalgh T, Campbell-Richards D, Vijayaraghavan S, et al. New models of self-management education for minority ethnic groups: pilot randomized trial of a story-sharing intervention. J Health Serv Res Policy. Jan. 2011;16(1):28-36. X-3. [pmid: 20739577].
1499 Greenhalgh T, Collard A, Begum N. Sharing stories: complex intervention for diabetes education in minority ethnic groups who do not speak English. BMJ. Mar. 19. 2005;330(7492):628. X-2, X-3. [pmid: 15774990].
1500 Greenhalgh T, Collard A, Campbell-Richards D, et al. Storylines of self-management: narratives of people with diabetes from a multiethnic inner city population. J Health Serv Res Policy. Jan. 2011;16(1):37-43. X-2, X-3. [pmid: 20819914].
1501 Greenslit N. Pharmaceutical branding: identity, individuality, and illness. Mol Interv. Oct. 2002;2(6):342-5. X-1, X-6, X-7, X-9. [pmid: 14993408].
1502 Greenwald BJ, Edwards JU. Worksite education programs by county extension agents to promote colorectal cancer prevention and screening. Gastroenterol Nurs. Sep-Oct. 2010;33(5):348-52. X-4, X-6. [pmid: 20890157].
1503 Greenwell G, Perlow M. Knowledge regarding preventive care for breast cancer in African American women in west Kentucky. Ky Nurse. Oct-Dec. 2002;50(4):5-6. X-1, X-7, X-9. [pmid: 12430341].
1504 Gregg EW, Geiss LS, Saaddine J, et al. Use of diabetes preventive care and complications risk in two African-American communities. Am J Prev Med. Oct. 2001;21(3):197-202. X-2. [pmid: 11567840].
1505 Gregory KD, Johnson CT, Johnson TRB, et al. The Content of Prenatal Care update 2005. Womens Health Issues. Jul-Aug. 2006;16(4):198-215. X-1, X-2, X-4, X-6. [pmid: 16920524].
1506 Greig A, Howe D. Social understanding, attachment security of preschool children and maternal mental health. British Journal of Developmental Psychology. 2001;19(Part 3):381-93. X-2, X-4, X-5.
1507 Greineder DK, Loane KC, Parks P. A randomized controlled trial of a pediatric asthma outreach program. J Allergy Clin Immunol. Mar. 1999;103(3 Pt 1):436-40. X-6, X-9. [pmid: 10069877].
1508 Grey M, Boland EA, Davidson M, et al. Short-term effects of coping skills training as adjunct to intensive therapy in adolescents. Diabetes Care. Jun. 1998;21(6):902-8. X-4, X-6. [pmid: 9614605].
1509 Grey M, Jaser SS, Holl MG, et al. A multifaceted school-based intervention to reduce risk for type 2 diabetes in at-risk youth. Prev Med. Aug-Sep. 2009;49(2-3):122-8. X-6, X-9. [pmid: 19643125].
1510 Griffith DM, Yonas M, Mason M, et al. Considering organizational factors in addressing health care disparities: two case examples. Health Promot Pract. May. 2010;11(3):367-76. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19346409].
1511 Griffith KA. Biological, psychological and behavioral, and social variables influencing colorectal cancer screening in African Americans. Nurs Res. Sep-Oct. 2009;58(5):312-20. X-2. [pmid: 19752671].
1512 Griffiths C, Foster G, Barnes N, et al. Specialist nurse intervention to reduce unscheduled asthma care in a deprived multiethnic area: the east London randomised controlled trial for high risk asthma (ELECTRA). BMJ. Jan. 17. 2004;328(7432):144. X-2, X-3. [pmid: 14718266].
1513 Griggs JJ, Culakova E, Sorbero ME, et al. Social and racial differences in selection of breast cancer adjuvant chemotherapy regimens. J Clin Oncol. Jun. 20. 2007;25(18):2522-7. X-2. [pmid: 17577029].
1514 Griggs JJ, Sorbero ME, Ahrendt GM, et al. The pen and the scalpel: effect of diffusion of information on nonclinical variations in surgical treatment. Med Care. Jul. 2009;47(7):749-57. X-2. [pmid: 19536033].
1515 Griggs JJ, Sorbero ME, Mallinger JB, et al. Vitality, mental health, and satisfaction with information after breast cancer. Patient Educ Couns. Apr. 2007;66(1):58-66. X-2. [pmid: 17137744].
1516 Grigg-Saito D, Och S, Liang S, et al. Building on the strengths of a Cambodian refugee community through community-based outreach. Health Promot Pract. Oct. 2008;9(4):415-25. X-1, X-2, X-4. [pmid: 17494947].
1517 Grigg-Saito D, Toof R, Silka L, et al. Long-term development of a “whole community” best practice model to address health disparities in the Cambodian refugee and immigrant community of Lowell, Massachusetts. Am J Public Health. Nov. 2010;100(11):2026-9. X-1, X-2, X-4, X-5. [pmid: 20864723].
1518 Grilli R, Mainini F, Penna A, et al. Inappropriate Halsted mastectomy and patient volume in Italian hospitals. Am J Public Health. Dec. 1993;83(12):1762-4. X-2, X-3. [pmid: 8259814].
1519 Grindel CG, Brown L, Caplan L, et al. The effect of breast cancer screening messages on knowledge, attitudes, perceived risk, and mammography screening of African American women in the rural South. Oncol Nurs Forum. Jul. 2004;31(4):801-8. X-7, X-9. [pmid: 15252434].
1520 Grindel CG, McGehee LA, Patsdaughter CA, et al. Cancer prevention and screening behaviors in lesbians. Women Health. 2006;44(2):15-39. X-2, X-6. [pmid: 17255057].
1521 Grineski S. Coping with asthma in the central city: Parental experiences with children's health care. Journal of Health Care for the Poor and Underserved. Feb. 2008;19(1):227-36. X-2, X-4. [pmid: 18263998].
1522 Groeneveld PW. Preventing sudden death: implantable cardioverter-defibrillators in elderly cardiac patients. LDI Issue Brief. May-Jun. 2008;13(6):1-4. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18613344].
1523 Gross TM, Ter Veer A. Continuous glucose monitoring in previously unstudied population subgroups. Diabetes Technol Ther. Suppl 1. 2000;2:S27-34. X-6, X-7, X-9. [pmid: 11469629].
1524 Grossman E, Keegan T, Lessler AL, et al. Inside the health disparities collaboratives: a detailed exploration of quality improvement at community health centers. Med Care. May. 2008;46(5):489-96. X-6, X-9. [pmid: 18438197].
1525 Groth S. Are the Institute of Medicine recommendations for gestational weight gain appropriate for adolescents?. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 2007;36(1):21-7. X-2. [pmid: 17238943].
1526 Grubbs V, Gregorich SE, Perez-Stable EJ, et al. Health literacy and access to kidney transplantation. Clin J Am Soc Nephrol. Jan. 2009;4(1):195-200. X-2, X-4. [pmid: 19056617].
1527 Grunau GL, Ratner PA, Galdas PM, et al. Ethnic and gender differences in patient education about heart disease risk and prevention. Patient Education and Counseling. Aug. 2009;76(2):181-8. X-2, X-3. [pmid: 19232879].
1528 Grunau GL, Sheps S, Goldner EM, et al. Specific comorbidity risk adjustment was a better predictor of 5-year acute myocardial infarction mortality than general methods. J Clin Epidemiol. Mar. 2006;59(3):274-80. X-2, X-3, X-6. [pmid: 16488358].
1529 Grzywacz JG, Arcury TA, Bell RA, et al. Ethnic differences in elders' home remedy use: sociostructural explanations. Am J Health Behav. Jan-Feb. 2006;30(1):39-50. X-2, X-5. [pmid: 16430319].
1530 Grzywacz JG, Arcury TA, Ip EH, et al. Older adults' common sense models of diabetes. Am J Health Behav. May. 2011;35(3):318-33. X-2, X-4. [pmid: 21683021].
1531 Grzywacz JG, Suerken CK, Quandt SA, et al. Older adults' use of complementary and alternative medicine for mental health: findings from the 2002 National Health Interview Survey. J Altern Complement Med. Jun. 2006;12(5):467-73. X-2, X-6. [pmid: 16813511].
1532 Gu Q, Burt VL, Paulose-Ram R, et al. Gender differences in hypertension treatment, drug utilization patterns, and blood pressure control among US adults with hypertension: data from the National Health and Nutrition Examination Survey 1999-2004. Am J Hypertens. Jul. 2008;21(7):789-98. X-2. [pmid: 18451806].
1533 Gucciardi E, DeMelo M, Booth G, et al. Individual and contextual factors associated with follow-up use of diabetes self-management education programmes: a multisite prospective analysis. Diabet Med. May. 2009;26(5):510-7. X-2. [pmid: 19646191].
1534 Gucciardi E, DeMelo M, Offenheim A, et al. Patient factors associated with attrition from a self-management education programme. J Eval Clin Pract. Dec. 2007;13(6):913-9. X-2, X-3. [pmid: 18070262].
1535 Gucciardi E, Demelo M, Offenheim A, et al. Factors contributing to attrition behavior in diabetes self-management programs: a mixed method approach. BMC Health Serv Res. 2008;8:33. X-2, X-3, X-6. [pmid: 18248673].
1536 Gucciardi E, Wang SC, DeMelo M, et al. Characteristics of men and women with diabetes: observations during patients' initial visit to a diabetes education centre. Can Fam Physician. Feb. 2008;54(2):219-27. X-2, X-3. [pmid: 18272638].
1537 Guerra CE, Dominguez F, Shea JA. Literacy and knowledge, attitudes, and behavior about colorectal cancer screening. Journal of Health Communication. Oct-Nov. 2005;10(7):651-63. X-2. [pmid: 16278201].
1538 Guerra CE, Schwartz JS, Armstrong K, et al. Barriers of and facilitators to physician recommendation of colorectal cancer screening. J Gen Intern Med. Dec. 2007;22(12):1681-8. X-2, X-4, X-6. [pmid: 17939007].
1539 Guidry JJ, Fagan P, Walker V. Cultural sensitivity and readability of breast and prostate printed cancer education materials targeting African Americans. J Natl Med Assoc. Mar. 1998;90(3):165-9. X-2, X-4. [pmid: 9549980].
1540 Gulliford MC, Alert CV, Mahabir D, et al. Diabetes care in middle-income countries: a Caribbean case study. Diabet Med. Jun. 1996;13(6):574-81. X-2, X-3. [pmid: 8799663].
1541 Gunathilake W, Idampitiya CA, Siriwardana A, et al. An international partnership to implement innovative systems of health care delivery for diabetes in a developing country. Practical Diabetes International. 2009;26(4):145-7. X-1, X-2, X-3, X-5, X-6.
1542 Gupta RS, Weiss KB. The 2007 National Asthma Education and Prevention Program asthma guidelines: accelerating their implementation and facilitating their impact on children with asthma. Pediatrics. Mar. Suppl 3. 2009;123:S193-8. X-1, X-2, X-3, X-4, X-6. [pmid: 19221163].
1543 Gupta SK. Impact of a health education intervention program regarding breast self examination by women in a semi-urban area of Madhya Pradesh. India Asian Pac J Cancer Prev. 2009;10(6):1113-7. X-3, X-5. [pmid: 20192594].
1544 Gurwitz JH, McLaughlin TJ, Willison DJ, et al. Delayed hospital presentation in patients who have had acute myocardial infarction. Ann Intern Med. Apr. 15. 1997;126(8):593-9. X-2. [pmid: 9103125].
1545 Gustafson DH, Hawkins R, Pingree S, et al. Effect of computer support on younger women with breast cancer. J Gen Intern Med. Jul. 2001;16(7):435-45. X-6, X-7, X-9, X-10. [pmid: 11520380].
1546 Gustafson DH, Taylor JO, Thompson S, et al. Assessing the needs of breast cancer patients and their families. Qual Manag Health Care. Fall. 1993;2(1):6-17. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10131022].
1547 Gustavsson A, Branholm I. Experienced health, life satisfaction, sense of coherence, and coping resources in individuals living with heart failure. Scandinavian Journal of Occupational Therapy. 2003;10(3):138-43. X-2, X-4. [pmid: 21275511].
1548 Gwarzo UM, Sabitu K, Idris SH. Knowledge and practice of breast-self examination among female undergraduate students of Ahmadu Bello University Zaria, northwestern Nigeria. Ann Afr Med. Jan-Mar. 2009;8(1):55-8. X-2, X-3, X-6. [pmid: 19763009].
1549 Ha J, Carr D. The effect of parent-child geographic proximity on widowed parents' psychological adjustment and social integration. Research on Aging. 2005;27(5):578-610. X-2, X-4, X-5, X-6.
1550 Haafkens JA, Beune EJ, Moll van Charante EP, et al. A cluster-randomized controlled trial evaluating the effect of culturally-appropriate hypertension education among Afro-Surinamese and Ghanaian patients in Dutch general practice: study protocol. BMC Health Serv Res. 2009;9:193. X-3. [pmid: 19849857].
1551 Haber SG, Mitchell JB. Access to physicians' services for vulnerable Medicare beneficiaries. Inquiry. Winter. 1999;36(4):445-60. X-2, X-7. [pmid: 10711319].
1552 Habermann EB, Virnig BA, Durham SB, et al. Managed care enrollment and chronically disabled women with breast cancer. Am J Manag Care. Aug. 2008;14(8):514-20. X-2, X-4. [pmid: 18690767].
1553 Haerem JW, Ronning EJ, Leidal R. Home access to hospital discharge information on audiotape reduces sick leave and readmissions in patients with first-time myocardial infarction. Scand Cardiovasc J. 2000;34(2):219-22. X-4, X-6. [pmid: 10872714].
1554 Hagedoorn M, Keers JC, Links TP, et al. Improving self-management in insulin-treated adults participating in diabetes education. The role of overprotection by the partner. Diabet Med. Mar. 2006;23(3):271-7. X-2, X-6. [pmid: 16492210].
1555 Hagey R. The Native Diabetes Program: rhetorical process and praxis. Med Anthropol. Nov. 1989;12(1):7-33. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 2486129].
1556 Hahn EA, Cella D. Health outcomes assessment in vulnerable populations: Measurement challenges and recommendations. Archives of Physical Medicine and Rehabilitation. Apr. 2003;84(4):S35-S42. X-1, X-6, X-7, X-9. [pmid: 12692770].
1557 Hahn EA, Cella D, Dobrez D, et al. The talking touchscreen: A new approach to outcomes assessment in low literacy. Psycho-Oncology. Feb. 2004;13(2):86-95. X-2, X-4. [pmid: 14872527].
1558 Haiart DC, Henderson J. A comparison of interpretation of screening mammograms by a radiographer, a doctor and a radiologist: results and implications. Br J Clin Pract. Spring. 1991;45(1):43-5. X-2, X-3, X-4, X-6. [pmid: 1931542].
1559 Haire-Joshu D, Fisher EB Jr., Munro J, et al. A comparison of patient attitudes toward asthma self-management among acute and preventive care settings. J Asthma. 1993;30(5):359-71. X-2, X-4. [pmid: 8407736].
1560 Hairon N. Report finds inequity in access to breast surgery services. Nurs Times. Mar. 18-24. 2008;104(11):21-2. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18411814].
1561 Hajek P, West R, Lee A, et al. Randomized controlled trial of a midwife-delivered brief smoking cessation intervention in pregnancy. Addiction. Mar. 2001;96(3):485-94. X-3, X-5, X-6. [pmid: 11255587].
1562 Halabi S, Skinner CS, Samsa GP, et al. Factors associated with repeat mammography screening. J Fam Pract. Dec. 2000;49(12):1104-12. X-2, X-4, X-6. [pmid: 11132060].
1563 Hale NL, Bennett KJ, Probst JC. Diabetes care and outcomes: disparities across rural America. J Community Health. Aug. 2010;35(4):365-74. X-2, X-4, X-6. [pmid: 20386968].
1564 Halgunseth LC, Ispa JM, Csizmadia A, et al. Relations among maternal racial identity, maternal parenting behavior, and child outcomes in low-income, urban, black families. Journal of Black Psychology. 2005;31(4):418-40. X-2, X-4, X-5.
1565 Hall CP, Hall JD, Pfriemer JT, et al. Effects of a culturally sensitive education program on the breast cancer knowledge and beliefs of Hispanic women. Oncol Nurs Forum. Nov. 2007;34(6):1195-202. X-4. [pmid: 18024346].
1566 Hall CP, Wimberley PD, Hall JD, et al. Teaching breast cancer screening to African American women in the Arkansas Mississippi river delta. Oncol Nurs Forum. Jul. 2005;32(4):857-63. X-4. [pmid: 15990915].
1567 Hall L, Gore S, Witten B. Vocational rehabilitation: is your facility on track?. Nephrol News Issues. Dec. 2009;23(13):22-5. X-2, X-6. [pmid: 20050435].
1568 Hall PS, Hill MN, Roary MC, et al. A look at hypertension in young African-American men. Nurse Pract. Jan. 2003;28(1):59-60. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12544590].
1569 Hall TA. Designing culturally relevant educational materials for Mexican American clients. Diabetes Educ. Summer. 1987;13(3):281-5. X-1, X-6, X-7, X-9. [pmid: 3665715].
1570 Hallal JC. A descriptive analysis of knowledge about breast cancer. Health Values. Jul-Aug. 1983;7(4):11-4. X-2, X-4. [pmid: 10261565].
1571 Halm EA, Mora P, Leventhal H. No symptoms, no asthma: the acute episodic disease belief is associated with poor self-management among inner-city adults with persistent asthma. Chest. Mar. 2006;129(3):573-80. X-2, X-4. [pmid: 16537854].
1572 Halm EA, Wisnivesky JP, Leventhal H. Quality and access to care among a cohort of inner-city adults with asthma: who gets guideline concordant care?. Chest. Oct. 2005;128(4):1943-50. X-2, X-4, X-5. [pmid: 16236839].
1573 Halpern J, Johnson MD, Miranda J, et al. The partners in care approach to ethics outcomes in quality improvement programs for depression. Psychiatr Serv. May. 2004;55(5):532-9. X-1, X-6, X-7, X-9. [pmid: 15128961].
1574 Halterman JS, Aligne CA, Auinger P, et al. Inadequate therapy for asthma among children in the United States. Pediatrics. Jan. 2000;105(1 Pt 3):272-6. X-2, X-4. [pmid: 10617735].
1575 Halterman JS, Borrelli B, Fisher S, et al. Improving care for urban children with asthma: design and methods of the School-Based Asthma Therapy (SBAT) trial. J Asthma. May. 2008;45(4):279-86. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18446591].
1576 Hamalainen J, Isometsa E, Sihvo S, et al. Treatment of major depressive disorder in the Finnish general population. Depress Anxiety. 2009;26(11):1049-59. X-2, X-3, X-5. [pmid: 19123456].
1577 Hamilton FL, Bottle A, Vamos EP, et al. Impact of a pay-for-performance incentive scheme on age, sex, and socioeconomic disparities in diabetes management in UK primary care. J Ambul Care Manage. Oct-Dec. 2010;33(4):336-49. X-3. [pmid: 20838113].
1578 Hamilton P, Restrepo E. Weekend birth and higher neonatal mortality: a problem of patient acuity or quality of care?. J Obstet Gynecol Neonatal Nurs. Nov-Dec. 2003;32(6):724-33. X-2, X-4. [pmid: 14649592].
1579 Hamilton W, Round A, Goodchild R, et al. Do community based self-reading sphygmomanometers improve detection of hypertension? A feasibility study. J Public Health Med. Jun. 2003;25(2):125-30. X-2, X-3, X-4, X-6. [pmid: 12848401].
1580 Han HR, Kim J, Kim KB, et al. Implementation and success of nurse telephone counseling in linguistically isolated Korean American patients with high blood pressure. Patient Educ Couns. Jul. 2010;80(1):130-4. X-9. [pmid: 19945816].
1581 Han HR, Kim KB, Kang J, et al. Knowledge, beliefs, and behaviors about hypertension control among middle-aged Korean Americans with hypertension. Journal of Community Health. Oct. 2007;32(5):324-42. X-6, X-7, X-9. [pmid: 17922204].
1582 Han HR, Kim KB, Kim MT. Evaluation of the training of Korean community health workers for chronic disease management. Health Educ Res. Aug. 2007;22(4):513-21. X-2, X-3, X-4. [pmid: 17032707].
1583 Han PK, Lehman TC, Massett H, et al. Conceptual problems in laypersons' understanding of individualized cancer risk: a qualitative study. Health Expect. Mar. 2009;12(1):4-17. X-2, X-4. [pmid: 19250148].
1584 Hanania NA, David-Wang A, Kesten S, et al. Factors associated with emergency department dependence of patients with asthma. Chest. Feb. 1997;111(2):290-5. X-2, X-4, X-6. [pmid: 9041971].
1585 Handley MA, Shumway M, Schillinger D. Cost-effectiveness of automated telephone self-management support with nurse care management among patients with diabetes. Ann Fam Med. Nov-Dec. 2008;6(6):512-8. X-6, X-9. [pmid: 19001303].
1586 Hanel G, Henningsen P, Herzog W, et al. Depression, anxiety, and somatoform disorders: vague or distinct categories in primary care? Results from a large cross-sectional study. J Psychosom Res. Sep. 2009;67(3):189-97. X-2, X-3, X-4, X-6. [pmid: 19686874].
1587 Hanlon JT, Fillenbaum GG, Studenski SA, et al. Factors associated with suboptimal analgesic use in community-dwelling elderly. Ann Pharmacother. Jul-Aug. 1996;30(7-8):739-44. X-2, X-4, X-5, X-6. [pmid: 8826552].
1588 Hannan EL, Kumar D. Geographic variation in the utilization and choice of procedures for treating coronary artery disease in New York State. Ischaemic Heart Disease Patient Outcomes Research Team (PORT). J Health Serv Res Policy. Jul. 1997;2(3):137-43. X-2, X-4, X-6. [pmid: 10180374].
1589 Hanni KD, Garcia E, Ellemberg C, et al. Targeting the taqueria: implementing healthy food options at Mexican American restaurants. Health Promot Pract. Apr. 2009;10(2 Suppl):91S-9S. X-3, X-4, X-5. [pmid: 19454755].
1590 Hanninen J, Takala J, Keinanen-Kiukaanniemi S. Good continuity of care may improve quality of life in Type 2 diabetes. Diabetes Res Clin Pract. Jan. 2001;51(1):21-7. X-2, X-4, X-6. [pmid: 11137178].
1591 Hanprasitkam K, Wonghongkul T, Sucamvang K, et al. Factors predicting fatigue among Thai women with breast cancer. Thai Journal of Nursing Research. 2007. Jan-Mar. 2007;11(1):1-14. X-2, X-3, X-4, X-6.
1592 Hansen LK, Feigl P, Modiano MR, et al. An educational program to increase cervical and breast cancer screening in Hispanic women: a Southwest Oncology Group study. Cancer Nurs. Jan-Feb. 2005;28(1):47-53. X-7, X-9. [pmid: 15681982].
1593 Hansen MV, Pedersen-Bjergaard U, Heller SR, et al. Frequency and motives of blood glucose self-monitoring in type 1 diabetes. Diabetes Res Clin Pract. Aug. 2009;85(2):183-8. X-2, X-3, X-4, X-6. [pmid: 19497633].
1594 Hanson CL, De Guire MJ, Schinkel AM, et al. Empirical validation for a family-centered model of care. Diabetes Care. Oct. 1995;18(10):1347-56. X-2, X-4, X-6. [pmid: 8721936].
1595 Hanson H, Hodgson S. Cancer genetics and reproduction. Best Pract Res Clin Obstet Gynaecol. Feb. 2010;24(1):3-18. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19864186].
1596 Hanson J. Parental self-efficacy and asthma self-management skills. J Soc Pediatr Nurs. Oct-Dec. 1998;3(4):146-54. X-6, X-9. [pmid: 9884948].
1597 Hardman K, Hunt KJ, Carter RE, et al. Diabetes management and vaccination rates in the Southeast United States, 2000 through 2007. Ethn Dis. Winter. 2011;21(1):13-9. X-2, X-4, X-6. [pmid: 21462724].
1598 Harewood GC, Petersen BT, Ott BJ. Prospective assessment of the impact of feedback on colonoscopy performance. Aliment Pharmacol Ther. Jul. 15. 2006;24(2):313-8. X-6, X-9. [pmid: 16842458].
1599 Haringsma R, Engels GI, van der Leeden R, et al. Predictors of response to the ‘Coping with Depression’ course for older adults. A field study. Aging Ment Health. Jul. 2006;10(4):424-34. X-3, X-6. [pmid: 16798635].
1600 Harman JS, Edlund M, Fortney JC. Disparities in the Adequacy of Depression Treatment in the United States. Psychiatric Services. Dec. 2004;55(12):1379-85. X-2, X-4. [pmid: 15572565].
1601 Harman JS, Scholle SH, Ng JH, et al. Association of Health Plans' Healthcare Effectiveness Data and Information Set (HEDIS) performance with outcomes of enrollees with diabetes. Med Care. Mar. 2010;48(3):217-23. X-2, X-4, X-6. [pmid: 20125042].
1602 Harper G. GAKP responds to CMS proposed conditions for coverage. Nephrol News Issues. May. 2005;19(6):38. 43. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15945225].
1603 Harris A, Gao Y, Barclay L, et al. Consequences of birth policies and practices in post-reform China. Reprod Health Matters. Nov. 2007;15(30):114-24. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17938076].
1604 Harris DE, Aboueissa AM, Hartley D. Myocardial infarction and heart failure hospitalization rates in Maine, USA - variability along the urban-rural continuum. Rural Remote Health. Apr-Jun. 2008;8(2):980. X-2, X-4, X-6. [pmid: 18627216].
1605 Harris MI. Frequency of blood glucose monitoring in relation to glycemic control in patients with type 2 diabetes. Diabetes Care. Jun. 2001;24(6):979-82. X-2, X-4, X-6. [pmid: 11375356].
1606 Harris MI, Cowie CC, Eastman R. Health-insurance coverage for adults with diabetes in the U.S. population. Diabetes Care. Jun. 1994;17(6):585-91. X-2, X-4, X-6. [pmid: 8082529].
1607 Harris MI, Cowie CC, Howie LJ. Self-monitoring of blood glucose by adults with diabetes in the United States population. Diabetes Care. Aug. 1993;16(8):1116-23. X-2, X-4. [pmid: 8375241].
1608 Harris MI, Eastman RC, Cowie CC, et al. Racial and ethnic differences in glycemic control of adults with type 2 diabetes. Diabetes Care. Mar. 1999;22(3):403-8. X-2. [pmid: 10097918].
1609 Harsen GA. Identifying and overcoming barriers to learning: low literacy levels and vision impairment in elderly diabetics. Tenn Nurse. Fall. 2009;72(3):4. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19856541].
1610 Hartenbaum NP. What are the current guidelines on the use of implantable defibrillators in transportation safety critical work?. J Occup Environ Med. Jul. 2005;47(7):752-5. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 16010201].
1611 Hartmuller VW, Desmond SM. Professional and patient perspectives on nutritional needs of patients with cancer. Oncology Nursing Forum. Sep. 2004;31(5):989-96. X-2, X-4, X-6. [pmid: 15378100].
1612 Hartwell L. Patients educating patients. Let's add a little PEP to the renal community. Nephrol News Issues. Sep. 2003;17(10):67. X-1, X-6, X-7, X-9. [pmid: 14533518].
1613 Harum P, Galvez O, Mayol LG, et al. Immediate and delayed memory recall patterns of chronic hemodialysis adult hispanic patients. J Ren Nutr. Apr. 2003;13(2):98-104. X-2, X-4. [pmid: 12671832].
1614 Harvey I, Schulz A, Israel B, et al. The Healthy Connections project: a community-based participatory research project involving women at risk for diabetes and hypertension. Prog Community Health Partnersh. Winter. 2009;3(4):287-300. X-9. [pmid: 20097990].
1615 Harwell TS, McDowall JM, Gohdes D, et al. Measuring and improving preventive care for patients with diabetes in primary health centers. Am J Med Qual. Sep-Oct. 2002;17(5):179-84. X-4. [pmid: 12412945].
1616 Hasan RA, Zureikat GY, Camp J, et al. The positive impact of a disease management program on asthma morbidity in inner-city children. Pediatric Asthma, Allergy & Immunology. 2003;16(3):147-53. X-9.
1617 Haskell WL, Berra K, Arias E, et al. Multifactor cardiovascular disease risk reduction in medically underserved, high-risk patients. Am J Cardiol. Dec. 1. 2006;98(11):1472-9. X-9. [pmid: 17126653].
1618 Haslam C, Brown S, Atkinson S, et al. Patients' experiences of medication for anxiety and depression: effects on working life. Fam Pract. Apr. 2004;21(2):204-12. X-2, X-3, X-4, X-6. [pmid: 15020393].
1619 Hasnain-Wynia R, Kang R, Landrum MB, et al. Racial and ethnic disparities within and between hospitals for inpatient quality of care: an examination of patient-level Hospital Quality Alliance measures. J Health Care Poor Underserved. 2010;21(2):629-48. X-2, X-4. [pmid: 20453362].
1620 Hassan K, Heptulla RA. Glycemic control in pediatric type 1 diabetes: role of caregiver literacy. Pediatrics. May. 2010;125(5):e1104-8. X-2, X-4. [pmid: 20368322].
1621 Hassinger JP, Holubar SD, Pendlimari R, et al. Effectiveness of a multimedia-based educational intervention for improving colon cancer literacy in screening colonoscopy patients. Dis Colon Rectum. Sep. 2010;53(9):1301-7. X-4, X-6, X-7, X-9. [pmid: 20706074].
1622 Hastrup JL, Phillips SM, Vullo K, et al. Adolescents' knowledge of medical terminology and family health history. Health Psychol. 1992;11(1):41-7. X-2, X-6. [pmid: 1559533].
1623 Hatcher ME, Green LW, Levine DM, et al. Validation of a decision model for triaging hypertensive patients to alternate health education interventions. Soc Sci Med. 1986;22(8):813-9. X-6, X-9. [pmid: 3092363].
1624 Hatherly K, Smith L, Overland J, et al. Glycemic control and type 1 diabetes: the differential impact of model of care and income. Pediatr Diabetes. Mar. 2011;12(2):115-9. X-2, X-3, X-4, X-6. [pmid: 20522168].
1625 Haupt E, Herrmann R, Benecke-Timp A, et al. The KID Study. II: Socioeconomic baseline characteristics, psycho-social strain, standard of current medical care and education of the Federal Insurance for Salaried Employees' Institution (BfA) diabetic patients in inpatient rehabilitation. Kissingen Diabetes Intervention Study. Exp Clin Endocrinol Diabetes. 1996;104(5):378-86. X-2, X-3, X-6. [pmid: 8957273].
1626 Haupt E, Herrmann R, Benecke-Timp A, et al. The KID study IV: effects of inpatient rehabilitation on the frequency of glucose self-monitoring, quality of further primary care, on time being unable to work and on everyday psychic strain of type I and type II diabetics--a one-year follow-up. Kissingen Diabetes Intervention Study. Exp Clin Endocrinol Diabetes. 1997;105(1):21-31. X-2, X-3, X-6. [pmid: 9088891].
1627 Hausmann LR, Ibrahim SA, Mehrotra A, et al. Racial and ethnic disparities in pneumonia treatment and mortality. Med Care. Sep. 2009;47(9):1009-17. X-6, X-7, X-9. [pmid: 19648832].
1628 Hausmann LR, Kressin NR, Hanusa BH, et al. Perceived racial discrimination in health care and its association with patients' healthcare experiences: does the measure matter?. Ethn Dis. Winter. 2010;20(1):40-7. X-2, X-4. [pmid: 20178181].
1629 Hautman MA, Bomar P. Gender differences in knowing about hypertension: the black experience. Health Care Women Int. Jan-Mar. 1992;13(1):57-65. X-2, X-4. [pmid: 1556032].
1630 Haverkamp D, Perdue DG, Espey D, et al. A survey of Indian Health Service and tribal health providers' colorectal cancer screening knowledge, perceptions, and practices. J Health Care Poor Underserved. 2011;22(1):243-57. X-2, X-4. [pmid: 21317519].
1631 Havik OE, Maeland JG. Knowledge and expectations: perceived illness in myocardial infarction patients. Scand J Psychol. 1987;28(4):281-92. X-2, X-4. [pmid: 3449940].
1632 Hawkins SY. Improving glycemic control in older adults using a videophone motivational diabetes self-management intervention. Res Theory Nurs Pract. 2010;24(4):217-32. X-4, X-6. [pmid: 21197917].
1633 Hawley ST, Janz NK, Lillie SE, et al. Perceptions of care coordination in a population-based sample of diverse breast cancer patients. Patient Educ Couns. Dec. 2010;81(Suppl):S34-40. X-2, X-4. [pmid: 21074963].
1634 Hawley ST, Lantz PM, Janz NK, et al. Factors associated with patient involvement in surgical treatment decision making for breast cancer. Patient Educ Couns. Mar. 2007;65(3):387-95. X-2, X-4, X-6. [pmid: 17156967].
1635 Hawley ST, Volk RJ, Krishnamurthy P, et al. Preferences for colorectal cancer screening among racially/ethnically diverse primary care patients. Med Care. Sep. 2008;46(9 Suppl 1):S10-6. X-2. [pmid: 18725820].
1636 Hawley ST, Zikmund-Fisher B, Ubel P, et al. The impact of the format of graphical presentation on health-related knowledge and treatment choices. Patient Educ Couns. Dec. 2008;73(3):448-55. X-2, X-5. [pmid: 18755566].
1637 Hawthorne K, Tomlinson S. Pakistani moslems with Type 2 diabetes mellitus: effect of sex, literacy skills, known diabetic complications and place of care on diabetic knowledge, reported self-monitoring management and glycaemic control. Diabet Med. Jul. 1999;16(7):591-7. X-2, X-3, X-4. [pmid: 10445836].
1638 Hayes RP, Bernard AM, Slocum W, et al. Diabetes in urban African Americans: Assessment of diabetes-specific locus of control in patients with type 2 diabetes. Diabetes Educator. Jan-Feb. 2000;26(1):121-8. X-2, X-4. [pmid: 10776104].
1639 Hayes RP, Bowman L, Monahan PO, et al. Understanding diabetes medications from the perspective of patients with type 2 diabetes: prerequisite to medication concordance. Diabetes Educ. May-Jun. 2006;32(3):404-14. X-2, X-4, X-6. [pmid: 16772656].
1640 Hays R, Waterman AD. Improving preemptive transplant education to increase living donation rates: reaching patients earlier in their disease adjustment process. Prog Transplant. Dec. 2008;18(4):251-6. X-1, X-2, X-4, X-5. [pmid: 19186577].
1641 Hays RD, Morales LS. The RAND-36 measure of health-related quality of life. Annals of Medicine. Jul. 2001;33(5):350-7. X-1, X-2, X-4, X-5, X-6. [pmid: 11491194].
1642 Hazuda HP, Stern MP, Gaskill SP, et al. Ethnic differences in health knowledge and behaviors related to the prevention and treatment of coronary heart disease. The San Antonio Heart Study. Am J Epidemiol. Jun. 1983;117(6):717-28. X-2, X-4. [pmid: 6859027].
1643 Heaman M, Elliott LJ, Beaudoin C, et al. Preventable feto-infant mortality: application of a conceptual framework for perinatal health surveillance to Manitoba perinatal outcomes. Can J Public Health. Nov-Dec. Suppl 2. 2002;93:S27-32. X-2, X-3, X-4, X-6. [pmid: 12580387].
1644 Hebb JH, Fitzgerald D, Fan W. Health care disparities in disadvantaged Medicare beneficiaries: a national project review. J Health Hum Serv Adm. Fall. 2003;26(2):153-73. X-2, X-4. [pmid: 15330488].
1645 Hebert PL, Frick KD, Kane RL, et al. The Causes of Racial and Ethnic Differences in Influenza Vaccination Rates among Elderly Medicare Beneficiaries. Health Services Research. Apr. 2005;40(2):517-37. X-2, X-4, X-5. [pmid: 15762905].
1646 Heiken JP. CT colonography screening: ready for prime time?. Cancer Imaging. 2009;9(Spec No A):S59-62. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19965295].
1647 Heimbach JK, Biffl WL, Mitchell EL, et al. Breast conservation therapy in affiliated county, university, and private hospitals. Am J Surg. Dec. 1999;178(6):466-9. X-2, X-4, X-6. [pmid: 10670854].
1648 Heinberg LJ, Kutchman EM, Berger NA, et al. Parent involvement is associated with early success in obesity treatment. Clin Pediatr (Phila). May. 2010;49(5):457-65. X-5, X-6. [pmid: 19487764].
1649 Heiser D. Depression identification in the long-term care setting: the GDS vs. rhe MDS. Clinical Gerontologist. 2004;27(4):3-18. X-2, X-4, X-6.
1650 Heisler M, Faul JD, Hayward RA, et al. Mechanisms for racial and ethnic disparities in glycemic control in middle-aged and older Americans in the health and retirement study. Arch Intern Med. Sep. 24. 2007;167(17):1853-60. X-2, X-4. [pmid: 17893306].
1651 Heisler M, Piette JD. “I help you, and you help me”: facilitated telephone peer support among patients with diabetes. Diabetes Educ. Nov-Dec. 2005;31(6):869-79. X-2, X-4, X-6. [pmid: 16288094].
1652 Heisler M, Piette JD, Spencer M, et al. The relationship between knowledge of recent HbA1c values and diabetes care understanding and self-management. Diabetes Care. Apr. 2005;28(4):816-22. X-2, X-4, X-6. [pmid: 15793179].
1653 Heisler M, Smith DM, Hayward RA, et al. Racial disparities in diabetes care processes, outcomes, and treatment intensity. Med Care. Nov. 2003;41(11):1221-32. X-2, X-4. [pmid: 14583685].
1654 Heisler M, Spencer M, Forman J, et al. Participants' assessments of the effects of a community health worker intervention on their diabetes self-management and interactions with healthcare providers. Am J Prev Med. Dec. 2009;37(6 Suppl 1):S270-9. X-4. [pmid: 19896029].
1655 Heisler M, Vijan S, Anderson RM, et al. When do patients and their physicians agree on diabetes treatment goals and strategies, and what difference does it make?. Journal of General Internal Medicine. Nov. 2003;18(11):893-902. X-2, X-4, X-6. [pmid: 14687274].
1656 Helfrich CD, Savitz LA, Swiger KD, et al. Adoption and implementation of mandated diabetes registries by community health centers. Am J Prev Med. Jul. 2007;33(1 Suppl):S50-8. quiz S9-65. X-2, X-4. [pmid: 17584591].
1657 Helgeson VS, Reynolds KA, Escobar O, et al. The role of friendship in the lives of male and female adolescents: does diabetes make a difference?. J Adolesc Health. Jan. 2007;40(1):36-43. X-2, X-4, X-6. [pmid: 17185204].
1658 Heller A, Elliott MN, Haviland AM, et al. Patient Activation Status as a Predictor of Patient Experience Among Medicare Beneficiaries. Medical Care. Aug. 2009;47(8):850-7. X-2, X-4, X-6. [pmid: 19584763].
1659 Hellerstein DJ, Agosti V, Bosi M, et al. Impairment in psychosocial functioning associated with dysthymic disorder in the NESARC study. J Affect Disord. Dec. 2010;127(1-3):84-8. X-2, X-4, X-6. [pmid: 20471093].
1660 Helsel D, Mochel M, Bauer R. Chronic illness and Hmong shamans. J Transcult Nurs. Apr. 2005;16(2):150-4. X-2, X-4, X-5. [pmid: 15764638].
1661 Henderson LC. Divergent models of diabetes among American Indian elders. J Cross Cult Gerontol. Dec. 2010;25(4):303-16. X-2, X-4. [pmid: 20931270].
1662 Henderson SO, Bretsky P, DeQuattro V, et al. Treatment of hypertension in African Americans and Latinos: the effect of JNC VI on urban prescribing practices. J Clin Hypertens (Greenwich). Mar-Apr. 2003;5(2):107-12. X-2, X-4. [pmid: 12671322].
1663 Hendren S, Birkmeyer JD, Yin H, et al. Surgical complications are associated with omission of chemotherapy for stage III colorectal cancer. Dis Colon Rectum. Dec. 2010;53(12):1587-93. X-2, X-4. [pmid: 21178851].
1664 Hendren S, Griggs JJ, Epstein RM, et al. Study Protocol: A randomized controlled trial of patient navigation-activation to reduce cancer health disparities. BMC Cancer. Oct. 2010;10. X-9. [pmid: 20939928].
1665 Hendricks LE, Hendricks RT. Day treatment: a nontraditional strategy for teaching elderly blacks about diabetes. Diabetes Educ. Nov-Dec. 1996;22(6):565-6. X-1, X-6, X-7, X-9. [pmid: 8970286].
1666 Hendricks LE, Hendricks RT. The effect of diabetes self-management education with frequent follow-up on the health outcomes of African American men. Diabetes Educ. Nov-Dec. 2000;26(6):995-1002. X-4. [pmid: 11912812].
1667 Hendricks LE, Hendricks RT, Young AL. The Diabetes Day Treatment experiment: a preliminary report on what we learned. Diabetes Educ. May-Jun. 1999;25(3):364-73. X-6, X-7, X-9. [pmid: 10531856].
1668 Hendricks RT. African American specialty educators. Diabetes Educ. Nov-Dec. 2002;28(6):888-9. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12526630].
1669 Hendrickson SG, Williams J, Acee TW. Immigrant Hispanic mothers' participation in a dual-site safety intervention. Hispanic Health Care International. 2008;6(2):71-9. X-5.
1670 Hendricson WD, Wood PR, Hidalgo HA, et al. Implementation of a physician education intervention. The Childhood Asthma Project. Arch Pediatr Adolesc Med. Jun. 1994;148(6):595-601. X-3, X-6, X-10. [pmid: 8193683].
1671 Hendricson WD, Wood PR, Hidalgo HA, et al. Implementation of individualized patient education for Hispanic children with asthma. Patient Educ Couns. Nov. 1996;29(2):155-65. X-9. [pmid: 9006232].
1672 Hendrix CC, Sakauye KM, Karabatsos G, et al. The use of the Minimum Data Set to identify depression in the elderly. J Am Med Dir Assoc. Nov-Dec. 2003;4(6):308-12. X-2, X-4, X-6. [pmid: 14613597].
1673 Hendrix KH, Lackland DT, Egan BM. Cardiovascular risk factor control and treatment patterns in primary care. Managed Care Interface. 2003;16(11):21-6. X-2, X-4. [pmid: 14650370].
1674 Hendrix KH, Riehle JE, Egan BM. Ethnic, gender, and age-related differences in treatment and control of dyslipidemia in hypertensive patients. Ethn Dis. Winter. 2005;15(1):11-6. X-2, X-4. [pmid: 15720044].
1675 Henry DA, Sutherland D, Francis L. The use of non-prescription salbutamol inhalers by asthmatic patients in the Hunter Valley, New South Wales. Newcastle Retail Pharmacy Research Group. Med J Aust. Apr. 17. 1989;150(8):445-9. X-2, X-3, X-4, X-6. [pmid: 2716682].
1676 Hensley S. The latest thing. Minimally invasive heart surgery is all the rage. But it may not always be the right thing to do. Mod Healthc. Jun. 9. 1997;27(23):44-4. 8. 50. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10173019].
1677 Henson RM, Wyatt SW, Lee NC. The National Breast and Cervical Cancer Early Detection Program: a comprehensive public health response to two major health issues for women. J Public Health Manag Pract. Spring. 1996;2(2):36-47. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10186667].
1678 Heredia GC. The Hispanic/Latino Diabetes Educator Specialty. Diabetes Educ. Mar-Apr. 2003;29(2):218-20. X-1, X-6, X-7, X-9. [pmid: 12728750].
1679 Herenda S, Tahirovic H, Zildzic M. Impact of education on metabolic control in type 2 diabetic patients in family practice. Med Arh. 2007;61(4):236-9. X-2, X-3, X-6. [pmid: 18297999].
1680 Herman CJ, Speroff T, Cebul RD. Improving compliance with breast cancer screening in older women. Results of a randomized controlled trial. Arch Intern Med. Apr. 10. 1995;155(7):717-22. X-6. [pmid: 7695460].
1681 Herman PM, Larkey LK. Effects of an art-based curriculum on clinical trials attitudes and breast cancer prevention knowledge. Health Educ Behav. Oct. 2006;33(5):664-76. X-2, X-4. [pmid: 16740503].
1682 Hernandez-Valero MA, Thomson CA, Hernandez M, et al. Comparison of baseline dietary intake of Hispanic and matched non-Hispanic white breast cancer survivors enrolled in the Women's Healthy Eating and Living study. J Am Diet Assoc. Aug. 2008;108(8):1323-9. X-2, X-4. [pmid: 18656572].
1683 Herrera AP, Snipes SA, King DW, et al. Disparate Inclusion of Older Adults in Clinical Trials: Priorities and Opportunities for Policy and Practice Change. American Journal of Public Health. 2010;100:S105-S12. X-1, X-2, X-4, X-5, X-6. [pmid: 20147682].
1684 Herreria J. “Control your diabetes” campaign encourages a healthy lifestyle. National Diabetes Education Program. Profiles Healthc Mark. Jan-Feb. 1999;15(1):23-6. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10387457].
1685 Herrin J, Cangialose CB, Nicewander D, et al. Cost and effects of performance feedback and nurse case management for Medicare beneficiaries with diabetes: A randomized controlled trial. Population Health Management. Dec. 2007;10(6):328-36. X-6. [pmid: 18163861].
1686 Hesse BW, Shneiderman B. eHealth research from the user's perspective. American Journal of Preventive Medicine. May. 2007;32(5):S97-S103. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17466825].
1687 Hetherington SE. A controlled study of the effect of prepared childbirth classes on obstetric outcomes. Birth. Jun. 1990;17(2):86-90. X-6, X-9. [pmid: 2363771].
1688 Heuer L, Hess CW, Klug MG. Meeting the health care needs-of a rural Hispanic migrant population with diabetes. Journal of Rural Health. Sum. 2004;20(3):265-70. X-6, X-7, X-9. [pmid: 15298102].
1689 Heuer L, Lausch C. Living with diabetes: perceptions of Hispanic migrant farmworkers. J Community Health Nurs. Spring. 2006;23(1):49-64. X-2, X-4. [pmid: 16445364].
1690 Heuer LJ, Hess C, Batson A. Cluster clinics for migrant Hispanic farmworkers with diabetes: perceptions, successes, and challenges. Rural Remote Health. Jan-Mar. 2006;6(1):469. X-9, X-10. [pmid: 16573366].
1691 Hewitt J, Smeeth L, Chaturvedi N, et al. Self management and patient understanding of diabetes in the older person. Diabet Med. Jan. 2011;28(1):117-22. X-2, X-4, X-6. [pmid: 21166853].
1692 Hiatt RA, Pasick RJ, Stewart S, et al. Community-based cancer screening for underserved women: Design and baseline findings from the Breast and Cervical Cancer Intervention Study. Preventive Medicine: An International Journal Devoted to Practice and Theory. Sep. 2001;33(3):190-203. X-7, X-9. [pmid: 11522160].
1693 Hiatt RA, Perez-Stable EJ, Quesenberry C Jr., et al. Agreement between self-reported early cancer detection practices and medical audits among Hispanic and non-Hispanic white health plan members in northern California. Prev Med. May. 1995;24(3):278-85. X-2, X-4. [pmid: 7644451].
1694 Hibbard JH, Mahoney ER, Stock R, et al. Do increases in patient activation result in improved self-management behaviors?. Health Serv Res. Aug. 2007;42(4):1443-63. X-2, X-6. [pmid: 17610432].
1695 Hicks C, Fide J. The educational needs of non-specialist breast care nurses. Nurse Educ Today. Oct. 2003;23(7):509-21. X-2, X-3, X-4, X-5, X-6. [pmid: 12963360].
1696 Hicks LS, Fairchild DG, Horng MS, et al. Determinants of JNC VI guideline adherence, intensity of drug therapy, and blood pressure control by race and ethnicity. Hypertension. Oct. 2004;44(4):429-34. X-2, X-4. [pmid: 15326088].
1697 Hicks LS, O'Malley AJ, Lieu TA, et al. Impact of health disparities collaboratives on racial/ethnic and insurance disparities in US community health centers. Arch Intern Med. Feb. 8. 2010;170(3):279-86. X-7, X-8, X-9, X-12. [pmid: 20142575].
1698 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: A randomized controlled trial. Journal of General Internal Medicine. Apr. 2008;23(4):429-41. X-4, X-9. [pmid: 18373141].
1699 Hierholzer R. A critique of the clinical examples for the APA's “Guidelines regarding possible conflict between psychiatrists' religious commitments and psychiatric practice”. Ethics Med. Summer. 2001;17(2):93-8. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15069983].
1700 Higgins P, Murray ML. Perinatal outcomes and level of prenatal care: a study of the Southwestern United States. Journal of Perinatal Education. 1996;5(4):37-46. X-2, X-4, X-6.
1701 Hill A, De Zapien JG, Staten LK, et al. From program to policy: expanding the role of community coalitions. Prev Chronic Dis. Oct. 2007;4(4):A103. X-1, X-7, X-9. [pmid: 17875247].
1702 Hill MN, Bone LR, Hilton SC, et al. A clinical trial to improve high blood pressure care in young urban black men: recruitment, follow-up, and outcomes. Am J Hypertens. Jun. 1999;12(6):548-54. X-9. [pmid: 10371363].
1703 Hill MN, Han HR, Dennison CR, et al. Hypertension care and control in underserved urban African American men: behavioral and physiologic outcomes at 36 months. Am J Hypertens. Nov. 2003;16(11 Pt 1):906-13. X-9. [pmid: 14573327].
1704 Hill NE, Herman-Stahl MA. Neighborhood safety and social involvement: Associations with parenting behaviors and depressive symptoms among African-American and Euro-American mothers. Journal of Family Psychology. Jun. 2002;16(2):209-19. X-2, X-4, X-5. [pmid: 12085733].
1705 Hill-Briggs F, Batts-Turner M, Gary TL, et al. Training community health workers as diabetes educators for urban African Americans: value added using participatory methods. Prog Community Health Partnersh. Summer. 2007;1(2):185-94. X-3, X-10. [pmid: 20208238].
1706 Hill-Briggs F, Cooper DC, Loman K, et al. A qualitative study of problem solving and diabetes control in type 2 diabetes self-management. Diabetes Educ. Nov-Dec. 2003;29(6):1018-28. X-2, X-4. [pmid: 14692375].
1707 Hill-Briggs F, Gary TL, Bone LR, et al. Medication adherence and diabetes control in urban African Americans with type 2 diabetes. Health Psychol. Jul. 2005;24(4):349-57. X-2, X-4. [pmid: 16045370].
1708 Hill-Briggs F, Renosky R, Lazo M, et al. Development and pilot evaluation of literacy-adapted diabetes and CVD education in urban, diabetic African Americans. J Gen Intern Med. Sep. 2008;23(9):1491-4. X-4. [pmid: 18521688].
1709 Hill-Briggs F, Yeh HC, Gary TL, et al. Diabetes problem-solving scale development in an adult, African American sample. Diabetes Educ. Mar-Apr. 2007;33(2):291-9. X-2, X-4. [pmid: 17426304].
1710 Hilton S, Doherty S, Kendrick T, et al. Promotion of healthy behaviour among adults at increased risk of coronary heart disease in general practice: methodology and baseline data from the Change of Heart study. Health Education Journal. 1999;58(1):3-16. X-1, X-2, X-3, X-4, X-5, X-6.
1711 Hine J. Standards of palliative care in a renal care setting. EDTNA ERCA J. Oct-Dec. 1998;24(4):27-9. 35. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10222912].
1712 Hippisley-Cox J, O'Hanlon S, Coupland C. Association of deprivation, ethnicity, and sex with quality indicators for diabetes: population based survey of 53,000 patients in primary care. BMJ. Nov. 27. 2004;329(7477):1267-9. X-2, X-3, X-4. [pmid: 15548561].
1713 Hippisley-Cox J, Pringle M, Coupland C, et al. Waiting times for surgery -- inheritance for primary care organisations in Trent. Journal of Clinical Governance. 2002;10(2):63-9. X-2, X-3, X-4, X-6.
1714 Hirsh JM, Boyle DJ, Collier DH, et al. Limited Health Literacy Is a Common Finding in a Public Health Hospital's Rheumatology Clinic and Is Predictive of Disease Severity. Jcr-Journal of Clinical Rheumatology. Aug. 2011;17(5):236-41. X-1, X-2, X-5. [pmid: 21778910].
1715 Hirth RA, Turenne MN, Wheeler JR, et al. Provider monitoring and pay-for-performance when multiple providers affect outcomes: An application to renal dialysis. Health Serv Res. Oct. 2009;44(5 Pt 1):1585-602. X-2, X-4, X-6. [pmid: 19555398].
1716 Hjelm K, Nambozi G. Beliefs about health and illness: a comparison between Ugandan men and women living with diabetes mellitus. Int Nurs Rev. Dec. 2008;55(4):434-41. X-2, X-3, X-4. [pmid: 19146555].
1717 Hjelm KG, Bard K, Nyberg P, et al. Beliefs about health and diabetes in men of different ethnic origin. J Adv Nurs. Apr. 2005;50(1):47-59. X-2, X-3, X-4, X-6. [pmid: 15788065].
1718 Ho TM. Hypertension management: lifestyle interventions in a transcultural context. J Ren Care. Dec. 2009;35(4):176-84. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19909410].
1719 Ho TM, Fernandez M. Patient's sexual health: do we care enough?. J Ren Care. Oct-Dec. 2006;32(4):183-6. X-2, X-3, X-4, X-5, X-6. [pmid: 17345975].
1720 Hoare T, Thomas C, Biggs A, et al. Can the uptake of breast screening by Asian women be increased? A randomized controlled trial of a linkworker intervention. J Public Health Med. Jun. 1994;16(2):179-85. X-2, X-3. [pmid: 7946492].
1721 Hoekstra JW, Pollack CV Jr., Roe MT, et al. Improving the care of patients with non-ST-elevation acute coronary syndromes in the emergency department: the CRUSADE initiative. Acad Emerg Med. Nov. 2002;9(11):1146-55. X-1, X-2, X-3, X-4, X-6. [pmid: 12414463].
1722 Hoey HM. Background and methods for evaluating quality of life in children and adolescents with diabetes. Acta Biomed. Suppl 1. 2003;74:7-12. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12817794].
1723 Hofer TP, Hayward RA, Greenfield S, et al. The unreliability of individual physician “report cards” for assessing the costs and quality of care of a chronic disease. JAMA. Jun. 9. 1999;281(22):2098-105. X-2, X-4, X-6. [pmid: 10367820].
1724 Hoffelt Z, Fallon S, Wong BA, et al. Glaucoma public service announcements: factors associated with follow-up of participants with risk factors for glaucoma. Ophthalmology. Jul. 2011;118(7):1327-33. X-2, X-4, X-5. [pmid: 21439644].
1725 Hoffman L, Enders J, Luo J, et al. Impact of an antidepressant management program on medication adherence. Am J Manag Care. Jan. 2003;9(1):70-80. X-6, X-7. [pmid: 12549816].
1726 Hoffman-Goetz L, Donelle L, Thomson MD. Clinical guidelines about diabetes and the accuracy of peer information in an unmoderated online health forum for retired persons. Inform Health Soc Care. Mar. 2009;34(2):91-9. X-2, X-3, X-4, X-6. [pmid: 19412842].
1727 Hoffman-Goetz L, Meissner HI, Thomson MD. Literacy and cancer anxiety as predictors of health status: An exploratory study. Journal of Cancer Education. Jul. 2009;24(3):218-24. X-2, X-4, X-5. [pmid: 19526411].
1728 Hohler AD, Lee JD, Schulman EA, et al. Invited Article: Improving safety for the neurologic patient Evaluating medications, literacy, and abuse. Neurology. Aug. 2010;75(8):742-6. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 20733149].
1729 Hokanson P, Seshadri R, Miller KD. Underutilization of breast-conserving therapy in a predominantly rural population: need for improved surgeon and public education. Clin Breast Cancer. Apr. 2000;1(1):72-6. X-2, X-3, X-4, X-6. [pmid: 11899394].
1730 Holcomb JD, Kingery PM, Sherman LD, et al. Evaluation of a diabetes education program for fifth-grade students. Journal of Health Education. 1999;30(2):73-84. X-7, X-9, X-10.
1731 Holley JL, Barrington K, Kohn J, et al. Patient factors and the influence of nephrologists, social workers, and nurses on patient decisions to choose continuous peritoneal dialysis. Adv Perit Dial. 1991;7:108-10. X-2, X-4. [pmid: 1680403].
1732 Hollman G, Olsson AG, Ek AC. Disease knowledge and adherence to treatment in patients with familial hypercholesterolemia. J Cardiovasc Nurs. Mar-Apr. 2006;21(2):103-8. X-2, X-4, X-5, X-6. [pmid: 16601526].
1733 Holloway CM, Saskin R, Brackstone M, et al. Variation in the use of percutaneous biopsy for diagnosis of breast abnormalities in Ontario. Ann Surg Oncol. Oct. 2007;14(10):2932-9. X-2, X-3, X-4, X-6. [pmid: 17619931].
1734 Holmes-Rovner M, Williams GA, Hoppough S, et al. Colorectal cancer screening barriers in persons with low income. Cancer Pract. Sep-Oct. 2002;10(5):240-7. X-2, X-4. [pmid: 12236837].
1735 Holstein BE, Vesterdal Jorgensen H, Sestoft L. Illness-behaviour, attitude, and knowledge in newly diagnosed diabetics. Dan Med Bull. Jun. 1986;33(3):165-71. X-6, X-7, X-9. [pmid: 3720366].
1736 Holt CL, Klem PR. As you go, spread the word: spiritually based breast cancer education for African American women. Gynecol Oncol. Dec. 2005;99(3 Suppl 1):S141-2. X-7, X-9. [pmid: 16139347].
1737 Holt CL, Kyles A, Wiehagen T, et al. Development of a spiritually based breast cancer educational booklet for African American women. Cancer Control. Sep-Oct. 2003;10(5 Suppl):37-44. X-1, X-2, X-3, X-4, X-6. [pmid: 14581903].
1738 Holt CL, Lee C, Wright K. A spiritually based approach to breast cancer awareness: cognitive response analysis of communication effectiveness. Health Commun. Jan-Feb. 2008;23(1):13-22. X-2, X-10. [pmid: 18443989].
1739 Holt CL, Roberts C, Scarinci I, et al. Development of a spiritually based educational program to increase colorectal cancer screening among African American men and women. Health Commun. Jul. 2009;24(5):400-12. X-1, X-2, X-4. [pmid: 19657823].
1740 Holt CL, Shipp M, Eloubeidi M, et al. Use of focus group data to develop recommendations for demographically segmented colorectal cancer educational strategies. Health Educ Res. Oct. 2009;24(5):876-89. X-2, X-4. [pmid: 19395624].
1741 Holt EW, Tan J, Hosgood HD. The impact of spirometry on pediatric asthma diagnosis and treatment. J Asthma. Sep. 2006;43(7):489-93. X-2, X-4. [pmid: 16939987].
1742 Holubar SD, Hassinger JP, Dozois EJ, et al. Impact of a multimedia e-learning module on colon cancer literacy: a community-based pilot study. J Surg Res. Oct. 2009;156(2):305-11. X-2, X-4, X-6. [pmid: 19631335].
1743 Homer SD. Effect of education on school-age children's and parents' asthma management. J Spec Pediatr Nurs. Jul-Sep. 2004;9(3):95-102. X-4. [pmid: 15553551].
1744 Homko CJ, Santamore WP, Whiteman V, et al. Use of an internet-based telemedicine system to manage underserved women with gestational diabetes mellitus. Diabetes Technol Ther. Jun. 2007;9(3):297-306. X-4. [pmid: 17561800].
1745 Homko CJ, Sivan E, Reece EA. The impact of self-monitoring of blood glucose on self-efficacy and pregnancy outcomes in women with diet-controlled gestational diabetes. Diabetes Educ. May-Jun. 2002;28(3):435-43. X-4, X-6. [pmid: 12073958].
1746 Honda K, Gorin SS. A model of stage of change to recommend colonoscopy among urban primary care physicians. Health Psychology. Jan. 2006;25(1):65-73. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 16448299].
1747 Hong SI, Morrow-Howell N, Proctor E, et al. The quality of medical care for comorbid conditions of depressed elders. Aging Ment Health. May. 2008;12(3):323-32. X-2, X-4, X-6. [pmid: 18728945].
1748 Hopper SV, Schechtman KB. Factor associated with diabetic control and utilization patterns in a low-income, older adult population. Patient Educ Couns. Sep. 1985;7(3):275-88. X-2, X-4. [pmid: 10273959].
1749 Hoppichler F, Lechleitner M. Counseling programs and the outcome of gestational diabetes in Austrian and Mediterranean Turkish women. Patient Educ Couns. Dec. 15. 2001;45(4):271-4. X-2, X-3, X-4. [pmid: 11755772].
1750 Hopson S, Frankenfield D, Rocco M, et al. Variability in reasons for hemodialysis catheter use by race, sex, and geography: findings from the ESRD Clinical Performance Measures Project. Am J Kidney Dis. Oct. 2008;52(4):753-60. X-2, X-4. [pmid: 18514986].
1751 Horner RD, Oddone EZ, Stechuchak KM, et al. Racial variations in postoperative outcomes of carotid endarterectomy: evidence from the Veterans Affairs National Surgical Quality Improvement Program. Med Care. Jan. 2002;40(1 Suppl):I35-43. X-2, X-4. [pmid: 11789630].
1752 Horner SD, Surratt D, Juliusson S. Improving readability of patient education materials. J Community Health Nurs. Spring. 2000;17(1):15-23. X-1, X-6, X-7, X-9. [pmid: 10778026].
1753 Horner SD, Surratt D, Smith SB. The impact of asthma risk factors on home management of childhood asthma. J Pediatr Nurs. Jun. 2002;17(3):211-21. X-2, X-4. [pmid: 12094362].
1754 Horowitz CR, Williams L, Bickell NA. A community-centered approach to diabetes in East Harlem. Journal of General Internal Medicine. Jul. 2003;18(7):542-8. X-2, X-4. [pmid: 12848837].
1755 Horsburgh ME, Rice VH, Matuk L. Sense of coherence and life satisfaction: patient and spousal adaptation to home dialysis. ANNA J. Apr. 1998;25(2):219-28. discussion 29-30. X-2, X-3, X-4, X-6. [pmid: 9801501].
1756 Horsfield P, Teasdale S. Generating information from electronic patient records in general practice: a description of clinical care and gender inequalities in coronary heart disease using data from over two million patient records. Inform Prim Care. 2003;11(3):137-44. X-2, X-3, X-4. [pmid: 14680536].
1757 Hoskins G, Neville RG, Smith B, et al. Focus on asthma. The link between practice nurse training and asthma outcomes. British Journal of Community Nursing. 1999;4(5):222-8. X-2, X-4, X-6.
1758 Hosler AS, Godley K, Rowland DH. An initiative to improve diabetes care standards in healthcare organizations serving minorities. Diabetes Educ. Jul-Aug. 2002;28(4):581-9. X-9. [pmid: 12224198].
1759 Hosler AS, Melnik TA. Population-based assessment of diabetes care and self-management among Puerto Rican adults in New York City. Diabetes Educ. May-Jun. 2005;31(3):418-26. X-2, X-4. [pmid: 15919642].
1760 Houston JM, Martin M, Williams JE, et al. The Annual African American Conference on Diabetes: evolving program evaluation with evolving program implementation. Prev Chronic Dis. Jan. 2006;3(1):A18. X-2, X-4. [pmid: 16356371].
1761 Houston TK, Allison JJ, Sussman M, et al. Culturally appropriate storytelling to improve blood pressure: a randomized trial. Ann Intern Med. Jan. 18. 2011;154(2):77-84. X-9. [pmid: 21242364].
1762 Hovey JD. Acculturative stress, depression, and suicidal ideation among Mexican-American adolescents: implications for the development of suicide prevention programs in schools. Psychol Rep. Aug. 1998;83(1):249-50. X-2, X-4. [pmid: 9775681].
1763 Howard Caldwell C, Bell L, Brooks CL, et al. Engaging Nonresident African American Fathers in Intervention Research: What Practitioners Should Know About Parental Monitoring in Nonresident Families. Research on Social Work Practice. 2011;21(3):298-307. X-7, X-9.
1764 Howell EA, Holzman I, Kleinman LC, et al. Surfactant use for premature infants with respiratory distress syndrome in three New York city hospitals: discordance of practice from a community clinician consensus standard. J Perinatol. Sep. 2010;30(9):590-5. X-2, X-4, X-5. [pmid: 20182436].
1765 Howell EA, Mora PA, DiBonaventura MD, et al. Modifiable factors associated with changes in postpartum depressive symptoms. Arch Womens Ment Health. Apr. 2009;12(2):113-20. X-2, X-4, X-5, X-6. [pmid: 19238520].
1766 Howell MD. A 37-year-old man trying to choose a high-quality hospital: Review of hospital quality indicators. JAMA: Journal of the American Medical Association. Dec. 2009;302(21):2353-60. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19887653].
1767 Howes F, Hansen E, Williams D, et al. Barriers to diagnosing and managing hypertension—a qualitative study in Australian general practice. Aust Fam Physician. Jun-Jul. 2010;39(6):511-6. X-2, X-3, X-4, X-6. [pmid: 20628667].
1768 Hsin O, La Greca AM, Valenzuela J, et al. Adherence and glycemic control among Hispanic youth with type 1 diabetes: role of family involvement and acculturation. J Pediatr Psychol. Mar. 2010;35(2):156-66. X-2, X-4. [pmid: 19491214].
1769 Hsu HC, Tung HJ. What makes you good and happy? Effects of internal and external resources to adaptation and psychological well-being for the disabled elderly in Taiwan. Aging Ment Health. Sep. 2010;14(7):851-60. X-2, X-3, X-4, X-5, X-6. [pmid: 20665281].
1770 Hsu WC, Cheung S, Ong E, et al. Identification of linguistic barriers to diabetes knowledge and glycemic control in Chinese Americans with diabetes. Diabetes Care. Feb. 2006;29(2):415-6. X-2. [pmid: 16443897].
1771 Huang ES, Brown SE, Zhang JX, et al. The cost consequences of improving diabetes care: the community health center experience. Jt Comm J Qual Patient Saf. Mar. 2008;34(3):138-46. X-2, X-3, X-4, X-5, X-6. [pmid: 18419043].
1772 Huang ES, Zhang Q, Brown SE, et al. The cost-effectiveness of improving diabetes care in U.S. federally qualified community health centers. Health Serv Res. Dec. 2007;42(6 Pt 1):2174-93. discussion 294-323. X-6, X-9. [pmid: 17995559].
1773 Huang MC, Hsu CC, Wang HS, et al. Prospective randomized controlled trial to evaluate effectiveness of registered dietitian-led diabetes management on glycemic and diet control in a primary care setting in Taiwan. Diabetes Care. Feb. 2010;33(2):233-9. X-2. [pmid: 19910499].
1774 Huang MC, Hung CH. Quality of life and its predictors for middle-aged and elderly patients with type 2 diabetes mellitus. J Nurs Res. Sep. 2007;15(3):193-201. X-2, X-3, X-4, X-6. [pmid: 17806036].
1775 Huang MF, Courtney M, Edwards H, et al. Psychometric evaluation of the Chinese version of the Diabetes Coping Measure scale. J Nurs Scholarsh. 2009;41(4):385-90. X-2, X-3, X-4. [pmid: 19941584].
1776 Huang TT. Self-care behavior of adult asthma patients. J Asthma. Oct. 2007;44(8):613-9. X-2, X-3, X-4, X-6. [pmid: 17943571].
1777 Hudelson P, Huanca T, Charaly D, et al. Ethnographic studies of ARI in Bolivia and their use by the national ARI programme. Soc Sci Med. Dec. 1995;41(12):1677-83. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 8746867].
1778 Huffman FG, Vaccaro JA, Nath S, et al. Diabetes self management: are Cuban Americans receiving quality health care?. J Health Hum Serv Adm. Winter. 2009;32(3):278-304. X-7, X-9. [pmid: 20099581].
1779 Hughes HE, Love A, Peabody K, et al. Diabetes Education Programs for African American Women: what works?. Diabetes Educ. Jan-Feb. 2001;27(1):46-50. 2. 4. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11912616].
1780 Hughes HW, Connery SM, Rivera JO, et al. Adequacy of outpatient care among hospitalized adult asthmatics in a southwest US border city. Tex Med. Oct. 2008;104(10):55-62. X-6, X-7, X-9. [pmid: 19009464].
1781 Humphreys CT, Tallman B, Altmaier EM, et al. Sexual functioning in patients undergoing bone marrow transplantation: a longitudinal study. Bone Marrow Transplant. Apr. 2007;39(8):491-6. X-2, X-4, X-5. [pmid: 17322932].
1782 Humphry J, Jameson LM, Beckham S. Overcoming social and cultural barriers to care for patients with diabetes. West J Med. Sep. 1997;167(3):138-44. X-1, X-6, X-9. [pmid: 9308405].
1783 Hung CC, Chen YC, Mao HC, et al. Effects of systematic nursing instruction of mothers on using medication and on health status of asthmatic children. J Nurs Res. Mar. 2002;10(1):22-32. X-3, X-4, X-6. [pmid: 11923898].
1784 Hunt LM, Arar NH, Larme AC. Contrasting patient and practitioner perspectives in type 2 diabetes management. West J Nurs Res. Dec. 1998;20(6):656-76. discussion 77-82. X-2, X-4, X-6. [pmid: 9842286].
1785 Hunt LM, Pugh J, Valenzuela M. How patients adapt diabetes self-care recommendations in everyday life. J Fam Pract. Mar. 1998;46(3):207-15. X-2, X-4. [pmid: 9519018].
1786 Hunt LM, Valenzuela MA, Pugh JA. Porque me toco a mi? Mexican American diabetes patients' causal stories and their relationship to treatment behaviors. Soc Sci Med. Apr. 1998;46(8):959-69. X-2, X-4. [pmid: 9579748].
1787 Hurd SS, Lenfant C. The National Heart, Lung and Blood Institute asthma program. Chest. Jun. 1992;101(6 Suppl):359S-61S. X-1, X-6, X-7, X-9. [pmid: 1591931].
1788 Hurd TC, Muti P, Erwin DO, et al. An evaluation of the integration of non-traditional learning tools into a community based breast and cervical cancer education program: the Witness Project of Buffalo. BMC Cancer. May. 29. 2003;3:18. X-7, X-9. [pmid: 12775219].
1789 Hurdle DE. Breast cancer prevention with older women: a gender-focused intervention study. Health Care Women Int. Nov-Dec. 2007;28(10):872-87. X-6, X-7, X-9. [pmid: 17987458].
1790 Husaini BA, Sherkat DE, Levine R, et al. The effect of a church-based breast cancer screening education program on mammography rates among African-American women. J Natl Med Assoc. Feb. 2002;94(2):100-6. X-7, X-9. [pmid: 11853042].
1791 Huss K, Winkelstein M, Calabrese B, et al. Asthma management practices and education needs of head start directors and staff. J Sch Health. Oct. 2002;72(8):329-33. X-2, X-4. [pmid: 12389373].
1792 Hwang SY, Ryan CJ, Zerwic JJ. Korean immigrants' knowledge of heart attack symptoms and risk factors. J Immigr Minor Health. Feb. 2008;10(1):67-72. X-2, X-4. [pmid: 17503183].
1793 Hyland ME, Blake S, Greaves CJ, et al. Guidelines versus practice: UK asthma nurses often recommend intermittent, symptom-driven use of inhaled corticosteroids. Prim Care Respir J. Jun. 2009;18(2):114-7. X-2, X-3, X-4, X-6. [pmid: 18923800].
1794 Ibrahim AG, Mahmoud SA. Educational program on self-management for asthmatic school children. J Egypt Public Health Assoc. 1996;71(5-6):385-402. X-3, X-6. [pmid: 17214188].
1795 Ibrahim EM, al-Idrissi HY, al-Khadra AH, et al. Women's knowledge of and attitude toward breast cancer in a developing country: implications for program interventions--results based on interviewing 500 women in Saudi Arabia. J Cancer Educ. 1991;6(2):73-81. X-2, X-3, X-4, X-6. [pmid: 1911173].
1796 Ibrahim K, Taboonpong S, Nilmanat K. Coping and quality of life among Indonesians undergoing hemodialysis. Thai Journal of Nursing Research. 2009;13(2):109-16. X-2, X-3, X-4, X-6.
1797 Ibrahim SA, Babiker AG, Amin IK, et al. Factors associated with high risk of perinatal and neonatal mortality: an interim report on a prospective community-based study in rural Sudan. Paediatr Perinat Epidemiol. Apr. 1994;8(2):193-204. X-2, X-3, X-4. [pmid: 8047487].
1798 Ibrahim SA, Cook CF, Kwoh CK, et al. Racial differences in mortality among elderly patients admitted for heart failure. Research on Aging. 2001;23(4):457-72. X-2, X-4.
1799 Ilgen MA, McLouth C, Barry KL, et al. Pain interference in individuals in driver intervention programs for driving under the influence offenders. Subst Use Misuse. Jul. 2010;45(9):1406-19. X-2, X-4, X-5, X-6. [pmid: 20509742].
1800 Ilksoy N, Moore RH, Easley K, et al. Quality of care in African-American patients admitted for congestive heart failure at a university teaching hospital. Am J Cardiol. Mar. 1. 2006;97(5):690-3. X-2, X-4, X-6. [pmid: 16490439].
1801 Imperato PJ, Waisman J, Wallen M, et al. Breast cancer pathology practices among Medicare patients undergoing unilateral extended simple mastectomy. J Womens Health Gend Based Med. Jul-Aug. 2002;11(6):537-47. X-2, X-4, X-6. [pmid: 12225627].
1802 Indinnimeo L, Midulla F, Hindi-Alexander M, et al. Controlled studies of childhood asthma self-management in Italy using the “open airways” and “living with asthma” programs: a preliminary report. Health Educ Q. Fall. 1987;14(3):291-308. X-3, X-4. [pmid: 3654236].
1803 Indorf C, Sherry B, Mancl L. Comparisons of Yupik infant growth measurements with NCHS/CDC reference data. Alaska Med. Jan-Mar. 2001;43(1):6-12. 23. X-2, X-4, X-5. [pmid: 11345856].
1804 Ingram M, Ruiz M, Mayorga MT, et al. The Animadora Project: identifying factors related to the promotion of physical activity among Mexican Americans with diabetes. Am J Health Promot. Jul-Aug. 2009;23(6):396-402. X-2, X-4. [pmid: 19601479].
1805 Ingram M, Torres E, Redondo F, et al. The impact of promotoras on social support and glycemic control among members of a farmworker community on the US-Mexico border. Diabetes Educ. Jun. Suppl 6. 2007;33:172S-8S. X-9. [pmid: 17620398].
1806 Inkelas M, Decristofaro AH, McGlynn EA, et al. Outcome measurement in HEDIS: can risk adjustment save the low birth weight measure?. Health Serv Res. Dec. 2000;35(5 Pt 3):72-85. X-2, X-4. [pmid: 16148953].
1807 Insel K, Morrow D, Brewer B, et al. Executive function, working memory, and medication adherence among older adults. J Gerontol B Psychol Sci Soc Sci. Mar. 2006;61(2):P102-7. X-2, X-4, X-5, X-6. [pmid: 16497953].
1808 Irons BK, Seifert CF, Horton NA. Quality of care of a pharmacist-managed diabetes service compared to usual care in an indigent clinic. Diabetes Technol Ther. Jun. 2008;10(3):220-6. X-4, X-6. [pmid: 18473697].
1809 Irons BK, Vickers P, Esperat C, et al. The need for a community diabetes education curriculum for healthcare professionals. J Contin Educ Nurs. Sep-Oct. 2007;38(5):227-31. X-1, X-6, X-7, X-9. [pmid: 17907667].
1810 Irvine AA, Mitchell CM. Impact of community-based diabetes education on program attenders and nonattenders. Diabetes Educ. Jan-Feb. 1992;18(1):29-33. X-6, X-8. [pmid: 1729122].
1811 Irwin DE, Varni JW, Yeatts K, et al. Cognitive interviewing methodology in the development of a pediatric item bank: a patient reported outcomes measurement information system (PROMIS) study. Health and Quality of Life Outcomes. Jan. 2009:7. X-2, X-4, X-6. [pmid: 19193211].
1812 Isarankura-Na-Ayudhya C, Nantasenamat C, Dansethakul P, et al. Solving the barriers to diabetes education through the use of multimedia. Nurs Health Sci. Mar. 2010;12(1):58-66. X-3. [pmid: 20487327].
1813 Ishida DN, Toomata-Mayer TF, Braginsky NS. Beliefs and attitudes of Samoan women toward early detection of breast cancer and mammography utilization. Cancer. Jan. 1. 2001;91(1 Suppl):262-6. X-2, X-4. [pmid: 11148591].
1814 Ishikawa H, Takeuchi T, Yano E. Measuring functional, communicative, and critical health literacy among diabetic patients. Diabetes Care. May. 2008;31(5):874-9. X-2, X-4. [pmid: 18299446].
1815 Ishikawa H, Yano E, Fujimori S, et al. Patient health literacy and patient-physician information exchange during a visit. Fam Pract. Dec. 2009;26(6):517-23. X-2, X-4. [pmid: 19812242].
1816 Ishine M, Sakagami T, Sakamoto R, et al. Comprehensive geriatric assessment for community-dwelling elderly in Asia compared with those in Japan: VII. Khon Khen in Thailand. Geriatrics & Gerontology International. 2006;6(1):40-8. X-3.
1817 Ishine M, Wada T, Sakagami T, et al. Comprehensive geriatric assessment for community-dwelling elderly in Asia compared with those in Japan: III. Phuto in Vietnam. Geriatrics & Gerontology International. 2005;5(2):115-21. X-2, X-3, X-4, X-6.
1818 Ismail K. Psychological training for nurses improves HbA1c levels. Journal of Diabetes Nursing. 2009;13(3):119. X-3, X-6, X-7, X-9.
1819 Issell BF, Maskarinec G, Pagano I, et al. Breast cancer treatment among women of different ethnicity in Hawaii. Cancer Invest. 2005;23(6):497-504. X-2, X-4. [pmid: 16203657].
1820 Ivarsson B, Fridlund B, Sjoberg T. Information from health care professionals about sexual function and coexistence after myocardial infarction: a Swedish national survey. Heart Lung. Jul-Aug. 2009;38(4):330-5. X-2, X-3, X-4, X-6. [pmid: 19577704].
1821 Ivarsson B, Fridlund B, Sjoberg T. Health professionals' views on sexual information following MI. Br J Nurs. Sep. 9-22. 2010;19(16):1052-4. X-2, X-3, X-4, X-6. [pmid: 20852469].
1822 Ivers N, Schwandt M, Hum S, et al. A comparison of hospital and nonhospital colonoscopy: wait times, fees and guideline adherence to follow-up interval. Can J Gastroenterol. Feb. 2011;25(2):78-82. X-2, X-4, X-6. [pmid: 21321678].
1823 Iwasaki Y, Bartlett J, O'Neil J. An examination of stress among Aboriginal women and men with diabetes in Manitoba, Canada. Ethn Health. May. 2004;9(2):189-212. X-2, X-3, X-4. [pmid: 15223576].
1824 Jaarsma T, Steinke EE, Gianotten WL. Sexual Problems in Cardiac Patients How to Assess, When to Refer. Journal of Cardiovascular Nursing. Mar-Apr. 2010;25(2):159-64. X-1, X-2, X-3, X-4, X-6. [pmid: 20168196].
1825 Jaber LA, Pinelli NR, Brown MB, et al. Feasibility of group lifestyle intervention for diabetes prevention in Arab Americans. Diabetes Res Clin Pract. Mar. 2011;91(3):307-15. X-4, X-8. [pmid: 21168232].
1826 Jack L Jr., Toston T, Jack NH, et al. A gender-centered ecological framework targeting Black men living with diabetes: integrating a “masculinity” perspective in diabetes management and education research. Am J Mens Health. Mar. 2010;4(1):7-15. X-1, X-2, X-4, X-6. [pmid: 19477741].
1827 Jackson AL. Operation Sunday School--educating caring hearts to be healthy hearts. Public Health Rep. Jan-Feb. 1990;105(1):85-8. X-1, X-2, X-3, X-4, X-6. [pmid: 2106709].
1828 Jackson AP, Scheines R. Single mothers' self-efficacy, parenting in the home environment, and children's development in a two-wave study [corrected]. [published erratum appears in SOC WORK RES 2005 Jun;29(2):86]. Social Work Research. 2005;29(1):7-20. X-2, X-4.
1829 Jackson CL, Batts-Turner ML, Falb MD, et al. Computer and internet use among urban African Americans with type 2 diabetes. J Urban Health. Dec. 2005;82(4):575-83. X-2, X-4. [pmid: 16221917].
1830 Jackson GL, Powell AA, Ordin DL, et al. Developing and sustaining quality improvement partnerships in the VA: The Colorectal Cancer Care Collaborative. Journal of General Internal Medicine. Jan. 2010;25(Suppl 1):S38-S43. X-1, X-2, X-3, X-4, X-6. [pmid: 20077150].
1831 Jackson JE, Doescher MP, Saver BG, et al. Prescription drug coverage, health, and medication acquisition among seniors with one or more chronic conditions. Med Care. Nov. 2004;42(11):1056-65. X-2, X-4. [pmid: 15586832].
1832 Jackson JHt, Bramley TJ, Chiang TH, et al. Determinants of uncontrolled hypertension in an African-American population. Ethn Dis. Fall. 2002;12(4):S3-53-7. X-2, X-4. [pmid: 12477156].
1833 Jackson JL, Emery CF. Illness knowledge moderates the influence of coping style on quality of life among women with congestive heart failure. Heart & Lung. 2011;40(2):122-9. X-2, X-4, X-6. [pmid: 20561886].
1834 Jacob TC, Penn NE, Kulik JA, et al. Effects of cognitive style and maintenance strategies on breast self-examination (BSE) practice by African American women. J Behav Med. Dec. 1992;15(6):589-609. X-9. [pmid: 1484382].
1835 Jacobs DG. Depression screening as an intervention against suicide. J Clin Psychiatry. Suppl 2. 1999;60:42-5. discussion 51-2, 113-6. X-1, X-2, X-3, X-4, X-6. [pmid: 10073386].
1836 Jacobs DR Jr., Hannan PJ, Wallace D, et al. Interpreting age, period and cohort effects in plasma lipids and serum insulin using repeated measures regression analysis: the CARDIA Study. Stat Med. Mar. 30. 1999;18(6):655-79. X-2, X-4. [pmid: 10204196].
1837 Jacobs VR, Thoedtmann J, Euler U, et al. Physician-based active cost management of oncological therapies reducing pharmaceutical costs by 83.4 in two years without leaving standard of care. Onkologie. Aug. 2005;28(8-9):441-5. X-3, X-4, X-6. [pmid: 16160408].
1838 Jacobson S, Wood FG. Lessons learned from a very small pilot study. Online Journal of Rural Nursing & Health Care. 2006;6(2):16p. X-4.
1839 Jacobson TA, Thomas DM, Morton FJ, et al. Use of a low-literacy patient education tool to enhance pneumococcal vaccination rates. A randomized controlled trial. JAMA. Aug. 18. 1999;282(7):646-50. X-6, X-9. [pmid: 10517717].
1840 Jahanlou AS, Alishan Karami N. The effect of literacy level on health related-quality of life, self-efficacy and self-management behaviors in diabetic patients. Acta Med Iran. 2011;49(3):153-8. X-2, X-3, X-4. [pmid: 21681702].
1841 Jain N. Kidney Research UK's: a better life through education and empowerment. Br J Community Nurs. Apr. 2008;13(4):166-70. X-1, X-3, X-4. [pmid: 18595304].
1842 Jakicic JM, Jaramillo SA, Balasubramanyam A, et al. Effect of a lifestyle intervention on change in cardiorespiratory fitness in adults with type 2 diabetes: Results from the Look AHEAD Study. International Journal of Obesity. Mar. 2009;33(3):305-16. X-6, X-9. [pmid: 19153582].
1843 Jallo N, Bray K, Padden MP, et al. A nurse-driven quality improvement program to improve perinatal outcomes. The Journal of Perinatal & Neonatal Nursing. Jul-Sep. 2009;23(3):241-50. X-1, X-6, X-9. [pmid: 19704292].
1844 James PA, Cowan TM, Graham RP. Patient-centered clinical decisions and their impact on physician adherence to clinical guidelines. J Fam Pract. Apr. 1998;46(4):311-8. X-2, X-4, X-6. [pmid: 9564373].
1845 James TM, Greiner KA, Ellerbeck EF, et al. Disparities in colorectal cancer screening: a guideline-based analysis of adherence. Ethn Dis. Winter. 2006;16(1):228-33. X-2, X-4. [pmid: 16599375].
1846 James-Rogers A. What to say to CKD patients about working. Nephrol News Issues. Jun. 2005;19(7):S7. X-1, X-6, X-7, X-9. [pmid: 16008030].
1847 Jamil H, Hakim-Larson J, Farrag M, et al. Medical complaints among Iraqi American refugees with mental disorders. J Immigr Health. Jul. 2005;7(3):145-52. X-2, X-4, X-6. [pmid: 15900415].
1848 Jandorf L, Gutierrez Y, Lopez J, et al. Use of a patient navigator to increase colorectal cancer screening in an urban neighborhood health clinic. J Urban Health. Jun. 2005;82(2):216-24. X-9. [pmid: 15888638].
1849 Janisse HC, Cakan N, Ellis D, et al. Dietary vitamin D intake among high-risk adolescents with insulin dependent diabetes. Diabetes Educ. Mar-Apr. 2011;37(2):222-6. X-2, X-4. [pmid: 21372095].
1850 Janisse HC, Naar-King S, Ellis D. Brief report: Parent's health literacy among high-risk adolescents with insulin dependent diabetes. J Pediatr Psychol. May. 2010;35(4):436-40. X-2, X-4. [pmid: 19755494].
1851 Janke MC, Son JS, Payne LL. Self-regulation and adaptation of leisure activities among adults with arthritis. Activities, Adaptation & Aging. 2009;33(2):65-80. X-2, X-4, X-5, X-6.
1852 Jansa M, Diaz M, Franch J, et al. Anthropologic study of immigrant patients with T2DM from Morocco to Spain: practical implications for therapeutic patient education. European Diabetes Nursing. 2010;7(1):24-8. X-2, X-3, X-4.
1853 Janson-Bjerklie S, Ferketich S, Benner P. Predicting the outcomes of living with asthma. Res Nurs Health. Aug. 1993;16(4):241-50. X-2, X-4. [pmid: 8378554].
1854 Janz NK, Mujahid MS, Hawley ST, et al. Racial/ethnic differences in adequacy of information and support for women with breast cancer. Cancer. Sep. 1. 2008;113(5):1058-67. X-2, X-4. [pmid: 18618494].
1855 Janz NK, Schottenfeld D, Doerr KM, et al. A two-step intervention of increase mammography among women aged 65 and older. Am J Public Health. Oct. 1997;87(10):1683-6. X-6. [pmid: 9357355].
1856 Jaser SS, Whittemore R, Ambrosino JM, et al. Coping and psychosocial adjustment in mothers of young children with type 1 diabetes. Children's Health Care. 2009;38(2):91-106. X-2, X-4, X-6. [pmid: 19412355].
1857 Jaworska J, Dziemidok P, Kulik TB, et al. Frequency of self-monitoring and its effect on metabolic control in patients with type 2 diabetes. Ann Univ Mariae Curie Sklodowska Med. 2004;59(1):310-6. X-2, X-3, X-4, X-6. [pmid: 16146003].
1858 Jayadevappa R, Johnson JC, Bloom BS, et al. Effectiveness of transcendental meditation on functional capacity and quality of life of African Americans with congestive heart failure: a randomized control study. Ethn Dis. Winter. 2007;17(1):72-7. X-4. [pmid: 17274213].
1859 Jaycox LH, Miranda J, Meredith LS, et al. Impact of a primary care quality improvement intervention on use of psychotherapy for depression. Ment Health Serv Res. Jun. 2003;5(2):109-20. X-6, X-9. [pmid: 12801074].
1860 Jayne RL, Rankin SH. Application of Leventhal's self-regulation model to Chinese immigrants with type 2 diabetes. J Nurs Scholarsh. 2001;33(1):53-9. X-2, X-4. [pmid: 11253580].
1861 Jefferson LL. Exploring effects of therapeutic massage and patient teaching in the practice of diaphragmatic breathing on blood pressure, stress, and anxiety in hypertensive African-American women: an intervention study. J Natl Black Nurses Assoc. Jul. 2010;21(1):17-24. X-6, X-7, X-9. [pmid: 20857772].
1862 Jeglic E, Kobak KA, Engelhardt N, et al. A novel approach to rater training and certification in multinational trials. Int Clin Psychopharmacol. Jul. 2007;22(4):187-91. X-2, X-3, X-4, X-6. [pmid: 17519640].
1863 Jenerette C, Dixon J. Developing a short form of the simple Rathus assertiveness schedule using a sample of adults with sickle cell disease. J Transcult Nurs. Oct. 2010;21(4):314-24. X-2, X-4, X-5, X-6. [pmid: 20592057].
1864 Jenhani M, Gaha K, Nabouli R, et al. Effectiveness of patient education on glycemic control in insulin treated patients in general practice. Diabetes Metab. Sep. 2005;31(4 Pt 1):376-81. X-3, X-6. [pmid: 16369200].
1865 Jenkins C, McNary S, Carlson BA, et al. Reducing disparities for African Americans with diabetes: progress made by the REACH 2010 Charleston and Georgetown Diabetes Coalition. Public Health Rep. May-Jun. 2004;119(3):322-30. X-11. [pmid: 15158111].
1866 Jenkins C, Pope C, Magwood G, et al. Expanding the chronic care framework to improve diabetes management: the REACH case study. Prog Community Health Partnersh. Spring. 2010;4(1):65-79. X-1, X-2, X-3, X-4, X-6. [pmid: 20364080].
1867 Jenkins CN, McPhee SJ, Bird JA, et al. Effect of a media-led education campaign on breast and cervical cancer screening among Vietnamese-American women. Prev Med. Apr. 1999;28(4):395-406. X-9. [pmid: 10090869].
1868 Jenkins K, Alberry B, Daniel J, et al. Beyond communication: the development of a training program for hospital and hospice staff in the detection and management of psychological distress--preliminary results. Palliat Support Care. Mar. 2010;8(1):27-33. X-3, X-5, X-6. [pmid: 20163757].
1869 Jenkins RG, Ornstein SM, Nietert PJ, et al. Quality improvement for prevention of cardiovascular disease and stroke in an academic family medicine center: do racial differences in outcome exist?. Ethn Dis. Winter. 2006;16(1):132-7. X-11. [pmid: 16599361].
1870 Jennings AM, Mackinnon M, Sparkes P, et al. Education for patients with established NIDDM. Disparities between patients who do and do not attend. Diabetes Care. Jan. 1990;13(1):79-80. X-6, X-7, X-9. [pmid: 2298114].
1871 Jenny JL. A comparison of four age groups' adaptation to diabetes. Can J Public Health. May-Jun. 1984;75(3):237-44. X-6, X-7, X-9. [pmid: 6744196].
1872 Jeon YH, Essue B, Jan S, et al. Economic hardship associated with managing chronic illness: a qualitative inquiry. BMC Health Serv Res. 2009;9:182. X-2, X-3, X-4, X-5, X-6. [pmid: 19818128].
1873 Jeppesen KM, Coyle JD, Miser WF. Screening questions to predict limited health literacy: a cross-sectional study of patients with diabetes mellitus. Ann Fam Med. Jan-Feb. 2009;7(1):24-31. X-2, X-4. [pmid: 19139446].
1874 Jernigan VB, Lorig K. The internet diabetes self-management workshop for American Indians and Alaska Natives. Health Promot Pract. Mar. 2011;12(2):261-70. X-4, X-10, X-11. [pmid: 20534807].
1875 Jerome-D'Emilia B, Merwin E, Stern S. Feasibility of using technology to disseminate evidence to rural nurses and improve patient outcomes. J Contin Educ Nurs. Jan. 2010;41(1):25-32. X-7, X-9. [pmid: 20102140].
1876 Jha AK, Orav EJ, Epstein AM. The effect of financial incentives on hospitals that serve poor patients. Ann Intern Med. Sep. 7. 2010;153(5):299-306. X-6, X-7. [pmid: 20820039].
1877 Jibaja ML, Kingery P, Neff NE, et al. Tailored, interactive soap operas for breast cancer education of high-risk Hispanic women. J Cancer Educ. Winter. 2000;15(4):237-42. X-9. [pmid: 11199243].
1878 Jibaja-Weiss ML, Volk RJ. Utilizing computerized entertainment education in the development of decision aids for lower literate and naive computer users. Journal of Health Communication. Oct-Nov. 2007;12(7):681-97. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17934944].
1879 Jibaja-Weiss ML, Volk RJ, Friedman LC, et al. Preliminary testing of a just-in-time, user-defined values clarification exercise to aid lower literate women in making informed breast cancer treatment decisions. Health Expect. Sep. 2006;9(3):218-31. X-9. [pmid: 16911136].
1880 Jibaja-Weiss ML, Volk RJ, Granch TS, et al. Entertainment education for informed breast cancer treatment decisions in low-literate women: development and initial evaluation of a patient decision aid. J Cancer Educ. Fall. 2006;21(3):133-9. X-6, X-9. [pmid: 17371175].
1881 Jibaja-Weiss ML, Volk RJ, Granchi TS, et al. Entertainment education for breast cancer surgery decisions: a randomized trial among patients with low health literacy. Patient Educ Couns. Jul. 2011;84(1):41-8. X-6, X-9. [pmid: 20609546].
1882 Jibaja-Weiss ML, Volk RJ, Kingery P, et al. Tailored messages for breast and cervical cancer screening of low-income and minority women using medical records data. Patient Educ Couns. Jun. 2003;50(2):123-32. X-6, X-9. [pmid: 12781927].
1883 Johansson A, Svanborg E, Swahn E, et al. Sleep, arousal and health-related quality of life in men and women with coronary artery disease. Journal of Clinical Nursing. 2011;20(19/20):2787-801. X-2, X-6. [pmid: 21781201].
1884 Johnson AE, Yin M, Berg G. Utilization and financial outcomes of an asthma disease management program delivered to Medicaid members: results of a three-group comparison study. Disease Management & Health Outcomes. 2003;11(7):455-65. X-9.
1885 Johnson B, Chavkin W. Policy efforts to prevent ART-related preterm birth. Matern Child Health J. May. 2007;11(3):219-25. X-1, X-2, X-3, X-4, X-6. [pmid: 17066313].
1886 Johnson CE, Johnson T, Clark H, et al. A library-site asthma education program for inner-city communities. J Asthma. Jan-Feb. 2006;43(1):9-18. X-7, X-9. [pmid: 16448959].
1887 Johnson CS, McLeod PJ, Sharpe D, et al. Differences among core dimensions of the Centre for Epidemiological Studies Depression (CES-D) scale across age and gender groups. Canadian Journal of Community Mental Health. Spr. 2008;27(1):79-91. X-2, X-3, X-4.
1888 Johnson JA, Eurich DT, Toth EL, et al. Generalizability and persistence of a multifaceted intervention for improving quality of care for rural patients with type 2 diabetes. Diabetes Care. Apr. 2005;28(4):783-8. X-6, X-9. [pmid: 15793173].
1889 Johnson JL, Stern EB. Readability of patient education materials: a comparison of rural and urban cardiac rehabilitation sites in Minnesota. J Cardiopulm Rehabil. Mar-Apr. 2004;24(2):121-7. X-2, X-4, X-6. [pmid: 15052116].
1890 Johnson KH, Bazargan M, Bing EG. Alcohol consumption and compliance among inner-city minority patients with type 2 diabetes mellitus. Arch Fam Med. Nov-Dec. 2000;9(10):964-70. X-2, X-4. [pmid: 11115194].
1891 Johnson-Kozlow M. Colorectal Cancer Screening of Californian Adults of Mexican Origin as a Function of Acculturation. Journal of Immigrant and Minority Health. Aug. 2010;12(4):454-61. X-2, X-4. [pmid: 19252984].
1892 Johnson-Spruill I, Hammond P, Davis B, et al. Health of Gullah families in South Carolina with type 2 diabetes: diabetes self-management analysis from project SuGar. Diabetes Educ. Jan-Feb. 2009;35(1):117-23. X-2, X-4. [pmid: 19244567].
1893 Joish VN, Malone DC, Wendel C, et al. Profiling quality of diabetes care in a Veterans Affairs Healthcare System. Am J Med Qual. May-Jun. 2004;19(3):112-20. X-2, X-4, X-6. [pmid: 15212316].
1894 Jones BA, Culler CS, Kasl SV, et al. Is variation in quality of mammographic services race linked?. J Health Care Poor Underserved. Feb. 2001;12(1):113-26. X-2, X-4. [pmid: 11217224].
1895 Jones BA, Reams K, Calvocoressi L, et al. Adequacy of communicating results from screening mammograms to African American and White women. Am J Public Health. Mar. 2007;97(3):531-8. X-2, X-4. [pmid: 17267723].
1896 Jones C. Sexual activity after myocardial infarction. Nurs Stand. Aug. 19-25. 1992;6(48):25-8. X-1, X-2, X-3, X-4, X-6. [pmid: 1515329].
1897 Jones CA, Mawani S, King KM, et al. Tackling health literacy: adaptation of public hypertension educational materials for an Indo-Asian population in Canada. BMC Public Health. 2011;11:24. X-2, X-3, X-4. [pmid: 21223580].
1898 Jones D, Hendricks A, Comstock C, et al. Eye examinations for VA patients with diabetes: standardizing performance measures. Int J Qual Health Care. Apr. 2000;12(2):97-104. X-2, X-4, X-6. [pmid: 10830666].
1899 Jones JA, Wahlgren DR, Meltzer SB, et al. Increasing asthma knowledge and changing home environments for Latino families with asthmatic children. Patient Educ Couns. Jan. 2001;42(1):67-79. X-6, X-9. [pmid: 11080607].
1900 Jones JL, Ogunmodede F, Scheftel J, et al. Toxoplasmosis-related knowledge and practices among pregnant women in the United States. Infect Dis Obstet Gynecol. 2003;11(3):139-45. X-2, X-4, X-6. [pmid: 15022874].
1901 Jones L, Wright K, Wright A, et al. The Healthy African American Families' risk communications initiative: using community partnered participatory research to address preterm birth at the local level. Ethn Dis. Winter. 2010;20(1 Suppl 2):S2-30-5. X-1, X-2, X-4. [pmid: 20629244].
1902 Jones RA, Utz S, Wenzel J, et al. Use of complementary and alternative therapies by rural African Americans with type 2 diabetes. Altern Ther Health Med. Sep-Oct. 2006;12(5):34-8. X-2, X-4. [pmid: 17017753].
1903 Jones RG, Trivedi AN, Ayanian JZ. Factors influencing the effectiveness of interventions to reduce racial and ethnic disparities in health care. Soc Sci Med. Feb. 2010;70(3):337-41. X-2, X-4. [pmid: 19914755].
1904 Jones WL, Rimer B, Engstrom PF, et al. Important gaps in patients' knowledge prior to chemotherapy. Prog Clin Biol Res. 1983;130:391-400. X-6, X-7, X-9. [pmid: 6622474].
1905 Joo JH, Solano FX, Mulsant BH, et al. Predictors of adequacy of depression management in the primary care setting. Psychiatr Serv. Dec. 2005;56(12):1524-8. X-2, X-4, X-6. [pmid: 16339613].
1906 Jordan DN, Jordan JL. Self-care behaviors of Filipino-American adults with type 2 diabetes mellitus. J Diabetes Complications. Jul-Aug. 2010;24(4):250-8. X-2, X-4. [pmid: 19615920].
1907 Jorm AF, Christensen H, Griffiths KM. The impact of beyondblue: the national depression initiative on the Australian public's recognition of depression and beliefs about treatments. Aust N Z J Psychiatry. Apr. 2005;39(4):248-54. X-3. [pmid: 15777361].
1908 Jorm AF, Christensen H, Griffiths KM. Changes in depression awareness and attitudes in Australia: the impact of beyondblue: the national depression initiative. Aust N Z J Psychiatry. Jan. 2006;40(1):42-6. X-3, X-6. [pmid: 16403036].
1909 Jorm AF, Griffiths KM, Christensen H, et al. Providing information about the effectiveness of treatment options to depressed people in the community: a randomized controlled trial of effects on mental health literacy, help-seeking and symptoms. Psychol Med. Aug. 2003;33(6):1071-9. X-6, X-7, X-9. [pmid: 12946091].
1910 Josefson D. Media watch: the kidney dilemma. West J Med. Jun. 1999;170(6):373-4. X-1, X-2, X-3, X-4, X-6. [pmid: 11645169].
1911 Joseph CL, Havstad SL, Johnson D, et al. Factors associated with nonresponse to a computer-tailored asthma management program for urban adolescents with asthma. J Asthma. Aug. 2010;47(6):667-73. X-7, X-9. [pmid: 20642376].
1912 Joseph CL, Peterson E, Havstad S, et al. A web-based, tailored asthma management program for urban African-American high school students. Am J Respir Crit Care Med. May. 1. 2007;175(9):888-95. X-7, X-9. [pmid: 17290041].
1913 Joseph G, Beattie MS, Lee R, et al. Pre-counseling Education for Low Literacy Women at Risk of Hereditary Breast and Ovarian Cancer (HBOC): Patient Experiences Using the Cancer Risk Education Intervention Tool (CREdIT). Journal of Genetic Counseling. Oct. 2010;19(5):447-62. X-2, X-4. [pmid: 20490636].
1914 Joseph G, Dohan D. Recruiting minorities where they receive care: Institutional barriers to cancer clinical trials recruitment in a safety-net hospital. Contemporary Clinical Trials. Nov. 2009;30(6):552-7. X-2, X-4. [pmid: 19580887].
1915 Joshi R, Joshi N, Helmuth A. Improving ambulatory diabetes care in high-risk racial minorities: use of culture-specific education and close follow-up. Endocr Pract. Mar-Apr. 2010;16(2):171-7. X-9. [pmid: 19833583].
1916 Jovanovic L, Harrison RW 3rd. Advances in diabetes for the millennium: diabetes in minorities. MedGenMed. 2004;6(3 Suppl):2. X-1, X-6, X-7, X-9. [pmid: 15647707].
1917 Jowsey T, Gillespie J, Aspin C. Effective communication is crucial to self-management: the experiences of immigrants to Australia living with diabetes. Chronic Illn. Mar. 2011;7(1):6-19. X-2, X-3, X-4. [pmid: 21078683].
1918 Joyce R, Webb R, Peacock JL, et al. Adjusted mortality rates: a tool for creating more meaningful league tables for stillbirth and infant mortality rates. Public Health. Nov. 2002;116(6):315-21. X-2, X-3, X-4. [pmid: 12407470].
1919 Joyner-Grantham J, Mount DL, McCorkle OD, et al. Self-reported influences of hopelessness, health literacy, lifestyle action, and patient inertia on blood pressure control in a hypertensive emergency department population. Am J Med Sci. Nov. 2009;338(5):368-72. X-2, X-4. [pmid: 19838100].
1920 Juip MP. Implications of clinical advancement systems and nurse case managers on the diabetes educator. Diabetes Educ. Jan-Feb. 1993;19(1):77-8. X-1, X-6, X-7, X-9. [pmid: 8458303].
1921 Jula A, Puukka P, Karanko H. Multiple clinic and home blood pressure measurements versus ambulatory blood pressure monitoring. Hypertension. Aug. 1999;34(2):261-6. X-2, X-4. [pmid: 10454451].
1922 Junda T. Living with breast cancer: Thai women's perspective. Thai Journal of Nursing Research. 2004;8(3):208-22. X-2, X-3, X-4.
1923 Kafatos AG, Tsitoura S, Pantelakis SN, et al. Maternal and infant health education in a rural Greek community. Hygie. Mar. 1991;10(1):32-7. X-3. [pmid: 2040509].
1924 Kagawa-Singer M, Tanjasiri SP, Valdez A, et al. Outcomes of a breast health project for Hmong women and men in California. Am J Public Health. Oct. Suppl 2. 2009;99:S467-73. X-9. [pmid: 19443830].
1925 Kahan NR, Waitman DA, Blackman S, et al. Prior authorization to improve testing of glycosylated hemoglobin in a managed care setting. Am J Manag Care. Sep. 2009;15(9):582-4. X-2, X-3, X-4, X-6. [pmid: 19747022].
1926 Kahn LS, Fox CH, Carrington J, et al. Telephonic nurse case management for patients with diabetes and mental illnesses: a qualitative perspective. Chronic Illn. Dec. 2009;5(4):257-67. X-2, X-6. [pmid: 20156943].
1927 Kahn LS, Glaser K, Fox CH, et al. Diabetes educators in safety-net practices: a qualitative study. Diabetes Educ. Mar-Apr. 2011;37(2):212-9. X-2, X-4, X-6. [pmid: 21357750].
1928 Kaholokula JK, Haynes SN, Grandinetti A, et al. Ethnic differences in the relationship between depressive symptoms and health-related quality of life in people with type 2 diabetes. Ethnicity & Health. 2006;11(1):59-80. X-2, X-4. [pmid: 16338755].
1929 Kaholokula JK, Saito E, Mau MK, et al. Pacific Islanders' perspectives on heart failure management. Patient Educ Couns. Feb. 2008;70(2):281-91. X-2, X-4. [pmid: 18068939].
1930 Kaiser K, Miksch S. Versioning computer-interpretable guidelines: semi-automatic modeling of ‘Living Guidelines’ using an information extraction method. Artif Intell Med. May. 2009;46(1):55-66. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18950994].
1931 Kaissi AA, Parchman M. Organizational factors associated with self-management behaviors in diabetes primary care clinics. The Diabetes Educator. Sep-Oct. 2009;35(5):843-50. X-2, X-4, X-6. [pmid: 19783769].
1932 Kalauokalani D, Franks P, Oliver JW, et al. Can patient coaching reduce racial/ethnic disparities in cancer pain control? Secondary analysis of a randomized controlled trial. Pain Med. Jan-Feb. 2007;8(1):17-24. X-4. [pmid: 17244100].
1933 Kales HC, Blow FC, Welsh DE, et al. Herbal products and other supplements: use by elderly veterans with depression and dementia and their caregivers. J Geriatr Psychiatry Neurol. Mar. 2004;17(1):25-31. X-2, X-4, X-6. [pmid: 15018694].
1934 Kalichman SC, Cherry J, Cain D. Nurse-Delivered Antiretroviral Treatment Adherence Intervention for People With Low Literacy Skills and Living With HIV/AIDS. JANAC: Journal of the Association of Nurses in AIDS Care. Sep-Oct. 2005;16(5):3-15. X-4, X-5. [pmid: 16433105].
1935 Kalichman SC, Ramachandran B, Catz S. Adherence to combination antiretroviral therapies in HIV patients of low health literacy. Journal of General Internal Medicine. May. 1999;14(5):267-73. X-2, X-4, X-5. [pmid: 10337035].
1936 Kalichman SC, Rompa D. Emotional reactions to health status changes and emotional well-being among HIV-positive persons with limited reading literacy. Journal of Clinical Psychology in Medical Settings. Dec. 2000;7(4):203-11. X-2, X-4, X-5.
1937 Kalichman SC, Williams E, Nachimson D. Randomized community trial of a breast self-examination skills-building intervention for inner-city African-American women. J Am Med Womens Assoc. Winter. 2000;55(1):47-50. X-9. [pmid: 10680410].
1938 Kamara M. Interview with Makeda Kamara. Interview by Ina May Gaskin. Birth Gaz. Summer. 1992;8(3):4-11. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 1392647].
1939 Kamel NM, Badawy YA, el-Zeiny NA, et al. Sociodemographic determinants of management behaviour of diabetic patients. Part II. Diabetics' knowledge of the disease and their management behaviour. East Mediterr Health J. Sep. 1999;5(5):974-83. X-2, X-4, X-6. [pmid: 10983538].
1940 Kamel NM, Badawy YA, el-Zeiny NA, et al. Sociodemographic determinants of management behaviour of diabetic patients. Part I. Behaviour of patients in relation to management of their disease. East Mediterr Health J. Sep. 1999;5(5):967-73. X-2, X-4, X-6. [pmid: 10983537].
1941 Kandula NR, Nsiah-Kumi PA, Makoul G, et al. The relationship between health literacy and knowledge improvement after a multimedia type 2 diabetes education program. Patient Educ Couns. Jun. 2009;75(3):321-7. X-7, X-9, X-10. [pmid: 19395223].
1942 Kang HY, Yoo YS. Effects of a bereavement intervention program in middle-aged widows in Korea. Arch Psychiatr Nurs. Jun. 2007;21(3):132-40. X-3, X-5, X-6. [pmid: 17556106].
1943 Kanter DE, Turenne W, Slonim AD. Hospital-reported medical errors in premature neonates. Pediatr Crit Care Med. Mar. 2004;5(2):119-23. X-2, X-4, X-5. [pmid: 14987340].
1944 Kaplan CP, Crane LA, Stewart S, et al. Factors affecting follow-up among low-income women with breast abnormalities. J Womens Health (Larchmt). Mar. 2004;13(2):195-206. X-2, X-4. [pmid: 15072734].
1945 Kapp JM, Ryerson AB, Coughlin SS, et al. Racial and ethnic differences in mammography use among U.S. women younger than age 40. Breast Cancer Res Treat. Jan. 2009;113(2):327-37. X-2, X-4. [pmid: 18264758].
1946 Kapp JM, Walker R, Haneuse S, et al. Are there racial/ethnic disparities among women younger than 40 undergoing mammography?. Breast Cancer Res Treat. Nov. 2010;124(1):213-22. X-2, X-4. [pmid: 20204501].
1947 Kara B. Herbal product use in a sample of Turkish patients undergoing haemodialysis. J Clin Nurs. Aug. 2009;18(15):2197-205. X-2, X-3, X-4, X-6. [pmid: 19207805].
1948 Kara M, van der Bijl JJ, Shortridge-Baggett LM, et al. Cross-cultural adaptation of the Diabetes Management Self-Efficacy Scale for patients with type 2 diabetes mellitus: scale development. Int J Nurs Stud. Jul. 2006;43(5):611-21. X-2, X-3, X-4, X-6. [pmid: 16239003].
1949 Karaguzel G, Bircan I, Erisir S, et al. Metabolic control and educational status in children with type 1 diabetes: effects of a summer camp and intensive insulin treatment. Acta Diabetol. Dec. 2005;42(4):156-61. X-4, X-6. [pmid: 16382302].
1950 Karalis M. How to make the new conditions for coverage work in your dialysis clinic. Nephrol News Issues. Apr. 2009;23(4):28. 31. X-1, X-2, X-3, X-4, X-6. [pmid: 19437945].
1951 Karanja NM, McCullough ML, Kumanyika SK, et al. DASH trial. Pre-enrollment diets of Dietary Approaches to Stop Hypertension trial participants. Journal of the American Dietetic Association. 1999;99(8):S28-34. X-6, X-7, X-9. [pmid: 10450291].
1952 Karaoz B, Aksu H, Kucuk M. A qualitative study of the information needs of premenopausal women with breast cancer in terms of contraception, sexuality, early menopause, and fertility. Int J Gynaecol Obstet. May. 2010;109(2):118-20. X-2, X-3, X-4, X-6. [pmid: 20152978].
1953 Karasz A. Cultural differences in conceptual models of depression. Soc Sci Med. Apr. 2005;60(7):1625-35. X-2, X-4. [pmid: 15652693].
1954 Karlen A. Positive sexual effects of chronic illness: Case studies of women with lupus (SLE). Sexuality and Disability. Fal. 2002;20(3):191-208. X-1, X-2, X-3, X-4, X-5, X-6.
1955 Karliner LS, Hwang ES, Nickleach D, et al. Language barriers and patient-centered breast cancer care. Patient Education and Counseling. Aug. 2011;84(2):223-8. X-2, X-4. [pmid: 20685068].
1956 Karliner LS, Kim SE, Meltzer DO, et al. Influence of Language Barriers on Outcomes of Hospital Care for General Medicine Inpatients. Journal of Hospital Medicine. May-Jun. 2010;5(5):276-82. X-2, X-4, X-5. [pmid: 20533573].
1957 Karmaliani R, Bann CM, Mahmood MA, et al. Measuring antenatal depression and anxiety: Findings from a community-based study of women in Hyderabad, Pakistan. Women & Health. 2006;44(3):79-103. X-2, X-3, X-4, X-6. [pmid: 17255067].
1958 Karner A, Goransson A, Bergdahl B. Patients' conceptions of coronary heart disease--a phenomenographic analysis. Scand J Caring Sci. Mar. 2003;17(1):43-50. X-2, X-4, X-6. [pmid: 12581294].
1959 Karnick P, Margellos-Anast H, Seals G, et al. The pediatric asthma intervention: a comprehensive cost-effective approach to asthma management in a disadvantaged inner-city community. J Asthma. Jan-Feb. 2007;44(1):39-44. X-6, X-9. [pmid: 17365203].
1960 Karter AJ, Ferrara A, Darbinian JA, et al. Self-monitoring of blood glucose: language and financial barriers in a managed care population with diabetes. Diabetes Care. Apr. 2000;23(4):477-83. X-2, X-4. [pmid: 10857938].
1961 Karter AJ, Stevens MR, Brown AF, et al. Educational disparities in health behaviors among patients with diabetes: the Translating Research Into Action for Diabetes (TRIAD). Study BMC Public Health. 2007;7:308. X-2, X-4, X-6. [pmid: 17967177].
1962 Karter AJ, Subramanian U, Saha C, et al. Barriers to insulin initiation: the translating research into action for diabetes insulin starts project. Diabetes Care. Apr. 2010;33(4):733-5. X-2, X-4, X-6. [pmid: 20086256].
1963 Karve AM, Ou FS, Lytle BL, et al. Potential unintended financial consequences of pay-for-performance on the quality of care for minority patients. Am Heart J. Mar. 2008;155(3):571-6. X-2, X-4, X-5. [pmid: 18294498].
1964 Kaslow NJ, Leiner AS, Reviere S, et al. Suicidal, abused African American women's response to a culturally informed intervention. J Consult Clin Psychol. Aug. 2010;78(4):449-58. X-9. [pmid: 20658802].
1965 Kato N, Kinugawa K, Ito N, et al. Adherence to self-care behavior and factors related to this behavior among patients with heart failure in Japan. Heart Lung. Sep-Oct. 2009;38(5):398-409. X-2, X-3, X-4, X-6. [pmid: 19755190].
1966 Katon W, Unutzer J, Wells K, et al. Collaborative depression care: history, evolution and ways to enhance dissemination and sustainability. Gen Hosp Psychiatry. Sep-Oct. 2010;32(5):456-64. X-1, X-2, X-3, X-4, X-6. [pmid: 20851265].
1967 Katon WJ, Richardson L, Russo J, et al. Quality of Mental Health Care for Youth with Asthma and Comorbid Anxiety and Depression. Medical Care. Dec. 2006;44(12):1064-72. X-2, X-4, X-6. [pmid: 17122709].
1968 Katon WJ, Russo JE, Von Korff M, et al. Long-term effects on medical costs of improving depression outcomes in patients with depression and diabetes. Diabetes Care. Jun. 2008;31(6):1155-9. X-6, X-7, X-9. [pmid: 18332158].
1969 Katz MG, Jacobson TA, Veledar E, et al. Patient literacy and question-asking behavior during the medical encounter: A mixed-methods analysis. Journal of General Internal Medicine. Jun. 2007;22(6):782-6. X-2, X-4, X-5. [pmid: 17431697].
1970 Katz ML, Heaner S, Reiter P, et al. Development of an educational video to improve patient knowledge and communication with their healthcare providers about colorectal cancer screening. American Journal of Health Education. 2009;40(4):220-8. X-2, X-4. [pmid: 20209024].
1971 Katz ML, James AS, Pignone MP, et al. Colorectal cancer screening among African American church members: a qualitative and quantitative study of patient-provider communication. BMC Public Health. Dec. 15. 2004;4:62. X-2, X-4. [pmid: 15601463].
1972 Katz ML, Tatum C, Dickinson SL, et al. Improving colorectal cancer screening by using community volunteers: results of the Carolinas cancer education and screening (CARES) project. Cancer. Oct. 1. 2007;110(7):1602-10. X-9. [pmid: 17665496].
1973 Katz PP, Morris A, Julian L, et al. Onset of depressive symptoms among adults with asthma: results from a longitudinal observational cohort. Prim Care Respir J. Sep. 2010;19(3):223-30. X-2, X-4, X-6. [pmid: 20169291].
1974 Katz PP, Yelin EH, Smith S, et al. Perceived control of asthma: development and validation of a questionnaire. Am J Respir Crit Care Med. Feb. 1997;155(2):577-82. X-2, X-4, X-6. [pmid: 9032197].
1975 Kaufman DR, Patel VL, Hilliman C, et al. Usability in the real world: assessing medical information technologies in patients' homes. J Biomed Inform. Feb-Apr. 2003;36(1-2):45-60. X-2, X-4. [pmid: 14552846].
1976 Kaufman DR, Starren J, Patel VL, et al. A cognitive framework for understanding barriers to the productive use of a diabetes home telemedicine system. AMIA Annu Symp Proc. 2003:356-60. X-1, X-2, X-3, X-4, X-6. [pmid: 14728194].
1977 Kaul T. Helping African American children self-manage asthma: the importance of self-efficacy. J Sch Health. Jan. 2011;81(1):29-33. X-2, X-4. [pmid: 21158863].
1978 Kavanagh J, Oliver S, Lorenc T, et al. School-based cognitive-behavioural interventions: a systematic review of effects and inequalities. Health Sociology Review. 2009;18(1):61-78. X-1, X-2, X-3, X-4, X-6.
1979 Kawada T, Okada K. The metabolic syndrome: prevalence and associated lifestyles in Japanese workingmen. J Cardiometab Syndr. Fall. 2006;1(5):313-7. X-2, X-3, X-4, X-6. [pmid: 17679793].
1980 Kayaniyil S, Ardern CI, Winstanley J, et al. Degree and correlates of cardiac knowledge and awareness among cardiac inpatients. Patient Educ Couns. Apr. 2009;75(1):99-107. X-2, X-3, X-4. [pmid: 18952393].
1981 Kazancioglu R, Ozturk S, Ekiz S, et al. Can using a questionnaire for assessment of home visits to peritoneal dialysis patients make a difference to the treatment outcome?. J Ren Care. Jun. 2008;34(2):59-63. X-2, X-4, X-6. [pmid: 18498569].
1982 Kazemi-Saleh D, Pishgou B, Farrokhi F, et al. Gender impact on the correlation between sexuality and marital relation quality in patients with coronary artery disease. J Sex Med. Sep. 2008;5(9):2100-6. X-2, X-4. [pmid: 18221280].
1983 Keating NL, Kouri E, He Y, et al. Racial differences in definitive breast cancer therapy in older women: Are they explained by the hospitals where patients undergo surgery?. Medical Care. Jul. 2009;47(7):765-73. X-2, X-4. [pmid: 19536008].
1984 Keating T. Will success of hospital-based pay-for-performance project be duplicated in renal care?. Nephrol News Issues. Mar. 2008;22(3):12. X-1, X-6, X-7, X-9. [pmid: 18372674].
1985 Kee F, Reaney E, Savage G, et al. Are gatekeepers to renal services referring patients equitably?. J Health Serv Res Policy. Jan. 2007;12(1):36-41. X-2, X-3, X-4, X-6. [pmid: 17244396].
1986 Keeping LM, English LM. Informal and incidental learning with patients who use continuous ambulatory peritoneal dialysis. Nephrol Nurs J. Jun. 2001;28(3):313-4. 9. 22. discussion 23. X-2, X-4, X-6. [pmid: 12143453].
1987 Keeratiyutawong P, Hanucharurnkul S, Boonchauy W, et al. Effectiveness of a supportive-educative program on diabetic control, perceived self-care efficacy, and body mass index in persons with type 2 diabetes mellitus. Thai Journal of Nursing Research. 2005. Jan-Mar. 2005;9(1):1-12. X-3, X-6.
1988 Kellar I, Sutton S, Griffin S, et al. Evaluation of an informed choice invitation for type 2 diabetes screening. Patient Educ Couns. Aug. 2008;72(2):232-8. X-2, X-4, X-6, X-8. [pmid: 18513916].
1989 Keller C, Siegrist M. Effect of risk communication formats on risk perception depending on numeracy. Med Decis Making. Jul-Aug. 2009;29(4):483-90. X-2, X-4. [pmid: 19525484].
1990 Kelley MA. Culturally appropriate breast health educational intervention program for African-American women. J Natl Black Nurses Assoc. Jul. 2004;15(1):36-47. X-9. [pmid: 15712819].
1991 Kelley MA. Recruitment of African American women for research on breast cancer early detection: using culturally appropriate interventions. Southern Online Journal of Nursing Research. 2011;11(1):15p. X-5, X-7, X-9, X-10.
1992 Kelly J, Schumacher C, Mayer AM, et al. Diabetes care: a comparison of management systems. Alaska Med. Jan-Mar. 2000;42(1):13-9. 27. X-2, X-4, X-6. [pmid: 10822870].
1993 Kelly KM, Dickinson SL, Degraffinreid CR, et al. Colorectal cancer screening in 3 racial groups. Am J Health Behav. Sep-Oct. 2007;31(5):502-13. X-2, X-4. [pmid: 17555381].
1994 Kelly KM, Shedlosky-Shoemaker R, Porter K, et al. Cancer Recurrence Worry, Risk Perception, and Informational-Coping Styles Among Appalachian Cancer Survivors. Journal of Psychosocial Oncology. 2011;29(1):1-18. X-1, X-2, X-3, X-4, X-6. [pmid: 21240722].
1995 Kelso TM, Abou-Shala N, Heilker GM, et al. Comprehensive long-term management program for asthma: effect on outcomes in adult African-Americans. Am J Med Sci. Jun. 1996;311(6):272-80. X-4. [pmid: 8659554].
1996 Kelso TM, Self TH, Rumbak MJ, et al. Educational and long-term therapeutic intervention in the ED: effect on outcomes in adult indigent minority asthmatics. Am J Emerg Med. Nov. 1995;13(6):632-7. X-4. [pmid: 7575800].
1997 Kemp BJ, Bateham AL. The role of distress and social involvement in quality of life among people with spinal cord injury. Topics in Spinal Cord Injury Rehabilitation. 2010;16(2):72-80. X-2, X-4, X-5, X-6.
1998 Kemper P, Savage C, Niederbaumer P, et al. A study of the level of knowledge about diabetes management of low-income persons with diabetes. J Community Health Nurs. Winter. 2005;22(4):231-9. X-2, X-4. [pmid: 16245974].
1999 Kendrick JM, Wilson C, Elder RF, et al. Reliability of reporting of self-monitoring of blood glucose in pregnant women. J Obstet Gynecol Neonatal Nurs. May-Jun. 2005;34(3):329-34. X-2, X-4. [pmid: 15890831].
2000 Kenealy TW, Eggleton KS, Robinson EM, et al. Systematic care to reduce ethnic disparities in diabetes care. Diabetes Res Clin Pract. Sep. 2010;89(3):256-61. X-3. [pmid: 20570383].
2001 Kennedy BR. Psychosocial model: racism as a predictor of adherence and compliance to treatment and health outcomes among African Americans. Journal of Theory Construction & Testing. 2009;13(1):20-6. X-1, X-2, X-3, X-4, X-5, X-6.
2002 Kennedy TS, Oakland MJ, Brotherson MJ. Making feeding decisions for preterm low birth weight infants: a family systems approach. Topics in Clinical Nutrition. 2000;15(2):38. X-2, X-4, X-5, X-6.
2003 Keogh KM, Smith SM, White P, et al. Psychological family intervention for poorly controlled type 2 diabetes. Am J Manag Care. Feb. 2011;17(2):105-13. X-6. [pmid: 21473660].
2004 Kernohan EE. Evaluation of a pilot study for breast and cervical cancer screening with Bradford's minority ethnic women; a community development approach, 1991-93. Br J Cancer Suppl. Sep. 1996;29:S42-6. X-2, X-3, X-4. [pmid: 8782798].
2005 Kerr AJ, Looi JL, Garofalo D, et al. Acute Predict: a clinician-led cardiovascular disease quality improvement project (Predict-CVD 12). Heart Lung Circ. May-Jun. 2010;19(5-6):378-83. X-3. [pmid: 20392667].
2006 Kerr C, Murray E, Noble L, et al. The potential of Web-based interventions for heart disease self-management: a mixed methods investigation. J Med Internet Res. 2010;12(4):e56. X-3, X-6. [pmid: 21156471].
2007 Kerr EA, Smith DM, Kaplan SH, et al. The association between three different measures of health status and satisfaction among patients with diabetes. Med Care Res Rev. Jun. 2003;60(2):158-77. X-2, X-4, X-6. [pmid: 12800682].
2008 Keselman A, Logan R, Smith CA, et al. Developing Informatics tools and strategies for consumer-centered health communication. Journal of the American Medical Informatics Association. Jul-Aug. 2008;15(4):473-83. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18436895].
2009 Kessler RC, Berglund P, Demler O, et al. The epidemiology of major depressive disorder: results from the National Comorbidity Survey Replication (NCS-R). JAMA. Jun. 18. 2003;289(23):3095-105. X-2, X-4. [pmid: 12813115].
2010 Kesten S, Zive K, Chapman KR. Pharmacist knowledge and ability to use inhaled medication delivery systems. Chest. Dec. 1993;104(6):1737-42. X-2, X-4, X-6. [pmid: 8252954].
2011 Ketcham JD, Lutfey KE, Gerstenberger E, et al. Physician clinical information technology and health care disparities. Medical Care Research and Review. Dec. 2009;66(6):658-81. X-6, X-7, X-9. [pmid: 19564640].
2012 Keville T, Johnson TL, Epstein SS, et al. Women's Health Law Symposium, Rutgers School of Law-Newark, April 6, 1994. Women's Rights Law Report. Fall. 1994;16(1):17-41. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11654984].
2013 Keys IR. Take it to heart: a national health screening and education project in African-American communities. A joint project of the NMA and Bayer Corporation. J Natl Med Assoc. Dec. 1999;91(12):649-52. X-1, X-6, X-7, X-9. [pmid: 10628123].
2014 Keyserling TC, Ammerman AS, Davis CE, et al. A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. Mar-Apr. 1997;6(2):135-45. X-5. [pmid: 9075448].
2015 Keyserling TC, Ammerman AS, Samuel-Hodge CD, et al. A diabetes management program for African American women with type 2 diabetes. Diabetes Educ. Sep-Oct. 2000;26(5):796-805. X-2, X-10. [pmid: 11140007].
2016 Keyserling TC, Samuel-Hodge CD, Ammerman AS, et al. A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care. Sep. 2002;25(9):1576-83. X-9. [pmid: 12196430].
2017 Keyzer JF, Melnikow J, Kuppermann M, et al. Recruitment strategies for minority participation: challenges and cost lessons from the POWER interview. Ethn Dis. Summer. 2005;15(3):395-406. X-2, X-4. [pmid: 16108298].
2018 Khamseh ME, Vatankhah N, Baradaran HR. Knowledge and practice of foot care in Iranian people with type 2 diabetes. Int Wound J. Dec. 2007;4(4):298-302. X-2, X-3, X-4, X-6. [pmid: 18154624].
2019 Khan CM, Iida M, Stephens MA, et al. Spousal support following knee surgery: roles of self-efficacy and perceived emotional responsiveness. Rehabil Psychol. Feb. 2009;54(1):28-32. X-2, X-4, X-5, X-6. [pmid: 19618700].
2020 Khan JA, Shafquat A, Kundi A. Basic life support skills: assessment and education of spouse and first degree relatives of patients with coronary disease. J Coll Physicians Surg Pak. May. 2010;20(5):299-302. X-3, X-4, X-6. [pmid: 20642919].
2021 Khankari K, Eder M, Osborn CY, et al. Improving colorectal cancer screening among the medically underserved: A pilot study within a federally qualified health center. Journal of General Internal Medicine. Oct. 2007;22(10):1410-4. X-9. [pmid: 17653808].
2022 Khavjou OA, Finkelstein EA, Farris R, et al. Recall of three heart disease risk factor diagnoses among low-income women. J Womens Health (Larchmt). May. 2009;18(5):667-75. X-2, X-4. [pmid: 19405860].
2023 Khosla N, Gordon E, Nishi L, et al. Impact of a chronic kidney disease clinic on preemptive kidney transplantation and transplant wait times. Prog Transplant. Sep. 2010;20(3):216-20. X-2, X-4. [pmid: 20929105].
2024 Khrennikov A. Human subconscious as a p-adic dynamical system. J Theor Biol. Jul. 27. 1998;193(2):179-96. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 9714931].
2025 Khuwatsamrit K, Hanucharurnkul S, Chyun DA, et al. Social support, self-efficacy, and adherence to self-care requirements in patients with coronary artery disease. Thai Journal of Nursing Research. 2006;10(3):155-64. X-2, X-3, X-4, X-6.
2026 Kicera TJ, Douglas M, Guerra FA. Best-practice models that work: the CDC's Racial and Ethnic Adult Disparities Immunization Initiative (READII) Programs. Ethn Dis. Spring. 2005;15(2 Suppl 3):S3-17-S3-20. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15945362].
2027 Kicklighter JR, Stein MA. Factors influencing diabetic clients' ability to read and comprehend printed diabetic diet material. Diabetes Educ. Jan-Feb. 1993;19(1):40-6. X-2, X-4. [pmid: 8458298].
2028 Kidder B. P.O.W. (protect our women): results of a breast cancer prevention project targeted to older African-American women. Soc Work Health Care. 2008;47(1):60-72. X-9. [pmid: 18956513].
2029 Kiefe CI, McKay SV, Halevy A, et al. Is cost a barrier to screening mammography for low-income women receiving Medicare benefits? A randomized trial. Arch Intern Med. Jun. 13. 1994;154(11):1217-24. X-7. [pmid: 8203989].
2030 Kieffer EC, Willis SK, Odoms-Young AM, et al. Reducing disparities in diabetes among African-American and Latino residents of Detroit: the essential role of community planning focus groups. Ethn Dis. Summer. 2004;14(3 Suppl 1):S27-37. X-2, X-4. [pmid: 15682769].
2031 Kiger H. Outreach to multiethnic, multicultural, and multilingual women for breast cancer and cervical cancer education and screening: a model using professional and volunteer staffing. Fam Community Health. Oct-Dec. 2003;26(4):307-18. X-1, X-7, X-9. [pmid: 14528136].
2032 Kim C, McEwen LN, Gerzoff RB, et al. Is physician gender associated with the quality of diabetes care?. Diabetes Care. Jul. 2005;28(7):1594-8. X-2, X-4. [pmid: 15983306].
2033 Kim EH, Stolyar A, Lober WB, et al. Challenges to Using an Electronic Personal Health Record by a Low-Income Elderly Population. Journal of Medical Internet Research. Oct-Dec. 2009;11(4). X-2, X-4, X-5. [pmid: 19861298].
2034 Kim J, Han HR, Song H, et al. Compliance with home blood pressure monitoring among middle-aged Korean Americans with hypertension. J Clin Hypertens (Greenwich). Apr. 2010;12(4):253-60. X-9. [pmid: 20433546].
2035 Kim MJ, Ahn YH, Chon C, et al. Health disparities in lifestyle choices among hypertensive Korean Americans, non-Hispanic Whites, and Blacks. Biol Res Nurs. Jul. 2005;7(1):67-74. X-2, X-4. [pmid: 15920004].
2036 Kim MJ, Lee SJ, Ahn YH, et al. Lifestyle advice for Korean Americans and native Koreans with hypertension. J Adv Nurs. Mar. 2011;67(3):531-9. X-2. [pmid: 21077932].
2037 Kim MT, Han HR, Park HJ, et al. Constructing and testing a self-help intervention program for high blood pressure control in Korean American seniors--a pilot study. J Cardiovasc Nurs. Mar-Apr. 2006;21(2):77-84. X-4. [pmid: 16601523].
2038 Kim MT, Han HR, Song HJ, et al. A community-based, culturally tailored behavioral intervention for Korean Americans with type 2 diabetes. Diabetes Educ. Nov-Dec. 2009;35(6):986-94. X-4. [pmid: 19934458].
2039 Kim MT, Kim EY, Han HR, et al. Mail education is as effective as in-class education in hypertensive Korean patients. J Clin Hypertens (Greenwich). Mar. 2008;10(3):176-84. X-7, X-9. [pmid: 18326962].
2040 Kim S, Love F, Quistberg DA, et al. Association of health literacy with self-management behavior in patients with diabetes. Diabetes Care. Dec. 2004;27(12):2980-2. X-7, X-9. [pmid: 15562219].
2041 Kim SH. Health literacy and functional health status in Korean older adults. J Clin Nurs. Aug. 2009;18(16):2337-43. X-2, X-3, X-4, X-5. [pmid: 19583664].
2042 Kim Y, Evangelista LS, Phillips LR, et al. The End-Stage Renal Disease Adherence Questionnaire (ESRD-AQ): testing the psychometric properties in patients receiving in-center hemodialysis. Nephrol Nurs J. Jul-Aug. 2010;37(4):377-93. X-2, X-3. [pmid: 20830945].
2043 Kim YH, Sarna L. An intervention to increase mammography use by Korean American women. Oncol Nurs Forum. Jan-Feb. 2004;31(1):105-10. X-7, X-9. [pmid: 14722594].
2044 Kimble LP, Dunbar SB, McGuire DB, et al. Cardiac instrument development in a low-literacy population: the revised Chest Discomfort Diary. Heart Lung. Jul-Aug. 2001;30(4):312-20. X-2, X-4. [pmid: 11449218].
2045 Kimble LP, Dunbar SB, Weintraub WS, et al. Symptom clusters and health-related quality of life in people with chronic stable angina. Journal of Advanced Nursing. 2011;67(5):1000-11. X-2, X-4, X-6. [pmid: 21352270].
2046 King K. Educational factors affecting modality selection: a National Kidney Foundation study. EDTNA ERCA J. Jul-Sep. 1998;24(3):27-9. X-2, X-6. [pmid: 10392075].
2047 King KA, Strunk CM, Sorter MT. Preliminary Effectiveness of Surviving the Teens® Suicide Prevention and Depression Awareness Program on Adolescents' Suicidality and Self-Efficacy in Performing Help-Seeking Behaviors. Journal of School Health. 2011;81(9):581-90. X-4, X-5, X-6. [pmid: 21831072].
2048 King MG, Jenkins C, Hossler C, et al. People with diabetes: knowledge, perceptions, and applications of recommendations for diabetes management. Ethn Dis. Summer. 2004;14(3 Suppl 1):S128-33. X-2, X-4. [pmid: 15682782].
2049 King R. Illness attributions and myocardial infarction: the influence of gender and socio-economic circumstances on illness beliefs. J Adv Nurs. Mar. 2002;37(5):431-8. X-2, X-3, X-4. [pmid: 11843981].
2050 Kinney AY, Choi YA, DeVellis B, et al. Attitudes toward genetic testing in patients with colorectal cancer. Cancer Pract. Jul-Aug. 2000;8(4):178-86. X-2, X-4. [pmid: 11898257].
2051 Kinzie JD, Leung P, Boehnlein JK, et al. Antidepressant blood levels in Southeast Asians. Clinical and cultural implications. J Nerv Ment Dis. Aug. 1987;175(8):480-5. X-2, X-3, X-4. [pmid: 3625187].
2052 Kiritsi F, Tsiou C, Gouvelou-Deligianni G, et al. An investigation of risk factors for coronary heart disease in a greek [sic] population. Health Science Journal. 2008. Jan-Mar. 2008;2(1):41-50. X-2, X-3, X-4, X-6.
2053 Kirk JK, Bell RA, Bertoni AG, et al. Ethnic disparities: control of glycemia, blood pressure, and LDL cholesterol among US adults with type 2 diabetes. Ann Pharmacother. Sep. 2005;39(9):1489-501. X-1, X-2, X-3, X-4, X-6. [pmid: 16076917].
2054 Kirk JK, Strachan E, Martin CL, et al. Patient characteristics and process of care measures as predictors of glycemic control. Journal of Clinical Outcomes Management. 2010;17(1):27-30. X-2, X-4, X-6.
2055 Kiropoulos LA, Griffiths KM, Blashki G. Effects of a multilingual information website intervention on the levels of depression literacy and depression-related stigma in Greek-born and Italian-born immigrants living in Australia: a randomized controlled trial. J Med Internet Res. 2011;13(2):e34. X-3. [pmid: 21504872].
2056 Kisioglu AN, Aslan B, Ozturk M, et al. Improving control of high blood pressure among middle-aged Turkish women of low socio-economic status through public health training. Croat Med J. Aug. 2004;45(4):477-82. X-3, X-6. [pmid: 15311423].
2057 Kivimaki M, Shipley MJ, Ferrie JE, et al. Best-practice interventions to reduce socioeconomic inequalities of coronary heart disease mortality in UK: a prospective occupational cohort study. Lancet. Nov. 8. 2008;372(9650):1648-54. X-2, X-3, X-4. [pmid: 18994662].
2058 Klabunde CN, Riley GF, Mandelson MT, et al. Health plan policies and programs for colorectal cancer screening: a national profile. Am J Manag Care. Apr. 2004;10(4):273-9. X-2, X-4, X-6. [pmid: 15124504].
2059 Klabunde CN, Schenck AP, Davis WW. Barriers to colorectal cancer screening among Medicare consumers. Am J Prev Med. Apr. 2006;30(4):313-9. X-2, X-4. [pmid: 16530618].
2060 Klap R, Tang L, Schell T, et al. How quality improvement interventions for depression affect stigma concerns over time: A nine-year follow-up study. Psychiatric Services. Feb. 2009;60(2):258-61. X-6, X-10. [pmid: 19176423].
2061 Kleftaras G. Psychosocial factors and later life depressive symptoms in a Greek community sample. Physical & Occupational Therapy in Geriatrics. 2006;25(2):13-32. X-2, X-3, X-4, X-6.
2062 Kleinpeter MA. Health literacy affects peritoneal dialysis performance and outcomes. Adv Perit Dial. 2003;19:115-9. X-2, X-4. [pmid: 14763046].
2063 Klerman LV, Cleckley DC, Sinsky RJ, et al. Infant mortality review as a vehicle for quality improvement in a local health department. Jt Comm J Qual Improv. Mar. 2000;26(3):147-59. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10709148].
2064 Klerman LV, Ramey SL, Goldenberg RL, et al. A randomized trial of augmented prenatal care for multiple-risk, Medicaid-eligible African American women. Am J Public Health. Jan. 2001;91(1):105-11. X-9. [pmid: 11189800].
2065 Kleshinski JF, Crews C, Fry E, et al. A survey of herbal product use in a dialysis population in Northwest Ohio. J Ren Nutr. Apr. 2003;13(2):93-7. X-2, X-4, X-6. [pmid: 12671831].
2066 Klima C, Norr K, Vonderheid S, et al. Introduction of CenteringPregnancy in a public health clinic. J Midwifery Womens Health. Jan-Feb. 2009;54(1):27-34. X-7, X-9. [pmid: 19114236].
2067 Klimmek R, Snow D, Wenzel J. Insurance-related and financial challenges reported by managed care enrollees with breast cancer. Clinical Journal of Oncology Nursing. 2010;14(5):598-606. X-2, X-4. [pmid: 20880817].
2068 Kline KN. Cultural sensitivity and health promotion: assessing breast cancer education pamphlets designed for African American women. Health Commun. 2007;21(1):85-96. X-2, X-4. [pmid: 17461755].
2069 Klinnert MD, Liu AH, Pearson MR, et al. Short-term impact of a randomized multifaceted intervention for wheezing infants in low-income families. Arch Pediatr Adolesc Med. Jan. 2005;159(1):75-82. X-9. [pmid: 15630062].
2070 Kloos C, Hagen F, Lindloh C, et al. Cognitive function is not associated with recurrent foot ulcers in patients with diabetes and neuropathy. Diabetes Care. May. 2009;32(5):894-6. X-2, X-4, X-6. [pmid: 19244093].
2071 Klug C, Toobert DJ, Fogerty M. Healthy Changes for living with diabetes: an evidence-based community diabetes self-management program. Diabetes Educ. Nov-Dec. 2008;34(6):1053-61. X-6, X-8, X-9. [pmid: 19075087].
2072 Klymko KW, Artinian NT, Price JE, et al. Self-care production experiences in elderly African Americans with hypertension and cognitive difficulty. J Am Acad Nurse Pract. Apr. 2011;23(4):200-8. X-2, X-4. [pmid: 21489014].
2073 Klymko KW, Artinian NT, Washington OG, et al. Effect of impaired cognition on hypertension outcomes in older urban African Americans. Medsurg Nurs. Dec. 2008;17(6):405-10. X-2, X-4. [pmid: 19248406].
2074 Knapp C. Bronson Methodist Hospital: journey to excellence in quality and safety. Jt Comm J Qual Patient Saf. Oct. 2006;32(10):556-63. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17066993].
2075 Knapp PE, Showers KM, Phipps JC, et al. Self-monitoring of blood glucose with finger tip versus alternative site sampling: effect on glycemic control in insulin-using patients with type 2 diabetes. Diabetes Technol Ther. Apr. 2009;11(4):219-25. X-6, X-7, X-9. [pmid: 19344196].
2076 Knis-Matthews L, Bokara J, DeMeo L, et al. The meaning of higher education for people diagnosed with a mental illness: four students share their experiences. Psychiatr Rehabil J. Fall. 2007;31(2):107-14. X-2, X-3, X-4, X-6. [pmid: 18018954].
2077 Knowlton AR, Latkin CA, Chung S, et al. HIV and depressive symptoms among low-income illicit drug users. AIDS & Behavior. 2000;4(4):353-60. X-2, X-4.
2078 Ko CM, Sadler GR, Ryujin L, et al. Filipina American women's breast cancer knowledge, attitudes, and screening behaviors. BMC Public Health. Aug. 15. 2003;3:27. X-7, X-9. [pmid: 12921541].
2079 Kobayashi S. What caused the decline in breast cancer mortality in the United Kingdom?. Breast Cancer. 2004;11(2):156-9. X-2, X-3, X-4, X-6. [pmid: 15550861].
2080 Koch J. The role of exercise in the African-American woman with type 2 diabetes mellitus: application of the health belief model. J Am Acad Nurse Pract. Mar. 2002;14(3):126-9. X-2, X-4. [pmid: 11924335].
2081 Koch U. IPOS Sutherland Memorial Lecture: Psycho-oncology and health care research. Psycho-Oncology. Jun. 2008;17(6):533-7. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18452235].
2082 Koch-Weser S, Liang SL, Grigg-Saito DC. Self-reported health among Cambodians in Lowell, Massachusetts. J Health Care Poor Underserved. May. 2006;17(2 Suppl):133-45. X-2, X-4, X-5. [pmid: 16809880].
2083 Kocsis JH, Gelenberg AJ, Rothbaum B, et al. Chronic forms of major depression are still undertreated in the 21st century: systematic assessment of 801 patients presenting for treatment. J Affect Disord. Sep. 2008;110(1-2):55-61. X-2, X-4. [pmid: 18272232].
2084 Koenig K. Pilot study of low-income parents' perspectives of managing asthma in high-risk infants and toddlers. Pediatr Nurs. May-Jun. 2007;33(3):223-8. 42. X-2, X-4. [pmid: 17708181].
2085 Koh C, Nelson JM, Cook PF. Evaluation of a Patient Navigation Program. Clinical Journal of Oncology Nursing. Feb. 2011;15(1):41-8. X-4, X-6. [pmid: 21278040].
2086 Koh JC, Koo W. Chinese nutrition educational materials for renal patients. J Ren Nutr. Sep. 2007;17(5):357-9. X-1, X-6, X-7, X-9. [pmid: 17720107].
2087 Kohli HS, Teo PYK, Howie FMC, et al. How accessible is the Breast Screening Assessment Centre for Lanarkshire women?. Health Bulletin. 1995;53(3):153-8. X-2, X-3, X-4, X-6. [pmid: 7615386].
2088 Kokkinos PF, Narayan P, Colleran J, et al. Effects of moderate intensity exercise on serum lipids in African-American men with severe systemic hypertension. Am J Cardiol. Mar. 15. 1998;81(6):732-5. X-4. [pmid: 9527083].
2089 Kokkinos PF, Narayan P, Colleran JA, et al. Effects of regular exercise on blood pressure and left ventricular hypertrophy in African-American men with severe hypertension. N Engl J Med. Nov. 30. 1995;333(22):1462-7. X-4. [pmid: 7477146].
2090 Kolawole BA, Adegbenro C, Adegoke S, et al. Effectiveness of a structured diabetes education program on some non-glycemic endpoints in Nigerians with type 2 diabetes mellitus. Int Q Community Health Educ. 2008;29(4):381-8. X-3, X-6. [pmid: 19959429].
2091 Kolbe J, Vamos M, Fergusson W, et al. Determinants of management errors in acute severe asthma. Thorax. Jan. 1998;53(1):14-20. X-2, X-4, X-6. [pmid: 9577516].
2092 Kong CK, Roslani AC, Law CW, et al. Impact of socio-economic class on colorectal cancer patient outcomes in Kuala Lumpur and Kuching. Malaysia Asian Pac J Cancer Prev. 2010;11(4):969-74. X-2, X-3, X-4. [pmid: 21133609].
2093 Koontz MB, Cuttler L, Palmert MR, et al. Development and validation of a questionnaire to assess carbohydrate and insulin-dosing knowledge in youth with type 1 diabetes. Diabetes Care. Mar. 2010;33(3):457-62. X-2, X-4, X-6. [pmid: 20007940].
2094 Koro CE, L'Italien GJ, Fedder DO. Major CHD risk factors predominate among African-American women who are eligible for lipid-lowering drug therapy under the new ATP III guidelines. Eur J Cardiovasc Prev Rehabil. Oct. 2004;11(5):376-81. X-2, X-4. [pmid: 15616409].
2095 Korsen N, Cartwright C. Developing and disseminating a model to improve depression care in primary care practices. Journal of Clinical Outcomes Management. 2006;13(9):506-11. X-6, X-9.
2096 Kotseva K, Wood D, De Backer G, et al. EUROASPIRE III: a survey on the lifestyle, risk factors and use of cardioprotective drug therapies in coronary patients from 22 European countries. Eur J Cardiovasc Prev Rehabil. Apr. 2009;16(2):121-37. X-2, X-3, X-4, X-6. [pmid: 19287307].
2097 Kountz DS. Strategies for Improving Low Health Literacy. Postgraduate Medicine. Sep. 2009;121(5):171-7. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19820287].
2098 Kovess-Masfety V, Briffault X, Sapinho D. Prevalence, risk factors, and use of health care in depression: a survey in a large region of France between 1991 and 2005. Can J Psychiatry. Oct. 2009;54(10):701-9. X-2, X-3, X-4, X-6. [pmid: 19835677].
2099 Kozhimannil KB, Adams AS, Soumerai SB, et al. New Jersey's efforts to improve postpartum depression care did not change treatment patterns for women on medicaid. Health Aff (Millwood). Feb. 2011;30(2):293-301. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 21289351].
2100 Kraft AD, Quimbo SA, Solon O, et al. The health and cost impact of care delay and the experimental impact of insurance on reducing delays. J Pediatr. Aug. 2009;155(2):281-5 e1. X-7. [pmid: 19394034].
2101 Kralewski JE, Wallace W, Wingert TD, et al. The effects of medical group practice organizational factors on physicians' use of resources. J Healthc Manag. May-Jun. 1999;44(3):167-82. discussion 82-3. X-2, X-4, X-6. [pmid: 10537495].
2102 Kramer MH, Breydo E, Shubina M, et al. Prevalence and factors affecting home blood pressure documentation in routine clinical care: a retrospective study. BMC Health Serv Res. 2010;10:139. X-2, X-4. [pmid: 20504370].
2103 Krass I, Delaney C, Glaubitz S, et al. Measuring patient satisfaction with diabetes disease state management services in community pharmacy. Res Social Adm Pharm. Mar. 2009;5(1):31-9. X-2, X-6. [pmid: 19285287].
2104 Kratzke C, Garzon L, Lombard J, et al. Training community health workers: factors that influence mammography use. J Community Health. Dec. 2010;35(6):683-8. X-2, X-4. [pmid: 20411410].
2105 Krein SL, Heisler M, Piette JD, et al. The effect of chronic pain on diabetes patients' self-management. Diabetes Care. Jan. 2005;28(1):65-70. X-2, X-4, X-6. [pmid: 15616235].
2106 Kreitler S, Weissler K, Nurymberg K. The cognitive orientation of patients with type 2 diabetes in Israel. Patient Educ Couns. Jun. 2004;53(3):257-67. X-2, X-3, X-4, X-6. [pmid: 15186862].
2107 Krespi R, Bone M, Ahmad R, et al. Haemodialysis patients' beliefs about renal failure and its treatment. Patient Educ Couns. May. 2004;53(2):189-96. X-2, X-4, X-6. [pmid: 15140459].
2108 Kreuter MW, Alcaraz KI, Pfeiffer D, et al. Using dissemination research to identify optimal community settings for tailored breast cancer information kiosks. J Public Health Manag Pract. Mar-Apr. 2008;14(2):160-9. X-7, X-9. [pmid: 18287923].
2109 Kreuter MW, Holmes K, Alcaraz K, et al. Comparing narrative and informational videos to increase mammography in low-income African American women. Patient Educ Couns. Dec. 2010;81(Suppl):S6. 14. X-3, X-4, X-9. [pmid: 21071167].
2110 Kreuter MW, Lukwago SN, Bucholtz RD, et al. Achieving cultural appropriateness in health promotion programs: targeted and tailored approaches. Health Educ Behav. Apr. 2003;30(2):133-46. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12693519].
2111 Kreuter MW, Sugg-Skinner C, Holt CL, et al. Cultural tailoring for mammography and fruit and vegetable intake among low-income African-American women in urban public health centers. Prev Med. Jul. 2005;41(1):53-62. X-9. [pmid: 15916993].
2112 Krieger J, Collier C, Song L, et al. Linking community-based blood pressure measurement to clinical care: a randomized controlled trial of outreach and tracking by community health workers. Am J Public Health. Jun. 1999;89(6):856-61. X-6, X-9. [pmid: 10358675].
2113 Krieger J, Takaro TK, Song L, et al. A randomized controlled trial of asthma self-management support comparing clinic-based nurses and in-home community health workers: the Seattle-King County Healthy Homes II Project. Arch Pediatr Adolesc Med. Feb. 2009;163(2):141-9. X-9. [pmid: 19188646].
2114 Krieger JK, Takaro TK, Allen C, et al. The Seattle-King County healthy homes project: implementation of a comprehensive approach to improving indoor environmental quality for low-income children with asthma. Environ Health Perspect. Apr. Suppl 2. 2002;110:311-22. X-1, X-9. [pmid: 11929743].
2115 Krieger JW, Takaro TK, Song L, et al. The Seattle-King County Healthy Homes Project: a randomized, controlled trial of a community health worker intervention to decrease exposure to indoor asthma triggers. Am J Public Health. Apr. 2005;95(4):652-9. X-7, X-9. [pmid: 15798126].
2116 Kripalani S, Gatti ME, Jacobson TA. Association of age, health literacy, and medication management strategies with cardiovascular medication adherence. Patient Education and Counseling. Nov. 2010;81(2):177-81. X-2, X-4. [pmid: 20684870].
2117 Kripalani S, Henderson LE, Chiu EY, et al. Predictors of medication self-management skill in a low-literacy population. Journal of General Internal Medicine. Aug. 2006;21(8):852-6. X-2, X-4. [pmid: 16881946].
2118 Kripalani S, Jacobson TA, Mugalla IC, et al. Health Literacy and the Quality of Physician-Patient Communication During Hospitalization. Journal of Hospital Medicine. May-Jun. 2010;5(5):269-75. X-2, X-4. [pmid: 20533572].
2119 Krishnakumar A, Webster JD, Lumeng J, et al. Healthy Eating and Harambee : Curriculum Development for a Culturally-Centered Bio-Medically Oriented Nutrition Education Program to Reach African American Women of Childbearing Age. Maternal and Child Health Journal. 2010;14(4):535-47. X-5. [pmid: 19655237].
2120 Krishnan JA, Diette GB, Skinner EA, et al. Race and sex differences in consistency of care with national asthma guidelines in managed care organizations. Arch Intern Med. Jul. 9. 2001;161(13):1660-8. X-2, X-4. [pmid: 11434799].
2121 Krist AH, Jones RM, Woolf SH, et al. Timing of repeat colonoscopy: disparity between guidelines and endoscopists' recommendation. Am J Prev Med. Dec. 2007;33(6):471-8. X-2, X-4, X-6. [pmid: 18022063].
2122 Kristofco RE, Stewart AJ, Vega W. Perspectives on disparities in depression care. J Contin Educ Health Prof. Fall. Suppl 1. 2007;27:S18-25. X-1, X-2, X-3, X-4, X-6. [pmid: 18085576].
2123 Kronmuller KT, Saha R, Karr M, et al. Psychosocial factors associated with knowledge about affective disorders in patients with depression. Psychopathology. 2006;39(3):105-12. X-2, X-4, X-6. [pmid: 16531684].
2124 Krueger L. Experiences of Hmong patients on hemodialysis and the nurses working with them. Nephrol Nurs J. Jul-Aug. 2009;36(4):379-87. X-2, X-4. [pmid: 19715106].
2125 Krug A, Pattinson RC, Power DJ. Why children die: an under-5 health care survey in Mafikeng region. S Afr Med J. Mar. 2004;94(3):202-6. X-2, X-3, X-4, X-5, X-6. [pmid: 15098281].
2126 Kuerbis AN, Neighbors CJ, Morgenstern J. Depression's moderation of the effectiveness of intensive case management with substance-dependent women on temporary assistance for needy families: outpatient substance use disorder treatment utilization and outcomes. J Stud Alcohol Drugs. Mar. 2011;72(2):297-307. X-2, X-4. [pmid: 21388603].
2127 Kuhn D, Edelman P, Fulton BR. Daytime sleep and the threat to well-being of persons with dementia. Dementia. (14713012). 2005;4(2):233-47. X-2, X-4, X-5, X-6.
2128 Kumanyika SK. Can hypertension be prevented? Applications of risk modifications in black populations: U.S. populations. Ethn Dis. Winter. 1997;7(1):72-7. X-1, X-6, X-7, X-9. [pmid: 9253558].
2129 Kumanyika SK, Adams-Campbell L, Van Horn B, et al. Outcomes of a cardiovascular nutrition counseling program in African-Americans with elevated blood pressure or cholesterol level. J Am Diet Assoc. Nov. 1999;99(11):1380-91. X-9. [pmid: 10570675].
2130 Kumanyika SK, Charleston JB. Lose weight and win: a church-based weight loss program for blood pressure control among black women. Patient Educ Couns. Feb. 1992;19(1):19-32. X-7, X-8. [pmid: 1298945].
2131 Kumanyika SK, Cook NR, Cutler JA, et al. Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention Phase II. J Hum Hypertens. Jan. 2005;19(1):33-45. X-7, X-9. [pmid: 15372064].
2132 Kumar A, Ciccarese P, Quaglini S, et al. Relating UMLS semantic types and task-based ontology to computer-interpretable clinical practice guidelines. Stud Health Technol Inform. 2003;95:469-74. X-2, X-3, X-4, X-5, X-6. [pmid: 14664031].
2133 Kuo S, Fleming BB, Gittings NS, et al. Trends in care practices and outcomes among Medicare beneficiaries with diabetes. Am J Prev Med. Dec. 2005;29(5):396-403. X-2, X-4. [pmid: 16376702].
2134 Kuo YF, Raji MA, Markides KS, et al. Inconsistent use of diabetes medications, diabetes complications, and mortality in older mexican americans over a 7-year period: data from the Hispanic established population for the epidemiologic study of the elderly. Diabetes Care. Nov. 2003;26(11):3054-60. X-2, X-4. [pmid: 14578239].
2135 Kureshi J, Rocke AD, Tariq AQ. Perioperative knowledge and anxiety score of patients undergoing surgery. Middle East J Anesthesiol. Oct. 1995;13(3):325-33. X-2, X-3, X-4, X-5, X-6. [pmid: 8849988].
2136 Kurian AK, Borders TF. Racial and ethnic differences in the effects of regular providers and self-management education on diabetes preventive care. Ethn Dis. Autumn. 2006;16(4):786-91. X-2, X-4. [pmid: 17061728].
2137 Kurlan R, Richard IH, Deeley C. Medication tolerance and augmentation in restless legs syndrome: the need for drug class rotation. J Gen Intern Med. Dec. 2006;21(12):C1-4. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17105517].
2138 Kuschner WG, Hankinson TC, Wong HH, et al. Nonprescription bronchodilator medication use in asthma. Chest. Oct. 1997;112(4):987-93. X-2, X-4. [pmid: 9377963].
2139 Kusec S, Brborovic O, Schillinger D. Diabetes websites accredited by the Health On the Net Foundation Code of Conduct: readable or not?. Stud Health Technol Inform. 2003;95:655-60. X-2, X-3, X-4, X-6. [pmid: 14664062].
2140 Kusumoto L, Marques S, Haas VJ, et al. Adults and elderly on hemodialysis evaluation of health related quality of life…World Congress of Nephrology Nursing, Sao Paulo, April 22 to April 25, 2007. Acta Paulista de Enfermagem. 2008;21:152-9. X-2, X-3, X-4, X-6.
2141 Kutner N, Bowles T, Zhang R, et al. Dialysis facility characteristics and variation in employment rates: a national study. Clin J Am Soc Nephrol. Jan. 2008;3(1):111-6. X-2, X-4. [pmid: 18178781].
2142 Kwong KY, Morphew T, Huynh P, et al. Loss of asthma control in inner city children with asthma after withdraw of asthma controller medication. J Asthma. Dec. 2009;46(10):1001-5. X-2, X-7. [pmid: 19995137].
2143 La Roche MJ, Koinis-Mitchell D, Gualdron L. A culturally competent asthma management intervention: a randomized controlled pilot study. Ann Allergy Asthma Immunol. Jan. 2006;96(1):80-5. X-4. [pmid: 16440537].
2144 Labbate LA, Croft HA, Oleshansky MA. Antidepressant-related erectile dysfunction: Management via avoidance, switching antidepressants, antidotes, and adaptation. Journal of Clinical Psychiatry. 2003;64:11-9. X-1, X-2, X-3, X-4, X-6. [pmid: 12971811].
2145 Lacey EA, Kalsi GS, Macintosh MJ. Mixed method evaluation of an innovation to improve secondary prevention of coronary heart disease in primary care. Quality in Primary Care. 2004;12(4):259-65. X-6, X-9.
2146 Lacey EA, Musgrave RJ, Freeman JV, et al. Psychological morbidity after myocardial infarction in an area of deprivation in the UK: evaluation of a self-help package. Eur J Cardiovasc Nurs. Sep. 2004;3(3):219-24. X-3, X-6. [pmid: 15350231].
2147 Lacey L, Whitfield J, DeWhite W, et al. Referral adherence in an inner city breast and cervical cancer screening program. Cancer. Aug. 1. 1993;72(3):950-5. X-4. [pmid: 8334648].
2148 Lacey LP, Phillips CW, Ansell D, et al. An urban community-based cancer prevention screening and health education intervention in Chicago. Public Health Rep. Nov-Dec. 1989;104(6):536-41. X-1, X-6, X-7, X-9. [pmid: 2511585].
2149 Lachaine J, Petrella RJ, Merikle E, et al. Choices, persistence and adherence to antihypertensive agents: evidence from RAMQ data. Can J Cardiol. Apr. 2008;24(4):269-73. X-2, X-3, X-4. [pmid: 18401466].
2150 Laditka JN, Laditka SS. Race, ethnicity and hospitalization for six chronic ambulatory care sensitive conditions in the USA. Ethnicity & Health. 2006;11(3):247-63. X-2, X-4. [pmid: 16774877].
2151 Lagerveld SE, Blonk RWB, Brenninkmeijer V, et al. Return to work among employees with mental health problems: development and validation of a self-efficacy questionnaire. Work & Stress. 2010;24(4):359-75. X-2, X-5, X-6.
2152 Lagomasino IT, Dwight-Johnson M, Miranda J, et al. Disparities in depression treatment for Latinos and site of care. Psychiatr Serv. Dec. 2005;56(12):1517-23. X-2, X-4. [pmid: 16339612].
2153 Lai KQ, Nguyen TT, Mock J, et al. Increasing Vietnamese-American physicians' knowledge of cervical cancer and Pap testing: impact of continuing medical education programs. Ethn Dis. Summer. 2004;14(3 Suppl 1):S122-7. X-2, X-4, X-5. [pmid: 15682781].
2154 Lai LL. Community pharmacy-based hypertension disease-management program in a Latino/Hispanic-American population. Consult Pharm. May. 2007;22(5):411-6. X-4, X-8. [pmid: 17658958].
2155 Lai TY, Larson EL, Rockoff ML, et al. User acceptance of HIV TIDES--Tailored Interventions for Management of Depressive Symptoms in persons living with HIV/AIDS. J Am Med Inform Assoc. Mar-Apr. 2008;15(2):217-26. X-4, X-5, X-6. [pmid: 18096915].
2156 Lairson DR, Chan W, Newmark GR. Determinants of the demand for breast cancer screening among women veterans in the United States. Social Science & Medicine. Special Issue: Building trust and value in health systems in low- and middle-income countries. Oct. 2005;61(7):1608-17. X-2, X-4, X-6. [pmid: 16005790].
2157 Lakshminarayan K, Tsai AW, Tong X, et al. Utility of dysphagia screening results in predicting poststroke pneumonia. Stroke. Dec. 2010;41(12):2849-54. X-2, X-4, X-5, X-6. [pmid: 20947835].
2158 Lam TK, McPhee SJ, Mock J, et al. Encouraging Vietnamese-American women to obtain Pap tests through lay health worker outreach and media education. J Gen Intern Med. Jul. 2003;18(7):516-24. X-5. [pmid: 12848834].
2159 Lamers F, Jonkers CC, Bosma H, et al. Treating depression in diabetes patients: does a nurse-administered minimal psychological intervention affect diabetes-specific quality of life and glycaemic control? A randomized controlled trial. J Adv Nurs. Apr. 2011;67(4):788-99. X-3, X-6. [pmid: 21226754].
2160 Landis SE, Hulkower SD, Pierson S. Enhancing adherence with mammography through patient letters and physician prompts. A pilot study. N C Med J. Nov. 1992;53(11):575-8. X-4, X-6, X-9. [pmid: 1436150].
2161 Landon BE, Hicks LS, O'Malley AJ, et al. Improving the management of chronic disease at community health centers. N Engl J Med. Mar. 1. 2007;356(9):921-34. X-9. [pmid: 17329699].
2162 Landry SH, Smith KE, Swank PR. Responsive parenting: Establishing early foundations for social, communication, and independent problem-solving skills. Developmental Psychology. Jul. 2006;42(4):627-42. X-5. [pmid: 16802896].
2163 Lang DM, Sherman MS, Polansky M. Guidelines and realities of asthma management. The Philadelphia story. Arch Intern Med. Jun. 9. 1997;157(11):1193-200. X-2, X-4. [pmid: 9183230].
2164 Lange J, Evans-Benard S, Cooper J, et al. Puerto Rican women's perceptions of heart disease risk. Clin Nurs Res. Nov. 2009;18(4):291-306. X-2, X-4. [pmid: 19741240].
2165 Langhofer S, LaMunyon C. Do you know what condition your ‘conditions’ are in?. Nephrol News Issues. Sep. 2008;22(10):56-7. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18814559].
2166 Lansdorp-Vogelaar I, van Ballegooijen M, Zauber AG, et al. Individualizing colonoscopy screening by sex and race. Gastrointest Endosc. Jul. 2009;70(1):96-108. e1. 24. X-2, X-3. [pmid: 19467539].
2167 Lanting LC, Joung IMA, Vogel I, et al. Ethnic differences in outcomes of diabetes care and the role of self-management behavior. Patient Education and Counseling. Jul. 2008;72(1):146-54. X-2, X-3, X-4. [pmid: 18455354].
2168 Lantz PM, Richardson LC, Macklem DJ, et al. Strategies for follow-up and treatment services in state breast and cervical cancer screening programs. Womens Health Issues. Jan-Feb. 1999;9(1):42-9. X-6, X-7, X-9. [pmid: 9949695].
2169 Lantz PM, Stencil D, Lippert MT, et al. Breast and cervical cancer screening in a low-income managed care sample: the efficacy of physician letters and phone calls. Am J Public Health. Jun. 1995;85(6):834-6. X-9. [pmid: 7646664].
2170 Lantz PM, Stencil D, Lippert MT, et al. Implementation issues and costs associated with a proven strategy for increasing breast and cervical cancer screening among low-income women. J Public Health Manag Pract. Summer. 1996;2(3):54-9. X-2, X-4, X-6. [pmid: 10186680].
2171 Lappalainen R, Koikkalainen M, Julkunen J, et al. Association of sociodemographic factors with barriers reported by patients receiving nutrition counseling as part of cardiac rehabilitation. J Am Diet Assoc. Sep. 1998;98(9):1026-9. X-6, X-7, X-9. [pmid: 9739805].
2172 Lara M, Sherbourne C, Duan NH, et al. An English and Spanish pediatric asthma symptom scale. Medical Care. Mar. 2000;38(3):342-50. X-2, X-4. [pmid: 10718359].
2173 Lara MA, Navarro C, Rubi NA, et al. Two levels of intervention in low-income women with depressive symptoms: compliance and programme assessment. Int J Soc Psychiatry. Mar. 2003;49(1):43-57. X-4. [pmid: 12793515].
2174 Larkey L. Las mujeres saludables: reaching Latinas for breast, cervical and colorectal cancer prevention and screening. J Community Health. Feb. 2006;31(1):69-77. X-4, X-8. [pmid: 16482767].
2175 Larkey LK, Gonzalez J. Storytelling for promoting colorectal cancer prevention and early detection among Latinos. Patient Educ Couns. Aug. 2007;67(3):272-8. X-4. [pmid: 17524595].
2176 Larkey LK, Lopez AM, Minnal A, et al. Storytelling for promoting colorectal cancer screening among underserved Latina women: a randomized pilot study. Cancer Control. Jan. 2009;16(1):79-87. X-4. [pmid: 19078934].
2177 Larme AC, Pugh JA. Evidence-based guidelines meet the real world: the case of diabetes care. Diabetes Care. Oct. 2001;24(10):1728-33. X-2, X-4. [pmid: 11574433].
2178 Laroche HH, Davis MM, Forman J, et al. Children's roles in parents' diabetes self-management. Am J Prev Med. Dec. 2009;37(6 Suppl 1):S251-61. X-2, X-4. [pmid: 19896027].
2179 Laron Z. Psycho-social problems of diabetic children and adolescents. Acta Diabetol Lat. Jan-Mar. 1984;21(1):35-46. X-2, X-3, X-4, X-6. [pmid: 6730846].
2180 Larson LS, Wittrock DA, Sandgren AK. When a child is diagnosed with cancer: I. Sex differences in parental adjustment. Journal of Psychosocial Oncology. 1994;12(1/2):123-42. X-2, X-4, X-5.
2181 LaRue EM. Development and evaluation of SPAT: a web page assessment tool. Library Hi Tech. 2008;26(2):274-86. X-2, X-3, X-4, X-6.
2182 Lasater LM, Davidson AJ, Steiner JF, et al. Glycemic control in English- vs Spanish-speaking Hispanic patients with type 2 diabetes mellitus. Arch Intern Med. Jan. 8. 2001;161(1):77-82. X-2. [pmid: 11146701].
2183 Latham CL, Calvillo E. A health protection model for Hispanic adults with Type 2 diabetes. Journal of Clinical Nursing. Jul. 2007;16(7B):186-96. X-1, X-2, X-3, X-4. [pmid: 17584428].
2184 Latham CL, Calvillo E. Predictors of Successful Diabetes Management in Low-Income Hispanic People. Western Journal of Nursing Research. Apr. 2009;31(3):364-88. X-2, X-4. [pmid: 19261804].
2185 Lau DS, Lee G, Wong CC, et al. Characterization of systemic hypertension in the San Francisco Chinese community. Am J Cardiol. Aug. 15. 2005;96(4):570-3. X-2, X-4. [pmid: 16098313].
2186 Laughon K. Abused African American women's processes of staying healthy. West J Nurs Res. Apr. 2007;29(3):365-84. discussion 85-94. X-2, X-4, X-5. [pmid: 17420525].
2187 Laughon K, Gielen AC, Campbell JC, et al. The relationships among sexually transmitted infection, depression, and lifetime violence in a sample of predominantly African American women. Res Nurs Health. Aug. 2007;30(4):413-28. X-2, X-4, X-5. [pmid: 17654476].
2188 Lauver DR, Kane J. A motivational message, external barriers, and mammography utilization. Cancer Detect Prev. 1999;23(3):254-64. X-7, X-9. [pmid: 10337005].
2189 Lave JR, Peele PB, Xu Y, et al. An exploratory analysis of behavioral health care use within families. Psychiatr Serv. Jun. 2002;53(6):743-8. X-2, X-4. [pmid: 12045313].
2190 Lavin M, Hyde A. Sexuality as an aspect of nursing care for women receiving chemotherapy for breast cancer in an Irish context. Eur J Oncol Nurs. Feb. 2006;10(1):10-8. X-2, X-3, X-4, X-6. [pmid: 15908273].
2191 Lavis SJ. Perinatal mortality--ways of reducing the rate. Midwives Chron. Sep. 1983;96(1148):302-5. X-1, X-6, X-7, X-9. [pmid: 6557347].
2192 LaVonna Blair L, Lark GG, Gwendolyn F, et al. Transforming the Urban Food Desert From the Grassroots Up: A Model for Community Change. Family and Community Health. 2011;34(1S):S92. X-1, X-2, X-4, X-5. [pmid: 21160336].
2193 Lawlor E, Breslin JG, Renwick L, et al. Mental health literacy among Internet users. Early Interv Psychiatry. Nov. 2008;2(4):247-55. X-2, X-3, X-4, X-5, X-6. [pmid: 21352158].
2194 Lawrence SA, Lawrence RM. Helping patients cope with the stress of myocardial infarction. Nurs Forum. 1987;23(3):92-100. X-1, X-2, X-3, X-4, X-6. [pmid: 3509710].
2195 Lawson HW, Henson R, Bobo JK, et al. Implementing recommendations for the early detection of breast and cervical cancer among low-income women. MMWR Recomm Rep. Mar. 31. 2000;49(RR-2):37-55. X-1, X-2, X-4. [pmid: 15580731].
2196 Lazear KJ, Pires SA, Isaacs MR, et al. Depression among Low-Income Women of Color: Qualitative Findings from Cross-Cultural Focus Groups. Journal of Immigrant and Minority Health. Apr. 2008;10(2):127-33. X-2, X-4. [pmid: 18236157].
2197 Leahy J. A return to hope. Minn Med. Oct. 2008;91(10):32-3. X-1, X-6, X-7, X-9. [pmid: 18991011].
2198 Leaman H, Jackson PR. What benefit do patients expect from adding second and third antihypertensive drugs?. Br J Clin Pharmacol. Jan. 2002;53(1):93-9. X-2, X-4, X-6. [pmid: 11849200].
2199 Leas BF, Berman B, Kash KM, et al. Quality measurement in diabetes care. Population Health Management. Oct. 2009;12(5):265-71. X-2, X-3, X-4, X-6. [pmid: 19848568].
2200 Lebeau M, Mathoulin-Pelissier S, Bellera C, et al. Breast cancer care compared with clinical Guidelines: an observational study in France. BMC Public Health. 2011;11:45. X-2, X-3, X-4, X-6. [pmid: 21251274].
2201 Lee ACK, Tang SW, Leung SSK, et al. Depression literacy among Chinese stroke survivors. Aging & Mental Health. 2009;13(3):349-56. X-2, X-4. [pmid: 19484598].
2202 Lee CS, Hayes RB, McQuaid EL, et al. Predictors of retention in smoking cessation treatment among Latino smokers in the Northeast United States. Health Educ Res. Aug. 2010;25(4):687-97. X-2, X-4. [pmid: 20237106].
2203 Lee CS, Shiu AT. Perceived health care climate, diabetes knowledge and self-care practice of Hong Kong Chinese older patients: a pilot study. J Clin Nurs. May. 2004;13(4):534-5. X-3, X-6. [pmid: 15086640].
2204 Lee E, Mitchell-Herzfeld SD, Lowenfels AA, et al. Reducing low birth weight through home visitation: a randomized controlled trial. Am J Prev Med. Feb. 2009;36(2):154-60. X-9. [pmid: 19135906].
2205 Lee EJ, Parker V, DuBose L, et al. Demands and resources: parents of school-age children with asthma. J Pediatr Nurs. Dec. 2006;21(6):425-33. X-2, X-4. [pmid: 17101400].
2206 Lee GR, DeMaris A. Widowhood, gender, and depression: a longitudinal analysis. Research on Aging. 2007;29(1):56-72. X-2, X-4.
2207 Lee HY, Lytle K, Yang PN, et al. Mental health literacy in Hmong and Cambodian elderly refugees: a barrier to understanding, recognizing, and responding to depression. Int J Aging Hum Dev. 2010;71(4):323-44. X-2, X-4. [pmid: 21261138].
2208 Lee JE, Han HR, Song H, et al. Correlates of self-care behaviors for managing hypertension among Korean Americans: a questionnaire survey. Int J Nurs Stud. Apr. 2010;47(4):411-7. X-2, X-4. [pmid: 19863959].
2209 Lee KKA, Bose A, McCrimmon R. Treatment of hypertension and hypercholesterolaemia: audit. Diabetes & Primary Care. 2002;3(4):105-9. X-2, X-6.
2210 Lee R, Onopa J, Mau MK, et al. Diabetes care in a predominantly Native Hawaiian and Pacific Islander outpatient population. Hawaii Med J. May. 2010;69(5 Suppl 2):28-30. X-2, X-4. [pmid: 20544607].
2211 Lee S, Brunero S, Fairbrother G, et al. Profiling police presentations of mental health consumers to an emergency department. Int J Ment Health Nurs. Oct. 2008;17(5):311-6. X-2, X-3, X-4, X-5, X-6. [pmid: 18789040].
2212 Lee S, Wing YK, Wong KC. Knowledge and compliance towards lithium therapy among Chinese psychiatric patients in Hong Kong. Aust N Z J Psychiatry. Sep. 1992;26(3):444-9. X-2, X-3, X-4, X-5, X-6. [pmid: 1417630].
2213 Lee SK, Penner PL, Cox M. Impact of very low birth weight infants on the family and its relationship to parental attitudes. Pediatrics. Jul. 1991;88(1):105-9. X-2, X-3, X-4. [pmid: 2057246].
2214 Lee SYD, Gazmararian JA, Arozullah AM. Health literacy and social support among elderly Medicare enrollees in a managed care plan. Journal of Applied Gerontology. Aug. 2006;25(4):324-37. X-2, X-4, X-5.
2215 Lee Y, Kim H. Relationships between menopausal symptoms, depression, and exercise in middle-aged women: a cross-sectional survey. Int J Nurs Stud. Dec. 2008;45(12):1816-22. X-2, X-3, X-4, X-6. [pmid: 18692187].
2216 Lee YS. Awareness of blood pressure among older adults: a cross-sectional descriptive study. Int J Nurs Stud. Jul. 2007;44(5):796-804. X-2, X-4, X-6. [pmid: 16569407].
2217 Leenakul R, Boontong T, Phancharoenworakul K, et al. Development of nursing case management model for patients with myocardial infarction. Thai Journal of Nursing Research. 2006;10(2):120-32. X-2, X-4, X-6.
2218 Lefler LL, Nuss RL. Double jeopardy! Heart disease risk factors for older African American and Caucasian women. Medsurg Nurs. Nov-Dec. 2009;18(6):347-54. X-1, X-2, X-4. [pmid: 20088188].
2219 Legler J, Meissner HI, Coyne C, et al. The effectiveness of interventions to promote mammography among women with historically lower rates of screening. Cancer Epidemiol Biomarkers Prev. Jan. 2002;11(1):59-71. X-1, X-2, X-4. [pmid: 11815402].
2220 Legorreta AP, Leung KM, Berkbigler D, et al. Outcomes of a population-based asthma management program: quality of life, absenteeism, and utilization. Ann Allergy Asthma Immunol. Jul. 2000;85(1):28-34. X-6, X-7, X-9. [pmid: 10923601].
2221 Lehmann CA, Mintz N, Giacini JM. Impact of Telehealth on Healthcare Utilization by Congestive Heart Failure Patients. Disease Management & Health Outcomes. 2006;14(3):163-9. X-4, X-6.
2222 Lehti A, Hammarstrom A, Mattsson B. Recognition of depression in people of different cultures: a qualitative study. BMC Fam Pract. 2009;10:53. X-2, X-3, X-4. [pmid: 19635159].
2223 Leickly FE, Wade SL, Crain E, et al. Self-reported adherence, management behavior, and barriers to care after an emergency department visit by inner city children with asthma. Pediatrics. May. 1998;101(5):E8. X-2, X-4. [pmid: 9565441].
2224 Leiferman J. The effect of maternal depressive symptomatology on maternal behaviors associated with child health. Health Education & Behavior. Oct. 2002;29(5):596-607. X-2, X-4. [pmid: 12238703].
2225 Leikauf J, Federman AD. Comparisons of Self-Reported and Chart-Identified Chronic Diseases in Inner-City Seniors. Journal of the American Geriatrics Society. Jul. 2009;57(7):1219-25. X-2, X-4, X-6. [pmid: 19486197].
2226 Leino EV, Kisch J. Correlates and predictors of depression in college students: results from the Spring 2000 National College Health Assessment. American Journal of Health Education. 2005;36(2):66. X-2, X-4.
2227 Lemus FC, Tan A, Eschbach K, et al. Correlates of bacterial pneumonia hospitalizations in elders, Texas border. J Immigr Minor Health. Aug. 2010;12(4):423-32. X-2, X-4, X-6. [pmid: 19294512].
2228 Lenaway D, Koepsell TD, Vaughan T, et al. Evaluation of a public-private certified nurse-midwife maternity program for indigent women. Am J Public Health. Apr. 1998;88(4):675-9. X-9. [pmid: 9551018].
2229 Lennon-Dearing R, Florence J, Garrett L, et al. A rural community-based interdisciplinary curriculum: a social work perspective. Soc Work Health Care. 2008;47(2):93-107. X-1, X-2, X-4, X-5, X-6. [pmid: 18956502].
2230 Lentine KL, Schnitzler MA, Brennan DC, et al. Cardiac evaluation before kidney transplantation: a practice patterns analysis in Medicare-insured dialysis patients. Clin J Am Soc Nephrol. Jul. 2008;3(4):1115-24. X-2, X-4. [pmid: 18417743].
2231 Lenz ER, Mundinger MO, Kane RL, et al. Primary care outcomes in patients treated by nurse practitioners or physicians: two-year follow-up. Med Care Res Rev. Sep. 2004;61(3):332-51. X-5, X-6. [pmid: 15358970].
2232 Lenz O, Mekala DP, Patel DV, et al. Barriers to successful care for chronic kidney disease. BMC Nephrol. 2005;6:11. X-2, X-4, X-6. [pmid: 16250919].
2233 Leonard BJ, Jang YP, Savik K, et al. Psychosocial factors associated with levels of metabolic control in youth with type 1 diabetes. J Pediatr Nurs. Feb. 2002;17(1):28-37. X-2, X-4, X-6. [pmid: 11891492].
2234 Leone LA, James AS, Allicock M, et al. Obesity predicts differential response to cancer prevention interventions among African Americans. Health Education & Behavior. Dec. 2010;37(6):913-25. X-9. [pmid: 20713987].
2235 Lerman C, Hughes C, Benkendorf JL, et al. Racial differences in testing motivation and psychological distress following pretest education for BRCA1 gene testing. Cancer Epidemiol Biomarkers Prev. Apr. 1999;8(4 Pt 2):361-7. X-6, X-7, X-9. [pmid: 10207641].
2236 Lerman C, Hughes C, Trock BJ, et al. Genetic testing in families with hereditary nonpolyposis colon cancer. JAMA. May. 5. 1999;281(17):1618-22. X-2, X-4, X-6, X-8. [pmid: 10235155].
2237 Lerman C, Rimer BK, Daly M, et al. Recruiting high risk women into a breast cancer health promotion trial. Cancer Epidemiol Biomarkers Prev. Apr-May. 1994;3(3):271-6. X-2, X-4. [pmid: 8019378].
2238 Lerman C, Schwartz MD, Miller SM, et al. A randomized trial of breast cancer risk counseling: interacting effects of counseling, educational level, and coping style. Health Psychol. Mar. 1996;15(2):75-83. X-6, X-9. [pmid: 8681923].
2239 Lerman CE, Brody DS, Hui T, et al. Identifying hypertensive patients with elevated systolic workplace blood pressures. Am J Hypertens. Jul. 1990;3(7):544-8. X-2, X-4, X-6. [pmid: 2363893].
2240 Lerman I, Diaz JP, Ibarguengoitia ME, et al. Nonadherence to insulin therapy in low-income, type 2 diabetic patients. Endocr Pract. Jan-Feb. 2009;15(1):41-6. X-2, X-2, X-4. [pmid: 19211396].
2241 Leroyer C, Lebrun T, Proust A, et al. Knowledge, self-management, compliance and quality of life in asthma: a cross-sectional study of the French version of the Asthma Quality of Life Questionnaire. Qual Life Res. Apr. 1998;7(3):267-72. X-2, X-3, X-4, X-6. [pmid: 9584557].
2242 Lesley ML. Social problem solving training for African Americans: effects on dietary problem solving skill and DASH diet-related behavior change. Patient Educ Couns. Jan. 2007;65(1):137-46. X-4. [pmid: 16950591].
2243 Leslie NS, Deiriggi P, Gross S, et al. Knowledge, attitudes, and practices surrounding breast cancer screening in educated Appalachian women. Oncol Nurs Forum. Jul-Aug. 2003;30(4):659-67. X-2, X-4, X-6. [pmid: 12861325].
2244 Less LA, Ragoobirsingh D, Morrison EY, et al. A preliminary report on an assessment of a community-based intervention for diabetes control in adults with type 2 diabetes. Fam Pract. Jun. Suppl 1. 2010;27:i46-52. X-3, X-6. [pmid: 19965903].
2245 Lesser I, Rosales A, Zisook S, et al. Depression outcomes of Spanish- and english-speaking Hispanic outpatients in STAR*D. Psychiatr Serv. Nov. 2008;59(11):1273-84. X-2, X-7. [pmid: 18971403].
2246 Letourneau NL, Fedick CB, Willms JD. Mothering and domestic violence: a longitudinal analysis. Journal of Family Violence. 2007;22(8):649-59. X-2, X-3, X-4, X-5, X-6.
2247 Leung WC, Tregoning D, Farrer M. An audit on access to coronary artery surgery within a health district using New Zealand priority criteria as a benchmark. Public Health. Jan. 1999;113(1):13-7. X-2, X-3, X-4, X-6. [pmid: 10823743].
2248 Leventhal W, Ascanio R. Recognizing and overcoming barriers to colorectal screening in primary care. J S C Med Assoc. Feb. 2008;104(2):25-8. X-1, X-6, X-7, X-9. [pmid: 18396599].
2249 Levetan CS, Dawn KR, Robbins DC, et al. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. Jan. 2002;25(1):2-8. X-6. [pmid: 11772893].
2250 Levine DM, Bone LR, Hill MN, et al. The effectiveness of a community/academic health center partnership in decreasing the level of blood pressure in an urban African-American population. Ethn Dis. Summer. 2003;13(3):354-61. X-3, X-9. [pmid: 12894960].
2251 Levin-Scherz J, DeVita N, Timbie J. Impact of pay-for-performance contracts and network registry on diabetes and asthma HEDIS measures in an integrated delivery network. Med Care Res Rev. Feb. 2006;63(1 Suppl):14S-28S. X-2, X-4, X-6, X-7. [pmid: 16688922].
2252 Levinsky NG, Rettig RA. The Medicare end-stage renal disease program A report from the Institute of Medicine. N Engl J Med. Apr. 18. 1991;324(16):1143-8. X-1, X-2, X-4. [pmid: 2008193].
2253 Levin-Zamir D, Peterburg Y. Health literacy in health systems: perspectives on patient self-management in Israel. Health Promot Int. Mar. 2001;16(1):87-94. X-1, X-2, X-3, X-4, X-5. [pmid: 11257858].
2254 Leviton LC, Goldenberg RL, Baker CS, et al. Methods to encourage the use of antenatal corticosteroid therapy for fetal maturation: a randomized controlled trial. JAMA. Jan. 6. 1999;281(1):46-52. X-6. [pmid: 9892450].
2255 Levitt NS, Zwarenstein MF, Doepfmer S, et al. Public sector primary care of diabetics--a record review of quality of care in Cape Town. S Afr Med J. Aug. 1996;86(8 Suppl):1013-7. X-2, X-3, X-4, X-6. [pmid: 9180772].
2256 Levy C, Carter S, Priloutskaya G, et al. Critical elements in the design of culturally appropriate interventions intended to reduce health disparities: immunization rates among Hispanic seniors in New Mexico. J Health Hum Serv Adm. Fall. 2003;26(2):199-238. X-1, X-2, X-4. [pmid: 15330490].
2257 Levy M, Ferrand P, Chirat V. SESAM-DIABETE, an expert system for insulin-requiring diabetic patient education. Comput Biomed Res. Oct. 1989;22(5):442-53. X-1, X-2, X-3, X-4, X-6. [pmid: 2776447].
2258 Levy M, Heffner B, Stewart T, et al. The efficacy of asthma case management in an urban school district in reducing school absences and hospitalizations for asthma. J Sch Health. Aug. 2006;76(6):320-4. X-6, X-7, X-9. [pmid: 16918863].
2259 Lewin AB, Storch EA, Geffken GR, et al. Further examination of a structured adherence interview of diabetes for children, adolescents, and parents. Children's Health Care. 2005;34(2):149-64. X-2, X-4, X-6.
2260 Lewis BE, O'Mara P, Pezzella S. The development and implementation of a disease management program in a managed care setting. Annals of Long Term Care. 1999;7(6):226-31. X-6, X-9.
2261 Lewis C, Pignone M, Schild LA, et al. Effectiveness of a patient- and practice-level colorectal cancer screening intervention in health plan members: Design and baseline findings of the CHOICE Trial. Cancer. Apr. 2010;116(7):1664-73. X-6, X-9. [pmid: 20143439].
2262 Lewis FM, Darby EL. Adolescent adjustment and maternal breast cancer: a test of the “faucet hypothesis”. Journal of Psychosocial Oncology. 2003;21(4):81-104. X-2, X-4.
2263 Lewis MA, de la Sota A, Rachelefsky G, et al. ACT-asthma control y tratamiento para ninos: a progress report. Health Educ Q. Fall. 1987;14(3):281-90. X-9. [pmid: 3654235].
2264 Lewis MA, Lewis CE, Leake B, et al. Organizing the community to target poor Latino children with asthma. J Asthma. 1996;33(5):289-97. X-4, X-8. [pmid: 8827936].
2265 Lewis N, Gray SW, Freres DR, et al. Examining cross-source engagement with cancer-related information and its impact on doctor-patient relations. Health Commun. Dec. 2009;24(8):723-34. X-2, X-4, X-6. [pmid: 20183381].
2266 Lewis V, Ferguson TG, James C. Bridging the differences. Nephrol News Issues. Nov. 2003;17(12):88-91. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 14640015].
2267 Lewis WR, Ellrodt AG, Peterson E, et al. Trends in the use of evidence-based treatments for coronary artery disease among women and the elderly: findings from the get with the guidelines quality-improvement program. Circ Cardiovasc Qual Outcomes. Nov. 2009;2(6):633-41. X-11, X-12. [pmid: 20031902].
2268 Lewis WR, Peterson ED, Cannon CP, et al. An organized approach to improvement in guideline adherence for acute myocardial infarction: results with the Get With The Guidelines quality improvement program. Arch Intern Med. Sep. 8. 2008;168(16):1813-9. X-6. [pmid: 18779470].
2269 Li J, Garcia S, Castro HK, et al. Acceptance and expectations of information technology to support hypertension self-care in African Americans: a qualitative inquiry. AMIA Annu Symp Proc. 2007:1032. X-2, X-4. [pmid: 18694130].
2270 Li J, Lambert VA. Coping strategies and predictors of general well-being in women with breast cancer in the People's Republic of China. Nurs Health Sci. Sep. 2007;9(3):199-204. X-2, X-3, X-4, X-6. [pmid: 17688478].
2271 Li R, Zhang P, Barker L, et al. Impact of state mandatory insurance coverage on the use of diabetes preventive care. BMC Health Serv Res. 2010;10:133. X-2, X-4, X-6. [pmid: 20492699].
2272 Li R, Zhang P, Narayan KM. Self-monitoring of blood glucose before and after Medicare expansion among Medicare beneficiaries with diabetes who do not use insulin. Am J Public Health. Feb. 2008;98(2):358-64. X-2, X-4, X-6. [pmid: 18172142].
2273 Li S, Williams PL, Douglass CW. Development of a clinical guideline to predict undiagnosed diabetes in dental patients. J Am Dent Assoc. Jan. 2011;142(1):28-37. X-2, X-4, X-6. [pmid: 21193764].
2274 Li WW, Froelicher ES. Gender differences in Chinese immigrants: predictors for antihypertensive medication adherence. J Transcult Nurs. Oct. 2007;18(4):331-8. X-2, X-3, X-4. [pmid: 17911573].
2275 Li Y, Glance LG, Cai X, et al. Are patients with coexisting mental disorders more likely to receive CABG surgery from low-quality cardiac surgeons? The experience in New York State. Med Care. Jul. 2007;45(7):587-93. X-2, X-4. [pmid: 17571006].
2276 Liburd LC. Food, identity, and African-American women with type 2 diabetes: an anthropological perspective. Diabetes Spectrum. 2003;16(3):160-5. X-1, X-2, X-4.
2277 Liburd LC, Anderson LA, Edgar T, et al. Body size and body shape: perceptions of black women with diabetes. Diabetes Educ. May-Jun. 1999;25(3):382-8. X-2, X-4. [pmid: 10531858].
2278 Liburd LC, Namageyo-Funa A, Jack L Jr. Understanding “masculinity” and the challenges of managing type-2 diabetes among African-American men. J Natl Med Assoc. May. 2007;99(5):550-2. 4. 8. X-2, X-4. [pmid: 17534013].
2279 Licciardone JC, Kotsanos JG, Brinkman-Kaplan V, et al. Resource utilization and work or school loss reported by patients with diabetes: experience in diabetes training programs. Am J Manag Care. May. 1997;3(5):777-82. X-6, X-9. [pmid: 10169538].
2280 Lichtenberg PA. Assisting urban caregivers after nursing home placement: results from two preliminary programs. Clinical Gerontologist. 2006;30(2):65-77. X-5.
2281 Liebman J, Heffernan D, Sarvela P. Establishing diabetes self-management in a community health center serving low-income Latinos. Diabetes Educ. Jun. Suppl 6. 2007;33:132S-8S. X-6, X-9. [pmid: 17620392].
2282 Lied TR, Sheingold S. HEDIS performance trends in Medicare managed care. Health Care Financ Rev. Fall. 2001;23(1):149-60. X-2, X-4, X-6. [pmid: 12500369].
2283 Lieu TA, Lozano P, Finkelstein JA, et al. Racial/ethnic variation in asthma status and management practices among children in managed medicaid. Pediatrics. May. 2002;109(5):857-65. X-2, X-4. [pmid: 11986447].
2284 Liljestrand J, Pathmanathan I. Reducing maternal mortality: can we derive policy guidance from developing country experiences?. J Public Health Policy. 2004;25(3-4):299-314. X-1, X-2, X-3, X-4, X-6. [pmid: 15683067].
2285 Lillie SE, Brewer NT, O'Neill SC, et al. Retention and use of breast cancer recurrence risk information from genomic tests: the role of health literacy. Cancer Epidemiol Biomarkers Prev. Feb. 2007;16(2):249-55. X-2, X-4. [pmid: 17267389].
2286 Lim JW, Yi J, Zebrack B. Acculturation, social support, and quality of life for Korean immigrant breast and gynecological cancer survivors. Ethnicity & Health. 2008;13(3):243-60. X-2, X-4. [pmid: 18568975].
2287 Lin CC, Anderson RM, Chang CS, et al. Development and testing of the Diabetes Self-management Instrument: a confirmatory analysis. Res Nurs Health. Aug. 2008;31(4):370-80. X-2, X-3, X-4, X-6. [pmid: 18213627].
2288 Lin EH, Rutter CM, Katon W, et al. Depression and advanced complications of diabetes: a prospective cohort study. Diabetes Care. Feb. 2010;33(2):264-9. X-2, X-4, X-6. [pmid: 19933989].
2289 Lin EHB, Korff MV, Ludman EJ, et al. Enhancing adherence to prevent depression relapse in primary care. General Hospital Psychiatry. Sep-Oct. 2003;25(5):303-10. X-6, X-9. [pmid: 12972220].
2290 Lincoln A, Paasche-Orlow MK, Cheng DM, et al. Impact of health literacy on depressive symptoms and mental health-related: Quality of life among adults with addiction. Journal of General Internal Medicine. Aug. 2006;21(8):818-22. X-2, X-4. [pmid: 16881940].
2291 Lincoln NB, Radford KA, Game FL, et al. Education for secondary prevention of foot ulcers in people with diabetes: a randomised controlled trial. Diabetologia. Nov. 2008;51(11):1954-61. X-3, X-6. [pmid: 18758747].
2292 Lind A, Kaplan L, Berg GD. Evaluation of an asthma disease management program in a Medicaid population. Disease Management & Health Outcomes. 2006;14(3):151-61. X-9.
2293 Lind L, Sundvall E, Ahlfeldt H. Experiences from development of home health care applications based on emerging Java technology. Stud Health Technol Inform. 2001;84(Pt 1):830-4. X-1, X-2, X-4, X-6. [pmid: 11604851].
2294 Lindamer LA, Wear E, Sadler GR. Mammography stages of change in middle-aged women with schizophrenia: an exploratory analysis. BMC Psychiatry. 2006;6:49. X-2, X-4, X-6. [pmid: 17074091].
2295 Lindsay S, Bellaby P, Smith S, et al. Enabling healthy choices: is ICT the highway to health improvement?. Health (London). Jul. 2008;12(3):313-31. X-3, X-6. [pmid: 18579630].
2296 Lindstrom J, Louheranta A, Mannelin M, et al. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. Dec. 2003;26(12):3230-6. X-3, X-6. [pmid: 14633807].
2297 Lindstrom J, Neumann A, Sheppard KE, et al. Take action to prevent diabetes--the IMAGE toolkit for the prevention of type 2 diabetes in Europe. Horm Metab Res. Apr. Suppl 1. 2010;42:S37-55. X-1, X-2, X-3, X-4, X-6. [pmid: 20391307].
2298 Lingren C. New survey provides insight into CKD, exhaustion, anemia. Nephrol News Issues. Jan. 2003;17(2):29-31. X-1, X-2, X-3, X-4, X-6. [pmid: 12629826].
2299 Linsky A, McIntosh N, Cabral H, et al. Patient-Provider Language Concordance and Colorectal Cancer Screening. Journal of General Internal Medicine. Feb. 2011;26(2):142-7. X-2. [pmid: 20857340].
2300 Lipkus IM, Peters E. Understanding the Role of Numeracy in Health: Proposed Theoretical Framework and Practical Insights. Health Education & Behavior. Dec. 2009;36(6):1065-81. X-1, X-2, X-3, X-4, X-5. [pmid: 19834054].
2301 Lipkus IM, Peters E, Kimmick G, et al. Breast cancer patients' treatment expectations after exposure to the decision aid program Adjuvant Online: The influence of numeracy. Medical Decision Making. Jul-Aug. 2010;30(4):464-73. X-2, X-4. [pmid: 20160070].
2302 Lipman TH, Schucker MM, Ratcliffe SJ, et al. Diabetes risk factors in children: a partnership between nurse practitioner and high school students. MCN Am J Matern Child Nurs. Jan-Feb. 2011;36(1):56-62. X-2, X-4. [pmid: 21164318].
2303 Lippman H. Healthier communities on the horizon. State Health Care Am. 2002:38-42. X-1, X-6, X-7, X-9. [pmid: 12235762].
2304 Lipton R, Drum M, Burnet D, et al. Self-reported social class, self-management behaviors, and the effect of diabetes mellitus in urban, minority young people and their families. Arch Pediatr Adolesc Med. Sep. 2003;157(9):919-25. X-2, X-4. [pmid: 12963599].
2305 Lipton R, Losey L, Giachello AL, et al. Factors affecting diabetes treatment and patient education among Latinos: results of a preliminary study in Chicago. J Med Syst. Oct. 1996;20(5):267-76. X-2, X-4. [pmid: 9001994].
2306 Littenberg B, MacLean CD. Mandated diabetes registries will benefit persons with diabetes. Arch Intern Med. Apr. 28. 2008;168(8):797-9. discussion 802-3. X-1, X-6, X-7, X-9. [pmid: 18443253].
2307 Little BC, Hayworth J, Benson P, et al. Treatment of hypertension in pregnancy by relaxation and biofeedback. Lancet. Apr. 21. 1984;1(8382):865-7. X-4, X-6. [pmid: 6143184].
2308 Litzelman DK, Dittus RS, Miller ME, et al. Requiring physicians to respond to computerized reminders improves their compliance with preventive care protocols. J Gen Intern Med. Jun. 1993;8(6):311-7. X-6. [pmid: 8320575].
2309 Liu C. Comprehension of a colon cancer pamphlet among American adults at least 50 years of age. Health Education Journal. 2010;69(1):107-15. X-6, X-7, X-9.
2310 Liu CJ. Comprehension of a colon cancer pamphlet among American adults at least 50 years of age. Health Education Journal. Mar. 2010;69(1):107-15. X-2, X-4, X-6.
2311 Liu CL, Zaslavsky AM, Ganz ML, et al. The financial implications of availability and quality of a usual source of care for children with special health care needs. Maternal and Child Health Journal. Mar. 2008;12(2):243-59. X-2, X-4, X-6. [pmid: 17557198].
2312 Liu CY, Xia HO, Isaman DM, et al. Nursing clinical trial of breast self-examination education in China. Int Nurs Rev. Mar. 2010;57(1):128-34. X-3. [pmid: 20487485].
2313 Livaudais JC, Coronado GD, Espinoza N, et al. Educating Hispanic Women About Breast Cancer Prevention: Evaluation of a Home-Based Promotora-Led Intervention. Journal of Women's Health. (15409996). 2010;19(11):2049-56. X-4.
2314 Livaudais JC, Thompson B, Islas I, et al. Type 2 diabetes among rural Hispanics in Washington State: perspectives from community stakeholders. Health Promot Pract. Jul. 2010;11(4):589-99. X-2, X-4. [pmid: 20488960].
2315 Livingston JN, Smith NP, Mills C, et al. Theater as a tool to educate African Americans about breast cancer. J Cancer Educ. 2009;24(4):297-300. X-7, X-9, X-11. [pmid: 19838888].
2316 Llahana SV, Poulton BC, Coates VE. The paediatric diabetes specialist nurse and diabetes education in childhood. J Adv Nurs. Feb. 2001;33(3):296-306. X-2, X-3, X-4, X-6. [pmid: 11251716].
2317 Lloyd CE, Wing RR, Orchard TJ, et al. Psychosocial correlates of glycemic control: the Pittsburgh Epidemiology of Diabetes Complications (EDC) Study. Diabetes Res Clin Pract. Aug-Sep. 1993;21(2-3):187-95. X-2, X-4. [pmid: 8269821].
2318 Lloyd LL, Ammary NJ, Epstein LG, et al. A transdisciplinary approach to improve health literacy and reduce disparities. Health Promot Pract. Jul. 2006;7(3):331-5. X-2, X-3, X-4, X-5. [pmid: 16760237].
2319 Lo B, Parham L. The impact of web 2.0 on the doctor-patient relationship. J Law Med Ethics. Spring. 2010;38(1):17-26. X-1, X-2, X-4. [pmid: 20446980].
2320 Lobar S, Brooten D, Youngblut JM, et al. The experience of being an Asthma Amigo in a program to decrease asthma episodes in Hispanic children. J Pediatr Nurs. Oct. 2008;23(5):364-71. X-1, X-2, X-4. [pmid: 18804017].
2321 Lobb EA, Butow PN, Meiser B, et al. Tailoring communication in consultations with women from high risk breast cancer families. Br J Cancer. Aug. 27. 2002;87(5):502-8. X-2, X-3, X-4. [pmid: 12189544].
2322 Loewe R, Schwartzman J, Freeman J, et al. Doctor talk and diabetes: towards an analysis of the clinical construction of chronic illness. Soc Sci Med. Nov. 1998;47(9):1267-76. X-2, X-4, X-6. [pmid: 9783869].
2323 Logsdon MC, Hutti MH. Readability: an important issue impacting healthcare for women with postpartum depression. MCN Am J Matern Child Nurs. Nov-Dec. 2006;31(6):350-5. X-2, X-4. [pmid: 17149109].
2324 Logsdon RG, McCurry SM, Teri L. Time-limited support groups for individuals with early stage dementia and their care partners: preliminary outcomes from a controlled clinical trial. Clinical Gerontologist. 2006;30(2):5-19. X-1, X-2, X-5, X-6.
2325 Loh S, Packer TL, Yip CH, et al. Targeting health disparity in breast cancer: insights into women's knowledge of their cancer profile in Malaysia. Asian Pac J Cancer Prev. Oct-Dec. 2009;10(4):631-6. X-3, X-6. [pmid: 19827884].
2326 Loignon C, Bedos C, Sevigny R, et al. Understanding the self-care strategies of patients with asthma. Patient Educ Couns. May. 2009;75(2):256-62. X-2, X-3, X-4, X-6. [pmid: 19041209].
2327 Loiselle CG, Edgar L, Batist G, et al. The impact of a multimedia informational intervention on psychosocial adjustment among individuals with newly diagnosed breast or prostate cancer: a feasibility study. Patient Educ Couns. Jul. 2010;80(1):48-55. X-6, X-7, X-9. [pmid: 19854604].
2328 Long JD, Armstrong ML, Amos E, et al. Pilot using World Wide Web to prevent diabetes in adolescents. Clin Nurs Res. Feb. 2006;15(1):67-79. X-4. [pmid: 16410623].
2329 Long VA, Martin T, Janson-Sand C. The great beginnings program: impact of a nutrition curriculum on nutrition knowledge, diet quality, and birth outcomes in pregnant and parenting teens. J Am Diet Assoc. Mar. 2002;102(3 Suppl):S86-9. X-6, X-7, X-9. [pmid: 11902397].
2330 Longo DR, Schubert SL, Wright BA, et al. Health information seeking, receipt, and use in diabetes self-management. Ann Fam Med. Jul-Aug. 2010;8(4):334-40. X-2, X-4, X-6. [pmid: 20644188].
2331 Lonner TD. The group as a basic asset to ethnic minority patients with diabetes. Diabetes Educ. Mar-Apr. 2001;27(2):193-6. X-1, X-6, X-7, X-9. [pmid: 11913003].
2332 Lopez Cabezas C, Falces Salvador C, Cubi Quadrada D, et al. Randomized clinical trial of a postdischarge pharmaceutical care program vs regular follow-up in patients with heart failure. Farm Hosp. Nov-Dec. 2006;30(6):328-42. X-3. [pmid: 17298190].
2333 Lora CM, Daviglus ML, Kusek JW, et al. CHRONIC KIDNEY DISEASE IN UNITED STATES HISPANICS: A GROWING PUBLIC HEALTH PROBLEM. Ethnicity & Disease. Fal. 2009;19(4):466-72. X-1, X-2, X-4. [pmid: 20073150].
2334 Lorch SA, Wade KC, Bakewell-Sachs S, et al. Racial differences in the use of respiratory medications in premature infants after discharge from the neonatal intensive care unit. J Pediatr. Dec. 2007;151(6):604-10. 10 e1. X-2, X-4, X-5. [pmid: 18035139].
2335 Lorch SA, Wade KC, Bakewell-Sachs S, et al. Antibiotic use in premature infants after discharge from the neonatal intensive care unit. Clin Pediatr (Phila). Apr. 2010;49(3):249-57. X-2, X-4, X-5. [pmid: 19448131].
2336 Lorig K, Ritter PL, Villa F, et al. Spanish diabetes self-management with and without automated telephone reinforcement: two randomized trials. Diabetes Care. Mar. 2008;31(3):408-14. X-9. [pmid: 18096810].
2337 Lorig KR, Ritter PL, González VM. Hispanic Chronic Disease Self-Management: A Randomized Community-Based Outcome Trial. Nursing Research. Nov-Dec. 2003;52(6):361-9. X-8, X-10. [pmid: 14639082].
2338 Lorig KR, Ritter PL, Jacquez A. Outcomes of border health Spanish/English chronic disease self-management programs. Diabetes Educ. May-Jun. 2005;31(3):401-9. X-4, X-8. [pmid: 15919640].
2339 Lou VWQ, Zhang Y. Evaluating the effectiveness of a participatory empowerment group for Chinese type 2 diabetes patients. Research on Social Work Practice. 2006;16(5):491-9. X-3, X-6. [pmid: 21551025].
2340 Love RR, Brown RL, Davis JE, et al. Frequency and determinants of screening for breast cancer in primary care group practice. Arch Intern Med. Sep. 27. 1993;153(18):2113-7. X-2, X-4. [pmid: 8379802].
2341 Lovell K, Bower P, Richards D, et al. Developing guided self-help for depression using the Medical Research Council complex interventions framework: a description of the modelling phase and results of an exploratory randomised controlled trial. BMC Psychiatry. 2008;8:91. X-4, X-6. [pmid: 19025646].
2342 Lozano P, Finkelstein JA, Carey VJ, et al. A multisite randomized trial of the effects of physician education and organizational change in chronic-asthma care: health outcomes of the Pediatric Asthma Care Patient Outcomes Research Team II Study. Arch Pediatr Adolesc Med. Sep. 2004;158(9):875-83. X-6. [pmid: 15351753].
2343 Lozano P, Grothaus LC, Finkelstein JA, et al. Variability in asthma care and services for low-income populations among practice sites in managed Medicaid systems. Health Serv Res. Dec. 2003;38(6 Pt 1):1563-78. X-2, X-4. [pmid: 14727788].
2344 Ludescher G, Nishiwaki R, Lewis D, et al. Black male college students and hypertension: a qualitative investigation. Health Educ Res. Jun. 1993;8(2):271-82. X-2, X-4. [pmid: 10148833].
2345 Ludwick-Rosenthal R, Neufeld RW. Preparation for undergoing an invasive medical procedure: Interacting effects of information and coping style. Journal of Consulting and Clinical Psychology. Feb. 1993;61(1):156-64. X-2, X-4, X-6. [pmid: 8450101].
2346 Lujan J. Testing the diabetes knowledge and health beliefs of Mexican Americans on the Texas-Mexico border. Hispanic Health Care International. 2008;6(1):9-20. X-2, X-4.
2347 Lujan J, Ostwald SK, Ortiz M. Promotora diabetes intervention for Mexican Americans. Diabetes Educ. Jul-Aug. 2007;33(4):660-70. X-9. [pmid: 17684167].
2348 Lukkarinen H, Kyngas H. Experiences of the onset of coronary artery disease in a spouse. Eur J Cardiovasc Nurs. Sep. 2003;2(3):189-94. X-2, X-4, X-6. [pmid: 14622626].
2349 2350. Lunelli RP, Rabello ER, Stein R, et al. Sexual activity after myocardial infarction: taboo or lack of knowledge?. Arq Bras Cardiol. Mar. 2008;90(3):156-9. X-2, X-4, X-6. [pmid: 18392393].
2350 Luo N, Johnson JA, Shaw JW, et al. Relative efficiency of the EQ-5D, HUI2, and HUI3 index scores in measuring health burden of chronic medical conditions in a population health survey in the United States. Med Care. Jan. 2009;47(1):53-60. X-2, X-4. [pmid: 19106731].
2351 Luque JS, Rivers BM, Gwede CK, et al. Barbershop Communications on Prostate Cancer Screening Using Barber Health Advisers. American Journal of Mens Health. Mar. 2011;5(2):129-39. X-4, X-5. [pmid: 20413392].
2352 Luquis RR, Villanueva Cruz IJ. Knowledge, attitudes, and perceptions about breast cancer and breast cancer screening among Hispanic women residing in South Central Pennsylvania. J Community Health. Feb. 2006;31(1):25-42. X-2, X-4. [pmid: 16482764].
2353 Luty J, Peters T. Comparison of cigarette smoking and non-smoking in alcohol misusers. Journal of Substance Use. 2006;11(1):37-43. X-2, X-4, X-5, X-6.
2354 Ly DP, Lopez L, Isaac T, et al. How do black-serving hospitals perform on patient safety indicators? Implications for national public reporting and pay-for-performance. Med Care. Dec. 2010;48(12):1133-7. X-2, X-4, X-5. [pmid: 21063225].
2355 Lynch BM, Cerin E, Newman B, et al. Physical activity, activity change, and their correlates in a population-based sample of colorectal cancer survivors. Ann Behav Med. Oct. 2007;34(2):135-43. X-2, X-4, X-6. [pmid: 17927552].
2356 Lyons MA. Psychosocial impact of cancer in low-income rural/urban women: phase I. Online Journal of Rural Nursing & Health Care. 2004;4(1):18p. X-2, X-4.
2357 Lyons MA, Shelton MM. Psychosocial impact of cancer in low-income rural/urban women: phase II. Online Journal of Rural Nursing & Health Care. 2004;4(2):27p. X-2, X-4.
2358 Lyons T 2nd, Gourley G, Holt JM. Diabetes management: current diagnostic criteria, drug therapies, and state legislation. Am J Manag Care. Oct. 1997;3(10):1599-608. quiz 161-4. X-1, X-2, X-4, X-6. [pmid: 10178463].
2359 Ma C, Warren J, Stanek J. Adaptive filtering and prioritizing of diabetes consumer information for promoting consumer-provider partnership and communication. AMIA Annu Symp Proc. 2003:921. X-1, X-6, X-7, X-9. [pmid: 14728427].
2360 Ma GX, Shive S, Tan Y, et al. Community-based colorectal cancer intervention in underserved Korean Americans. Cancer Epidemiol. Nov. 2009;33(5):381-6. X-9. [pmid: 19914880].
2361 Ma Y, Li W, Olendzki BC, et al. Dietary quality 1 year after diagnosis of coronary heart disease. J Am Diet Assoc. Feb. 2008;108(2):240-6. discussion 6-7. X-2, X-4. [pmid: 18237571].
2362 Maar M, Gzik D, Larose T. Beyond expectations: why do Aboriginal and Euro-Canadian patients with type 2 diabetes on a Northern, rural island demonstrate better outcomes for glycemic, blood pressure and lipid management than comparison populations?. Canadian Journal of Diabetes. 2010;34(2):127-35. X-2, X-3, X-4.
2363 Mabiso A, Williams KP, Todem D, et al. Longitudinal analysis of domain-level breast cancer literacy among African-American women. Health Educ Res. Feb. 2010;25(1):151-61. X-7, X-9. [pmid: 19861639].
2364 Mabotuwana T, Warren J. An ontology-based approach to enhance querying capabilities of general practice medicine for better management of hypertension. Artificial Intelligence in Medicine. Oct. 2009;47(2):87-103. X-1, X-2, X-3, X-4, X-6. [pmid: 19709865].
2365 Mabotuwana T, Warren J. ChronoMedIt--a computational quality audit framework for better management of patients with chronic conditions. J Biomed Inform. Feb. 2010;43(1):144-58. X-2, X-4, X-5, X-6. [pmid: 19703585].
2366 Macabasco-O'Connell A, Crawford MH, Stotts N, et al. Self-care behaviors in indigent patients with heart failure. J Cardiovasc Nurs. May-Jun. 2008;23(3):223-30. X-2, X-4. [pmid: 18437064].
2367 Macabasco-O'Connell A, DeWalt DA, Broucksou KA, et al. Relationship Between Literacy, Knowledge, Self-Care Behaviors, and Heart Failure-Related Quality of Life Among Patients With Heart Failure. Journal of General Internal Medicine. Sep. 2011;26(9):979-86. X-2, X-4. [pmid: 21369770].
2368 Macaulay AC, Paradis G, Potvin L, et al. Primary prevention of Type 2 diabetes in First Nations: experiences of the Kahnawake Schools Diabetes Prevention Project. Canadian Journal of Diabetes Care. 1998;22(3):44-9. X-3.
2369 MacDonald DJ, Sarna L, Uman GC, et al. Health beliefs of women with and without breast cancer seeking genetic cancer risk assessment. Cancer Nurs. Sep-Oct. 2005;28(5):372-9. quiz 80-1. X-2. [pmid: 16192828].
2370 Mackert M, Love B, Whitten P. Patient education on mobile devices: an e-health intervention for low health literate audiences. Journal of Information Science. Feb. 2009;35(1):82-93. X-9.
2371 MacMaster SA, Jones JL, Rasch RFR, et al. Evaluation of a faith-based culturally relevant program for African American substance users at risk for HIV in the southern United States. Research on Social Work Practice. 2007;17(2):229-38. X-4, X-5.
2372 Macmullen NJ, Shen JJ, Tymkow C. Adverse maternal outcomes in women with asthma versus women without asthma. Appl Nurs Res. Feb. 2010;23(1):e9. e13. X-2, X-4, X-6. [pmid: 20122503].
2373 Macrae FA, St John DJ, Ambikapathy A, et al. Factors affecting compliance in colorectal cancer screening. Results of a study performed in Ballarat. Med J Aust. Jun. 9. 1986;144(12):621-3. X-2, X-3, X-4. [pmid: 3713601].
2374 Madden MH, Tomsik P, Terchek J, et al. Keys to successful diabetes self-management for uninsured patients: social support, observational learning, and turning points: a safety net providers' strategic alliance study. J Natl Med Assoc. Mar. 2011;103(3):257-64. X-2, X-4. [pmid: 21671529].
2375 Maddigan SL, Majumdar SR, Guirguis LM, et al. Improvements in patient-reported outcomes associated with an intervention to enhance quality of care for rural patients with type 2 diabetes: results of a controlled trial. Diabetes Care. Jun. 2004;27(6):1306-12. X-3. [pmid: 15161780].
2376 Maddigan SL, Majumdar SR, Toth EL, et al. Health-related quality of life deficits associated with varying degrees of disease severity in type 2 diabetes. Health Qual Life Outcomes. 2003;1:78. X-6, X-7, X-9. [pmid: 14675484].
2377 Madigan ME, Smith-Wheelock L, Krein SL. Healthy hair starts with a healthy body: hair stylists as lay health advisors to prevent chronic kidney disease. Prev Chronic Dis. Jul. 2007;4(3):A64. X-7, X-9. [pmid: 17572968].
2378 Madison A, Hung R, Jean-Louis E. The Boston Haitian HIV Prevention Coalition formative evaluation: a participatory approach to community self-assessment. Ethn Dis. Summer. 2004;14(3 Suppl 1):S20-6. X-2, X-4, X-5. [pmid: 15682768].
2379 Madrid E, Mennie GW, Newton PL. Asthma: challenges in vulnerable populations. JAAPA. Feb. 2006;19(2):41-6. quiz 7-8. X-1, X-6, X-7, X-9. [pmid: 16483075].
2380 Magai C, Consedine NS, Adjei BA, et al. Psychosocial influences on suboptimal adjuvant breast cancer treatment adherence among African American women: Implications for education and intervention. Health Education & Behavior. Dec. 2008;35(6):835-54. X-2, X-4. [pmid: 17909222].
2381 Magana CG, Hovey JD. Psychosocial stressors associated with Mexican migrant farmworkers in the midwest United States. Journal of Immigrant Health. 2003;5(2):75-86. X-2, X-4, X-5. [pmid: 14512761].
2382 Magee M, Bowling A, Copeland J, et al. The ABCs of diabetes: diabetes self-management education program for African Americans affects A1C, lipid-lowering agent prescriptions, and emergency department visits. Diabetes Educ. Jan-Feb. 2011;37(1):95-103. X-4, X-7, X-8, X-9. [pmid: 21292623].
2383 Maguire KC, Gardner J, Sopory P, et al. Formative research regarding kidney disease health information in a Latino American sample: Associations among message frame, threat, efficacy, message effectiveness, and behavioral intention. Communication Education. Jul. 2010;59(3):344-59. X-6, X-7, X-9.
2384 Mah CA, Soumerai SB, Adams AS, et al. Racial differences in impact of coverage on diabetes self-monitoring in a health maintenance organization. Med Care. May. 2006;44(5):392-7. X-2. [pmid: 16641656].
2385 Mahalingaiah S, Berry KF, Hornstein MD, et al. Does a woman's educational attainment influence in vitro fertilization outcomes?. Fertil Steril. Jun. 30. 2011;95(8):2618-20. X-2, X-4, X-5. [pmid: 21601850].
2386 Mahfouz EM, Awadalla HI. Compliance to diabetes self-management in rural El-Mina, Egypt. Cent Eur J Public Health. Mar. 2011;19(1):35-41. X-2, X-3, X-4, X-6. [pmid: 21526654].
2387 Mahmood SS. A modern epidemic in a historic city. Tackling diabetes in Old Delhi. Pharos Alpha Omega Alpha Honor Med Soc. Spring. 2011;74(2):30-3. X-2, X-3. [pmid: 21615070].
2388 Mahon SM, Williams MT, Spies MA. Screening for second cancers and osteoporosis in long-term survivors. Cancer Pract. Nov-Dec. 2000;8(6):282-90. X-2, X-4. [pmid: 11898145].
2389 Mahoney MC, Michalek AM. Health status of American Indians/Alaska Natives: general patterns of mortality. Fam Med. Mar. 1998;30(3):190-5. X-2, X-4. [pmid: 9532441].
2390 Maillet NA, D'Eramo Melkus G, Spollett G. Using focus groups to characterize the health beliefs and practices of black women with non-insulin-dependent diabetes. Diabetes Educ. Jan-Feb. 1996;22(1):39-46. X-2, X-4. [pmid: 8697955].
2391 Mainous AG 3rd, Diaz VA, Koopman RJ, et al. Quality of care for Hispanic adults with diabetes. Fam Med. May. 2007;39(5):351-6. X-2, X-4. [pmid: 17476609].
2392 Majumdar SR, Guirguis LM, Toth EL, et al. Controlled trial of a multifaceted intervention for improving quality of care for rural patients with type 2 diabetes. Diabetes Care. Nov. 2003;26(11):3061-6. X-3, X-6. [pmid: 14578240].
2393 Makinen S, Suominen T, Lauri S. What asthma patients know about their illness and its treatment. Clin Nurse Spec. Nov. 1999;13(6):277-82. X-2, X-3, X-4. [pmid: 11188563].
2394 Makoul G, Cameron KA, Baker DW, et al. A multimedia patient education program on colorectal cancer screening increases knowledge and willingness to consider screening among Hispanic/Latino patients. Patient Educ Couns. Aug. 2009;76(2):220-6. X-7, X-9. [pmid: 19250791].
2395 Makrilakis K, Liatis S, Grammatikou S, et al. Implementation and effectiveness of the first community lifestyle intervention programme to prevent Type 2 diabetes in Greece. The DE-PLAN study. Diabet Med. Apr. 2010;27(4):459-65. X-3. [pmid: 20536519].
2396 Mal S. The language of care. Interview by Jo Carlowe. Nurs Stand. Oct. 28. Nov. 3. 1998;13(6):25-6. X-1, X-2, X-4, X-5, X-6. [pmid: 9919214].
2397 Malafa MP, Corman MM, Shibata D, et al. The Florida Initiative for Quality Cancer Care: a regional project to measure and improve cancer care. Cancer Control. Oct. 2009;16(4):318-27. X-1, X-6, X-9. [pmid: 19910918].
2398 Mallinger JB, Griggs JJ, Shields CG. Patient-centered care and breast cancer survivors' satisfaction with information. Patient Educ Couns. Jun. 2005;57(3):342-9. X-2, X-4, X-6. [pmid: 15893218].
2399 Malnory ME, Johnson TS. The reproductive life plan as a strategy to decrease poor birth outcomes. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 2011;40(1):109-19. quiz 20-1. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 21309093].
2400 Maly RC, Leake B, Silliman RA. Health care disparities in older patients with breast carcinoma: informational support from physicians. Cancer. Mar. 15. 2003;97(6):1517-27. X-7, X-9. [pmid: 12627517].
2401 Maly RC, Liu YH, Kwong E, et al. Breast Reconstructive Surgery in Medically Underserved Women With Breast Cancer The Role of Patient-Physician Communication. Cancer. Oct. 2009;115(20):4819-27. X-2, X-4. [pmid: 19626696].
2402 Maly RC, Umezawa Y, Ratliff CT, et al. Racial/ethnic group differences in treatment decision-making and treatment received among older breast carcinoma patients. Cancer. Feb. 15. 2006;106(4):957-65. X-2. [pmid: 16402372].
2403 Mancini J, Nogues C, Adenis C, et al. Patients' characteristics and rate of Internet use to obtain cancer information. J Public Health (Oxf). Sep. 2006;28(3):235-7. X-2, X-3, X-4. [pmid: 16809788].
2404 Mancuso C, Glendon G, Anson-Cartwright L, et al. Ethnicity, but not cancer family history, is related to response to a population-based mailed questionnaire. Ann Epidemiol. Jan. 2004;14(1):36-43. X-2, X-3, X-4. [pmid: 14664778].
2405 Mancuso CA, Rincon M. Impact of health literacy on longitudinal asthma outcomes. J Gen Intern Med. Aug. 2006;21(8):813-7. X-2, X-4. [pmid: 16881939].
2406 Mancuso CA, Rincon M. Asthma patients' assessments of health care and medical decision making: The role of health literacy. Journal of Asthma. 2006;43(1):41-4. X-2, X-4. [pmid: 16448964].
2407 Mancuso JM. The impact of health literacy and patient trust on glycemic control. West J Nurs Res. Dec. 2009;31(8):1086-7. X-6, X-7, X-9. [pmid: 20008315].
2408 Mancuso JM. Impact of health literacy and patient trust on glycemic control in an urban USA population. Nurs Health Sci. Mar. 2010;12(1):94-104. X-7, X-9. [pmid: 20487332].
2409 Mandelblatt J, Kaufman E, Sheppard VB, et al. Breast cancer prevention in community clinics: will low-income Latina patients participate in clinical trials?. Prev Med. Jun. 2005;40(6):611-8. X-2, X-4. [pmid: 15850856].
2410 Mandelblatt JS, Yabroff KR. Breast and cervical cancer screening for older women: recommendations and challenges for the 21st century. J Am Med Womens Assoc. Summer. 2000;55(4):210-5. X-1, X-2, X-4. [pmid: 10935354].
2411 Manfredi C, Czaja R, Freels S, et al. Prescribe for health. Improving cancer screening in physician practices serving low-income and minority populations. Arch Fam Med. Jul-Aug. 1998;7(4):329-37. X-9. [pmid: 9682686].
2412 Manfredi C, Lacey L, Warnecke R. Results of an intervention to improve compliance with referrals for evaluation of suspected malignancies at neighborhood public health centers. Am J Public Health. Jan. 1990;80(1):85-7. X-5, X-6. [pmid: 2293812].
2413 Mangione CM, Gerzoff RB, Williamson DF, et al. The association between quality of care and the intensity of diabetes disease management programs. Ann Intern Med. Jul. 18. 2006;145(2):107-16. X-2, X-4, X-6. [pmid: 16847293].
2414 Mangione-Smith R, Schonlau M, Chan KS, et al. Measuring the effectiveness of a collaborative for quality improvement in pediatric asthma care: does implementing the chronic care model improve processes and outcomes of care?. Ambul Pediatr. Mar-Apr. 2005;5(2):75-82. X-6. [pmid: 15780018].
2415 Manly JJ, Echemendia RJ. Race-specific norms: Using the model of hypertension to understand issues of race, culture, and education in neuropsychology. Archives of Clinical Neuropsychology. Mar. 2007;22(3):319-25. X-1, X-2, X-4. [pmid: 17350797].
2416 Mann DM, Ponieman D, Leventhal H, et al. Misconceptions about diabetes and its management among low-income minorities with diabetes. Diabetes Care. Apr. 2009;32(4):591-3. X-2, X-4. [pmid: 19131457].
2417 Mann JR, Mannan J, Quinones LA, et al. Religion, spirituality, social support, and perceived stress in pregnant and postpartum Hispanic women. J Obstet Gynecol Neonatal Nurs. Nov. 2010;39(6):645-57. X-2, X-4. [pmid: 21039849].
2418 Mann WC, McCarthy DP, Wu SS, et al. Relationship of health status, functional status, and psychosocial status to driving among elderly with disabilities. Physical & Occupational Therapy in Geriatrics. 2005;23(2/3):1-24. X-2, X-4, X-5, X-6.
2419 Manna DR, Bruijnzeels MA, Mokkink HG, et al. Ethnic specific recommendations in clinical practice guidelines: a first exploratory comparison between guidelines from the USA, Canada, the UK, and the Netherlands. Qual Saf Health Care. Oct. 2003;12(5):353-8. X-2, X-3, X-4, X-5, X-6. [pmid: 14532367].
2420 Manwell LB, Fleming MF, Mundt MP, et al. Treatment of problem alcohol use in women of childbearing age: results of a brief intervention trial. Alcohol Clin Exp Res. Oct. 2000;24(10):1517-24. X-6, X-9. [pmid: 11045860].
2421 Marcellin F, Bonono CR, Blanche J, et al. Higher risk of unsafe sex and impaired quality of life among patients not receiving antiretroviral therapy in Cameroon: results from the EVAL survey (ANRS 12-116). AIDS. Jan. Suppl 1. 2010;24:S17-25. X-2, X-3, X-4, X-5, X-6. [pmid: 20023436].
2422 Marchi KS, Fisher-Owens SA, Weintraub JA, et al. Most Pregnant Women in California Do Not Receive Dental Care: Findings from a Population-Based Study. Public Health Reports. Nov-Dec. 2010;125(6):831-42. X-2, X-4, X-6. [pmid: 21121228].
2423 Margellos-Anast H, Estarziau M, Kaufman G. Cardiovascular disease knowledge among culturally Deaf patients in Chicago. Prev Med. Mar. 2006;42(3):235-9. X-2, X-3. [pmid: 16460789].
2424 Margolis KL, Lurie N, McGovern PG, et al. Increasing breast and cervical cancer screening in low-income women. J Gen Intern Med. Aug. 1998;13(8):515-21. X-4, X-9. [pmid: 9734787].
2425 Margolis PA, Lannon CM, Stuart JM, et al. Practice based education to improve delivery systems for prevention in primary care: randomised trial. BMJ. Feb. 14. 2004;328(7436):388. X-5, X-6. [pmid: 14766718].
2426 Margolis PA, Stevens R, Bordley WC, et al. From concept to application: the impact of a community-wide intervention to improve the delivery of preventive services to children. Pediatrics. Sep. 2001;108(3):E42. X-4, X-6, X-7, X-9. [pmid: 11533360].
2427 Maric B, Kaan A, Araki Y, et al. The use of the Internet to remotely monitor patients with heart failure. Telemed J E Health. Jan-Feb. 2010;16(1):26-33. X-6, X-7, X-9. [pmid: 20070163].
2428 Marie D, Forsyth DK, Miles LK. Categorical ethnicity and mental health literacy in New Zealand. Ethnicity & Health. 2004;9(3):225-52. X-2, X-3, X-4, X-5. [pmid: 15369998].
2429 Marini I, Miller E. The physical and psychosocial health status of clients with spinal cord injury awarded damages in litigation. Journal of Life Care Planning. 2006;5(4):145-58. X-1, X-2, X-3, X-4, X-5, X-6.
2430 Mark TL, Gibson TB, McGuigan KA. The effects of antihypertensive step-therapy protocols on pharmaceutical and medical utilization and expenditures. Am J Manag Care. Feb. 2009;15(2):123-31. X-6, X-7, X-9. [pmid: 19284809].
2431 Marks GB, Jalaludin BB, Williamson M, et al. Use of “preventer” medications and written asthma management plans among adults with asthma in New South Wales. NSW Health Department Asthma Data Working Group. Med J Aust. Oct. 16. 2000;173(8):407-10. X-2, X-3, X-4. [pmid: 11090032].
2432 Marlow E, Melkus GD, Bosma AM. Professional development. STOP diabetes! An educational model for Native American adolescents in the prevention of diabetes. Diabetes Educator. 1998;24(4):441. X-9. [pmid: 9830948].
2433 Marmot MG. Psychosocial factors and blood pressure. Prev Med. Jul. 1985;14(4):451-65. X-1, X-2, X-4, X-5, X-6. [pmid: 3906628].
2434 Marquardt DN. Improvement in rural neonatal mortality: a case study of medical community intervention. Fam Med. Jul-Aug. 1990;22(4):269-74. X-6, X-9. [pmid: 2384200].
2435 Marsh C, Wang J, Kollias J, et al. Disparities in access to breast care nurses for breast surgeons: a National Breast Cancer Audit survey. Breast. Apr. 2010;19(2):142-6. X-2, X-3, X-4, X-6. [pmid: 20172728].
2436 Marsland CP, Logan RL. Coronary care and rehabilitation: patient and spouse responses. N Z Med J. Jun. 27. 1984;97(758):406-8. X-2, X-3, X-4. [pmid: 6589531].
2437 Martin A, Martin C, Martin PB, et al. ‘Inappropriate’ attendance at an accident and emergency department by adults registered in local general practices: how is it related to their use of primary care?. J Health Serv Res Policy. Jul. 2002;7(3):160-5. X-2, X-3, X-4, X-5, X-6. [pmid: 12171746].
2438 Martin CG, Andrade AA, Vila D, et al. The development of a community-based family asthma management intervention for Puerto Rican children. Prog Community Health Partnersh. Winter. 2010;4(4):315-24. X-1, X-3, X-9. [pmid: 21169709].
2439 Martin E. Improving influenza vaccination rates for pediatric asthmatics by use of an asthma educational tool and a patient electronic care system. Clinical Pediatrics. Jul. 2008;47(6):588-92. X-6, X-9. [pmid: 18441318].
2440 Martin M, Beebe J, Lopez L, et al. A qualitative exploration of asthma self-management beliefs and practices in Puerto Rican families. J Health Care Poor Underserved. 2010;21(2):464-74. X-2, X-4. [pmid: 20453350].
2441 Martin M, Hernandez O, Naureckas E, et al. Improving asthma research in an inner-city Latino neighborhood with community health workers. J Asthma. Dec. 2005;42(10):891-5. X-7, X-9. [pmid: 16393730].
2442 Martin MA, Catrambone CD, Kee RA, et al. Improving asthma self-efficacy: developing and testing a pilot community-based asthma intervention for African American adults. J Allergy Clin Immunol. Jan. 2009;123(1):153-9 e3. X-4. [pmid: 19130936].
2443 Martin MA, Hernandez O, Naureckas E, et al. Reducing home triggers for asthma: the Latino community health worker approach. J Asthma. Jun-Jul. 2006;43(5):369-74. X-9. [pmid: 16801141].
2444 Martin MA, Mosnaim GS, Rojas D, et al. Evaluation of an asthma medication training program for immigrant Mexican community health workers. Prog Community Health Partnersh. Spring. 2011;5(1):95-103. X-4, X-7, X-9, X-10. [pmid: 21441673].
2445 Martin MA, Swider SM, Olinger T, et al. Recruitment of Mexican American adults for an intensive diabetes intervention trial. Ethn Dis. Winter. 2011;21(1):7-12. X-2, X-4. [pmid: 21462723].
2446 Martin MT, Lane AJ, Neuman ME. Breast cancer screening program targeting rural Hispanics in southeastern Indiana: program evaluation. Hispanic Health Care International. 2009;7(3):153-9. X-2, X-4.
2447 Martin MY. Community health advisors effectively promote cancer screening. Ethn Dis. Spring. 2005;15(2 Suppl 2):S14-6. X-1, X-2, X-4, X-5. [pmid: 15822831].
2448 Martin MY, Kim YI, Kratt P, et al. Medication adherence among rural, low-income hypertensive adults: a randomized trial of a multimedia community-based intervention. Am J Health Promot. Jul-Aug. 2011;25(6):372-8. X-6, X-9. [pmid: 21721962].
2449 Martin MY, Kohler C, Kim YI, et al. Taking less than prescribed: medication nonadherence and provider-patient relationships in lower-income, rural minority adults with hypertension. J Clin Hypertens (Greenwich). Sep. 2010;12(9):706-13. X-2, X-3, X-4. [pmid: 20883231].
2450 Martin MY, Person SD, Shipp M, et al. Variations in physicians' advice for managing hypertension in women: a study using NHANES III. Prev Med. Oct. 2006;43(4):337-42. X-2, X-4. [pmid: 16782183].
2451 Martin TL, Selby JV, Zhang D. Physician and patient prevention practices in NIDDM in a large urban managed-care organization. Diabetes Care. Aug. 1995;18(8):1124-32. X-2, X-4. [pmid: 7587847].
2452 Martinez D, Aguado Loi CX, Martinez MM, et al. Development of a cancer camp for adult Spanish-speaking survivors: lessons learned from Camp Alegria. J Cancer Educ. Jan-Mar. 2008;23(1):4-9. X-7, X-9. [pmid: 18444040].
2453 Martinez JE, Panossian C, Gavioli F, et al. Comparative study of clinical characteristics and type of assistance for patients with fibromyalgia syndrome treated in a public health system versus private medical care: relationships to formal education and income. Journal of Musculoskeletal Pain. 2005;13(4):15-9. X-2, X-4, X-5, X-6.
2454 Martinez KG, Perez EA, Ramirez R, et al. The role of caregivers' depressive symptoms and asthma beliefs on asthma outcomes among low-income Puerto Rican children. J Asthma. Mar. 2009;46(2):136-41. X-2, X-4. [pmid: 19253118].
2455 Martinez NC, Bader J. Analysis of behavioral risk factor surveillance system data to assess the health of Hispanic Americans with diabetes in El Paso County, Texas. Diabetes Educ. Jul-Aug. 2007;33(4):691-9. X-2, X-4. [pmid: 17684170].
2456 Martinez NC, Tripp-Reimer T. Diabetes nurse educators' prioritized elder foot care behaviors. Diabetes Educ. Nov-Dec. 2005;31(6):858-68. X-2, X-4, X-6. [pmid: 16288093].
2457 Martinez-Castelao A, De Alvaro F, Gorriz JL. Epidemiology of diabetic nephropathy in Spain. Kidney Int Suppl. Dec. 2005;(99):S20-4. X-2, X-3, X-4. [pmid: 16336572].
2458 Marton C. How women with mental health conditions evaluate the quality of information on mental health web sites: a qualitative approach. Journal of Hospital Librarianship. 2010;10(3):235-50. X-2, X-4, X-5, X-6.
2459 Masaquel A, Wells K, Ettner SL. How does the persistence of depression influence the continuity and type of health insurance and coverage limits on mental health therapy?. J Ment Health Policy Econ. Sep. 2007;10(3):133-44. X-2, X-4. [pmid: 17890830].
2460 Masmoudi A, Frikha M, Daoud J. Feasibility of quality of life assessment in routine clinical oncology practice: a Tunisian study. East Mediterr Health J. Mar-Apr. 2009;15(2):362-8. X-2, X-3, X-4. [pmid: 19554983].
2461 Massaro E, Claiborne N. Effective strategies for reaching high-risk minorities with diabetes. Diabetes Educ. Nov-Dec. 2001;27(6):820-6. 8. X-6, X-9. [pmid: 12211923].
2462 Massett HA. Appropriateness of Hispanic print materials: a content analysis. Health Educ Res. Jun. 1996;11(2):231-42. X-7, X-9. [pmid: 10163408].
2463 2464. Massing MW, Henley N, Biggs D, et al. Prevalence and care of diabetes mellitus in the Medicare population of North Carolina. Baseline findings from the Medicare Healthcare Quality Improvement Program. N C Med J. Mar-Apr. 2003;64(2):51-7. X-2, X-4. [pmid: 12774733].
2464 Matson Koffman D, Granade SA, Anwuri VV. Strategies for establishing policy, environmental, and systems-level interventions for managing high blood pressure and high cholesterol in health care settings: a qualitative case study. Prev Chronic Dis. Jul. 2008;5(3):A83. X-2, X-4, X-6. [pmid: 18558033].
2465 Matthews AK, Berrios N, Darnell JS, et al. A qualitative evaluation of a faith-based breast and cervical cancer screening intervention for African American women. Health Educ Behav. Oct. 2006;33(5):643-63. X-2, X-4. [pmid: 16861590].
2466 Matthews PH, Darbisi C, Sandmann L, et al. Disseminating health information and diabetes care for Latinos via electronic information kiosks. J Immigr Minor Health. Dec. 2009;11(6):520-6. X-7, X-9. [pmid: 18392935].
2467 Matud MP, Hernandez JA, Marrero RJ. Work role and health in a sample of Spanish women. Feminism & Psychology. 2002;12(3):363-78. X-2, X-3, X-4, X-5, X-6.
2468 Matzke GR. Healthcare reform 2009 and its implications for pharmacists. Ann Pharmacother. Dec. 2009;43(12):2088-92. X-3. [pmid: 19920155].
2469 Mauldon M, Melkus GD, Cagganello M. Tomando Control: a culturally appropriate diabetes education program for Spanish-speaking individuals with type 2 diabetes mellitus--evaluation of a pilot project. Diabetes Educ. Sep-Oct. 2006;32(5):751-60. X-4. [pmid: 16971708].
2470 Mausbach BT, Semple SJ, Strathdee SA, et al. Efficacy of a behavioral intervention for increasing safer sex behaviors in HIV-positive MSM methamphetamine users: results from the EDGE study. Drug Alcohol Depend. Mar. 16. 2007;87(2-3):249-57. X-5. [pmid: 17182196].
2471 Mavalankar D, Singh A, Patel SR, et al. Saving mothers and newborns through an innovative partnership with private sector obstetricians: Chiranjeevi scheme of Gujarat, India. Int J Gynaecol Obstet. Dec. 2009;107(3):271-6. X-2, X-3, X-4. [pmid: 19846090].
2472 Maxwell AE, Bastani R, Crespi CM, et al. Behavioral mediators of colorectal cancer screening in a randomized controlled intervention trial. Prev Med. Feb. 1. 2011;52(2):167-73. X-4, X-6, X-7, X-9, X-10. [pmid: 21111754].
2473 Maxwell AE, Bastani R, Danao LL, et al. Results of a community-based randomized trial to increase colorectal cancer screening among Filipino Americans. Am J Public Health. Nov. 2010;100(11):2228-34. X-8, X-9. [pmid: 20864724].
2474 Maxwell AE, Jo AM, Chin SY, et al. Impact of a print intervention to increase annual mammography screening among Korean American women enrolled in the National Breast and Cervical Cancer Early Detection Program. Cancer Detect Prev. 2008;32(3):229-35. X-9. [pmid: 18799271].
2475 Maxwell M, Pratt R. Prevention and management of depression in primary care in Europe: a holistic model of care and interventions--position paper of the European Forum for Primary Care. Qual Prim Care. 2008;16(3):187-96. X-1, X-2, X-3, X-4. [pmid: 18700100].
2476 May KM, Rew L. Mexican American youths' and mothers' explanatory models of diabetes prevention. J Spec Pediatr Nurs. Jan. 2010;15(1):6-15. X-2, X-4. [pmid: 20074109].
2477 Mayberry RM, Davis T, Alema-Mensah E, et al. Determinants of glycemic status monitoring in Black and White Medicaid beneficiaries with diabetes mellitus. J Health Care Poor Underserved. Nov. 2005;16(4 Suppl A):31-49. X-2. [pmid: 16327095].
2478 Mayer JA, Lewis EC, Slymen DJ, et al. Patient reminder letters to promote annual mammograms: a randomized controlled trial. Prev Med. Oct. 2000;31(4):315-22. X-6. [pmid: 11006056].
2479 Mayer-Davis EJ, D'Antonio A, Martin M, et al. Pilot study of strategies for effective weight management in type 2 diabetes: Pounds Off with Empowerment (POWER). Fam Community Health. Jul. 2001;24(2):27-35. X-4. [pmid: 11373164].
2480 Mayer-Davis EJ, D'Antonio AM, Smith SM, et al. Pounds off with empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health. Oct. 2004;94(10):1736-42. X-6, X-9. [pmid: 15451743].
2481 Maynard C, Sun H, Lowy E, et al. The use of percutaneous coronary intervention in black and white veterans with acute myocardial infarction. BMC Health Serv Res. 2006;6:107. X-2. [pmid: 16923183].
2482 Mayo R, Scott DB, Williams DG. The Upstate Witness Project: addressing breast and cervical cancer disparities in African American churches. J S C Med Assoc. Dec. 2009;105(7):290-6. X-6, X-7, X-8, X-9. [pmid: 20108721].
2483 Mayr FB, Yende S, D'Angelo G, et al. Do hospitals provide lower quality of care to black patients for pneumonia?. Crit Care Med. Mar. 2010;38(3):759-65. X-2, X-4. [pmid: 20009756].
2484 Mbaezue N, Mayberry R, Gazmararian J, et al. The impact of health literacy on self-monitoring of blood glucose in patients with diabetes receiving care in an inner-city hospital. J Natl Med Assoc. Jan. 2010;102(1):5-9. X-2, X-4. [pmid: 20158130].
2485 McAndrew LM, Horowitz CR, Lancaster KJ, et al. Association between self-monitoring of blood glucose and diet among minority patients with diabetes. J Diabetes. Jun. 2011;3(2):147-52. X-2, X-4. [pmid: 21599868].
2486 McBean AM, Huang Z, Virnig BA, et al. Racial variation in the control of diabetes among elderly medicare managed care beneficiaries. Diabetes Care. Dec. 2003;26(12):3250-6. X-2, X-4. [pmid: 14633810].
2487 McBean AM, Yu XH. The underuse of screening services among elderly women with diabetes. Diabetes Care. Jun. 2007;30(6):1466-72. X-2, X-4, X-6. [pmid: 17351285].
2488 McCabe M, Gohdes D, Morgan F, et al. Training effective interpreters for diabetes care and education: a new challenge. Diabetes Educ. Sep-Oct. 2006;32(5):714-20. X-7, X-9. [pmid: 16971705].
2489 McCabe M, Morgan F, Curley H, et al. The informed consent process in a cross-cultural setting: is the process achieving the intended result?. Ethn Dis. Spring. 2005;15(2):300-4. X-7, X-9. [pmid: 15825977].
2490 McCabe M, Morgan F, Smith M, et al. Lessons learned: Challenges in interpreting diabetes concepts in the Navajo language. Diabetes Care. Jun. 2003;26(6):1913-4. X-1, X-6, X-7, X-9. [pmid: 12766132].
2491 McCann TV, Clark E. Australian Bachelor of Midwifery students' mental health literacy: an exploratory study. Nurs Health Sci. Mar. 2010;12(1):14-20. X-2, X-3, X-4. [pmid: 20487320].
2492 McCarthy BD, Yood MU, Bolton MB, et al. Redesigning primary care processes to improve the offering of mammography. The use of clinic protocols by nonphysicians. J Gen Intern Med. Jun. 1997;12(6):357-63. X-6. [pmid: 9192253].
2493 McCleary-Jones V. Health literacy and its association with diabetes knowledge, self-efficacy and disease self-management among African Americans with diabetes mellitus. ABNF J. Spring. 2011;22(2):25-32. X-2, X-4. [pmid: 21675666].
2494 McClellan L, Schlundt D. Overview of Nashville REACH 2010's approach to eliminating disparities in diabetes and cardiovascular disease. J Ambul Care Manage. Apr-Jun. 2006;29(2):106-11. X-1, X-2, X-4. [pmid: 16552319].
2495 McClellan WM, Wasse H, McClellan AC, et al. Treatment center and geographic variability in pre-ESRD care associate with increased mortality. J Am Soc Nephrol. May. 2009;20(5):1078-85. X-2, X-4, X-6. [pmid: 19321704].
2496 McCloskey J. Promotores as partners in a community-based diabetes intervention program targeting Hispanics. Fam Community Health. Jan-Mar. 2009;32(1):48-57. X-2, X-4. [pmid: 19092434].
2497 McCloskey J, Flenniken D. Overcoming cultural barriers to diabetes control: a qualitative study of southwestern New Mexico Hispanics. J Cult Divers. Fall. 2010;17(3):110-5. X-4, X-7, X-9. [pmid: 20860336].
2498 McClure DL. Training challenge: when the patient speaks a different language. Adv Perit Dial. 2010;26:88-90. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 21348387].
2499 McClure LA, Glaser SL, Shema SJ, et al. Availability and Accuracy of Medical Record Information on Language Usage of Cancer Patients from a Multi-Ethnic Population. Journal of Immigrant and Minority Health. Aug. 2010;12(4):480-8. X-2, X-4, X-5. [pmid: 19685187].
2500 McComb MN, Tickle-Degnen L. Developing the construct of social support in Parkinson's disease. Physical & Occupational Therapy in Geriatrics. 2005;24(1):45-60. X-2, X-4, X-5, X-6.
2501 McConnell R, Milam J, Richardson J, et al. Educational intervention to control cockroach allergen exposure in the homes of hispanic children in Los Angeles: results of the La Casa study. Clin Exp Allergy. Apr. 2005;35(4):426-33. X-7, X-9. [pmid: 15836749].
2502 McConnell YJ, Inglis K, Porter GA. Timely access and quality of care in colorectal cancer: are they related?. Int J Qual Health Care. Jun. 2010;22(3):219-28. X-2, X-4, X-6. [pmid: 20207714].
2503 McCorkle R, Siefert ML, Dowd MF, et al. Effects of advanced practice nursing on patient and spouse depressive symptoms, sexual function, and marital interaction after radical prostatectomy. Urol Nurs. Feb. 2007;27(1):65-77. discussion 8-80. X-5, X-6. [pmid: 17390930].
2504 McCowen C, Hackett AF, Court S, et al. Are families of diabetic children adequately taught?. Br Med J (Clin Res Ed). May. 24. 1986;292(6532):1361. X-6, X-7, X-9. [pmid: 3085846].
2505 McDermott J, Drews C, Green D, et al. Evaluation of prenatal care information on birth certificates. Paediatr Perinat Epidemiol. Jan. 1997;11(1):105-21. X-2, X-4, X-5, X-6. [pmid: 9018732].
2506 McDermott M, Silva J, Rydman R, et al. Practice variations in treating urban minority asthmatics in Chicago. J Med Syst. Oct. 1996;20(5):255-66. X-2, X-4. [pmid: 9001993].
2507 McDonald M, Grimm RH Jr. Compliance with hypertension treatment. Strategies for improving patient cooperation. Postgrad Med. Jun. 1985;77(8):233-6. 41. 2. X-1, X-2, X-4. [pmid: 4001041].
2508 McDonald MV, Pezzin LE, Peng TR, et al. Understanding the complexity of hypertensive African American home care patients: challenges to intervention. Ethn Dis. Spring. 2009;19(2):148-53. X-2, X-4. [pmid: 19537225].
2509 McDowell H, Kim E, Shaw BR, et al. Predictors and effects of training on an online health education and support system for women with breast cancer. Journal of Computer-Mediated Communication. Apr. 2010;15(3):412-26. X-2, X-6. [pmid: 21949474].
2510 McDowell J, Courtney M, Edwards H, et al. Validation of the Australian/English version of the Diabetes Management Self-Efficacy Scale. Int J Nurs Pract. Aug. 2005;11(4):177-84. X-2, X-3, X-4, X-6. [pmid: 15985096].
2511 McElmurry BJ, McCreary LL, Park CG, et al. Implementation, outcomes, and lessons learned from a collaborative primary health care program to improve diabetes care among urban Latino populations. Health Promotion Practice. Apr. 2009;10(2):293-302. X-9. [pmid: 18344318].
2512 McEntee ML, Cuomo LR, Dennison CR. Patient-, Provider-, and System-Level Barriers to Heart Failure Care. Journal of Cardiovascular Nursing. Jul-Aug. 2009;24(4):290-8. X-1, X-2, X-4. [pmid: 19465864].
2513 McEwan SR, Hau C, Daly F, et al. Heart and arterial disease risk factors measured in an office workforce: changes from 1993 to 1996 The Scottish Heart and Arterial Risk Prevention Group (SHARP). Scott Med J. Jun. 1998;43(3):74-7. X-2, X-3. [pmid: 9682291].
2514 McEwen MM, Baird M, Pasvogel A, et al. Health-illness transition experiences among Mexican immigrant women with diabetes. Fam Community Health. Jul-Sep. 2007;30(3):201-12. X-4, X-7, X-9. [pmid: 17563482].
2515 McEwen MM, Pasvogel A, Gallegos G, et al. Type 2 diabetes self-management social support intervention at the U.S.-Mexico border. Public Health Nurs. Jul. 2010;27(4):310-9. X-2, X-4. [pmid: 20626831].
2516 McEwen MM, Rentfro A, Vincent D. Diabetes care in the U.S.-Mexico border region. Nurse Pract. Mar. 2009;34(3):14-21. X-1, X-6, X-7, X-9. [pmid: 19240632].
2517 McFarlane SI, Chaiken RL, Hirsch S, et al. Near-normoglycaemic remission in African-Americans with Type 2 diabetes mellitus is associated with recovery of beta cell function. Diabet Med. Jan. 2001;18(1):10-6. X-2, X-4. [pmid: 11168335].
2518 McGillion MH, Watt-Watson J, Stevens B, et al. Randomized controlled trial of a psychoeducation program for the self-management of chronic cardiac pain. Journal of Pain and Symptom Management. Aug. 2008;36(2):126-40. X-6, X-9. [pmid: 18395397].
2519 McGinn J, Davis C. Geographic variation, physician characteristics, and diabetes care disparities in a metropolitan area, 2003-2004. Diabetes Res Clin Pract. May. 2006;72(2):162-9. X-6, X-7, X-9. [pmid: 16426696].
2520 McGivney WT, Barker ML, Bost JE, et al. Panel discussion. Data needs in cancer. Oncology (Williston Park). Nov. 1998;12(11A):147-56. X-1, X-2, X-4. [pmid: 10028508].
2521 McGough PM. Medical concerns about physician-assisted suicide. Seattle Univ Law Rev. Spring. 1995;18(3):521-30. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11656835].
2522 McGovern MP, Boroujerdi MA, Taylor MW, et al. The effect of the UK incentive-based contract on the management of patients with coronary heart disease in primary care. Fam Pract. Feb. 2008;25(1):33-9. X-2, X-3, X-4. [pmid: 18222938].
2523 McGovern MP, Williams DJ, Hannaford PC, et al. Introduction of a new incentive and target-based contract for family physicians in the UK: good for older patients with diabetes but less good for women?. Diabet Med. Sep. 2008;25(9):1083-9. X-2, X-3, X-4. [pmid: 18937676].
2524 McGrady ME, Laffel L, Drotar D, et al. Depressive symptoms and glycemic control in adolescents with type 1 diabetes: mediational role of blood glucose monitoring. Diabetes Care. May. 2009;32(5):804-6. X-2, X-4, X-6. [pmid: 19228870].
2525 McGregor MJ, Reid RJ, Schulzer M, et al. Socioeconomic status and hospital utilization among younger adult pneumonia admissions at a Canadian hospital. BMC Health Serv Res. 2006;6:152. X-2, X-3, X-4. [pmid: 17125520].
2526 McGuffin M, Wright J. Information-seeking behavior of radiation therapy patients. Radiation Therapist. 2004;13(2):93-8. X-2, X-4, X-5, X-6.
2527 McGuire TG, Ayanian JZ, Ford DE, et al. Testing for statistical discrimination by race/ethnicity in panel data for depression treatment in primary care. Health Serv Res. Apr. 2008;43(2):531-51. X-2, X-4. [pmid: 18370966].
2528 McIntyre-Miller A. Baby Bumps--addressing social inequalities. Pract Midwife. Jan. 2010;13(1):29-31. X-1, X-6, X-7, X-9. [pmid: 20162887].
2529 McKeever C, Faddis C, Koroloff N, et al. Wellness Within REACH: mind, body, and soul: a no-cost physical activity program for African Americans in Portland, Oregon, to combat cardiovascular disease. Ethn Dis. Summer. 2004;14(3 Suppl 1):S93-101. X-7, X-9, X-10. [pmid: 15682777].
2530 McKeever C, Koroloff N, Faddis C. The African American Wellness Village in Portland, Ore. Prev Chronic Dis. Jul. 2006;3(3):A104. X-1, X-2, X-4. [pmid: 16776865].
2531 McKellar JD, Humphreys K, Piette JD. Depression increases diabetes symptoms by complicating patients' self-care adherence. Diabetes Educ. May-Jun. 2004;30(3):485-92. X-6, X-7, X-9. [pmid: 15208846].
2532 McKinney PA, Feltbower RG, Stephenson CR, et al. Children and young people with diabetes in Yorkshire: a population-based clinical audit of patient data 2005/2006. Diabet Med. Nov. 2008;25(11):1276-82. X-2, X-3, X-4. [pmid: 19046216].
2533 McKnight A, Merrett JD. Smoking in pregnancy--a health education problem. J R Coll Gen Pract. Apr. 1986;36(285):161-4. X-2, X-3, X-4, X-6. [pmid: 3735200].
2534 McLean G, Guthrie B, Sutton M. Differences in the quality of primary medical care for CVD and diabetes across the NHS: evidence from the quality and outcomes framework. BMC Health Serv Res. 2007;7:74. X-2, X-3, X-4. [pmid: 17535429].
2535 McLean J, Pietroni P. Self care--who does best?. Soc Sci Med. 1990;30(5):591-6. X-6, X-9. [pmid: 2309137].
2536 McMullen A, Yoos HL, Anson E, et al. Asthma care of children in clinical practice: do parents report receiving appropriate education?. Pediatr Nurs. Jan-Feb. 2007;33(1):37-44. X-6, X-7, X-9. [pmid: 17410999].
2537 McNabb W, Quinn M, Kerver J, et al. The PATHWAYS church-based weight loss program for urban African-American women at risk for diabetes. Diabetes Care. Oct. 1997;20(10):1518-23. X-4, X-5. [pmid: 9314627].
2538 McNamara RL, Powe NR, Shaffer T, et al. Capitation for cardiologists: accepting risk for coronary artery disease under managed care. Am J Cardiol. Nov. 15. 1998;82(10):1178-82. X-2, X-4. [pmid: 9832090].
2539 McNeal B, Salisbury Z, Baumgardner P, et al. Comprehension assessment of diabetes education program participants. Diabetes Care. May-Jun. 1984;7(3):232-5. X-2, X-4, X-6. [pmid: 6734392].
2540 McNeill D, Kelley E. How the national healthcare quality and disparities reports can catalyze quality improvement. Med Care. Mar. 2005;43(3 Suppl):I82-8. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15746595].
2541 McPhee SJ, Bird JA, Davis T, et al. Barriers to breast and cervical cancer screening among Vietnamese-American women. American Journal of Preventive Medicine. May-Jun. 1997;13(3):205-13. X-2, X-4. [pmid: 9181209].
2542 McPhee SJ, Bird JA, Jenkins CN, et al. Promoting cancer screening. A randomized, controlled trial of three interventions. Arch Intern Med. Aug. 1989;149(8):1866-72. X-4, X-6. [pmid: 2764657].
2543 McSweeney JC, Pettey CM, Fischer EP, et al. Going the distance: overcoming challenges in recruitment and retention of Black and White women in multisite, longitudinal study of predictors of coronary heart disease. Res Gerontol Nurs. Oct. 2009;2(4):256-64. X-1, X-7, X-9. [pmid: 20077981].
2544 McTavish FM, Gustafson DH, Owens BH, et al. CHESS (Comprehensive Health Enhancement Support System): an interactive computer system for women with breast cancer piloted with an underserved population. J Ambul Care Manage. Jul. 1995;18(3):35-41. X-2, X-4. [pmid: 10143478].
2545 Mead H, Andres E, Katch H, et al. Gender differences in psychosocial issues affecting low-income, underserved patients' ability to manage cardiovascular disease. Womens Health Issues. Sep. 2010;20(5):308-15. X-2, X-4. [pmid: 20800766].
2546 Mead H, Andres E, Ramos C, et al. Barriers to effective self-management in cardiac patients: The patient's experience. Patient Education and Counseling. Apr. 2010;79(1):69-76. X-2, X-4. [pmid: 19748205].
2547 Meade CD, Calvo A. Developing community-academic partnerships to enhance breast health among rural and Hispanic migrant and seasonal farmworker women. Oncol Nurs Forum. Nov-Dec. 2001;28(10):1577-84. X-1, X-2, X-4. [pmid: 11759305].
2548 Meade CD, Calvo A, Cuthbertson D. Impact of culturally, linguistically, and literacy relevant cancer information among Hispanic farmworker women. J Cancer Educ. Spring. 2002;17(1):50-4. X-9. [pmid: 12000108].
2549 Meade CD, Menard J, Thervil C, et al. Addressing cancer disparities through community engagement: Improving breast health among Haitian women. Oncology Nursing Forum. Nov. 2009;36(6):716-22. X-2, X-4. [pmid: 19887360].
2550 Meadows KA, Wise PH. Questionnaire design in diabetes care and research. 1: Getting the question right. Diabet Med. Oct. 1988;5(7):699-704. X-1, X-6, X-7, X-9. [pmid: 2975559].
2551 Mechakra-Tahiri SD, Zunzunegui MV, Dube M, et al. Associations of social relationships with consultation for symptoms of depression: a community study of depression in older men and women in Quebec. Psychol Rep. Apr. 2011;108(2):537-52. X-2, X-3, X-4, X-6. [pmid: 21675568].
2552 Mednick L, Cogen FR, Streisand R. Satisfaction and quality of life in children with type 1 diabetes and their parents following transition to insulin pump therapy. Children's Health Care. 2004;33(3):169-83. X-2, X-4, X-6.
2553 Meetoo D. Dietary pattern of self-care among Asian and Caucasian diabetic patients. Br J Nurs. Oct. 14-27. 2004;13(18):1074-8. X-2, X-4. [pmid: 15564992].
2554 Mehler PS, Sabel A, Trantanella A, et al. Variation in prehospital and discharge quality of care among acute myocardial infarction patients at a safety net hospital. Crit Pathw Cardiol. Sep. 2009;8(3):127-30. X-2, X-4. [pmid: 19726934].
2555 Mehrotra R, Bajaj S, Kumar D, et al. Influence of education and occupation on knowledge about diabetes control. Natl Med J India. Nov-Dec. 2000;13(6):293-6. X-2, X-3. [pmid: 11209483].
2556 Mehta RH, Bufalino VJ, Pan W, et al. Achieving rapid reperfusion with primary percutaneous coronary intervention remains a challenge: insights from American Heart Association's Get With the Guidelines program. Am Heart J. Jun. 2008;155(6):1059-67. X-2, X-4. [pmid: 18513520].
2557 Mehta RH, Das S, Tsai TT, et al. Quality improvement initiative and its impact on the management of patients with acute myocardial infarction. Arch Intern Med. Nov. 13. 2000;160(20):3057-62. X-6. [pmid: 11074734].
2558 Mehta RH, Montoye CK, Faul J, et al. Enhancing quality of care for acute myocardial infarction: shifting the focus of improvement from key indicators to process of care and tool use: the American College of Cardiology Acute Myocardial Infarction Guidelines Applied in Practice Project in Michigan: Flint and Saginaw Expansion. J Am Coll Cardiol. Jun. 16. 2004;43(12):2166-73. X-6. [pmid: 15193675].
2559 Mehta RH, Montoye CK, Gallogly M, et al. Improving quality of care for acute myocardial infarction: The Guidelines Applied in Practice (GAP) Initiative. JAMA. Mar. 13. 2002;287(10):1269-76. X-6. [pmid: 11886318].
2560 Mehta SN, Volkening LK, Anderson BJ, et al. Dietary behaviors predict glycemic control in youth with type 1 diabetes. Diabetes Care. Jul. 2008;31(7):1318-20. X-2, X-4. [pmid: 18390798].
2561 Meischke H, Bowen D, Kuniyuki A. Awareness of genetic testing for breast cancer risk among women with a family history of breast cancer: effect of women's information sources on their awareness. Cancer Detect Prev. 2001;25(4):319-27. X-2, X-4. [pmid: 11531008].
2562 Melkus GD, Whittemore R, Mitchell J. Type 2 diabetes in urban black and rural white women. Diabetes Educ. Mar-Apr. 2009;35(2):293-301. X-2, X-4. [pmid: 19204103].
2563 Mello M. Plugging the gap--diabetes. Nurs Times. Oct. 21-27. 1992;88(43):34-6. X-1, X-6, X-7, X-9. [pmid: 1437602].
2564 Mellor D, Davison T, McCabe M, et al. The management of depressed elderly care recipients: family perspectives on the skills of professional carers. J Community Health Nurs. Jan-Mar. 2008;25(1):44-61. X-2, X-4. [pmid: 18444065].
2565 Mellor L, Hoskins P. Problems of diabetes education in different cultures. Diabetes Educ. Fall. 1986;12(4):384-6. X-1, X-6, X-7, X-9. [pmid: 3640702].
2566 Melnikow J, Paterniti D, Azari R, et al. Preferences of Women Evaluating Risks of Tamoxifen (POWER) study of preferences for tamoxifen for breast cancer risk reduction. Cancer. May. 15. 2005;103(10):1996-2005. X-2, X-4, X-6. [pmid: 15825209].
2567 Memis S, Evci ED, Ergin F, et al. A population- based study on awareness of heart attack in Aydin city-Turkey. Anadolu Kardiyol Derg. Aug. 2009;9(4):304-10. X-2, X-3, X-4. [pmid: 19666433].
2568 Mendelsohn AL, Dreyer BP, Fierman AH, et al. Law-level lead exposure and behavior in early childhood. Pediatrics. Mar. 1998;101(3). X-2, X-4, X-5, X-6. [pmid: 9481029].
2569 Mendelson SG, McNeese-Smith D, Koniak-Griffin D, et al. A community-based parish nurse intervention program for Mexican American women with gestational diabetes. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2008;37(4):415-25. X-4. [pmid: 18754979].
2570 Mendes AB, Fittipaldi JA, Neves RC, et al. Prevalence and correlates of inadequate glycaemic control: results from a nationwide survey in 6,671 adults with diabetes in Brazil. Acta Diabetol. Jun. 2010;47(2):137-45. X-2, X-3, X-4. [pmid: 19655083].
2571 Mendes AP, Bastos F, Paiva A. A pessoa com InsuficiÃªncia CardÃaca. Factores que facilitam/dificultam a transiÃ§Ã£o saÃºde/doenÃ§a. Referência: Revista Científica da Unidade de Investigação em Ciências da Saúde: Domínio de Enfermagem. 2010;3(2):7-16. X-2, X-3, X-4, X-6.
2572 Meneses K, McNees P, Azuero A, et al. Preliminary evaluation of psychoeducational support interventions on quality of life in rural breast cancer survivors after primary treatment. Cancer Nurs. Sep-Oct. 2009;32(5):385-97. X-4, X-6. [pmid: 19661796].
2573 Meneses KD, Yarbro CH. Cultural perspectives of international breast health and breast cancer education. Journal of Nursing Scholarship. Jun. 2007;39(2):105-12. X-6, X-7, X-9. [pmid: 17535309].
2574 Meng YY, Babey SH, Hastert TA, et al. Uncontrolled asthma means missed work and school, emergency department visits for many Californians. Policy Brief UCLA Cent Health Policy Res. Jul. 2008;(PB2008-2):1-8. X-1, X-2, X-4. [pmid: 18810806].
2575 Meng YY, Leung KM, Berkbigler D, et al. Compliance with US asthma management guidelines and specialty care: a regional variation or national concern?. J Eval Clin Pract. May. 1999;5(2):213-21. X-2, X-4. [pmid: 10471231].
2576 Meng YY, Pourat N, Cosway R, et al. Estimated cost impacts of law to expand coverage for self-management education to children with asthma in California. Journal of Asthma. Jun. 2010;47(5):581-6. X-2, X-4, X-6. [pmid: 20560832].
2577 Menon U, Szalacha LA, Belue R, et al. Interactive, culturally sensitive education on colorectal cancer screening. Med Care. Sep. 2008;46(9 Suppl 1):S44-50. X-6, X-7, X-9. [pmid: 18725832].
2578 Merighi JR, Ehlebracht K. Workplace resources, patient caseloads, and job satisfaction of renal social workers in the United States. A Survey/Part 1. Nephrol News Issues. Apr. 2004;18(5):58-60. 2. 4. passim. X-6, X-7, X-9. [pmid: 15125167].
2579 Merikangas KR, Jin R, He JP, et al. Prevalence and correlates of bipolar spectrum disorder in the world mental health survey initiative. Arch Gen Psychiatry. Mar. 2011;68(3):241-51. X-2, X-3, X-4, X-5, X-6. [pmid: 21383262].
2580 Merkin SS, Karlamangla A, Crimmins E, et al. Education differentials by race and ethnicity in the diagnosis and management of hypercholesterolemia: a national sample of U.S. adults (NHANES 1999-2002). Int J Public Health. 2009;54(3):166-74. X-2, X-5. [pmid: 19219403].
2581 Merriam PA, Tellez TL, Rosal MC, et al. Methodology of a diabetes prevention translational research project utilizing a community-academic partnership for implementation in an underserved Latino community. Bmc Medical Research Methodology. Mar. 2009:9. X-7, X-9. [pmid: 19208234].
2582 Merrick EL. Treatment of major depression before and after implementation of a behavioral health carve-out plan. Psychiatr Serv. Dec. 1998;49(12):1563-7. X-6, X-7, X-9. [pmid: 9856617].
2583 Merrick EL. Effects of a behavioral health carve-out on inpatient-related quality indicators for major depression treatment. Med Care. Oct. 1999;37(10):1023-33. X-6, X-7, X-9. [pmid: 10524369].
2584 Merrick NJ, Houchens R, Tillisch S, et al. Quality of hospital care of children with asthma: Medicaid versus privately insured patients. J Health Care Poor Underserved. May. 2001;12(2):192-207. X-2, X-4. [pmid: 11370187].
2585 Merrick RD, Olive KE, Hamdy RC, et al. Factors influencing the accuracy of home blood pressure measurement. South Med J. Nov. 1997;90(11):1110-4. X-2, X-4, X-5, X-6. [pmid: 9386053].
2586 Merrill RM, Chatterley A, Shields EC. Perceived effectiveness among college students of selected statistical measures in motivating exercise behavior. American Journal of Health Education. 2005;36(2):94-101. X-2, X-4, X-5, X-6.
2587 Merritt SL. Learning style preferences of coronary artery disease patients. Cardiovasc Nurs. Mar-Apr. 1991;27(2):7-11. discussion 2. X-2, X-4. [pmid: 2070376].
2588 Messier L, Schmitz N, Elisha B, et al. Lifestyle and care indicators in individuals with major, minor and no depression: a community-based diabetes study in Quebec. Canadian Journal of Diabetes. 2011;35(1):22-30. X-2, X-3, X-4, X-6.
2589 Messina CR, Lane DS, Glanz K, et al. Relationship of social support and social burden to repeated breast cancer screening in the women's health initiative. Health Psychol. Nov. 2004;23(6):582-94. X-6, X-7, X-9. [pmid: 15546226].
2590 Metayer N, Jean-Louis E, Madison A. Overcoming historical and institutional distrust: key elements in developing and sustaining the community mobilization against HIV in the Boston Haitian community. Ethn Dis. Summer. 2004;14(3 Suppl 1):S46-52. X-1, X-2, X-4, X-5. [pmid: 15682771].
2591 Metghalchi S, Rivera M, Beeson L, et al. Improved clinical outcomes using a culturally sensitive diabetes education program in a Hispanic population. Diabetes Educ. Jul-Aug. 2008;34(4):698-706. X-4. [pmid: 18669812].
2592 Meyer IH, Sternfels P, Fagan JK, et al. Characteristics and correlates of asthma knowledge among emergency department users in Harlem. J Asthma. Oct. 2001;38(7):531-9. X-2, X-4, X-6. [pmid: 11714075].
2593 Meyer LC. Why centers of excellence are gaining momentum. J Health Care Benefits. May-Jun. 1994;3(5):52-6. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10133665].
2594 Mezza E, Consiglio V, Soragna G, et al. CKD patients and erythropoietin: do we need evidence-based informed consent?. Int J Artif Organs. Jun. 2005;28(6):591-9. X-2, X-3, X-4, X-6. [pmid: 16015569].
2595 Mian SI, Brauer PM. Dietary education tools for South Asians with diabetes. Can J Diet Pract Res. Spring. 2009;70(1):28-35. X-2, X-3, X-4. [pmid: 19261204].
2596 Miazga EJ, Biesboer AN, Hayney MS. Updated recommendations for the use of pneumococcal polysaccharide vaccine. J Am Pharm Assoc (2003). Mar-Apr. 1. 2010;50(2):321-3. X-1, X-6, X-7, X-9. [pmid: 20199968].
2597 Michalowski KM, Gold JA, Morse DL, et al. Reducing disparities in lipid testing for African-Americans with diabetes: interim report. J Health Hum Serv Adm. Winter. 2003;26(3):363-81. X-7, X-9. [pmid: 15704639].
2598 Michielutte R, Sharp PC, Foley KL, et al. Intervention to increase screening mammography among women 65 and older. Health Educ Res. Apr. 2005;20(2):149-62. X-6, X-9. [pmid: 15254001].
2599 Middelkoop BJ, van der Wal G. Culture-specific diabetes care for Surinam South Asians with a low socio-economic position: who benefits?. Patient Educ Couns. Jun. 2004;53(3):353-8. X-3, X-4. [pmid: 15186874].
2600 Midmer D, Wilson L, Cummings S. A randomized, controlled trial of the influence of prenatal parenting education on postpartum anxiety and marital adjustment. Fam Med. Mar. 1995;27(3):200-5. X-6, X-9. [pmid: 7774781].
2601 Miech RA, Kim J, McConnell C, et al. A growing disparity in diabetes-related mortality U.S. trends, 1989-2005. Am J Prev Med. Feb. 2009;36(2):126-32. X-2, X-4. [pmid: 19062239].
2602 Mieczkowski TA, Wilson SA. Adult pneumococcal vaccination: a review of physician and patient barriers. Vaccine. Jan. 31. 2002;20(9-10):1383-92. X-1, X-2, X-4. [pmid: 11818157].
2603 Mielck A, Reitmeir P, Rathmann W. Knowledge about diabetes and participation in diabetes training courses: the need for improving health care for diabetes patients with low SES. Exp Clin Endocrinol Diabetes. May. 2006;114(5):240-8. X-2, X-4. [pmid: 16804798].
2604 Mier N, Bocanegra-Alonso A, Zhan D, et al. Health-related quality of life in a binational population with diabetes at the Texas-Mexico border. Rev Panam Salud Publica. Mar. 2008;23(3):154-63. X-2, X-4. [pmid: 18397581].
2605 Migliaresi P, Celentano A, Palmieri V, et al. Knowledge of cardiovascular risk factors and awareness of non-pharmacological approach for risk prevention in young survivors of acute myocardial infarction. The cardiovascular risk prevention project “Help Your Heart Stay Young”. Nutr Metab Cardiovasc Dis. Jul. 2007;17(6):468-72. X-2, X-4. [pmid: 17379491].
2606 Miller DP Jr., Brownlee CD, McCoy TP, et al. The effect of health literacy on knowledge and receipt of colorectal cancer screening: a survey study. BMC Fam Pract. 2007;8:16. X-2, X-4. [pmid: 17394668].
2607 Miller DP, Spangler JG, Case LD, et al. Effectiveness of a Web-Based Colorectal Cancer Screening Patient Decision Aid A Randomized Controlled Trial in a Mixed-Literacy Population. American Journal of Preventive Medicine. Jun. 2011;40(6):608-15. X-7, X-9. [pmid: 21565651].
2608 Miller L, Shade M, Vasireddy V. Beyond screening: assessment of perinatal depression in a perinatal care setting. Arch Womens Ment Health. Oct. 2009;12(5):329-34. X-6, X-7, X-9. [pmid: 19499284].
2609 Miller SA, Mancuso CA, Boutin-Foster C, et al. Associations between posttraumatic stress disorder and hemoglobin A1(C) in low-income minority patients with diabetes. Gen Hosp Psychiatry. Mar-Apr. 2011;33(2):116-22. X-2, X-4. [pmid: 21596204].
2610 Miller ST, Marolen KN, Beech BM. Perceptions of physical activity and motivational interviewing among rural African-American women with type 2 diabetes. Womens Health Issues. Jan-Feb. 2010;20(1):43-9. X-2, X-4. [pmid: 19944621].
2611 Miller ST, Mushi C, Ahmed NU, et al. Using focus groups to understand health-related practices and perceptions of African Americans: Nashville REACH 2010 preliminary findings. Ethn Dis. Summer. 2004;14(3 Suppl 1):S70-6. X-2, X-4. [pmid: 15682774].
2612 Miller ST, Schlundt DG, Larson C, et al. Exploring ethnic disparities in diabetes, diabetes care, and lifestyle behaviors: the Nashville REACH 2010 community baseline survey. Ethn Dis. Summer. 2004;14(3 Suppl 1):S38-45. X-2, X-4. [pmid: 15682770].
2613 Miller ST, Seib HM, Dennie SP. African American perspectives on health care: the voice of the community. J Ambul Care Manage. Jul. 2001;24(3):37-44. X-6, X-7, X-9. [pmid: 11433554].
2614 Millett C, Dodhia H. Diabetes retinopathy screening: audit of equity in participation and selected outcomes in South East London. J Med Screen. 2006;13(3):152-5. X-2, X-3, X-4. [pmid: 17007657].
2615 Millett C, Gray J, Bottle A, et al. Ethnic disparities in blood pressure management in patients with hypertension after the introduction of pay for performance. Ann Fam Med. Nov-Dec. 2008;6(6):490-6. X-2, X-3, X-4. [pmid: 19001300].
2616 Millett C, Gray J, Saxena S, et al. Ethnic disparities in diabetes management and pay-for-performance in the UK: the Wandsworth Prospective Diabetes Study. PLoS Med. Jun. 2007;4(6):e191. X-2, X-3, X-4. [pmid: 17564486].
2617 Millett C, Gray J, Wall M, et al. Ethnic disparities in coronary heart disease management and pay for performance in the UK. J Gen Intern Med. Jan. 2009;24(1):8-13. X-2, X-3, X-4. [pmid: 18953616].
2618 Mills G, Barnes R, Rodell DE, et al. An evaluation of an inpatient cardiac patient/family education program. Heart Lung. Jul. 1985;14(4):400-6. X-1, X-6, X-7, X-9. [pmid: 3847417].
2619 Minai BA, Martin JE, Cohn RC. Results of a physician and respiratory therapist collaborative effort to improve long-term metered-dose inhaler technique in a pediatric asthma clinic. Respir Care. Jun. 2004;49(6):600-5. X-4, X-6, X-9. [pmid: 15165293].
2620 Miranda J, Azocar F, Organista KC, et al. Treatment of depression among impoverished primary care patients from ethnic minority groups. Psychiatr Serv. Feb. 2003;54(2):219-25. X-9. [pmid: 12556604].
2621 Miranda J, Chung JY, Green BL, et al. Treating depression in predominantly low-income young minority women: a randomized controlled trial. JAMA. Jul. 2. 2003;290(1):57-65. X-7, X-9. [pmid: 12837712].
2622 Miranda J, Cooper LA. Disparities in care for depression among primary care patients. J Gen Intern Med. Feb. 2004;19(2):120-6. X-6, X-7, X-9. [pmid: 15009791].
2623 Miranda J, Green BL, Krupnick JL, et al. One-year outcomes of a randomized clinical trial treating depression in low-income minority women. J Consult Clin Psychol. Feb. 2006;74(1):99-111. X-7. [pmid: 16551147].
2624 Miranda J, Hepner KA, Azocar F, et al. Development of a patient-report measure of psychotherapy for depression. Adm Policy Ment Health. May. 2010;37(3):245-53. X-6, X-7, X-9. [pmid: 19757020].
2625 Mirvis DM, Burns R, Gaschen L, et al. Variation in utilization of cardiac procedures in the Department of Veterans Affairs health care system: effect of race. J Am Coll Cardiol. Nov. 1. 1994;24(5):1297-304. X-2, X-4. [pmid: 7930253].
2626 Mirvis DM, Graney MJ. Impact of race and age on the effects of regionalization of cardiac procedures in the Department of Veterans Affairs Health Care System. Am J Cardiol. Apr. 15. 1998;81(8):982-7. X-2, X-4. [pmid: 9576157].
2627 Mischoulon D, McColl-Vuolo R, Howarth S, et al. Management of major depression in the primary care setting. Psychother Psychosom. Mar-Apr. 2001;70(2):103-7. X-4. [pmid: 11244391].
2628 Mishel MH, Germino BB, Gil KM, et al. Benefits from an uncertainty management intervention for African-American and Caucasian older long-term breast cancer survivors. Psychooncology. Nov. 2005;14(11):962-78. X-6, X-7, X-9, X-10. [pmid: 15712339].
2629 Mishra SI, Chavez LR, Magana JR, et al. Improving breast cancer control among Latinas: evaluation of a theory-based educational program. Health Educ Behav. Oct. 1998;25(5):653-70. X-4. [pmid: 9768384].
2630 Mitchell C, Notterman D, Brooks-Gunn J, et al. Role of mother's genes and environment in postpartum depression. Proc Natl Acad Sci U S A. May. 17. 2011;108(20):8189-93. X-2, X-4. [pmid: 21576482].
2631 Mitchell EA, Ferguson V, Norwood M. Asthma education by community child health nurses. Arch Dis Child. Dec. 1986;61(12):1184-9. X-3. [pmid: 3545094].
2632 Mitikulena A, Smith RB. Views of Pacific Islands people with noninsulin dependent diabetes: a Wellington survey. N Z Med J. Dec. 13. 1996;109(1035):467-9. X-2, X-3, X-4. [pmid: 9006628].
2633 Mitra A, Bhattacharya D. Ethical problems faced in villages of rural Bengal while conducting researches on chronic diseases like diabetes. Indian J Med Sci. Nov. 2006;60(11):475-84. X-1, X-3. [pmid: 17090871].
2634 Mittelmark MB, Luepker RV, Jacobs DR, et al. Community-wide prevention of cardiovascular disease: education strategies of the Minnesota Heart Health Program. Prev Med. Jan. 1986;15(1):1-17. X-6, X-9. [pmid: 3714655].
2635 Mock J, Nguyen T, Nguyen KH, et al. Processes and capacity-building benefits of lay health worker outreach focused on preventing cervical cancer among Vietnamese. Health Promot Pract. Jul. 2006;7(3 Suppl):223S-32S. X-2, X-4, X-5. [pmid: 16760246].
2636 Mock KS, Phillips KD, Sowell RL. Depression and sleep dysfunction as predictors of fatigue in HIV-infected African-American women. Clinical Excellence for Nurse Practitioners. 2002;6(2):9-16. X-2, X-4, X-5.
2637 Moffet HH, Parker MM, Sarkar U, et al. Adherence to Laboratory Test Requests by Patients With Diabetes: The Diabetes Study of Northern California (DISTANCE). American Journal of Managed Care. May. 2011;17(5):339-44. X-2, X-4, X-6. [pmid: 21718081].
2638 Mohrmann CC, Coleman EA, Coon SK, et al. An analysis of printed breast cancer information for African American women. J Cancer Educ. Spring. 2000;15(1):23-7. X-2, X-4. [pmid: 10730799].
2639 Monay V, Mangione CM, Sorrell-Thompson A, et al. Services delivered by faith-community nurses to individuals with elevated blood pressure. Public Health Nurs. Nov-Dec. 2010;27(6):537-43. X-2, X-4, X-6. [pmid: 21087307].
2640 Monga U, Kerrigan AJ, Garber S, et al. Pre- and post-radiotherapy sexual functioning in prostate cancer patients. Sexuality & Disability. 2001;19(4):239-52. X-2, X-4, X-5, X-6.
2641 Montague MC, Nichols SA, Dutta AP. Self-management in African American women with diabetes. Diabetes Educ. Sep-Oct. 2005;31(5):700-11. X-2, X-4. [pmid: 16203854].
2642 Montealegre F, Chardon D, Vargas W, et al. Measuring asthma disparities in Hispanics: adherence to the national guidelines for asthma treatment in emergency departments in Puerto Rico. Ann Allergy Asthma Immunol. Nov. 2004;93(5):472-7. X-2, X-4. [pmid: 15562887].
2643 Montgomery BD, McMeniman E, Cameron SK, et al. Sex, pain and cranberries - ideas from the 2006 Registrar Research Workshop. Aust Fam Physician. Jan-Feb. 2007;36(1-2):93-4. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17310543].
2644 Montgomery DA, Amos RJ. Nutrition information needs during cardiac rehabilitation: perceptions of the cardiac patient and spouse. J Am Diet Assoc. Sep. 1991;91(9):1078-83. X-1, X-2, X-4. [pmid: 1918759].
2645 Montgomery M. Breast self-exam: relevance for young female childhood cancer survivors. Southern Online Journal of Nursing Research. 2008;8(2):2p. X-6, X-7, X-9.
2646 Montoye CK, Mehta RH, Baker PL, et al. A rapid-cycle collaborative model to promote guidelines for acute myocardial infarction. Jt Comm J Qual Saf. Sep. 2003;29(9):468-78. X-6. [pmid: 14513670].
2647 Moody-Ayers SY, Stewart AL, Covinsky KE, et al. Prevalence and correlates of perceived societal racism in older African-American adults with type 2 diabetes mellitus. J Am Geriatr Soc. Dec. 2005;53(12):2202-8. X-2, X-4. [pmid: 16398910].
2648 Moore C, Yee J, Malluche H, et al. Relationship between bone histology and markers of bone and mineral metabolism in African-American hemodialysis patients. Clin J Am Soc Nephrol. Sep. 2009;4(9):1484-93. X-2, X-4. [pmid: 19713297].
2649 Moore DE Jr., Cervero RM, Fox R. A conceptual model of CME to address disparities in depression care. J Contin Educ Health Prof. Fall. Suppl 1. 2007;27:S40-54. X-1, X-2, X-3, X-4. [pmid: 18085583].
2650 Moore DE Jr., Niebler SE, Schlundt DG, et al. A conceptual model for using action inquiry technologies to address disparities in depression. J Contin Educ Health Prof. Fall. Suppl 1. 2007;27:S55-64. X-1, X-2, X-4, X-6. [pmid: 18085578].
2651 Moore DE Jr., Overstreet KM, Like RC, et al. Improving depression care for ethnic and racial minorities: a concept for an intervention that integrates CME planning with improvement strategies. J Contin Educ Health Prof. Fall. Suppl 1. 2007;27:S65-74. X-1, X-6, X-7, X-9. [pmid: 18085584].
2652 Moore G. Screening is key to preventing colorectal cancer. Bus Health. Jun. 2001;19(6):40. X-1, X-6, X-7, X-9. [pmid: 11434097].
2653 Moore ML, Ketner M, Walsh K, et al. Listening to women at risk for preterm birth. MCN Am J Matern Child Nurs. Nov-Dec. 2004;29(6):391-7. X-2, X-4. [pmid: 15618866].
2654 Moorin RE, Holman CD. The effects of socioeconomic status, accessibility to services and patient type on hospital use in Western Australia: a retrospective cohort study of patients with homogenous health status. BMC Health Serv Res. 2006;6:74. X-2, X-3, X-4, X-5, X-6. [pmid: 16774689].
2655 Moreno L, Dale SB, Chen AY, et al. Costs to Medicare of the Informatics for Diabetes Education and Telemedicine (IDEATel) home telemedicine demonstration: findings from an independent evaluation. Diabetes Care. Jul. 2009;32(7):1202-4. X-6, X-9. [pmid: 19366971].
2656 Morgan A, Jorm A. Awareness of beyondblue: the national depression initiative in Australian young people. Australas Psychiatry. Aug. 2007;15(4):329-33. X-2, X-3, X-4. [pmid: 17612888].
2657 Morgan C, Levin G. A cancer-prevention intervention for disadvantaged women: design and implementation. J Cancer Educ. Fall. 1995;10(3):168-75. X-9. [pmid: 8534604].
2658 Morgan CJ, Muetzelfeldt L, Curran HV. Consequences of chronic ketamine self-administration upon neurocognitive function and psychological wellbeing: a 1-year longitudinal study. Addiction. Jan. 2010;105(1):121-33. X-2, X-4, X-5, X-6. [pmid: 19919593].
2659 Morgan JB, Williams P, Foote KD, et al. Do mothers understand healthy eating principles for low-birth-weight infants?. Public Health Nutr. Sep. 2006;9(6):700-6. X-2, X-3, X-4, X-5. [pmid: 16925874].
2660 Morgan PD, Barnett K, Perdue B, et al. African American women with breast cancer and their spouses' perception of care received from physicians. ABNF J. Jan-Feb. 2006;17(1):32-7. X-2. [pmid: 16596898].
2661 Morgan PD, Fogel J, Tyler ID, et al. Culturally targeted educational intervention to increase colorectal health awareness among African Americans. J Health Care Poor Underserved. Aug. 2010;21(3 Suppl):132-47. X-4, X-9. [pmid: 20675951].
2662 Morgan PD, Gaston-Johansson F, Mock V. Spiritual well-being, religious coping, and the quality of life of African American breast cancer treatment: a pilot study. ABNF J. Spring. 2006;17(2):73-7. X-2, X-4. [pmid: 18402347].
2663 Morgan RC Jr. Report of the NMA panel on mammography. J Natl Med Assoc. Jul. 1997;89(7):440-3. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 9220692].
2664 Morin D, Cobigo V, Rivard M, et al. Intellectual disabilities and depression: How to adapt psychological assessment and intervention. Canadian Psychology/Psychologie canadienne. Aug. 2010;51(3):185-93. X-1, X-6, X-7, X-9.
2665 Morisky DE, Lees NB, Sharif BA, et al. Reducing disparities in hypertension control: a community-based hypertension control project (CHIP) for an ethnically diverse population. Health Promotion Practice. 2002;3(2):264-75. X-9.
2666 Morrato EH, Druss BG, Hartung DM, et al. Small area variation and geographic and patient-specific determinants of metabolic testing in antipsychotic users. Pharmacoepidemiol Drug Saf. Jan. 2011;20(1):66-75. X-2, X-4, X-5, X-6. [pmid: 21182154].
2667 Morrato EH, Hill JO, Wyatt HR, et al. Are health care professionals advising patients with diabetes or at risk for developing diabetes to exercise more?. Diabetes Care. Mar. 2006;29(3):543-8. X-2. [pmid: 16505503].
2668 Morris AM, Baldwin LM, Matthews B, et al. Reoperation as a quality indicator in colorectal surgery: a population-based analysis. Ann Surg. Jan. 2007;245(1):73-9. X-2, X-4. [pmid: 17197968].
2669 Morris E, Haward RA, Gilthorpe MS, et al. The impact of the Calman-Hine report on the processes and outcomes of care for Yorkshire's colorectal cancer patients. Br J Cancer. Oct. 23. 2006;95(8):979-85. X-2, X-3. [pmid: 17047646].
2670 Morris E, Haward RA, Gilthorpe MS, et al. The impact of the Calman-Hine report on the processes and outcomes of care for Yorkshire's breast cancer patients. Ann Oncol. Feb. 2008;19(2):284-91. X-2, X-3, X-4. [pmid: 17785759].
2671 Morris GS, Graney MJ, Bevilacqua SA, et al. A nonpharmacologic intervention for syndrome X in a low-income urban population. J Tenn Med Assoc. Jul. 1995;88(7):265-7. X-7, X-9. [pmid: 7658689].
2672 Morris NS, MacLean CD, Chew LD, et al. The Single Item Literacy Screener: evaluation of a brief instrument to identify limited reading ability. BMC Fam Pract. 2006;7:21. X-2, X-4. [pmid: 16563164].
2673 Morris NS, MacLean CD, Littenberg B. Literacy and health outcomes: a cross-sectional study in 1002 adults with diabetes. BMC Fam Pract. 2006;7:49. X-2, X-4. [pmid: 16907968].
2674 Morrison C. Determining crucial correlates of breast self-examination in older women with low incomes. Oncol Nurs Forum. Jan-Feb. 1996;23(1):83-93. X-2, X-4. [pmid: 8628714].
2675 Morrow D, Clark D, Tu W, et al. Correlates of health literacy in patients with chronic heart failure. Gerontologist. Oct. 2006;46(5):669-76. X-6, X-7, X-9. [pmid: 17050758].
2676 Morrow D, Clark D, Tu WZ, et al. Correlates of health literacy in patients with chronic heart failure. Gerontologist. Oct. 2006;46(5):669-76. X-2, X-4. [pmid: 17050758].
2677 Morrow DG, Weiner M, Deer MM, et al. Patient-centered instructions for medications prescribed for the treatment of heart failure. Am J Geriatr Pharmacother. Mar. 2004;2(1):44-52. X-6, X-7, X-9. [pmid: 15555478].
2678 Morrow DG, Weiner M, Steinley D, et al. Patients' health literacy and experience with instructions: influence preferences for heart failure medication instructions. J Aging Health. Aug. 2007;19(4):575-93. X-6, X-7, X-9. [pmid: 17682075].
2679 Morrow DG, Weiner M, Young J, et al. Improving medication knowledge among older adults with heart failure: a patient-centered approach to instruction design. Gerontologist. Aug. 2005;45(4):545-52. X-4, X-6. [pmid: 16051918].
2680 Morrow M, Mujahid M, Lantz PM, et al. Correlates of breast reconstruction: results from a population-based study. Cancer. Dec. 1. 2005;104(11):2340-6. X-2, X-4. [pmid: 16216000].
2681 Mortensen EM, Cornell J, Whittle J. Racial variations in processes of care for patients with community-acquired pneumonia. BMC Health Serv Res. Aug. 10. 2004;4(1):20. X-2, X-4. [pmid: 15304197].
2682 Morton E, Tambor E, Rimer BK, et al. Impact of National Cancer Institute revised mammography screening guidelines on women 40-49. Womens Health Issues. Sep-Oct. 1996;6(5):246-54. X-6, X-7, X-9. [pmid: 8870503].
2683 Mosca L, Linfante AH, Benjamin EJ, et al. National study of physician awareness and adherence to cardiovascular disease prevention guidelines. Circulation. Feb. 1. 2005;111(4):499-510. X-6, X-7, X-9. [pmid: 15687140].
2684 Moser M, Franklin SS. Hypertension management: results of a new national survey for the hypertension education foundation: Harris interactive. J Clin Hypertens (Greenwich). May. 2007;9(5):316-23. X-2, X-4. [pmid: 17485966].
2685 Moses RG. Diabetic clinics: a review of ethnic, suburban and medical referral patterns. Aust Clin Rev. Dec. 1983;(11):21-4. X-1, X-2, X-3, X-4. [pmid: 6675638].
2686 Mosher CE, DuHamel KN, Egert J, et al. Self-efficacy for Coping With Cancer in a Multiethnic Sample of Breast Cancer Patients: Associations With Barriers to Pain Management and Distress. Clinical Journal of Pain. Mar-Apr. 2010;26(3):227-34. X-2, X-4. [pmid: 20173437].
2687 Mosnaim G, Kohrman C, Sharp LK, et al. Coping with asthma in immigrant Hispanic families: a focus group study. Ann Allergy Asthma Immunol. Oct. 2006;97(4):477-83. X-2, X-4. [pmid: 17069102].
2688 Mosnaim GS, Cohen MS, Rhoads CH, et al. Use of MP3 players to increase asthma knowledge in inner-city African-American adolescents. Int J Behav Med. 2008;15(4):341-6. X-4. [pmid: 19005935].
2689 Mosnaim GS, Sadowski LS, Durazo-Arvizu RA, et al. Parental language and asthma among urban Hispanic children. Journal of Allergy and Clinical Immunology. Nov. 2007;120(5):1160-5. X-2, X-4. [pmid: 17983874].
2690 Moss L, Crane PB. Exploring polypharmacy in elderly women after myocardial infarction. J Women Aging. Jan. 2010;22(1):22-33. X-2, X-4, X-6. [pmid: 20391146].
2691 Moth G, Schiotz PO, Parner E, et al. Use of lung function tests in asthmatic children is associated with lower risk of hospitalization. A Danish population-based follow-up study. J Asthma. Nov. 2010;47(9):1022-30. X-2, X-3, X-4, X-6. [pmid: 20936993].
2692 Moth G, Schiotz PO, Vedsted P. A Danish population-based cohort study of newly diagnosed asthmatic children's care pathway - adherence to guidelines. BMC Health Serv Res. 2008;8:130. X-2, X-3, X-4. [pmid: 18549494].
2693 Moudgil H, Honeybourne D. Differences in asthma management between white European and Indian subcontinent ethnic groups living in socioeconomically deprived areas in the Birmingham (UK) conurbation. Thorax. Jun. 1998;53(6):490-4. X-2, X-3, X-4. [pmid: 9713449].
2694 Moudgil H, Marshall T, Honeybourne D. Asthma education and quality of life in the community: a randomised controlled study to evaluate the impact on white European and Indian subcontinent ethnic groups from socioeconomically deprived areas in Birmingham, UK. Thorax. Mar. 2000;55(3):177-83. X-3. [pmid: 10679534].
2695 Mousa SM, Brooks E, Dietrich M, et al. Community health workers speak out about the Kin KeeperSM model. J Cancer Educ. Jun. 2010;25(2):236-41. X-6, X-9. [pmid: 20204574].
2696 Movahedi M, Hajarizadeh B, Rahimi A, et al. Trends and geographical inequalities of the main health indicators for rural Iran. Health Policy Plan. May. 2009;24(3):229-37. X-2, X-3, X-4, X-6. [pmid: 19304787].
2697 Moy F, Sallam AA, Wong M. The results of a worksite health promotion programme in Kuala Lumpur, Malaysia. Health Promot Int. Dec. 2006;21(4):301-10. X-3, X-5. [pmid: 16963785].
2698 Muchiri JW, Gericke G, Rheeder P. Elements of effective nutrition education for adults with diabetes mellitus in resource-poor settings: a review. Health SA Gesondheid. 2009;14(1):1-9. X-1, X-6, X-7, X-9.
2699 Muhlhauser I, Overmann H, Bender R, et al. Risk factors of severe hypoglycaemia in adult patients with Type I diabetes--a prospective population based study. Diabetologia. Nov. 1998;41(11):1274-82. X-2, X-3, X-4, X-6. [pmid: 9833933].
2700 Muhlhauser I, Overmann H, Bender R, et al. Social status and the quality of care for adult people with type I (insulin-dependent) diabetes mellitus--a population-based study. Diabetologia. Oct. 1998;41(10):1139-50. X-2, X-3, X-4, X-6. [pmid: 9794099].
2701 Muhlhauser I, Overmann H, Bender R, et al. Predictors of mortality and end-stage diabetic complications in patients with Type 1 diabetes mellitus on intensified insulin therapy. Diabet Med. Oct. 2000;17(10):727-34. X-6, X-7. [pmid: 11110506].
2702 Mui AC. Living alone and depression among older Chinese immigrants. Journal of Gerontological Social Work. 1998;30(3/4):147-66. X-2, X-4.
2703 Mui AC. Stress, coping, and depression among elderly Korean immigrants. Journal of Human Behavior in the Social Environment. 2001;3(3/4):281-99. X-2, X-4.
2704 Mui AC, Kang SY, Kang D, et al. English language proficiency and health-related quality of life among Chinese and Korean immigrant elders. Health & Social Work. May. 2007;32(2):119-27. X-2, X-4, X-5. [pmid: 17571645].
2705 Mularski RA, Asch SM, Shrank WH, et al. The quality of obstructive lung disease care for adults in the United States as measured by adherence to recommended processes. Chest. Dec. 2006;130(6):1844-50. X-2, X-4, X-5. [pmid: 17167007].
2706 Mulgirigama A, Illangasekera U. Study of the quality of care at a diabetic clinic in Sri Lanka. J R Soc Promot Health. Sep. 2000;120(3):164-9. X-2, X-3, X-4. [pmid: 11077804].
2707 Mull DS, Mull JD, Kundi MZ, et al. Mothers' perceptions of severe pneumonia in their own children: a controlled study in Pakistan. Soc Sci Med. Apr. 1994;38(7):973-87. X-2, X-3, X-4. [pmid: 8202745].
2708 Mullin V, Cella D, Chang CH, et al. Development of three African language translations of the FACT-G. Quality of Life Research. Mar. 2000;9(2):139-49. X-2, X-4, X-5, X-6. [pmid: 10983478].
2709 Mullins CD, Blatt L, Gbarayor CM, et al. Health disparities: a barrier to high-quality care. Am J Health Syst Pharm. Sep. 15. 2005;62(18):1873-82. X-1, X-6, X-7, X-9. [pmid: 16141106].
2710 Mulrow C, Bailey S, Sonksen PH, et al. Evaluation of an Audiovisual Diabetes Education Program: negative results of a randomized trial of patients with non-insulin-dependent diabetes mellitus. J Gen Intern Med. Jul-Aug. 1987;2(4):215-9. X-6, X-9. [pmid: 2441013].
2711 Mulvaney C, Kendrick D. Do maternal depressive symptoms, stress and a lack of social support influence whether mothers living in deprived circumstances adopt safety practices for the prevention of childhood injury?. Child: Care, Health and Development. May. 2006;32(3):311-9. X-2, X-3, X-4, X-5, X-6.
2712 Mulvaney SA, Mudasiru E, Schlundt DG, et al. Self-management in type 2 diabetes: the adolescent perspective. Diabetes Educ. Jul-Aug. 2008;34(4):674-82. X-2, X-4. [pmid: 18669809].
2713 Mulvaney SA, Schlundt DG, Mudasiru E, et al. Parent perceptions of caring for adolescents with type 2 diabetes. Diabetes Care. May. 2006;29(5):993-7. X-2, X-4. [pmid: 16644626].
2714 Mundinger MO, Kane RL, Lenz ER, et al. Primary care outcomes in patients treated by nurse practitioners or physicians: a randomized trial…. Copyright CO 2000 American Medical Association. All rights reserved. JAMA. January. 5. 2000;283(No. 1):59-68. Academic Nurse. 2000;17(1):8-17. X-6, X-7, X-9. [pmid: 10632281].
2715 Munn EM. Nonparticipation in mammography screening: apathy, anxiety or cost?. N Z Med J. Jul. 14. 1993;106(959):284-6. X-2, X-3, X-4. [pmid: 8321446].
2716 Munoz RF, Mendelson T. Toward evidence-based interventions for diverse populations: The San Francisco General Hospital prevention and treatment manuals. J Consult Clin Psychol. Oct. 2005;73(5):790-9. X-1, X-6, X-7, X-9. [pmid: 16287379].
2717 Munro JF, Haire-Joshu D, Fisher EB, et al. Articulation of asthma and its care among low-income emergency care recipients. J Asthma. 1996;33(5):313-25. X-2, X-4. [pmid: 8827938].
2718 Munzenberger P, Secord E, Thomas R. Relationship between patient, caregiver, and asthma characteristics, responsibility for management, and indicators of asthma control within an urban clinic. J Asthma. Feb. 2010;47(1):41-5. X-2, X-4, X-6. [pmid: 20100019].
2719 Murimi MW, Harpel T. Practicing Preventive Health: The Underlying Culture Among Low-Income Rural Populations. Journal of Rural Health. Sum. 2010;26(3):273-82. X-2, X-4. [pmid: 20633096].
2720 Murphey C, Rew L. Three intervention models for exploring oral health in pregnant minority adolescents. J Spec Pediatr Nurs. Apr. 2009;14(2):132-41. X-1, X-6, X-7, X-9. [pmid: 19356207].
2721 Murphy FG, Satterfield D, Anderson RM, et al. Diabetes educators as cultural translators. Diabetes Educ. Mar-Apr. 1993;19(2):113-6. 8. X-1, X-6, X-7, X-9. [pmid: 8458306].
2722 Murphy NJ, Boyko EJ, Schraer CD, et al. Use of a reflectance photometer as a diabetes mellitus screening tool under field conditions. Arctic Med Res. Oct. 1993;52(4):170-4. X-2, X-4. [pmid: 8305095].
2723 Murphy TE Jr. Underwriting chronic renal failure. J Insur Med. 2001;33(4):358-9. X-1. [pmid: 11877918].
2724 Murray J, Saxena S, Millett C, et al. Reductions in risk factors for secondary prevention of coronary heart disease by ethnic group in south-west London: 10-year longitudinal study (1998-2007). Fam Pract. Aug. 2010;27(4):430-8. X-2, X-3, X-4. [pmid: 20538744].
2725 Murray MD, Tu W, Wu J, et al. Factors associated with exacerbation of heart failure treatment adherence and health literacy skills. Clin Pharmacol Ther. Jun. 2009;85(6):651-8. X-2, X-4. [pmid: 19262464].
2726 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. X-7, X-9. [pmid: 17502632].
2727 Murray MD, Young JM, Morrow DG, et al. Methodology of an ongoing, randomized, controlled trial to improve drug use for elderly patients with chronic heart failure. Am J Geriatr Pharmacother. Mar. 2004;2(1):53-65. X-6, X-7, X-9. [pmid: 15555479].
2728 Murray T, Kelsberg G, Safranek S, et al. Clinical inquiries. Do any folk remedies or herbals help induce labor?. J Fam Pract. Aug. 2008;57(8):542-4. X-1, X-2, X-3, X-4, X-5, X-6, X-7. [pmid: 18687232].
2729 Murrock CJ, Gary FA. A culturally-specific dance intervention to increase functional capacity in African American women. J Cult Divers. Winter. 2008;15(4):168-73. X-6, X-7, X-9. [pmid: 19202718].
2730 Musil CM, Morris DL, Haug MR, et al. Recurrent symptoms: well-being and management. Soc Sci Med. Jun. 2001;52(11):1729-40. X-2, X-4, X-5. [pmid: 11327144].
2731 Mutea NK, Baker CM. Kenyan nurses' involvement in managing hospitalized diabetic patients. International Journal of Nursing Practice. Feb. 2008;14(1):40-6. X-2, X-3, X-4. [pmid: 18190483].
2732 Mvula MM, Miller JM Jr. Is knowledge of health behavior associated with low birth weight?. J Matern Fetal Med. May-Jun. 1999;8(3):134-7. X-2, X-4. [pmid: 10338069].
2733 Mynatt S, Wicks M, Bolden L. Pilot study of INSIGHT therapy in African American women. Arch Psychiatr Nurs. Dec. 2008;22(6):364-74. X-7, X-9. [pmid: 19026925].
2734 Naeem AG. The role of culture and religion in the management of diabetes: a study of Kashmiri men in Leeds. J R Soc Promot Health. Jun. 2003;123(2):110-6. X-2, X-3, X-4. [pmid: 12852196].
2735 Nagelkerk J, Reick K, Meengs L. Perceived barriers and effective strategies to diabetes self-management. J Adv Nurs. Apr. 2006;54(2):151-8. X-2, X-4, X-6. [pmid: 16553701].
2736 Nagler RH, Gray SW, Romantan A, et al. Differences in information seeking among breast, prostate, and colorectal cancer patients: results from a population-based survey. Patient Educ Couns. Dec. 2010;81(Suppl):S54-62. X-2, X-4, X-6. [pmid: 20934297].
2737 Nagy MC, Leeper JD, Hullett S, et al. The rural Alabama pregnancy and infant health program. Fam Community Health. Aug. 1988;11(2):49-56. X-1, X-6, X-7, X-9. [pmid: 10288524].
2738 Nahm ES, Blum K, Scharf B, et al. Exploration of patients' readiness for an eHealth management program for chronic heart failure: a preliminary study. J Cardiovasc Nurs. Nov-Dec. 2008;23(6):463-71. X-2, X-4, X-6. [pmid: 18953206].
2739 Nakagasien P, Nuntaboot K, Sangchart B. Cultural care for persons with diabetes in the community: an ethnographic study in Thailand. Thai Journal of Nursing Research. 2008;12(2):121-9. X-2, X-3, X-4, X-6.
2740 Nakawatase Y, Taru C, Tsutou A, et al. Development of an evaluation scale for self-management behavior related to physical activity of type 2 diabetic patients. Diabetes Care. Nov. 2007;30(11):2843-8. X-2, X-4, X-6. [pmid: 17644618].
2741 Nakayasu K, Nakaya Y, Oki Y, et al. Long-term follow-up in japanese public office workers of the influence of blood pressure on ECG changes. Circ J. Jun. 2004;68(6):563-7. X-2, X-3, X-4. [pmid: 15170093].
2742 Nakhla M, Daneman D, To T, et al. Transition to adult care for youths with diabetes mellitus: findings from a Universal Health Care System. Pediatrics. Dec. 2009;124(6):e1134-41. X-2, X-4. [pmid: 19933731].
2743 Nakhleh RE, Jones B, Zarbo RJ. Mammographically directed breast biopsies: a College of American Pathologists Q-Probes study of clinical physician expectations and of specimen handling and reporting characteristics in 434 institutions. Arch Pathol Lab Med. Jan. 1997;121(1):11-8. X-2, X-4, X-6. [pmid: 9111087].
2744 Nannenga MR, Montori VM, Weymiller AJ, et al. A treatment decision aid may increase patient trust in the diabetes specialist. The Statin Choice randomized trial. Health Expectations: An International Journal of Public Participation in Health Care & Health Policy. Mar. 2009;12(1):38-44. X-4, X-6. [pmid: 19250151].
2745 Nante N, Messina G, Cecchini M, et al. Sex differences in use of interventional cardiology persist after risk adjustment. J Epidemiol Community Health. Mar. 2009;63(3):203-8. X-2, X-3, X-4. [pmid: 19052034].
2746 Napoles-Springer AM, Ortiz C, O'Brien H, et al. Developing a Culturally Competent Peer Support Intervention for Spanish-speaking Latinas with Breast Cancer. Journal of Immigrant and Minority Health. Aug. 2009;11(4):268-80. X-2, X-4. [pmid: 18340533].
2747 Narula P, Cataletto M, Kier C, et al. Reports from the field: quality improvement. Collaboration of pediatric practices and managed care organizations in educational intervention for childhood asthma. Journal of Clinical Outcomes Management. 2006;13(12):701-5. X-6, X-9.
2748 Nash D, Azeez S, Vlahov D, et al. Evaluation of an intervention to increase screening colonoscopy in an urban public hospital setting. J Urban Health. Mar. 2006;83(2):231-43. X-9, X-11. [pmid: 16736372].
2749 Nasir LS, Nasir AK. Introducing Arabic language patient education materials in Jordan. Patient Educ Couns. Feb. 2006;60(2):142-5. X-2, X-3, X-4, X-6. [pmid: 16442456].
2750 Natale-Pereira A, Enard KR, Nevarez L, et al. The Role of Patient Navigators in Eliminating Health Disparities. Cancer. Aug. 2011;117(15):3543-52. X-1, X-2, X-4, X-5, X-6. [pmid: 21780089].
2751 Nath C. Literacy and diabetes self-management - Low literacy affects outcomes; communication is key. American Journal of Nursing. Jun. 2007;107(6):43-9. X-1, X-7, X-9. [pmid: 17563437].
2752 Nath CL, Gross KM, Jacques CH. A survey of physician awareness of West Virginia's coverage for treatment of diabetes. Diabetes Educ. Nov-Dec. 2000;26(6):943-8. X-2, X-4. [pmid: 11912806].
2753 Nattinger AB, Panzer RJ, Janus J. Improving the utilization of screening mammography in primary care practices. Arch Intern Med. Sep. 1989;149(9):2087-92. X-6, X-9. [pmid: 2774785].
2754 Naughton J, Dorn J, Imamura D. Outcomes measurement in cardiac rehabilitation: the National Exercise and Heart Disease Project. Journal of Rehabilitation Outcomes Measurement. 2000;4(4):64-75. X-6, X-7, X-9.
2755 Navarro AM, Senn KL, McNicholas LJ, et al. Por La Vida model intervention enhances use of cancer screening tests among Latinas. Am J Prev Med. Jul. 1998;15(1):32-41. X-9. [pmid: 9651636].
2756 Naylor MD, Brooten DA, Campbell RL, et al. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. J Am Geriatr Soc. May. 2004;52(5):675-84. X-6. [pmid: 15086645].
2757 Neafsey PJ, Anderson E, Peabody S, et al. Beta testing of a network-based health literacy program tailored for older adults with hypertension. Comput Inform Nurs. Nov-Dec. 2008;26(6):311-9. X-6, X-7, X-9. [pmid: 19047879].
2758 Neafsey PJ, Shellman J. Adverse self-medication practices of older adults with hypertension attending blood pressure clinics: adverse self-medication practices. Internet Journal of Advanced Nursing Practice. 2001;5(1):15p. X-2, X-4, X-6.
2759 Neal D, Magwood G, Jenkins C, et al. Racial disparity in the diagnosis of obesity among people with diabetes. J Health Care Poor Underserved. May. 2006;17(2 Suppl):106-15. X-2, X-4. [pmid: 16809878].
2760 Neiman GS, Savage HE. Development of infants and toddlers with clefts from birth to three years of age. Cleft Palate-Craniofacial Journal. May. 1997;34(3):218-25. X-2, X-4, X-5. [pmid: 9167072].
2761 Nekhlyudov L, Li R, Fletcher SW. Information and involvement preferences of women in their 40s before their first screening mammogram. Arch Intern Med. Jun. 27. 2005;165(12):1370-4. X-2, X-4. [pmid: 15983285].
2762 Nelson J, Gould J. Hidden in the mirror: A reflective conversation about research with marginalized communities. Reflective Practice. Aug. 2005;6(3):327-39. X-1, X-2, X-4.
2763 Nelson KA, Highstein GR, Garbutt J, et al. A randomized controlled trial of parental asthma coaching to improve outcomes among urban minority children. Arch Pediatr Adolesc Med. Jun. 2011;165(6):520-6. X-6, X-9. [pmid: 21646584].
2764 Nelson KM, Chapko MK, Reiber G, et al. The association between health insurance coverage and diabetes care; data from the 2000 Behavioral Risk Factor Surveillance System. Health Serv Res. Apr. 2005;40(2):361-72. X-2, X-4. [pmid: 15762896].
2765 Nelson M, Lean ME, Connor H, et al. Survey of dietetic provision for patients with diabetes. Diabet Med. Aug. 2000;17(8):565-71. X-2, X-3, X-4, X-6. [pmid: 11073177].
2766 Nerenz DR, Liu YW, Williams KL, et al. A simulation model approach to analysis of the business case for eliminating health care disparities. BMC Med Res Methodol. 2011;11:31. X-2, X-4. [pmid: 21418594].
2767 Netterstrom B, Blond M, Nielsen M, et al. Development of depressive symptoms and depression during organizational change--a two-year follow-up study of civil servants. Scand J Work Environ Health. Nov. 2010;36(6):445-8. X-2, X-3, X-4, X-6. [pmid: 20686739].
2768 Nettles A, Belton A. An overview of training curricula for diabetes peer educators. Family Practice. Jun. 2010;27:I33-I9. X-1, X-2, X-4. [pmid: 19131580].
2769 Newbould J, Smith F, Francis SA. ‘I'm fine doing it on my own’: partnerships between young people and their parents in the management of medication for asthma and diabetes. J Child Health Care. Jun. 2008;12(2):116-28. X-2, X-3, X-4, X-6. [pmid: 18469296].
2770 Newcomb PA, Klein R, Massoth KM. Education to increase ophthalmologic care in older onset diabetes patients: indications from the Wisconsin Epidemiologic Study of Diabetic Retinopathy. J Diabetes Complications. Oct-Dec. 1992;6(4):211-7. X-6, X-9. [pmid: 1482778].
2771 Newcomb PA, McGrath KW, Covington JK, et al. Barriers to patient-clinician collaboration in asthma management: the patient experience. J Asthma. Mar. 2010;47(2):192-7. X-2, X-4, X-6. [pmid: 20170328].
2772 Newcomer JW, Hennekens CH. Severe mental illness and risk of cardiovascular disease. JAMA: Journal of the American Medical Association. Oct. 2007;298(15):1794-6. X-1, X-2, X-3, X-4, X-6.
2773 Newell A. When a diagnosis is elusive: new research program addresses rare diseases. Nurs Womens Health. Oct. 2008;12(5):436-7. X-1, X-2, X-4, X-5, X-6. [pmid: 18837724].
2774 Newlin K, Melkus GD, Jefferson V, et al. Recruitment of black women with type 2 diabetes into a self-management intervention trial. Ethn Dis. Autumn. 2006;16(4):956-62. X-2, X-4, X-7. [pmid: 17061753].
2775 Newlin K, Melkus GD, Tappen R, et al. Relationships of religion and spirituality to glycemic control in Black women with type 2 diabetes. Nurs Res. Sep-Oct. 2008;57(5):331-9. X-2, X-4. [pmid: 18794717].
2776 Newman JE, Sorenson JR, DeVellis BM, et al. Gender differences in psychosocial reactions to cystic fibrosis carrier testing. Am J Med Genet. Nov. 22. 2002;113(2):151-7. X-2, X-4. [pmid: 12407705].
2777 Newman KD, Weaver MT. Insulin measurement and preparation among diabetic patients at a county hospital. Nurse Pract. Mar. 1994;19(3):44-5. 8. X-2, X-4, X-6. [pmid: 8008262].
2778 Newton AN, Ewer SR. Inpatient cancer treatment: an analysis of financial and nonfinancial performance measures by hospital-ownership type. Journal of Health Care Finance. 2010;37(2):56-80. X-2, X-4, X-6. [pmid: 21294439].
2779 Ng SM, Li AM, Lou VW, et al. Incorporating family therapy into asthma group intervention: a randomized waitlist-controlled trial. Fam Process. Mar. 2008;47(1):115-30. X-3, X-6, X-7, X-9, X-10. [pmid: 18411833].
2780 Ngo VK, Asarnow JR, Lange J, et al. Outcomes for youths from racial-ethnic minority groups in a quality improvement intervention for depression treatment. Psychiatr Serv. Oct. 2009;60(10):1357-64. X-4. [pmid: 19797376].
2781 Nguyen BH, McPhee SJ, Stewart SL, et al. Colorectal cancer screening in Vietnamese Americans. Journal of Cancer Education. Jan. 2008;23(1):37-45. X-2, X-4. [pmid: 18444045].
2782 Nguyen BH, Pham JT, Chew RA, et al. Effectiveness of continuing medical education in increasing colorectal cancer screening knowledge among Vietnamese American physicians. J Health Care Poor Underserved. 2010;21(2):568-81. X-7, X-9. [pmid: 20453357].
2783 Nguyen JD, Carson ML, Parris KM, et al. A comparison pilot study of public health field nursing home visitation program interventions for pregnant Hispanic adolescents. Public Health Nurs. Sep-Oct. 2003;20(5):412-8. X-7, X-9. [pmid: 12930465].
2784 Nguyen K, Zahran H, Iqbal S, et al. Factors associated with asthma control among adults in five New England states, 2006-2007. J Asthma. Aug. 2011;48(6):581-8. X-2, X-4. [pmid: 21668319].
2785 Nguyen T, Vo PH, McPhee SJ, et al. Promoting early detection of breast cancer among Vietnamese-American women. Results of a controlled trial. Cancer. Jan. 1. 2001;91(1 Suppl):267-73. X-9. [pmid: 11148592].
2786 Nguyen TT, Le G, Nguyen T, et al. Breast cancer screening among Vietnamese Americans: a randomized controlled trial of lay health worker outreach. Am J Prev Med. Oct. 2009;37(4):306-13. X-9. [pmid: 19765502].
2787 Nguyen TT, Love MB, Liang C, et al. A pilot study of lay health worker outreach and colorectal cancer screening among Chinese Americans. J Cancer Educ. Sep. 2010;25(3):405-12. X-9. [pmid: 20204570].
2788 Nguyen TT, McPhee SJ, Bui-Tong N, et al. Community-based participatory research increases cervical cancer screening among Vietnamese-Americans. J Health Care Poor Underserved. May. 2006;17(2 Suppl):31-54. X-5. [pmid: 16809874].
2789 Nguyen TU, Tran JH, Kagawa-Singer M, et al. A qualitative assessment of community-based breast health navigation services for Southeast Asian women in Southern California: recommendations for developing a navigator training curriculum. Am J Public Health. Jan. 2011;101(1):87-93. X-2, X-4. [pmid: 21088273].
2790 Nguyen TUN, Tran JH, Kagawa-Singer M, et al. A Qualitative Assessment of Community-Based Breast Health Navigation Services for Southeast Asian Women in Southern California: Recommendations for Developing a Navigator Training Curriculum. American Journal of Public Health. Jan. 2011;101(1):87-93. X-2, X-4. [pmid: 21088273].
2791 Nichols C, Holt CL, Shipp M, et al. Physician knowledge, perceptions of barriers, and patient colorectal cancer screening practices. Am J Med Qual. Mar-Apr. 2009;24(2):116-22. X-2, X-4, X-6. [pmid: 19233946].
2792 Nichols LO, Martindale-Adams J, Greene WA, et al. Dementia caregivers' most pressing concerns. Clinical Gerontologist. 2009;32(1):1-14. X-2, X-4, X-6.
2793 Nicholson TR, Taylor JP, Gosden C, et al. National guidelines for psychological care in diabetes: how mindful have we been?. Diabet Med. Apr. 2009;26(4):447-50. X-2, X-3, X-4, X-6. [pmid: 19388977].
2794 Nicol ED, Fittall B, Roughton M, et al. NHS heart failure survey: a survey of acute heart failure admissions in England, Wales and Northern Ireland. Heart. Feb. 2008;94(2):172-7. X-2, X-3, X-4. [pmid: 18003672].
2795 Nicolucci A, Cavaliere D, Scorpiglione N, et al. A comprehensive assessment of the avoidability of long-term complications of diabetes. A case-control study. SID-AMD Italian Study Group for the Implementation of the St. Vincent Declaration. Diabetes Care. Sep. 1996;19(9):927-33. X-2, X-3, X-4. [pmid: 8875084].
2796 Nicolucci A, Cucinotta D, Squatrito S, et al. Clinical and socio-economic correlates of quality of life and treatment satisfaction in patients with type 2 diabetes. Nutr Metab Cardiovasc Dis. Jan. 2009;19(1):45-53. X-2, X-4. [pmid: 18450436].
2797 Nielsen BB. The nurse's role in mammography screening. Cancer Nurs. Oct. 1989;12(5):271-5. X-1, X-6, X-7, X-9. [pmid: 2804962].
2798 Nikkhou K. Prediabetes: an effective target for decreasing racial and ethnic health disparity. Conn Med. Jun-Jul. 2011;75(6):361-3. X-13. [pmid: 21755854].
2799 Ninan PT. Dissolving the burden of generalized anxiety disorder. Journal of Clinical Psychiatry. 2001;62:5-10. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11577790].
2800 Noakes H. Perceptions of black African and African-Caribbean people regarding insulin. Journal of Diabetes Nursing. 2010;14(4):148. X-2, X-4.
2801 Nobel J. Bridging the knowledge-action gap in diabetes: information technologies, physician incentives and consumer incentives converge. Chronic Illn. Mar. 2006;2(1):59-69. X-1, X-2, X-3, X-4. [pmid: 17175683].
2802 Nokes KM, Coleman CL, Cashen M, et al. Health literacy and health outcomes in HIV seropositive persons. Research in Nursing & Health. Dec. 2007;30(6):620-7. X-2, X-4, X-5. [pmid: 18022832].
2803 Nolan T, Desmond K, Herlich R, et al. Knowledge of cystic fibrosis in patients and their parents. Pediatrics. Feb. 1986;77(2):229-35. X-2, X-4. [pmid: 3945536].
2804 Nordmann A, Frach B, Walker T, et al. Reliability of patients measuring blood pressure at home: prospective observational study. BMJ. Oct. 30. 1999;319(7218):1172. X-1, X-6, X-7, X-9. [pmid: 10541509].
2805 Norekval TM, Fridlund B, Moons P, et al. Sense of coherence -- a determinant of quality of life over time in older female acute myocardial infarction survivors. Journal of Clinical Nursing. 2010;19(5-6):820-31. X-2, X-4, X-6. [pmid: 19732247].
2806 Normand SLT, Wolf RE, McNeil BJ. Discriminating quality of hospital care in the United States. Medical Decision Making. May-Jun. 2008;28(3):308-22. X-2, X-4, X-6. [pmid: 18310529].
2807 Norr KF, Crittenden KS, Lehrer EL, et al. Maternal and infant outcomes at one year for a nurse-health advocate home visiting program serving African Americans and Mexican Americans. Public Health Nurs. May-Jun. 2003;20(3):190-203. X-9. [pmid: 12716399].
2808 Nothlings U, Boeing H, Maskarinec G, et al. Food intake of individuals with and without diabetes across different countries and ethnic groups. Eur J Clin Nutr. May. 2011;65(5):635-41. X-2, X-3, X-4. [pmid: 21346715].
2809 Nothwehr FK, Guare J, Marrero DG, et al. Sequencing diet and exercise programs for African American women with diabetes. Diabetes Educ. Mar-Apr. 2001;27(2):245-51. X-9. [pmid: 11913007].
2810 Nourjah P, Wagener DK, Eberhardt M, et al. Knowledge of risk factors and risk behaviors related to coronary heart disease among blue and white collar males. J Public Health Policy. Winter. 1994;15(4):443-59. X-2, X-4. [pmid: 7883945].
2811 Novato TS, Grossi SAA, Kimura M. Quality of life and self-esteem of adolescents with diabetes mellitus. Acta Paulista de Enfermagem. 2008;21(4):562-7. X-2, X-3, X-4, X-6.
2812 Nte AR, Oruamabo RS. A seven-year audit of a diarrhoea training unit (DTU) in Port Harcourt, Nigeria. Afr J Med Med Sci. Mar. 2002;31(1):63-6. X-2, X-3, X-4, X-5, X-6. [pmid: 12518933].
2813 Nthangeni G, Steyn NP, Alberts M, et al. Dietary intake and barriers to dietary compliance in black type 2 diabetic patients attending primary health-care services. Public Health Nutr. Apr. 2002;5(2):329-38. X-2, X-3, X-4, X-6. [pmid: 12020385].
2814 Ntiri DW, Stewart M. Transformative learning intervention: effect on functional health literacy and diabetes knowledge in older. African Americans Gerontol Geriatr Educ. 2009;30(2):100-13. X-4. [pmid: 19440898].
2815 Ntiri DW, Stewart M. Recruitment challenges: Lessons from senior centers and older African-American participants in a literacy study. Educational Gerontology. Feb. 2010;36(2):148-54. X-1, X-2, X-4.
2816 Nuno T, Martinez ME, Harris R, et al. A Promotora-administered group education intervention to promote breast and cervical cancer screening in a rural community along the U.S.-Mexico border: a randomized controlled trial. Cancer Causes Control. Mar. 2011;22(3):367-74. X-9. [pmid: 21184267].
2817 Nuraini E, Parker E. Improving knowledge of antenatal care (ANC) among pregnant women: a field trial in central Java. Indonesia Asia Pac J Public Health. 2005;17(1):3-8. X-3, X-4. [pmid: 16044824].
2818 Nurss JR, el-Kebbi IM, Gallina DL, et al. Diabetes in urban African Americans: functional health literacy of municipal hospital outpatients with diabetes. Diabetes Educ. Sep-Oct. 1997;23(5):563-8. X-2, X-4. [pmid: 9355373].
2819 Nutting PA, Gallagher KM, Riley K, et al. Implementing a Depression Improvement Intervention in Five Health Care Organizations: Experience from the RESPECT-Depression Trial. Administration and Policy in Mental Health and Mental Health Services Research. Mar. 2007;34(2):127-37. X-2, X-4, X-6. [pmid: 16967338].
2820 Nwasuruba C, Khan M, Egede LE. Racial/ethnic differences in multiple self-care behaviors in adults with diabetes. Journal of General Internal Medicine. Jan. 2007;22(1):115-20. X-2, X-4. [pmid: 17351850].
2821 Nwasuruba C, Osuagwu C, Bae S, et al. Racial differences in diabetes self-management and quality of care in Texas. J Diabetes Complications. Mar-Apr. 2009;23(2):112-8. X-2, X-4. [pmid: 18413179].
2822 Obrador GT. Anemia of chronic kidney disease and end-stage renal disease: are there unique issues in disadvantaged populations?. Ethn Dis. Spring. 2009;19(1 Suppl 1):S1-52-5. X-1, X-2, X-4, X-5. [pmid: 19484876].
2823 O'Brien T, Denham SA. Diabetes care and education in rural regions. Diabetes Educ. Mar-Apr. 2008;34(2):334-47. X-1, X-2, X-3, X-4. [pmid: 18375783].
2824 Ocampo-Balabagno AV. Functional health performance outcomes of compliance to home instruction program after myocardial infarction. Philippine Journal of Nursing. 1999;69(3-4):20-9. X-3, X-4, X-6.
2825 O'Connell AM, Crawford MH, Abrams J. Heart failure disease management in an indigent population. Am Heart J. Feb. 2001;141(2):254-8. X-4. [pmid: 11174340].
2826 O'Connor GT, Quinton HB, Kahn R, et al. Case-mix adjustment for evaluation of mortality in cystic fibrosis. Pediatr Pulmonol. Feb. 2002;33(2):99-105. X-2, X-4. [pmid: 11802245].
2827 O'Connor MJ, Whaley SE. Health care provider advice and risk factors associated with alcohol consumption following pregnancy recognition. J Stud Alcohol. Jan. 2006;67(1):22-31. X-2, X-4. [pmid: 16536126].
2828 O'Connor PJ, Desai J, Solberg LI, et al. Randomized trial of quality improvement intervention to improve diabetes care in primary care settings. Diabetes Care. Aug. 2005;28(8):1890-7. X-6, X-9. [pmid: 16043728].
2829 Odegard PS, Gray SL. Barriers to medication adherence in poorly controlled diabetes mellitus. Diabetes Educ. Jul-Aug. 2008;34(4):692-7. X-2, X-4. [pmid: 18669811].
2830 O'Dell K, O'Dell M. Socio-ecological resources for diabetes self-management. J Miss State Med Assoc. Apr. 2006;47(4):99-103. X-2, X-4. [pmid: 17941211].
2831 O'Dell K, O'Dell M, Taylor J. Access to medications and intermediate markers of health outcomes of a clinic population of patients with diabetes. J Miss State Med Assoc. Jun. 2008;49(6):170-3. X-6, X-7, X-9. [pmid: 19295040].
2832 O'Driscoll JM, Shave R, Cushion CJ. A National Health Service Hospital's cardiac rehabilitation programme: a qualitative analysis of provision. J Clin Nurs. Oct. 2007;16(10):1908-18. X-2, X-3, X-4, X-6. [pmid: 17880480].
2833 Oetzel J, De Vargas F, Ginossar T, et al. Hispanic women's preferences for breast health information: subjective cultural influences on source, message, and channel. Health Commun. 2007;21(3):223-33. X-2, X-4. [pmid: 17567254].
2834 Ofili E, Pemu PI, Gulaya V, et al. Targeting healthcare disparities: an integrated model to improve treatment rates of dyslipidemia in African American patients. Curr Atheroscler Rep. Jul. 2005;7(4):249-50. X-6, X-9. [pmid: 15975316].
2835 Ogce F, Ozkan S. Changes in functional status and physical and psychological symptoms in women receiving chemotherapy for breast cancer. Asian Pac J Cancer Prev. Jul-Sep. 2008;9(3):449-52. X-2, X-3, X-4, X-6. [pmid: 18990020].
2836 Ogedegbe G, Mancuso CA, Allegrante JP. Expectations of blood pressure management in hypertensive African-American patients: a qualitative study. J Natl Med Assoc. Apr. 2004;96(4):442-9. X-2, X-4. [pmid: 15101664].
2837 Oh EG, Bang SY, Hyun SS, et al. Effects of a 6-month lifestyle modification intervention on the cardiometabolic risk factors and health-related qualities of life in women with metabolic syndrome. Metabolism. Jul. 2010;59(7):1035-43. X-3, X-4, X-5, X-6. [pmid: 20045151].
2838 Ohldin A, Young B, Derleth A, et al. Ethnic differences in satisfaction and quality of life in veterans with ischemic heart disease. J Natl Med Assoc. Jun. 2004;96(6):799-808. X-2, X-4. [pmid: 15233490].
2839 Okelo SO, Patino CM, Hansel NN, et al. Use of asthma specialist care in high-risk inner-city Black children. Pediatric Asthma, Allergy & Immunology. 2007;20(4):255-62. X-2, X-4.
2840 Okuyama T, Akechi T, Yamashita H, et al. Reliability and validity of the Japanese version of the Short-form Supportive Care Needs Survey questionnaire (SCNS-SF34-J). Psychooncology. Sep. 2009;18(9):1003-10. X-2, X-3, X-4, X-6. [pmid: 19177464].
2841 Okuyama T, Nakane Y, Endo C, et al. Mental health literacy in Japanese cancer patients: Ability to recognize depression and preferences of treatment--Comparison with Japanese lay public. Psycho-Oncology. Sep. 2007;16(9):834-42. X-2, X-3, X-4, X-6. [pmid: 17120276].
2842 Oladele CR, Barnett E. Racial/Ethnic and social class differences in preventive care practices among persons with diabetes. BMC Public Health. 2006;6:259. X-2, X-4. [pmid: 17052356].
2843 Olaya W, Wong J, Morgan JW, et al. Factors associated with variance in compliance with a sentinel lymph node dissection quality measure in early-stage breast cancer. Ann Surg Oncol. Oct. Suppl 3. 2010;17:297-302. X-2, X-4. [pmid: 20853050].
2844 Oldfield SR, Dreher HM. The Concept of Health Literacy Within the Older Adult Population. Holistic Nursing Practice. Jul-Aug. 2010;24(4):204-12. X-1, X-2, X-3, X-4, X-5. [pmid: 20588129].
2845 Oleske DM, Galvez A, Cobleigh MA, et al. Are tri-ethnic low-income women with breast cancer effective teachers of the importance of breast cancer screening to their first-degree relatives? Results from a randomized clinical trial. Breast J. Jan-Feb. 2007;13(1):19-27. X-6, X-7, X-9. [pmid: 17214789].
2846 Olfson M, Gameroff MJ, Marcus SC, et al. Outpatient treatment of child and adolescent depression in the United States. Arch Gen Psychiatry. Dec. 2003;60(12):1236-42. X-2, X-4, X-6. [pmid: 14662556].
2847 Olivares R. Important considerations in iron management and nutritional status in select hemodialysis populations. Nephrol Nurs J. Jul-Aug. 2007;34(4):425-32. quiz 33-4. X-1, X-6, X-7, X-9. [pmid: 17891911].
2848 Oliver RC, Brown LJ, Loe H. Periodontal diseases in the United States population. J Periodontol. Feb. 1998;69(2):269-78. X-1, X-2, X-4, X-5. [pmid: 9526927].
2849 Olley BO. Improving well-being through psycho-education among voluntary counseling and testing seekers in Nigeria: a controlled outcome study. AIDS Care. Nov. 2006;18(8):1025-31. X-3, X-4, X-5, X-6. [pmid: 17012095].
2850 Olowu JA, Sowunmi A, Abohweyere AE. Congenital malaria in a hyperendemic area: a revisit. Afr J Med Med Sci. Sep-Dec. 2000;29(3-4):211-3. X-2, X-3, X-4. [pmid: 11713991].
2851 Olsen B, Berg CA, Wiebe D. Dissimilarity in mother and adolescent illness representations of type 1 diabetes and negative emotional adjustment. Psychology & Health. 2008;23(1):113-29. X-2, X-4, X-6.
2852 Olshansky E, Sacco D, Fitzgerald K, et al. Living with diabetes: normalizing the process of managing diabetes. Diabetes Educ. Nov-Dec. 2008;34(6):1004-12. X-2, X-4, X-6. [pmid: 19075082].
2853 Olson R, Sabogal F, Perez A. Viva la Vida: helping Latino Medicare beneficiaries with diabetes live their lives to the fullest. Am J Public Health. Feb. 2008;98(2):205-8. X-11, X-12. [pmid: 18172150].
2854 Olsson I, Dahl AA. Personality problems are considerably associated with somatic morbidity and health care utilisation. Eur Psychiatry. Oct. 2009;24(7):442-9. X-2, X-3, X-4, X-5, X-6. [pmid: 19540726].
2855 Omar MA, Schiffman RF. Satisfaction and adequacy of prenatal care utilization among rural low-income women. Outcomes Management for Nursing Practice. 2000;4(2):91-6. X-2, X-4. [pmid: 11111590].
2856 Omoigberale AI, Sadoh WE, Nwaneri DU. A 4 year review of neonatal outcome at the University of Benin Teaching Hospital, Benin City. Niger J Clin Pract. Sep. 2010;13(3):321-5. X-2, X-3, X-4, X-6. [pmid: 20857794].
2857 O'Neill MS. Helping schoolchildren with asthma breathe easier: partnerships in community-based environmental health education. Environ Health Perspect. May. 1996;104(5):464-6. X-1, X-2, X-4. [pmid: 8743428].
2858 Onwudiwe NC, Mullins CD, Winston RA, et al. Barriers to self-management of diabetes: a qualitative study among low-income minority diabetics. Ethn Dis. Winter. 2011;21(1):27-32. X-2, X-4. [pmid: 21462726].
2859 Onyirimba F, Apter A, Reisine S, et al. Direct clinician-to-patient feedback discussion of inhaled steroid use: its effect on adherence. Ann Allergy Asthma Immunol. Apr. 2003;90(4):411-5. X-4. [pmid: 12722963].
2860 Opuni KA, Smith PB, Arvey H, et al. The Northeast Adolescent Project: a collaborative effort to address teen-age pregnancy in Houston, Texas. J Sch Health. May. 1994;64(5):212-4. X-6, X-9. [pmid: 8078317].
2861 O'Reilly CL, Bell JS, Chen TF. Pharmacists' beliefs about treatments and outcomes of mental disorders: a mental health literacy survey. Aust N Z J Psychiatry. Dec. 2010;44(12):1089-96. X-2, X-3, X-4. [pmid: 21070104].
2862 Oreskovic S, Bozicevic I, Mastilica M, et al. Health-care resource use by asthmatics in Croatia. J Asthma. Jun. 2002;39(4):351-8. X-2, X-3, X-4. [pmid: 12095186].
2863 Ornstein S, Jenkins RG, Nietert PJ, et al. A multimethod quality improvement intervention to improve preventive cardiovascular care: a cluster randomized trial. Ann Intern Med. Oct. 5. 2004;141(7):523-32. X-6. [pmid: 15466769].
2864 Ornstein SM, Garr DR, Jenkins RG, et al. Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services. J Fam Pract. Jan. 1991;32(1):82-90. X-9. [pmid: 1985140].
2865 Orona CJ, Koenig BA, Davis AJ. Cultural aspects of nondisclosure. Camb Q Healthc Ethics. Summer. 1994;3(3):338-46. X-6, X-7, X-9. [pmid: 7994457].
2866 Orvik E, Johansen OE, Gullestad L, et al. Health-related quality of life in patients with type 2 diabetes compared to their spouses: substudy of the Asker Baerum Cardiovascular Diabetes Study. European Diabetes Nursing. 2006;3(1):21-6. X-3, X-6, X-7, X-9.
2867 Osborn CY, Amico KR, Cruz N, et al. A brief culturally tailored intervention for Puerto Ricans with type 2 diabetes. Health Educ Behav. Dec. 2010;37(6):849-62. X-3, X-9, X-10. [pmid: 21076128].
2868 Osborn CY, Bains SS, Egede LE. Health literacy, diabetes self-care, and glycemic control in adults with type 2 diabetes. Diabetes Technol Ther. Nov. 2010;12(11):913-9. X-2, X-4. [pmid: 20879964].
2869 Osborn CY, Cavanaugh K, Wallston KA, et al. Self-efficacy links health literacy and numeracy to glycemic control. J Health Commun. Suppl 2. 2010;15:146-58. X-2, X-4. [pmid: 20845200].
2870 Osborn CY, Egede LE. Validation of an information–motivation–behavioral skills model of diabetes self-care (IMB-DSC). Patient Education and Counseling. Apr. 2010;79(1):49-54. X-2, X-4, X-6. [pmid: 19699601].
2871 Osborn CY, Paasche-Orlow MK, Bailey SC, et al. The mechanisms linking health literacy to behavior and health status. Am J Health Behav. Jan-Feb. 2011;35(1):118-28. X-2, X-4. [pmid: 20950164].
2872 Osborn CY, Rivet Amico K, Fisher WA, et al. An information-motivation-behavioral skills analysis of diet and exercise behavior in Puerto Ricans with diabetes. J Health Psychol. Nov. 2010;15(8):1201-13. X-2, X-3, X-4. [pmid: 20453056].
2873 Osganian SK, Zapka JG, Feldman HA, et al. Use of emergency medical services for suspected acute cardiac ischemia among demographic and clinical patient subgroups: the REACT trial. Rapid Early Action for Coronary Treatment. Prehosp Emerg Care. Apr-Jun. 2002;6(2):175-85. X-7. [pmid: 11962564].
2874 Osime OC, Okojie O, Aigbekaen ET, et al. Knowledge attitude and practice about breast cancer among civil servants in Benin City, Nigeria. Ann Afr Med. Dec. 2008;7(4):192-7. X-2, X-3, X-4, X-6. [pmid: 19623922].
2875 Osinski M. Part 1: workforce. More nephrologists eying evolving subspecialty. Nephrol News Issues. Jan. 454. 2009;23(1):42-5. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19235358].
2876 Oster NV, Welch V, Schild L, et al. Differences in self-management behaviors and use of preventive services among diabetes management enrollees by race and ethnicity. Dis Manag. Jun. 2006;9(3):167-75. X-2, X-4. [pmid: 16764534].
2877 Otero-Sabogal R, Arretz D, Siebold S, et al. Physician-community health worker partnering to support diabetes self-management in primary care. Qual Prim Care. 2010;18(6):363-72. X-4. [pmid: 21294977].
2878 Otsuki M, Eakin MN, Rand CS, et al. Adherence feedback to improve asthma outcomes among inner-city children: A randomized trial. Pediatrics. Dec. 2009;124(6):1513-21. X-9. [pmid: 19948623].
2879 Ovbiagele B, Hutchison P, Handschumacher L, et al. Educating and mobilizing youth to detect undiagnosed elevated blood pressure: searching for the silent killer. Ethn Dis. Winter. 2008;18(1):84-8. X-4, X-8. [pmid: 18447105].
2880 Ovbiagele B, Hutchison P, Handschumacher L, et al. Impact of an urban community hypertension screening program on participating high school students. Ethn Dis. Winter. 2011;21(1):68-73. X-4, X-7, X-10. [pmid: 21462733].
2881 Overberg R, Otten W, de Man A, et al. How breast cancer patients want to search for and retrieve information from stories of other patients on the internet: an online randomized controlled experiment. J Med Internet Res. 2010;12(1):e7. X-3, X-4, X-6. [pmid: 20215101].
2882 Overby KJ, Lo B, Litt IF. Knowledge and concerns about acquired immunodeficiency syndrome and their relationship to behavior among adolescents with hemophilia. Pediatrics. Feb. 1989;83(2):204-10. X-2, X-4, X-5, X-6. [pmid: 2783626].
2883 Overland JE, Hoskins PL, McGill MJ, et al. Low literacy: a problem in diabetes education. Diabet Med. Nov. 1993;10(9):847-50. X-2, X-4. [pmid: 8281731].
2884 Overstreet KM, Moore DE Jr., Kristofco RE, et al. Addressing disparities in diagnosing and treating depression: a promising role for continuing medical education. J Contin Educ Health Prof. Fall. Suppl 1. 2007;27:S5-8. X-1, X-2, X-4. [pmid: 18085580].
2885 Owen WF Jr., Szczech LA, Frankenfield DL. Healthcare system interventions for inequality in quality: corrective action through evidence-based medicine. J Natl Med Assoc. Aug. 2002;94(8 Suppl):83S-91S. X-1, X-6, X-7, X-9. [pmid: 12152918].
2886 Owens B. A test of the self-help model and use of complementary and alternative medicine among Hispanic women during treatment for breast cancer. Oncol Nurs Forum. Jul. 2007;34(4):E42-50. X-2, X-4. [pmid: 17723972].
2887 Owens B, Jackson M, Berndt A. Complementary therapy used by Hispanic women during treatment for breast cancer. J Holist Nurs. Sep. 2009;27(3):167-76. X-2, X-4. [pmid: 19372389].
2888 Owens CS. Diabetes and obesity risks in African American young adult freshmen attending a historically Black college/university. Journal of Health Care for the Poor and Underserved. Nov. 2008;19(4):1096-118. X-2, X-4. [pmid: 19029739].
2889 Ozkan S, Ogce F. Psychometric analysis of the Inventory of Functional Status--Cancer (IFS-CA) in Turkish women. J Transcult Nurs. Apr. 2009;20(2):187-93. X-2, X-3, X-4, X-6. [pmid: 19164650].
2890 Ozminkowski RJ, White AJ, Hassol A, et al. Minimizing racial disparity regarding receipt of a cadaver kidney transplant. Am J Kidney Dis. Dec. 1997;30(6):749-59. X-2, X-4. [pmid: 9398117].
2891 Paasche-Orlow M. Caring for patients with limited health literacy: a 76-year-old man with multiple medical problems. JAMA. Sep. 14. 2011;306(10):1122-9. X-1, X-2, X-4, X-5, X-6. [pmid: 21828309].
2892 Paasche-Orlow MK, Riekert KA, Bilderback A, et al. Tailored education may reduce health literacy disparities in asthma self-management. Am J Respir Crit Care Med. Oct. 15. 2005;172(8):980-6. X-2, X-4. [pmid: 16081544].
2893 Paasche-Orlow MK, Wolf MS. The causal pathways linking health literacy to health outcomes. American Journal of Health Behavior. Sep-Oct. 2007;31:S19-S26. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17931132].
2894 Pacquiao D. The relationship between cultural competence education and increasing diversity in nursing schools and practice settings. Journal of Transcultural Nursing. Jan. 2007;18(1):28S-37S. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 17204813].
2895 Pakseresht M, Mead E, Gittelsohn J, et al. Awareness of chronic disease diagnosis amongst family members is associated with healthy dietary knowledge but not behaviour amongst Inuit in Arctic Canada. J Hum Nutr Diet. Oct. Suppl 1. 2010;23:100-9. X-2, X-3, X-4, X-5, X-6. [pmid: 21158968].
2896 Palhares LC, Gallani MBJ, Gemignani T, et al. Quality of life, dyspnea and ventricular function in patients with hypertension. Journal of Advanced Nursing. 2010;66(10):2287-96. X-2, X-4, X-6. [pmid: 20735508].
2897 Palinkas LA, Ell K, Hansen M, et al. Sustainability of collaborative care interventions in primary care settings. Journal of Social Work. 2011. Jan. 01. 2011;11(1):99-117. X-2, X-4.
2898 Palta M, Sadek-Badawi M, Evans M, et al. Functional assessment of a multicenter very low-birth-weight cohort at age 5 years. Newborn Lung Project Arch Pediatr Adolesc Med. Jan. 2000;154(1):23-30. X-2, X-4, X-5, X-6. [pmid: 10632246].
2899 Pamies RJ, Nsiah-Kumi PA. Multicultural medicine and ensuring good health for all. Ethn Dis. Spring. 2006;16(2 Suppl 3):S3-14-20. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 16774019].
2900 Pan AW, Chung L, Chen TJ, et al. Occupational Competence, Environmental Support and Quality of Life for People with Depression: A Path Analysis. American Journal of Psychiatric Rehabilitation. 2011. Jan-Mar. 2011;14(1):40-54. X-2, X-4, X-6.
2901 Pandhi N, Smith MA, Kind AJ, et al. The quality of diabetes care following hospitalization for ischemic stroke. Cerebrovasc Dis. 2009;27(3):235-40. X-2, X-4. [pmid: 19176956].
2902 Pandit AU, Tang JW, Bailey SC, et al. Education, literacy, and health: Mediating effects on hypertension knowledge and control. Patient Educ Couns. Jun. 2009;75(3):381-5. X-2, X-4. [pmid: 19442477].
2903 Panieri E, Lazarus D, Dent DM, et al. A study of the patient factors affecting reconstruction after mastectomy for breast carcinoma. Am Surg. Feb. 2003;69(2):95-7. X-2, X-4. [pmid: 12641345].
2904 Panpakdee O, Hanucharurnkul S, Sritanyarat W, et al. Self-care process in Thai people with hypertension: an emerging model. Thai Journal of Nursing Research. 2003;7(2):121-36. X-2, X-3, X-4, X-6.
2905 Paquette IM, Kemp JA, Finlayson SR. Patient and hospital factors associated with use of sphincter-sparing surgery for rectal cancer. Dis Colon Rectum. Feb. 2010;53(2):115-20. X-2, X-4. [pmid: 20087084].
2906 Parboosingh J, Inhaber S. A catalyst for change in communication skills: the Canadian Breast Cancer Initiative. Cancer Prev Control. Feb. 1999;3(1):19-24. X-1, X-2, X-3, X-4, X-6. [pmid: 10474748].
2907 Parchman ML, Flannagan D, Ferrer RL, et al. Communication competence, self-care behaviors and glucose control in patients with type 2 diabetes. Patient Educ Couns. Oct. 2009;77(1):55-9. X-2, X-4. [pmid: 19359125].
2908 Pardhan S, Mahomed I. Knowledge, self-help and socioeconomic factors in South Asian and Caucasian diabetic patients. Eye (Lond). May. 2004;18(5):509-13. X-2, X-4. [pmid: 15131683].
2909 Paris CA, Imperatore G, Klingensmith G, et al. Predictors of insulin regimens and impact on outcomes in youth with type 1 diabetes: the SEARCH for Diabetes in Youth study. J Pediatr. Aug. 2009;155(2):183-9 e1. X-2, X-4. [pmid: 19394043].
2910 Pariser D, O'Hanlon A. Effects of telephone intervention on arthritis self-efficacy, depression, pain, and fatigue in older adults with arthritis. J Geriatr Phys Ther. 2005;28(3):67-73. X-4, X-5, X-6. [pmid: 16386168].
2911 Park S, Sappenfield WM, Bish C, et al. Assessment of the Institute of Medicine recommendations for weight gain during pregnancy: Florida, 2004-2007. Matern Child Health J. Apr. 2011;15(3):289-301. X-2, X-4, X-6. [pmid: 20306221].
2912 Parker EA, Israel BA, Robins TG, et al. Evaluation of Community Action Against Asthma: a community health worker intervention to improve children's asthma-related health by reducing household environmental triggers for asthma. Health Educ Behav. Jun. 2008;35(3):376-95. X-6, X-7, X-9. [pmid: 17761540].
2913 Parker RM, Williams MV, Weiss BD, et al. Health literacy - Report of the Council on Scientific Affairs. Jama-Journal of the American Medical Association. Feb. 1999;281(6):552-7. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10022112].
2914 Parker W. Black-white infant mortality disparity in the United States: a societal litmus test. Public Health Reports. 2003;118(4):336-7. X-1, X-2, X-4. [pmid: 12815080].
2915 Parkerton PH, Smith DG, Belin TR, et al. Physician performance assessment: nonequivalence of primary care measures. Med Care. Sep. 2003;41(9):1034-47. X-2, X-4, X-6. [pmid: 12972843].
2916 Parks CP. Development of a hypertension educational pamphlet for the black community: a model approach. Health Educ. Oct-Nov. 1988;19(5):8-12. X-13. [pmid: 3152254].
2917 Parks JK, Diaz-Arrastia R, Gentilello LM, et al. Postinjury employment as a surrogate for functional outcomes: a quality indicator for trauma systems. Baylor University Medical Center Proceedings. 2010;23(4):355-8. X-2, X-4, X-5, X-6. [pmid: 20944755].
2918 Parry KK, Mobley T, Allen O. Use of folk treatments for diabetic plantar ulcers among African Americans with Type II diabetes. International Journal of Rehabilitation & Health. 1996;2(4):265-75. X-2, X-4.
2919 Parvin IA, Ahmad SA, Islam MN. Knowledge about inhaler use among the chronic asthma patients in selected hospitals. Bangladesh Med Res Counc Bull. Aug. 2011;37(2):47-50. X-1, X-2, X-3, X-4. [pmid: 21877604].
2920 Paschal AM, Lewis RK, Martin A, et al. Evaluating the impact of a hypertension program for African Americans. J Natl Med Assoc. Apr. 2006;98(4):607-15. X-9. [pmid: 16623074].
2921 Paskett E, Tatum C, Rushing J, et al. Randomized trial of an intervention to improve mammography utilization among a triracial rural population of women. J Natl Cancer Inst. Sep. 6. 2006;98(17):1226-37. X-7, X-9. [pmid: 16954475].
2922 Paskett ED, Case LD, Masten KB, et al. Breast cancer screening education in the workplace. J Cancer Educ. Summer. 1994;9(2):101-4. X-2, X-4, X-10. [pmid: 7917893].
2923 Paskett ED, DeGraffinreid C, Tatum CM, et al. The recruitment of African-Americans to cancer prevention and control studies. Prev Med. Sep-Oct. 1996;25(5):547-53. X-5, X-7, X-10. [pmid: 8888322].
2924 Paskett ED, Tatum C, Rushing J, et al. Racial differences in knowledge, attitudes, and cancer screening practices among a triracial rural population. Cancer. Dec. 1. 2004;101(11):2650-9. X-2, X-4. [pmid: 15505784].
2925 Paskett ED, Tatum C, Wilson A, et al. Use of a photoessay to teach low-income African American women about mammography. J Cancer Educ. Winter. 1996;11(4):216-20. X-4. [pmid: 8989635].
2926 Paskett ED, Tatum CM, D'Agostino R Jr., et al. Community-based interventions to improve breast and cervical cancer screening: results of the Forsyth County Cancer Screening (FoCaS) Project. Cancer Epidemiol Biomarkers Prev. May. 1999;8(5):453-9. X-8, X-9. [pmid: 10350442].
2927 Patel K, Larson C, Hargreaves M, et al. Community screening outcomes for diabetes, hypertension, and cholesterol: Nashville REACH 2010 project. J Ambul Care Manage. Apr-Jun. 2010;33(2):155-62. X-2, X-4. [pmid: 20228639].
2928 Patel UD, Ou FS, Ohman EM, et al. Hospital performance and differences by kidney function in the use of recommended therapies after non-ST-elevation acute coronary syndromes. Am J Kidney Dis. Mar. 2009;53(3):426-37. X-2, X-4, X-5, X-6. [pmid: 19100672].
2929 Paul VK, Sachdev HS, Mavalankar D, et al. Reproductive health, and child health and nutrition in India: meeting the challenge. Lancet. Jan. 22. 2011;377(9762):332-49. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 21227494].
2930 Paulson JF, Dauber SE, Leiferman JA. Parental Depression, Relationship Quality, and Nonresident Father Involvement With Their Infants. Journal of Family Issues. 2011;32(4):528-49. X-2, X-4, X-5, X-6.
2931 Paulus SM. Warthen v. Toms River Community Memorial Hospital. Issues Law Med. May. 1986;1(6):479-82. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11644049].
2932 Pavlish CL, Noor S, Brandt J. Somali immigrant women and the American health care system: Discordant beliefs, divergent expectations, and silent worries. Social Science & Medicine. Jul. 2010;71(2):353-61. X-2, X-4, X-5. [pmid: 20494500].
2933 Paz SH, Liu HH, Fongwa MN, et al. Readability estimates for commonly used health-related quality of life surveys. Quality of Life Research. Sep. 2009;18(7):889-900. X-2, X-3, X-4, X-5, X-6. [pmid: 19590979].
2934 Paz SH, Varma R, Klein R, et al. Noncompliance with vision care guidelines in Latinos with type 2 diabetes mellitus: the Los Angeles Latino Eye Study. Ophthalmology. Aug. 2006;113(8):1372-7. X-2, X-4. [pmid: 16769120].
2935 Pearce CW, Hawkins JW, Carver-Chase D, et al. Comprehensive interdisciplinary care: making a difference in pregnancy outcomes for Hispanic women. Public Health Nurs. Dec. 1996;13(6):416-24. X-9. [pmid: 9111806].
2936 Peddle CJ, Plotnikoff RC, Wild TC, et al. Medical, demographic, and psychosocial correlates of exercise in colorectal cancer survivors: an application of self-determination theory. Support Care Cancer. Jan. 2008;16(1):9-17. X-2, X-4, X-6. [pmid: 17569994].
2937 Peek ME, Wagner J, Tang H, et al. Self-reported racial discrimination in health care and diabetes outcomes. Med Care. Jul. 2011;49(7):618-25. X-2, X-4. [pmid: 21478770].
2938 Peek ME, Wilson SC, Gorawara-Bhat R, et al. Barriers and facilitators to shared decision-making among African-Americans with diabetes. J Gen Intern Med. Oct. 2009;24(10):1135-9. X-2, X-4. [pmid: 19578818].
2939 Peele PB, Siminoff LA, Xu Y, et al. Decreased use of adjuvant breast cancer therapy in a randomized controlled trial of a decision aid with individualized risk information. Med Decis Making. May-Jun. 2005;25(3):301-7. X-1, X-6, X-7, X-9. [pmid: 15951457].
2940 Peiris D, Murray J, Scully D, et al. Cardiovascular risk management at a Maori-led Primary Health Organisation--findings from a cross-sectional audit. N Z Med J. Nov. 14. 2008;121(1285):35-46. X-2, X-3, X-4. [pmid: 19079435].
2941 Peleg R, Gehtman P, Blancovich I, et al. Outcomes of an intervention programme for treatment of asthma in a primary care clinic for Bedouins in southern Israel. Fam Pract. Oct. 2002;19(5):448-51. X-3. [pmid: 12356692].
2942 Pemminati S, Prabha Adhikari MR, Pathak R, et al. Prevalence of metabolic syndrome (METS) using IDF 2005 guidelines in a semi urban south Indian (Boloor Diabetes Study) population of Mangalore. J Assoc Physicians India. Nov. 2010;58:674-7. X-2, X-3, X-4, X-6. [pmid: 21510460].
2943 Pendleton L, House WC. Preferences for treatment approaches in medical care. College students versus diabetic outpatients. Med Care. Jul. 1984;22(7):644-6. X-2, X-4, X-5, X-6. [pmid: 6748782].
2944 Peniston EG, Kulkosky PJ. Alpha-theta brainwave training and beta-endorphin levels in alcoholics. Alcohol Clin Exp Res. Apr. 1989;13(2):271-9. X-4, X-5, X-6. [pmid: 2524976].
2945 Pennell P, Leclercq B, Delahunty MI, et al. The utility of non-HDL in managing dyslipidemia of stage 5 chronic kidney disease. Clin Nephrol. Nov. 2006;66(5):336-47. X-6, X-7, X-9. [pmid: 17140163].
2946 Pereira A, Niggebrugge A, Powles J, et al. Potential generation of geographical inequities by the introduction of primary percutaneous coronary intervention for the management of ST segment elevation myocardial infarction. Int J Health Geogr. 2007;6:43. X-2, X-3, X-4, X-6. [pmid: 17888181].
2947 Pereira JL, Koski S, Hanson J, et al. Internet usage among women with breast cancer: an exploratory study. Clin Breast Cancer. Jul. 2000;1(2):148-53. discussion 54-5. X-2, X-4, X-6. [pmid: 11899653].
2948 Perez M, Findley SE, Mejia M, et al. The impact of community health worker training and programs in NYC. J Health Care Poor Underserved. Feb. 2006;17(1 Suppl):26-43. X-9. [pmid: 16520505].
2949 Perraud S, Fogg L, Kopytko E, et al. Predictive validity of the Depression Coping Self-Efficacy Scale (DCSES). Res Nurs Health. Apr. 2006;29(2):147-60. X-2, X-4, X-6. [pmid: 16532479].
2950 Perrin EC, Sack S. Health and development of gay and lesbian youths: Implications for HIV/AIDS. Aids Patient Care and Stds. Apr. 1998;12(4):303-13. X-1, X-2, X-4, X-5. [pmid: 11361957].
2951 Perrin KM, Burke SG, O'Connor D, et al. Factors contributing to intervention fidelity in a multi-site chronic disease self-management program. Implementation Science. 2006:1. X-1, X-2, X-3, X-4, X-6. [pmid: 17067388].
2952 Perrin PB, Johnston A, Vogel B, et al. A culturally sensitive Transition Assistance Program for stroke caregivers: examining caregiver mental health and stroke rehabilitation. J Rehabil Res Dev. 2010;47(7):605-17. X-4, X-5, X-6. [pmid: 21110257].
2953 Perry E, Swartz J, Brown S, et al. Peer mentoring: a culturally sensitive approach to end-of-life planning for long-term dialysis patients. Am J Kidney Dis. Jul. 2005;46(1):111-9. X-6, X-7, X-9. [pmid: 15983964].
2954 Perry H, Berggren W, Berggren G, et al. Long-term reductions in mortality among children under age 5 in rural Haiti: effects of a comprehensive health system in an impoverished setting. Am J Public Health. Feb. 2007;97(2):240-6. X-2, X-3, X-4, X-5. [pmid: 17194853].
2955 Persell SD, Keating NL, Landrum MB, et al. Relationship of diabetes-specific knowledge to self-management activities, ambulatory preventive care, and metabolic outcomes. Prev Med. Oct. 2004;39(4):746-52. X-2, X-4, X-6. [pmid: 15351541].
2956 Persell SD, Osborn CY, Richard R, et al. Limited health literacy is a barrier to medication reconciliation in ambulatory care. J Gen Intern Med. Nov. 2007;22(11):1523-6. X-2, X-4. [pmid: 17786521].
2957 Persky V, Turyk M, Piorkowski J, et al. Inner-city asthma: the role of the community. Chest. Nov. 2007;132(5 Suppl):831S-9S. X-1, X-2, X-3, X-4, X-6. [pmid: 17998347].
2958 Peters AL, Legorreta AP, Ossorio RC, et al. Quality of outpatient care provided to diabetic patients. A health maintenance organization experience. Diabetes Care. Jun. 1996;19(6):601-6. X-2, X-4, X-6. [pmid: 8725859].
2959 Peters DP. Colon cancer screening: recommendations and barriers to patient participation. Nurse Pract. Dec. 2008;33(12):14-20. quiz 1. X-1, X-2, X-3, X-4, X-6. [pmid: 19057341].
2960 Peters KF, Kong F, Horne R, et al. Living with Marfan syndrome I. Perceptions of the condition. Clin Genet. Oct. 2001;60(4):273-82. X-2, X-4, X-5, X-6. [pmid: 11683773].
2961 Peters RM Jr. XML: defining the transition from paper to digital records. J AHIMA. Jan. 2000;71(1):34-8. quiz 9-40. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11009647].
2962 Peters RM, Benkert R, Butler K, et al. Provider adherence to JNC 7 guidelines and blood pressure outcomes in African Americans. Journal of Clinical Outcomes Management. 2007;14(1):32-40. X-2, X-4.
2963 Peters RM, Olsen KL. Kidney disease awareness among high-risk African Americans. American Journal for Nurse Practitioners. 2010;14(3):40-7. X-2, X-4.
2964 Peters RM, Templin TN. Measuring blood pressure knowledge and self-care behaviors of African Americans. Res Nurs Health. Dec. 2008;31(6):543-52. X-2, X-4. [pmid: 18491375].
2965 Peters RM, Templin TN. Theory of planned behavior, self-care motivation, and blood pressure self-care. Res Theory Nurs Pract. 2010;24(3):172-86. X-2, X-4. [pmid: 20949834].
2966 Peterson ED, Bynum DZ, Roe MT. Association of evidence-based care processes and outcomes among patients with acute coronary syndromes: performance matters. J Cardiovasc Nurs. Jan-Feb. 2008;23(1):50-5. X-6, X-9. [pmid: 18158508].
2967 Peterson ED, Shah BR, Parsons L, et al. Trends in quality of care for patients with acute myocardial infarction in the National Registry of Myocardial Infarction from 1990 to 2006. Am Heart J. Dec. 2008;156(6):1045-55. X-2, X-4. [pmid: 19032998].
2968 Peterson NB, Dwyer KA, Mulvaney SA, et al. The influence of health literacy on colorectal cancer screening knowledge, beliefs and behavior. J Natl Med Assoc. Oct. 2007;99(10):1105-12. X-2, X-4. [pmid: 17987913].
2969 Peterson PN, Shetterly SM, Clarke CL, et al. Health literacy and outcomes among patients with heart failure. JAMA. Apr. 27. 2011;305(16):1695-701. X-2, X-4. [pmid: 21521851].
2970 Peterson-Sweeney K, McMullen A, Yoos HL, et al. Impact of asthma education received from health care providers on parental illness representation in childhood asthma. Res Nurs Health. Apr. 2007;30(2):203-12. X-6, X-7, X-9. [pmid: 17380521].
2971 Petrazzuoli F, Soler JK, Buono N, et al. Quality of care for hypertensive patients with type 2 diabetes in a rural area of Southern Italy: is the recording of patient data and the achievement of quality indicators targets satisfactory?. Rural Remote Health. Jul-Sep. 2010;10(3):1258. X-2, X-3, X-4, X-6. [pmid: 20843159].
2972 Petri M, Spence D, Bone LR, et al. Coronary artery disease risk factors in the Johns Hopkins Lupus Cohort: prevalence, recognition by patients, and preventive practices. Medicine (Baltimore). Sep. 1992;71(5):291-302. X-2, X-4, X-6. [pmid: 1522805].
2973 Petrides P, Petermann F, Henrichs HR, et al. Coping with employment discrimination against diabetics: trends in social medicine and social psychology. Patient Educ Couns. Sep. 1995;26(1-3):203-8. X-2, X-3, X-4, X-6. [pmid: 7494723].
2974 Petterson T, Dornan TL, Albert T, et al. Are information leaflets given to elderly people with diabetes easy to read?. Diabet Med. Jan-Feb. 1994;11(1):111-3. X-2, X-3, X-4, X-6. [pmid: 8181240].
2975 Peveler RC, Davies BA, Mayou RA, et al. Self-care behaviour and blood glucose control in young adults with type 1 diabetes mellitus. Diabet Med. Jan-Feb. 1993;10(1):74-80. X-2, X-4. [pmid: 8435992].
2976 Peyrot M, Rubin RR. Levels and risks of depression and anxiety symptomatology among diabetic adults. Diabetes Care. Apr. 1997;20(4):585-90. X-6, X-7, X-9. [pmid: 9096984].
2977 Peyrot M, Rubin RR, Kruger DF, et al. Correlates of insulin injection omission. Diabetes Care. Feb. 2010;33(2):240-5. X-2, X-4. [pmid: 20103556].
2978 Pham HH, Schrag D, Hargraves JL, et al. Delivery of Preventive Services to Older Adults by Primary Care Physicians. JAMA: Journal of the American Medical Association. Jul. 2005;294(4):473-81. X-2, X-4. [pmid: 16046654].
2979 Pham JC, Kelen GD, Pronovost PJ. National study on the quality of emergency department care in the treatment of acute myocardial infarction and pneumonia. Acad Emerg Med. Oct. 2007;14(10):856-63. X-2, X-4, X-6. [pmid: 17898249].
2980 Philip EJ, DuHamel K, Jandorf L. Evaluating the impact of an educational intervention to increase CRC screening rates in the African American community: a preliminary study. Cancer Causes Control. Oct. 2010;21(10):1685-91. X-9. [pmid: 20535541].
2981 Philis-Tsimikas A, Walker C. Improved care for diabetes in underserved populations. J Ambul Care Manage. Jan. 2001;24(1):39-43. X-9. [pmid: 11189795].
2982 Philis-Tsimikas A, Walker C, Rivard L, et al. Improvement in diabetes care of underinsured patients enrolled in project dulce: a community-based, culturally appropriate, nurse case management and peer education diabetes care model. Diabetes Care. Jan. 2004;27(1):110-5. X-9. [pmid: 14693975].
2983 Phillippi JC. Women's Perceptions of Access to Prenatal Care in the United States: A Literature Review. Journal of Midwifery & Womens Health. May-Jun. 2009;54(3):219-25. X-1, X-2, X-3, X-4, X-6. [pmid: 19410214].
2984 Phillips CE, Rothstein JD, Beaver K, et al. Patient navigation to increase mammography screening among inner city women. Journal of General Internal Medicine. Feb. 2011;26(2):123-9. X-9. [pmid: 20931294].
2985 Phillips JM. Breast cancer and African American women: moving beyond fear, fatalism, and silence. Oncol Nurs Forum. Jul. 1999;26(6):1001-7. X-1, X-6, X-7, X-9. [pmid: 10420418].
2986 Phillips KA, Kerlikowske K, Baker LC, et al. Factors associated with women's adherence to mammography screening guidelines. Health Serv Res. Apr. 1998;33(1):29-53. X-2, X-4. [pmid: 9566176].
2987 Phillips LS. Diabetes: update on management and treatment. Ethn Dis. Summer. 2003;13(3 Suppl 3):S3-32-3. X-1, X-2, X-3, X-4, X-6. [pmid: 14552446].
2988 Phillips LS, Ziemer DC, Doyle JP, et al. An endocrinologist-supported intervention aimed at providers improves diabetes management in a primary care site: improving primary care of African Americans with diabetes (IPCAAD) 7. Diabetes Care. Oct. 2005;28(10):2352-60. X-9. [pmid: 16186262].
2989 Phillips P, Wilson D, Beilby J, et al. Diabetes complications and risk factors in an Australian population. How well are they managed?. Int J Epidemiol. Oct. 1998;27(5):853-9. X-2, X-3, X-4, X-6. [pmid: 9839743].
2990 Phillips RSC. Preventing depression: a program for African American elders with chronic pain. Family & Community Health. 2000;22(4):57-65. X-5.
2991 Philp F, Lucock MP, Wilson AR. Primary care-based guided self-help for depression provided by a nurse practitioner: a pilot evaluation. Primary Care Mental Health. 2006;4(3):159-64. X-4, X-6.
2992 Phinney A, Wallhagen M. Recognizing and understanding the symptoms of type 2 diabetes. Can J Nurs Res. Dec. 2003;35(4):108-24. X-2, X-4. [pmid: 14746124].
2993 Piane G. A comparison of the effect of a hypertension education program among black and white participants. J Health Care Poor Underserved. Fall. 1990;1(2):243-53. X-11, X-12. [pmid: 2130904].
2994 Pichert JW, McClellan LH, Larson C, et al. Development and evaluation of a bible college-based course on faith and health. J Ambul Care Manage. Apr-Jun. 2006;29(2):141-50. X-1, X-2, X-4, X-5. [pmid: 16552323].
2995 Pierce DK, Connor SL, Sexton G, et al. Knowledge of and attitudes toward coronary heart disease and nutrition in Oregon families. Prev Med. Jul. 1984;13(4):390-5. X-2, X-4, X-6. [pmid: 6504867].
2996 Pierce-Bulger M, Nighswander T. Nutaqsiivik--an approach to reducing infant mortality using quality improvement principles. Qual Manag Health Care. Spring. 2001;9(3):40-6. X-5. [pmid: 11372502].
2997 Piette JD. Patient education via automated calls: a study of English and Spanish speakers with diabetes. Am J Prev Med. Aug. 1999;17(2):138-41. X-4, X-7. [pmid: 10490057].
2998 Piette JD. Satisfaction with automated telephone disease management calls and its relationship to their use. Diabetes Educ. Nov-Dec. 2000;26(6):1003-10. X-10. [pmid: 11912804].
2999 Piette JD, Lange I, Issel M, et al. Use of telephone care in a cardiovascular disease management programme for type 2 diabetes patients in Santiago, Chile. Chronic Illn. Jun. 2006;2(2):87-96. X-2, X-3, X-4. [pmid: 17175652].
3000 Piette JD, Mah CA. The feasibility of automated voice messaging as an adjunct to diabetes outpatient care. Diabetes Care. Jan. 1997;20(1):15-21. X-4, X-6. [pmid: 9028687].
3001 Piette JD, McPhee SJ, Weinberger M, et al. Use of automated telephone disease management calls in an ethnically diverse sample of low-income patients with diabetes. Diabetes Care. Aug. 1999;22(8):1302-9. X-7, X-9. [pmid: 10480775].
3002 Piette JD, Richardson C, Himle J, et al. A randomized trial of telephonic counseling plus walking for depressed diabetes patients. Med Care. Jul. 2011;49(7):641-8. X-6, X-9. [pmid: 21478777].
3003 Piette JD, Schillinger D, Potter MB, et al. Dimensions of patient-provider communication and diabetes self-care in an ethnically diverse population. J Gen Intern Med. Aug. 2003;18(8):624-33. X-2, X-4. [pmid: 12911644].
3004 Piette JD, Wagner TH, Potter MB, et al. Health insurance status, cost-related medication underuse, and outcomes among diabetes patients in three systems of care. Med Care. Feb. 2004;42(2):102-9. X-2, X-4. [pmid: 14734946].
3005 Piette JD, Weinberger M, McPhee SJ, et al. Do automated calls with nurse follow-up improve self-care and glycemic control among vulnerable patients with diabetes?. Am J Med. Jan. 2000;108(1):20-7. X-9. [pmid: 11059437].
3006 Pike EV, Richmond CM, Hobson A, et al. Development and evaluation of an integrated asthma awareness curriculum for the elementary school classroom. J Urban Health. Feb. Suppl 1. 2011;88:61-7. X-4, X-6. [pmid: 21337052].
3007 Pilkington FB, Daiski I, Bryant T, et al. The experience of living with diabetes for low-income Canadians. Canadian Journal of Diabetes. 2010;34(2):119-26. X-2, X-3, X-4.
3008 Pinar R, Arslanoglu I, Isguven P, et al. Self-efficacy and its interrelation with family environment and metabolic control in Turkish adolescents with type 1 diabetes. Pediatr Diabetes. Dec. 2003;4(4):168-73. X-2, X-3, X-4. [pmid: 14710777].
3009 Pineda RG. Predictors of breastfeeding and breastmilk feeding among very low birth weight infants. Breastfeed Med. Feb. 2011;6(1):15-9. X-2, X-4. [pmid: 20807105].
3010 Pineda RG, Foss J, Richards L, et al. Breastfeeding changes for VLBW infants in the NICU following staff education. Neonatal Netw. Sep-Oct. 2009;28(5):311-9. X-5, X-6. [pmid: 19720595].
3011 Pinhas-Hamiel O, Zeitler P. Barriers to the treatment of adolescent type 2 diabetes--a survey of provider perceptions. Pediatr Diabetes. Mar. 2003;4(1):24-8. X-2, X-4, X-6. [pmid: 14655520].
3012 Pinnock H, Sheikh A. Primary care research and clinical practice: respiratory disease. Postgrad Med J. Feb. 2009;85(1000):74-9. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19329701].
3013 Pinzon-Perez H, Mountcastle K. Proposed recommendations for health policies in childhood diabesity prevention in the Dominican Republic: implications for nursing. Hispanic Health Care International. 2010;8(3):165-73. X-1, X-2, X-3, X-4, X-5.
3014 Piper CN, Elder K, Glover S, et al. Asthma management plans for children can lead to a healthier life. Ethn Dis. Spring. 2008;18(2):238. X-1, X-2, X-3, X-4, X-6. [pmid: 18507283].
3015 Piper CN, Elder K, Glover S, et al. Racial influences associated with asthma management among children in the United States. Ethn Dis. Spring. 2008;18(2):225-7. X-2, X-4. [pmid: 18507278].
3016 Piper CN, Elder K, Glover S, et al. Disparities between asthma management and insurance type among children. J Natl Med Assoc. Jul. 2010;102(7):556-61. X-2, X-4. [pmid: 20690318].
3017 Pipkin M, Eggers PW, Larive B, et al. Recruitment and training for home hemodialysis: experience and lessons from the Nocturnal Dialysis Trial. Clin J Am Soc Nephrol. Sep. 2010;5(9):1614-20. X-2, X-4, X-6. [pmid: 20576829].
3018 Pisu M, Azuero A, Meneses K, et al. Out of pocket cost comparison between Caucasian and minority breast cancer survivors in the Breast Cancer Education Intervention (BCEI). Breast Cancer Res Treat. Jun. 2011;127(2):521-9. X-2, X-10. [pmid: 20976542].
3019 Pittrof R, Goodburn E. Should we change the focus of health promotion in sexual health clinics?. Sex Health. Dec. 2010;7(4):407-10. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 21062578].
3020 Plaza CI. Finance, pharmaceuticals issue brief: mandated benefits: diabetes coverage requirements: year end report-2003. Issue Brief Health Policy Track Serv. Dec. 31. 2003:1-8. X-1, X-2, X-3, X-4, X-6. [pmid: 14870750].
3021 Plescia M, Groblewski M. A community-oriented primary care demonstration project: refining interventions for cardiovascular disease and diabetes. Ann Fam Med. Mar-Apr. 2004;2(2):103-9. X-2, X-4, X-6. [pmid: 15083848].
3022 Plescia M, Groblewski M, Chavis L. A lay health advisor program to promote community capacity and change among change agents. Health Promot Pract. Oct. 2008;9(4):434-9. X-2, X-4, X-5, X-6. [pmid: 17105806].
3023 Plescia M, Herrick H, Chavis L. Improving health behaviors in an African American community: the Charlotte Racial and Ethnic Approaches to Community Health project. Am J Public Health. Sep. 2008;98(9):1678-84. X-9, X-10. [pmid: 18633087].
3024 Pliskin NH, Yurk HM, Ho LT, et al. Neurocognitive function in chronic hemodialysis patients. Kidney International. May. 1996;49(5):1435-40. X-2, X-3, X-4, X-6. [pmid: 8731111].
3025 Poduval RD, Wolgemuth C, Ferrell J, et al. Hyperphosphatemia in dialysis patients: is there a role for focused counseling?. J Ren Nutr. Jul. 2003;13(3):219-23. X-2, X-4. [pmid: 12874747].
3026 Polikandrioti M, Evaggelou E, Zerva S, et al. Evaluation of depression in patients undergoing chemotherapy. Health Science Journal. 2008;2(3):162-72. X-2, X-4, X-5, X-6.
3027 Politi MC, Clark MA, Ombao H, et al. Communicating uncertainty can lead to less decision satisfaction: a necessary cost of involving patients in shared decision making?. Health Expectations. Mar. 2011;14(1):84-91. X-2, X-4, X-5, X-6. [pmid: 20860780].
3028 Pollock JB, Jaffery JB. Knowledge of phosphorus compared with other nutrients in maintenance dialysis patients. J Ren Nutr. Sep. 2007;17(5):323-8. X-2, X-4. [pmid: 17720101].
3029 Polonsky WH, Fisher L, Earles J, et al. Assessing psychosocial distress in diabetes: development of the diabetes distress scale. Diabetes Care. Mar. 2005;28(3):626-31. X-2, X-4, X-6. [pmid: 15735199].
3030 Polonsky WH, Fisher L, Guzman S, et al. Are patients' initial experiences at the diagnosis of type 2 diabetes associated with attitudes and self-management over time?. Diabetes Educ. Sep-Oct. 2010;36(5):828-34. X-2, X-4, X-6. [pmid: 20729511].
3031 Polonsky WH, Jelsovsky Z, Panzera S, et al. Primary care physicians identify and act upon glycemic abnormalities found in structured, episodic blood glucose monitoring data from non-insulin-treated type 2 diabetes. Diabetes Technol Ther. May. 2009;11(5):283-91. X-2, X-4, X-6. [pmid: 19425876].
3032 Polzer RL. African Americans and diabetes: spiritual role of the health care provider in self-management. Res Nurs Health. Apr. 2007;30(2):164-74. X-2, X-4. [pmid: 17380517].
3033 Polzer RL, Miles MS. Spirituality in African Americans with diabetes: self-management through a relationship with God. Qual Health Res. Feb. 2007;17(2):176-88. X-2, X-4. [pmid: 17220389].
3034 Pomerantz KL, Muhammad AA, Downey S, et al. Connecting for health literacy: health information partners. Health Promot Pract. Jan. 2010;11(1):79-88. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18544664].
3035 Pomeroy EC, Green DL, Laningham LV. Couples who care: the effectiveness of a psychoeducational group intervention for HIV serodiscordant couples. Research on Social Work Practice. 2002;12(2):238-52. X-5, X-6.
3036 Pommier BE. Factors affecting learning in a coronary artery disease rehabilitation class. Rehabil Nurs. Mar-Apr. 1992;17(2):64-7. X-6, X-10. [pmid: 1553418].
3037 Ponzo MG, Gucciardi E, Weiland M, et al. Gender, ethnocultural, and psychosocial barriers to diabetes self-management in Italian women and men with type 2 diabetes. Behavioral Medicine. Win. 2006;31(4):153-60. X-2, X-3, X-4. [pmid: 16526349].
3038 Popkess-Vawter S. The adult living with diabetes mellitus. Nurs Clin North Am. Dec. 1983;18(4):777-89. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 6557515].
3039 Popoola MM. Living with diabetes: The holistic experiences of Nigerians and African Americans. Holist Nurs Pract. Jan-Feb. 2005;19(1):10-6. X-2, X-4, X-5. [pmid: 15736725].
3040 Porter SJ, Chapman-Novakofski KM, Scherer JA. Your Guide to Diet and Diabetes: web-based diabetes education tailored to Hispanics. J Nutr Educ Behav. Sep-Oct. 2009;41(5):374-6. X-1, X-7, X-9. [pmid: 19717123].
3041 Porterfield DS, Kinsinger L. Quality of care for uninsured patients with diabetes in a rural area. Diabetes Care. Feb. 2002;25(2):319-23. X-2, X-4. [pmid: 11815503].
3042 Portnoy DB, Roter D, Erby LH. The role of numeracy on client knowledge in BRCA genetic counseling. Patient Educ Couns. Oct. 2010;81(1):131-6. X-2, X-4. [pmid: 19854023].
3043 Portnoy JM, Jennings D. Utilization patterns in an asthma intervention. Ann Allergy Asthma Immunol. Jul. 2006;97(1 Suppl 1):S25-30. X-6, X-9. [pmid: 16892768].
3044 Poss J, Jezewski MA. The role and meaning of susto in Mexican Americans' explanatory model of type 2 diabetes. Med Anthropol Q. Sep. 2002;16(3):360-77. X-2, X-4. [pmid: 12227261].
3045 Poss JE, Jezewski MA, Stuart AG. Home remedies for type 2 diabetes used by Mexican Americans in El Paso, Texas. Clin Nurs Res. Nov. 2003;12(4):304-23. X-2, X-4. [pmid: 14620689].
3046 Postma JM, Smalley K, Ybarra V, et al. The feasibility and acceptability of a home-visitation, asthma education program in a rural, Latino/a population. J Asthma. Mar. 2011;48(2):139-46. X-4, X-8, X-9, X-10. [pmid: 21043988].
3047 Poston WS 2nd, Haddock CK, Olvera NE, et al. Evaluation of a culturally appropriate intervention to increase physical activity. Am J Health Behav. Jul-Aug. 2001;25(4):396-406. X-5. [pmid: 11488550].
3048 Potvin L, Cargo M, McComber AM, et al. Implementing participatory intervention and research in communities: lessons from the Kahnawake Schools Diabetes Prevention Project in Canada. Soc Sci Med. Mar. 2003;56(6):1295-305. X-1, X-2, X-3, X-4, X-6. [pmid: 12600366].
3049 Poulsen B, Graversen HP, Beckmann J, et al. A comparative study of post-operative psychosocial function in women with primary operable breast cancer randomized to breast conservation therapy or mastectomy. Eur J Surg Oncol. Aug. 1997;23(4):327-34. X-2, X-4, X-6. [pmid: 9315062].
3050 Poureslami I, Rootman I, Doyle-Waters MM, et al. Health literacy, language, and ethnicity-related factors in newcomer asthma patients to Canada: a qualitative study. J Immigr Minor Health. Apr. 2011;13(2):315-22. X-2, X-3, X-4. [pmid: 20938742].
3051 Povar GJ, Mantell M, Morris LA. Patients' therapeutic preferences in an ambulatory care setting. Am J Public Health. Dec. 1984;74(12):1395-7. X-2, X-4, X-5. [pmid: 6507693].
3052 Povlsen L, Olsen B, Ladelund S. Educating families from ethnic minorities in type 1 diabetes-experiences from a Danish intervention study. Patient Educ Couns. Nov. 2005;59(2):164-70. X-3, X-4. [pmid: 16257621].
3053 Povlsen L, Olsen B, Ladelund S. Diabetes in children and adolescents from ethnic minorities: barriers to education, treatment and good metabolic control. J Adv Nurs. Jun. 2005;50(6):576-82. X-2, X-3, X-4. [pmid: 15926962].
3054 Povlsen L, Olsen B, Ladelund S. Educating families from ethnic minorities in type 1 diabetes--experiences from a Danish intervention study. Patient Education and Counseling. Nov. 2005;59(2):164-70. X-14. [pmid: 16257621].
3055 Powe BD, Cooper DL, Harmond L, et al. Comparing knowledge of colorectal and prostate cancer among African American and Hispanic men. Cancer Nurs. Sep-Oct. 2009;32(5):412-7. X-2, X-4. [pmid: 19661793].
3056 Powe BD, Daniels EC, Finnie R, et al. Perceptions about breast cancer among African American women: do selected educational materials challenge them?. Patient Educ Couns. Feb. 2005;56(2):197-204. X-2, X-4. [pmid: 15653249].
3057 Powe BD, Finnie R, Ko J. Enhancing knowledge of colorectal cancer among African Americans: why are we waiting until age 50?. Gastroenterol Nurs. Jan-Feb. 2006;29(1):42-9. X-2, X-4. [pmid: 16552299].
3058 Powe BD, Ntekop E, Barron M. An intervention study to increase colorectal cancer knowledge and screening among community elders. Public Health Nurs. Sep-Oct. 2004;21(5):435-42. X-6, X-9. [pmid: 15363024].
3059 Powe BD, Underwood S, Canales M, et al. Perceptions about breast cancer among college students: implications for nursing education. J Nurs Educ. Jun. 2005;44(6):257-65. X-2, X-4, X-5, X-6. [pmid: 16021802].
3060 Powe BD, Weinrich S. An intervention to decrease cancer fatalism among rural elders. Oncol Nurs Forum. Apr. 1999;26(3):583-8. X-4, X-6. [pmid: 10214599].
3061 Powell CK, Hill EG, Clancy DE. The relationship between health literacy and diabetes knowledge and readiness to take health actions. The Diabetes Educator. Jan-Feb. 2007;33(1):144-51. X-2, X-4. [pmid: 17272800].
3062 Powell ME, Carter V, Bonsi E, et al. Increasing mammography screening among African American women in rural areas. Journal of Health Care for the Poor and Underserved. Nov. 2005;16(4,SupplA):11-21. X-7, X-9. [pmid: 16327093].
3063 3064. Power J, Brown L, Ritvo P. A qualitative study examining psychosocial distress, coping, and social support across the stages and phases of epithelial ovarian cancer. Health Care Women Int. Apr. 2008;29(4):366-83. X-2, X-4, X-5, X-6. [pmid: 18389433].
3064 Powers BJ, King JL, Ali R, et al. The Cholesterol, Hypertension, and Glucose Education (CHANGE) study for African Americans with diabetes: study design and methodology. Am Heart J. Sep. 2009;158(3):342-8. X-1, X-9. [pmid: 19699855].
3065 Press J, Fagan J, Bernd E. Child care, work, and depressive symptoms among low-income mothers. Journal of Family Issues. 2006;27(5):609-32. X-2, X-4, X-5.
3066 Press VG, Pincavage AT, Pappalardo AA, et al. The Chicago Breathe Project: a regional approach to improving education on asthma inhalers for resident physicians and minority patients. J Natl Med Assoc. Jul. 2010;102(7):548-55. X-1, X-4, X-7, X-9. [pmid: 20690317].
3067 Price CS, Spence SH, Sheffield J, et al. The development and psychometric properties of a measure of social and adaptive functioning for children and adolescents. J Clin Child Adolesc Psychol. Mar. 2002;31(1):111-22. X-2, X-4, X-5, X-6. [pmid: 11845643].
3068 Pridham K, Brown R, Clark R, et al. Effect of guided participation on feeding competencies of mothers and their premature infants. Res Nurs Health. Jun. 2005;28(3):252-67. X-4, X-5. [pmid: 15884024].
3069 Pridham K, Melby JN, Brown R, et al. The contribution of infant, maternal, and family conditions to maternal feeding competencies. Parenting: Science & Practice. 2010. Jan-Mar. 2010;10(1):18-42. X-2, X-4, X-5.
3070 Primm AB, Cabot D, Pettis J, et al. The acceptability of a culturally-tailored depression education videotape to African Americans. J Natl Med Assoc. Nov. 2002;94(11):1007-16. X-4. [pmid: 12443007].
3071 Primo CC, Costa Sipioni RM, et al. Using the International Classification for Nursing Practice in the care of women with mastectomy. Acta Paulista de Enfermagem. 2010;23(6):803-10. X-2, X-3, X-4, X-5, X-6.
3072 Prins MA, Verhaak PF, Smolders M, et al. Patient factors associated with guideline-concordant treatment of anxiety and depression in primary care. J Gen Intern Med. Jul. 2010;25(7):648-55. X-2, X-3, X-4, X-6. [pmid: 20049547].
3073 Prisant LM. Fixed low-dose combination therapy: current recommendations. Manag Care. Aug. 2003;12(8 Suppl Hypertension):45-50. X-1, X-2, X-3, X-4, X-6. [pmid: 12971592].
3074 Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. May. 1999;53(5):311-6. X-3. [pmid: 10396539].
3075 Pulgaron ER, Salamon KS, Patterson CA, et al. A problem-solving intervention for children with persistent asthma: a pilot of a randomized trial at a pediatric summer camp. J Asthma. Nov. 2010;47(9):1031-9. X-4, X-6. [pmid: 20858029].
3076 Pulignano G, Del Sindaco D, Minardi G, et al. Translation and validation of the Italian version of the European Heart Failure Self-care Behaviour Scale. J Cardiovasc Med (Hagerstown). Jul. 2010;11(7):493-8. X-2, X-3, X-4. [pmid: 20407384].
3077 Purmort J, Coady MH, Bucciarelli A, et al. Asthma education in a subsidized preschool setting. J Health Care Poor Underserved. Nov. 2008;19(4):1241-7. X-7, X-9. [pmid: 19029749].
3078 Pushaw J. A conversation with Janice Pushaw. Manag Care Interface. Suppl C. 2003:18-20. X-1, X-2, X-3, X-4, X-6. [pmid: 14569633].
3079 Putkonen H, Weizmann-Henelius G, Collander J, et al. Neonaticides may be more preventable and heterogeneous than previously thought - neonaticides in Finland 1980-2000. Arch Womens Ment Health. Feb. 2007;10(1):15-23. X-2, X-3, X-4, X-5, X-6. [pmid: 17216371].
3080 Pyatak E. Participation in occupation and diabetes self-management in emerging adulthood. Am J Occup Ther. Jul-Aug. 2011;65(4):462-9. X-2, X-4. [pmid: 21834462].
3081 Qaseem A, Snow V, Denberg TD, et al. Using Second-Generation Antidepressants to Treat Depressive Disorders: A Clinical Practice Guideline from the American College of Physicians. Annals of Internal Medicine. Nov. 2008;149(10):725-U10. X-1, X-2, X-3, X-4, X-6. [pmid: 19017591].
3082 Qin DB, Way N, Rana M. The “model minority” and their discontent: examining peer discrimination and harassment of Chinese American immigrant youth. New Dir Child Adolesc Dev. Fall. 2008;2008(121):27-42. X-2, X-4, X-5. [pmid: 18792949].
3083 Quandt SA, Bell RA, Snively BM, et al. Dietary fat reduction behaviors among African American, American Indian, and white older adults with diabetes. J Nutr Elder. Apr. 2009;28(2):143-57. X-2, X-4. [pmid: 20396599].
3084 Quillin JM, McClish DK, Jones RM, et al. Duration of an intervention's impact on perceived breast cancer risk. Health Educ Behav. Dec. 2008;35(6):855-65. X-6, X-7, X-9. [pmid: 19011219].
3085 Quillin JM, Silberg J, Jones RM, et al. Tolerance for ambiguity could influence awareness of breast cancer genetic testing and inform health education. Cancer Causes Control. Dec. 2008;19(10):1227-32. X-2, X-4, X-5. [pmid: 18592383].
3086 Quimbo SA, Peabody JW, Shimkhada R, et al. Evidence of a causal link between health outcomes, insurance coverage, and a policy to expand access: experimental data from children in the Philippines. Health Econ. May. 2011;20(5):620-30. X-3. [pmid: 20540042].
3087 Quinley JC, Shih A. Improving Physician Coverage of Pneumococcal Vaccine: A Randomized Trial of a Telephone Intervention. Journal of Community Health: The Publication for Health Promotion and Disease Prevention. Apr. 2004;29(2):103-15. X-9. [pmid: 15065730].
3088 Quinn G, Vadaparampil S, Wilson C, et al. Attitudes of high-risk women toward preimplantation genetic diagnosis. Fertil Steril. Jun. 2009;91(6):2361-8. X-2, X-4, X-5, X-6. [pmid: 18440521].
3089 Quinn GP, McIntyre J, Vadaparampil ST. Preferences for Hereditary Breast and Ovarian Cancer Information among Mexican, Cuban and Puerto Rican Women at. Risk Public Health Genomics. 2011;14(4-5):248-58. X-2, X-4. [pmid: 20150724].
3090 Quinn MT, Cook S, Nash K, et al. Addressing religion and spirituality in African Americans with diabetes. Diabetes Educ. Sep-Oct. 2001;27(5):643-4. 7. 8. 55. X-1, X-6, X-7, X-9. [pmid: 12212014].
3091 Quinn MT, McNabb WL. Training lay health educators to conduct a church-based weight-loss program for African American women. Diabetes Educ. Mar-Apr. 2001;27(2):231-8. X-5. [pmid: 11913005].
3092 Quinn RR, Laupacis A, Hux JE, et al. Predicting the risk of 1-year mortality in incident dialysis patients: accounting for case-mix severity in studies using administrative data. Med Care. Mar. 2011;49(3):257-66. X-2, X-3, X-4, X-6. [pmid: 21301370].
3093 Radnai M, Pal A, Novak T, et al. Benefits of periodontal therapy when preterm birth threatens. J Dent Res. Mar. 2009;88(3):280-4. X-4, X-6. [pmid: 19329465].
3094 Rafique G, Shaikh F. Identifying needs and barriers to diabetes education in patients with diabetes. J Pak Med Assoc. Aug. 2006;56(8):347-52. X-2, X-3, X-4, X-6. [pmid: 16967784].
3095 Raftopoulos V. Pain, satisfaction with quality of pain management and depressive symptoms in elderly hospitalized patients. ICUs & Nursing Web Journal. 2005. Jan-Mar. 2005;(21):17p. X-2, X-3, X-4, X-6.
3096 Ragnarson Tennvall G, Apelqvist J. Health-related quality of life in patients with diabetes mellitus and foot ulcers. J Diabetes Complications. Sep-Oct. 2000;14(5):235-41. X-2, X-4, X-6. [pmid: 11113684].
3097 Rahim-Williams B. Beliefs, behaviors, and modifications of type 2 diabetes self-management among African American women. J Natl Med Assoc. Mar. 2011;103(3):203-15. X-2, X-4. [pmid: 21671524].
3098 Rahim-Williams B, Tomar S, Blanchard S, et al. Influences of adult-onset diabetes on orofacial pain and related health behaviors. J Public Health Dent. Spring. 2010;70(2):85-92. X-2, X-4, X-6. [pmid: 19765201].
3099 Rahman AA, Daud WNW, Sulaiman SA, et al. The impact of knowledge and sociodemographic factors on the dangerous use of herbal medicines during pregnancy in Tumpat district. International Medical Journal. 2008;15(3):209-12. X-2, X-3, X-4.
3100 Rahman SM, Dignan MB, Shelton BJ. Factors influencing adherence to guidelines for screening mammography among women aged 40 years and older. Ethn Dis. Fall. 2003;13(4):477-84. X-2, X-4. [pmid: 14632267].
3101 Rai S, Kivisalu T, Rabheru K, et al. Electroconvulsive therapy clinical database: a standardized approach in tertiary care psychiatry. J EC T. Dec. 2010;26(4):304-9. X-1, X-2, X-4, X-5, X-6. [pmid: 20357667].
3102 Rainis T, Halloun L, Keren D, et al. Colorectal cancer among Arab-Israeli women--possible reasons for increased incidence and mortality. J Gastrointest Cancer. Jun. 2010;41(2):130-4. X-3. [pmid: 20108055].
3103 Raiz L, Monroe J. Employment post-transplant: a biopsychosocial analysis. Soc Work Health Care. 2007;45(3):19-37. X-2, X-4. [pmid: 17855228].
3104 Ramirez AG. Hypertension in Hispanic Americans: Overview of the population. Public Health Reports. 1996;111:25-6. X-1, X-2, X-4. [pmid: 8898766].
3105 Ramirez M, Teresi J, Holmes D. A comparison of characteristics of white and African-American participants of adult day health care centers in New York State. Journal of Social Work in Long-Term Care. 2002;1(1):89-106. X-2, X-4, X-5.
3106 Ramos E, Goncalves MS, Bensi CG, et al. Spirituality correlates positively with higher quality of life and negatively with depression in low income Brazilian cancer patients. Supportive & Palliative Cancer Care. 2006;3(1):15-8. X-2, X-3, X-4, X-5, X-6.
3107 Ramsden VR, Shuaib A, Reeder BA, et al. Risk factor awareness: a randomized telephone survey of public knowledge. Can J Public Health. Sep-Oct. Suppl 2. 1994;85:S57-60. X-2, X-3, X-4, X-5, X-6. [pmid: 7804953].
3108 Rance K, O'Laughlen M, Ting S. Improving asthma care for African American children by increasing national asthma guideline adherence. J Pediatr Health Care. Jul-Aug. 2011;25(4):235-49. X-6, X-9. [pmid: 21700138].
3109 Rankin D, Heller S, Lawton J. Understanding information and education gaps among people with type 1 diabetes: a qualitative investigation. Patient Educ Couns. Apr. 2011;83(1):87-91. X-2, X-3, X-4, X-6. [pmid: 20570079].
3110 Rankins J, Sampson W, Brown B, et al. Dietary Approaches to Stop Hypertension (DASH) intervention reduces blood pressure among hypertensive African American patients in a neighborhood health care center. J Nutr Educ Behav. Sep-Oct. 2005;37(5):259-64. X-4, X-9. [pmid: 16053815].
3111 Rantanen M, Kallio T, Johansson K, et al. Knowledge expectations of patients on dialysis treatment. Nephrol Nurs J. May-Jun. 2008;35(3):249-55. quiz 56. X-2, X-4, X-6. [pmid: 18649585].
3112 Rasgon S, Schwankovsky L, James-Rogers A, et al. An intervention for employment maintenance among blue-collar workers with end-stage renal disease. Am J Kidney Dis. Sep. 1993;22(3):403-12. X-4, X-6. [pmid: 8372836].
3113 Rask KJ, Ziemer DC, Kohler SA, et al. Patient activation is associated with healthy behaviors and ease in managing diabetes in an indigent population. Diabetes Educ. Jul-Aug. 2009;35(4):622-30. X-2, X-4. [pmid: 19419972].
3114 Rathore SS, Foody JM, Wang Y, et al. Race, quality of care, and outcomes of elderly patients hospitalized with heart failure. JAMA: Journal of the American Medical Association. May. 2003;289(19):2517-24. X-2, X-4. [pmid: 12759323].
3115 Rathore SS, Masoudi FA, Wang Y, et al. Socioeconomic status, treatment, and outcomes among elderly patients hospitalized with heart failure: findings from the National Heart Failure Project. Am Heart J. Aug. 2006;152(2):371-8. X-2, X-4. [pmid: 16875925].
3116 Rauscher GH, Earp JA, O'Malley M. Relation between intervention exposures, changes in attitudes, and mammography use in the North Carolina Breast Cancer Screening Program. Cancer Epidemiol Biomarkers Prev. May. 2004;13(5):741-7. X-2, X-4. [pmid: 15159304].
3117 Rautava P, Erkkola R, Sillanpaa M. The outcome and experiences of first pregnancy in relation to the mother's childbirth knowledge: the Finnish Family Competence Study. J Adv Nurs. Oct. 1991;16(10):1226-32. X-2, X-3, X-4, X-6. [pmid: 1757689].
3118 Rawl SM, Champion VL, Scott LL, et al. A randomized trial of two print interventions to increase colon cancer screening among first-degree relatives. Patient Educ Couns. May. 2008;71(2):215-27. X-6, X-9. [pmid: 18308500].
3119 Rawl SM, Menon U, Champion VL, et al. Do benefits and barriers differ by stage of adoption for colorectal cancer screening?. Health Educ Res. Apr. 2005;20(2):137-48. X-2, X-4, X-6. [pmid: 15314036].
3120 Raz S, Lauterbach MD, Hopkins TL, et al. SEVERITY OF PERINATAL CEREBRAL INJURY AND DEVELOPMENTAL OUTCOME - A DOSE-RESPONSE RELATIONSHIP. Neuropsychology. Jan. 1995;9(1):91-101. X-2, X-4, X-5, X-6.
3121 Reach G. Linguistic barriers in diabetes care. Diabetologia. Aug. 2009;52(8):1461-3. X-1, X-2, X-3, X-4, X-6. [pmid: 19526213].
3122 Reach G, Zerrouki A, Leclercq D, et al. Adjusting insulin doses: from knowledge to decision. Patient Educ Couns. Jan. 2005;56(1):98-103. X-2, X-4, X-6. [pmid: 15590229].
3123 Reaves PY, Weaver R, Gaines F, et al. Culturally-sensitive wellness challenge interventions in predominantly African American adults in the southern region of Florida: an observational study. Internet Journal of Health. 2009;8(2):21. X-4, X-9.
3124 Rector AL, Brandt S, Schneider T. Getting the foot out of the pelvis: modeling problems affecting use of SNOMED CT hierarchies in practical applications. Journal of the American Medical Informatics Association. Jul. 2011;18(4):432-40. X-2, X-3, X-4, X-5, X-6. [pmid: 21515545].
3125 Reddan D, Klassen P, Frankenfield DL, et al. National profile of practice patterns for hemodialysis vascular access in the United States. J Am Soc Nephrol. Aug. 2002;13(8):2117-24. X-2, X-4. [pmid: 12138144].
3126 Redline S, Wright EC, Kattan M, et al. Short-term compliance with peak flow monitoring: results from a study of inner city children with asthma. Pediatr Pulmonol. Apr. 1996;21(4):203-10. X-4, X-9. [pmid: 9121848].
3127 Redman BK. Patient adherence or patient self-management in transplantation: an ethical analysis. Progress in Transplantation. Mar. 2009;19(1):90-4. X-1, X-2, X-4, X-5, X-6. [pmid: 19341069].
3128 Reed SD, Li Y, Oddone EZ, et al. Economic evaluation of home blood pressure monitoring with or without telephonic behavioral self-management in patients with hypertension. Am J Hypertens. Feb. 2010;23(2):142-8. X-2, X-6. [pmid: 19927132].
3129 Rees CA, Karter AJ, Young BA. Race/ethnicity, social support, and associations with diabetes self-care and clinical outcomes in NHANES. Diabetes Educ. May-Jun. 2010;36(3):435-45. X-2, X-4. [pmid: 20332281].
3130 Rees CE, Bath PA. The psychometric properties of the Miller Behavioural Style Scale with adult daughters of women with early breast cancer: a literature review and empirical study. J Adv Nurs. Aug. 2000;32(2):366-74. X-2, X-4, X-6. [pmid: 10964184].
3131 Regestein QR, Friebely J, Shifren J, et al. Neuropsychological effects of methyltestosterone in women using menopausal hormone replacement. Journal of Women's Health & Gender-Based Medicine. 2001;10(7):671-6. X-5, X-6.
3132 Regula J, Kaminski MF. Targeting risk groups for screening. Best Pract Res Clin Gastroenterol. Aug. 2010;24(4):407-16. X-1, X-2, X-3, X-4. [pmid: 20833345].
3133 Rehman US, Boucher EM, Duong D, et al. A context-informed approach to the study of negative-feedback seeking in depression. Behav Res Ther. Feb. 2008;46(2):239-52. X-2, X-4, X-6. [pmid: 18191811].
3134 Reichsman A, Werner J, Cella P, et al. Opportunities for improved diabetes care among patients of safety net practices: a safety net providers' strategic alliance study. J Natl Med Assoc. Jan. 2009;101(1):4-11. X-2, X-4. [pmid: 19245066].
3135 Reid BV. “It's like you're down on a bed of affliction”: aging and diabetes among black Americans. Soc Sci Med. Jun. 1992;34(12):1317-23. X-2, X-4. [pmid: 1529369].
3136 Reid FD, Cook DG, Whincup PH. Use of statins in the secondary prevention of coronary heart disease: is treatment equitable?. Heart. Jul. 2002;88(1):15-9. X-2, X-3, X-4. [pmid: 12067933].
3137 Reid LV, Hatch J, Parrish T. The role of a historically black university and the black church in community-based health initiatives: the project DIRECT experience. J Public Health Manag Pract. Nov. 2003;(Suppl):S70-3. X-1, X-2, X-5. [pmid: 14677334].
3138 Reilly CM, Higgins M, Smith A, et al. Development, psychometric testing, and revision of the Atlanta Heart Failure Knowledge Test. J Cardiovasc Nurs. Nov-Dec. 2009;24(6):500-9. X-2, X-4, X-6. [pmid: 19858959].
3139 Reinschmidt KM, Chong J. SONRISA: a curriculum toolbox for promotores to address mental health and diabetes. Prev Chronic Dis. Oct. 2007;4(4):A101. X-2, X-4. [pmid: 17875245].
3140 Reinschmidt KM, Teufel-Shone NI, Bradford G, et al. Taking a broad approach to public health program adaptation: adapting a family-based diabetes education program. J Prim Prev. Apr. 2010;31(1-2):69-83. X-1, X-2, X-4. [pmid: 20140646].
3141 Reis SE, Holubkov R, Zell KA, et al. Unstable angina: specialty-related disparities in implementation of practice guidelines. Clin Cardiol. Mar. 1998;21(3):207-10. X-2, X-6. [pmid: 9541766].
3142 Reisinger EL, DiIorio C. Individual, seizure-related, and psychosocial predictors of depressive symptoms among people with epilepsy over six months. Epilepsy Behav. Jun. 2009;15(2):196-201. X-2, X-4, X-6. [pmid: 19303457].
3143 Renker PR. “Keep a blank face. I need to tell you what has been happening to me. MCN Am J Matern Child Nurs. Mar-Apr. 2002;27(2):109-16. X-2, X-4, X-6. [pmid: 11984280].
3144 Renner PM. NCQA's evolving clinical performance measures. Manag Care. Sep. 2002;11(9 Suppl):19-22. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12369339].
3145 Renukuntla VS, Hassan K, Wheat S, et al. Disaster preparedness in pediatric type 1 diabetes mellitus. Pediatrics. Nov. 2009;124(5):e973-7. X-2, X-4, X-6. [pmid: 19822589].
3146 Renzi PM, Ghezzo H, Goulet S, et al. Paper stamp checklist tool enhances asthma guidelines knowledge and implementation by primary care physicians. Can Respir J. May-Jun. 2006;13(4):193-7. X-3, X-4, X-6. [pmid: 16779463].
3147 Repke JT, Power ML, Holzman GB, et al. Hypertension in pregnancy and preeclampsia. Knowledge and clinical practice among obstetrician-gynecologists. J Reprod Med. Jun. 2002;47(6):472-6. X-2, X-4, X-6. [pmid: 12092016].
3148 Resnick HE, Shorr RI, Kuller L, et al. Prevalence and clinical implications of American Diabetes Association-defined diabetes and other categories of glucose dysregulation in older adults: the health, aging and body composition study. J Clin Epidemiol. Sep. 2001;54(9):869-76. X-2, X-4. [pmid: 11520645].
3149 Reyes-Rodriguez ML, Sala M, Von Holle A, et al. A Description of Disordered Eating Behaviors in Latino Males. Journal of American College Health. 2011. Jan-Mar. 2011;59(4):266-72. X-2, X-3, X-4, X-5. [pmid: 21308586].
3150 Reynolds HE, Larkin GN, Jackson VP, et al. Fixed-facility workplace screening mammography. AJR Am J Roentgenol. Feb. 1997;168(2):507-10. X-4, X-6. [pmid: 9016236].
3151 Reynolds KD, Gillum JL, Hyman DJ, et al. Comparing two strategies to modify dietary behavior and serum cholesterol. J Cardiovasc Risk. Feb. 1997;4(1):1-5. X-5, X-6. [pmid: 9215513].
3152 Rhee H, Belyea MJ, Elward KS. Patterns of asthma control perception in adolescents: associations with psychosocial functioning. J Asthma. Sep. 2008;45(7):600-6. X-2, X-4, X-6. [pmid: 18773334].
3153 Rhee H, Belyea MJ, Hunt JF, et al. Effects of a peer-led asthma self-management program for adolescents. Arch Pediatr Adolesc Med. Jun. 2011;165(6):513-9. X-6, X-9. [pmid: 21646583].
3154 Rhee MK, Cook CB, El-Kebbi I, et al. Barriers to diabetes education in urban patients: perceptions, patterns, and associated factors. Diabetes Educ. May-Jun. 2005;31(3):410-7. X-2, X-4. [pmid: 15919641].
3155 Rhee MK, Cook CB, El-Kebbi I, et al. Barriers to diabetes education in urban patients - Perceptions, patterns, and associated factors. Diabetes Educator. May-Jun. 2005;31(3):410-7. X-14. [pmid: 15919641].
3156 Rhee MK, Slocum W, Ziemer DC, et al. Patient adherence improves glycemic control. Diabetes Educ. Mar-Apr. 2005;31(2):240-50. X-2, X-4, X-6. [pmid: 15797853].
3157 Rhoades DA, Roubideaux Y, Buchwald D. Diabetes care among older urban American Indians and Alaska Natives. Ethn Dis. Autumn. 2004;14(4):574-9. X-2, X-4. [pmid: 15724778].
3158 Rhoads KF, Ackerson LK, Jha AK, et al. Quality of colon cancer outcomes in hospitals with a high percentage of Medicaid patients. J Am Coll Surg. Aug. 2008;207(2):197-204. X-2, X-4. [pmid: 18656047].
3159 Rhodes P, Nocon A, Booth M, et al. A service users' research advisory group from the perspectives of both service users and researchers. Health Soc Care Community. Sep. 2002;10(5):402-9. X-1, X-2, X-3, X-4, X-6. [pmid: 12390226].
3160 Ribeiro MA, Harrigan RC. The use of Complementary and Alternative Medicine by Asian women of Hawai'i in the treatment of breast cancer. Hawaii Med J. Jul. 2006;65(7):198-205. X-2, X-4. [pmid: 16948400].
3161 Rice DM. Diabetes educators: a disruption to embrace. Diabetes Educ. Sep-Oct. 2007;33(5):747-9. X-1, X-6, X-7, X-9. [pmid: 17925582].
3162 Rice MC, Wicks MN, Martin JC. Health risk characteristics of Black female informal caregivers on welfare. Clin Nurs Res. Feb. 2008;17(1):20-31. X-2, X-4, X-5. [pmid: 18184976].
3163 Rice T, Clark R. Practical ethics. Cancer can't stop Betty. Hosp Health Netw. Mar. 2005;79(3):24. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15835043].
3164 Rich M. Health literacy via media literacy - Video intervention/prevention assessment. American Behavioral Scientist. Oct. 2004;48(2):165-88. X-1, X-2, X-4, X-5, X-6.
3165 Rich MW, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. Nov. 2. 1995;333(18):1190-5. X-6. [pmid: 7565975].
3166 Rich MW, Gray DB, Beckham V, et al. Effect of a multidisciplinary intervention on medication compliance in elderly patients with congestive heart failure. Am J Med. Sep. 1996;101(3):270-6. X-6, X-9. [pmid: 8873488].
3167 Richards CS, Ward PA, Roa BB, et al. Screening for 185delAG in the Ashkenazim. Am J Hum Genet. May. 1997;60(5):1085-98. X-2, X-4. [pmid: 9150156].
3168 Richards M, Sainsbury R, Kerr D. Inequalities in breast cancer care and outcome. Br J Cancer. 1997;76(5):634-8. X-1, X-2, X-3, X-4, X-6. [pmid: 9303363].
3169 Richardson A, Adner N, Nordstrom G. Persons with insulin-dependent diabetes mellitus: acceptance and coping ability. J Adv Nurs. Mar. 2001;33(6):758-63. X-2, X-4, X-6. [pmid: 11298213].
3170 Richardson R, Richards DA, Barkham M. Self-help books for people with depression: the role of the therapeutic relationship. Behav Cogn Psychother. Jan. 2010;38(1):67-81. X-2, X-3, X-4, X-6. [pmid: 19995466].
3171 Ridley J, Baker J, Mills C, et al. Chronic kidney disease: what's in a name?. CANNT J. Apr-Jun. 2009;19(2):19-22. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19606648].
3172 Ridsdale L, Kwan I, Cryer C. The effect of a special nurse on patients' knowledge of epilepsy and their emotional state. Epilepsy Evaluation Care Group Br J Gen Pract. Apr. 1999;49(441):285-9. X-2, X-4, X-5, X-6. [pmid: 10736906].
3173 Ried LD, Johnson RE, Brody KK, et al. Medical care utilization among older HMO members with and without hypertension. J Am Geriatr Soc. Mar. 1995;43(3):222-9. X-2, X-4. [pmid: 7884107].
3174 Riegel B, Carlson B, Glaser D, et al. Standardized telephonic case management in a Hispanic heart failure population - An effective intervention. Disease Management & Health Outcomes. 2002;10(4):241-9. X-4.
3175 Riegel B, Dickson VV. A situation-specific theory of heart failure self-care. Journal of Cardiovascular Nursing. May-Jun. 2008;23(3):190-6. X-1, X-2, X-3, X-4, X-6. [pmid: 18437059].
3176 Riegel B, Moser DK, Powell M, et al. Nonpharmacologic care by heart failure experts. J Card Fail. Mar. 2006;12(2):149-53. X-2, X-4. [pmid: 16520265].
3177 Riekert KA, Borrelli B, Bilderback A, et al. The development of a motivational interviewing intervention to promote medication adherence among inner-city, African-American adolescents with asthma. Patient Educ Couns. Jan. 2011;82(1):117-22. X-4. [pmid: 20371158].
3178 Rigsby BD. Hypertension improvement through healthy lifestyle modifications. ABNF J. Spring. 2011;22(2):41-3. X-4. [pmid: 21675668].
3179 Riley DL, Stewart DE, Grace SL. Continuity of cardiac care: cardiac rehabilitation participation and other correlates. Int J Cardiol. Jul. 31. 2007;119(3):326-33. X-2, X-3, X-6. [pmid: 17258332].
3180 Riley J, Pristave R. Important legal, regulatory issues impacting renal care in 2008. Nephrol News Issues. Dec. 2008;22(13):48-9. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19149317].
3181 Riley J, Pristave R, Kannensohn KJ. New conditions for coverage will impose a host of new requirements on dialysis clinics. Nephrol News Issues. Apr. 2005;19(5):25-6. 8. 30. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15861764].
3182 Rimer BK, Conaway M, Lyna P, et al. The impact of tailored interventions on a community health center population. Patient Educ Couns. Jun. 1999;37(2):125-40. X-9. [pmid: 14528540].
3183 Rimmer JH, Silverman K, Braunschweig C, et al. Feasibility of a health promotion intervention for a group of predominantly African American women with type 2 diabetes. Diabetes Educ. Jul-Aug. 2002;28(4):571-80. X-4. [pmid: 12224197].
3184 Rimpela AH, Savonius B, Rimpela MK, et al. Asthma and allergic rhinitis among Finnish adolescents in 1977-91. Scandinavian Journal of Social Medicine. 1995;23(1):60-5. X-2, X-3, X-4. [pmid: 7784855].
3185 Ringback Weitoft G, Ericsson O, Lofroth E, et al. Equal access to treatment? Population-based follow-up of drugs dispensed to patients after acute myocardial infarction in Sweden. Eur J Clin Pharmacol. Apr. 2008;64(4):417-24. X-2, X-3, X-6. [pmid: 18180914].
3186 Rintala DH, Hart KA, Priebe MM. Pain in persons with spinal cord injury at two points in time: utilization of health care and lifestyle changes. SCI Psychosocial Process. 2004;17(4):221. X-2, X-4, X-5, X-6.
3187 Risser J, Jacobson TA, Kripalani S. Development and psychometric evaluation of the Self-efficacy for Appropriate Medication Use Scale (SEAMS) in low-literacy patients with chronic disease. J Nurs Meas. 2007;15(3):203-19. X-2, X-4. [pmid: 18232619].
3188 Ritter PL, Lee J, Lorig K. Moderators of chronic disease self-management programs: who benefits?. Chronic Illn. Jun. 2011;7(2):162-72. X-7, X-8, X-9. [pmid: 21357642].
3189 Rivera-Vasquez O, Mabiso A, Hammad A, et al. A Community-Based Approach to Translating and Testing Cancer Literacy Assessment Tools. Journal of Cancer Education. 2009;24(4):319-25. X-2, X-4. [pmid: 19838892].
3190 Rizzo M, Bumpers H, Okoli J, et al. Improving on national quality indicators of breast cancer care in a large public hospital as a means to decrease disparities for African American women. Ann Surg Oncol. Jan. 2011;18(1):34-9. X-2, X-4. [pmid: 20625838].
3191 Roach JL, Turenne MN, Hirth RA, et al. Using race as a case-mix adjustment factor in a renal dialysis payment system: potential and pitfalls. Am J Kidney Dis. Nov. 2010;56(5):928-36. X-2, X-4. [pmid: 20888100].
3192 Roaeid RB, Kablan AA. Profile of diabetes health care at Benghazi Diabetes Centre, Libyan Arab Jamahiriya. East Mediterr Health J. Jan-Feb. 2007;13(1):168-76. X-2, X-3, X-4, X-6. [pmid: 17546919].
3193 Robare JF, Bayles CM, Newman AB, et al. The “10 keys” to healthy aging: 24-month follow-up results from an innovative community-based prevention program. Health Educ Behav. Aug. 2011;38(4):379-88. X-6, X-9. [pmid: 21652780].
3194 Robb KA, Miles A, Campbell J, et al. Can cancer risk information raise awareness without increasing anxiety? A randomized trial. Preventive Medicine: An International Journal Devoted to Practice and Theory. Sep. 2006;43(3):187-90. X-3, X-6. [pmid: 16765428].
3195 Robbins EJ, Kinney JM, Kart CS. Promoting active engagement in health research: lessons from an undergraduate gerontology capstone course. Gerontol Geriatr Educ. 2008;29(2):105-23. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19042230].
3196 Robbins JM, Holland P. Passage of policy statement on the high risk of blindness, lower-extremity amputations, and oral health consequences in minority populations due to diabetes. J Am Podiatr Med Assoc. Jun. 2001;91(6):313-5. X-1, X-2, X-3, X-4. [pmid: 11420351].
3197 Robbins JM, Thatcher GE, Webb DA, et al. Nutritionist visits, diabetes classes, and hospitalization rates and charges: the Urban Diabetes Study. Diabetes Care. Apr. 2008;31(4):655-60. X-2, X-4, X-6. [pmid: 18184894].
3198 Robert MP, Marcia LF, Willie JP. A partnership to reduce African American infant mortality in Genesee County, Michigan / Commentary. Public Health Reports. 2003;118(4):324. X-1, X-2, X-4. [pmid: 12815079].
3199 Roberts C. Conditions for coverage: get ready for changes in access management. Nephrol News Issues. Aug. 2008;22(9):26. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 18778000].
3200 Roberts K, Cockerham TR, Waugh WJ. An innovative approach to managing depression: focus on HEDIS standards. J Healthc Qual. Nov-Dec. 2002;24(6):11-7. quiz 7, 64. X-1, X-4, X-6. [pmid: 12432857].
3201 Roberts MM, French K, Duffy J. Breast cancer and breast self-examination: what do Scottish women know?. Soc Sci Med. 1984;18(9):791-7. X-2, X-3, X-4, X-6. [pmid: 6729539].
3202 Roberts MM, Robinson SE, French K, et al. Edinburgh breast education campaign on breast cancer and breast self-examination: was it worth while?. J Epidemiol Community Health. Dec. 1986;40(4):338-43. X-3, X-4, X-6. [pmid: 3655626].
3203 Roberts NJ, Evans G, Blenkhorn P, et al. Development of an electronic pictorial asthma action plan and its use in primary care. Patient Educ Couns. Jul. 2010;80(1):141-6. X-4, X-6, X-9, X-10. [pmid: 19879092].
3204 Roberts NJ, Mohamed Z, Wong PS, et al. The development and comprehensibility of a pictorial asthma action plan. Patient Educ Couns. Jan. 2009;74(1):12-8. X-2, X-3, X-6. [pmid: 18789626].
3205 Robertson-Beckley R. Reducing barriers to reach more women for breast cancer services results of consumer focus groups. ABNF J. Nov-Dec. 2000;11(6):138-40. X-2, X-4. [pmid: 11760285].
3206 Robinson BM, Port FK. International hemodialysis patient outcomes comparisons revisited: the role of practice patterns and other factors. Clin J Am Soc Nephrol. Dec. Suppl 1. 2009;4:S12-7. X-2, X-3. [pmid: 19995994].
3207 Robinson E, Rankin SH, Arnstein P, et al. Meeting the needs of unpartnered elders: a peer training program involving elders with myocardial infarction. Prog Cardiovasc Nurs. Fall. 1998;13(4):13-23. X-1, X-6. [pmid: 10234749].
3208 Robinson JE, Ellis JE. Mistiming of intercourse as a primary cause of failure to conceive: results of a survey on use of a home-use fertility monitor. Curr Med Res Opin. Feb. 2007;23(2):301-6. X-2, X-4, X-5, X-6. [pmid: 17288684].
3209 Robinson JR, Drotar D, Boutry M. Problem-solving abilities among mothers of infants with failure to thrive. Journal of Pediatric Psychology. Jan-Feb. 2001;26(1):21-32. X-2, X-4, X-5, X-6. [pmid: 11145729].
3210 Robinson L, Rempel H. Methamphetamine use and HIV symptom self-management. J Assoc Nurses AIDS Care. Sep-Oct. 2006;17(5):7-14. X-2, X-4, X-5, X-6. [pmid: 16979510].
3211 Robinson LD Jr., Calmes DP, Bazargan M. The impact of literacy enhancement on asthma-related outcomes among underserved children. J Natl Med Assoc. Aug. 2008;100(8):892-6. X-4, X-8, X-9. [pmid: 18717138].
3212 Robinson-Whelen S, Hughes RB, Taylor HB, et al. Depression self-management program for rural women with physical disabilities. Rehabilitation Psychology. Aug. 2007;52(3):254-62. X-2, X-4, X-6.
3213 Roca B, Nadal E, Rovira RE, et al. Usefulness of a hypertension education program. South Med J. Nov. 2003;96(11):1133-7. X-4, X-6. [pmid: 14632363].
3214 Roccella EJ. The good news about hypertension. Stat Bull Metrop Insur Co. Apr-Jun. 1989;70(2):29. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 2727890].
3215 Roccella EJ, Lenfant C. National High Blood Pressure Education Programme using data to focus communications to minority populations. J Hum Hypertens. Jan. 1995;9(1):53-7. X-6, X-7, X-9. [pmid: 7731003].
3216 Rocha-Goldberg M, Corsino L, Batch B, et al. Hypertension Improvement Project (HIP) Latino: results of a pilot study of lifestyle intervention for lowering blood pressure in Latino adults. Ethnicity & Health. 2010;15(3):269-82. X-4. [pmid: 20379894].
3217 Roche RA, Stovall CE, Suarez L, et al. Language differences in interpretation of breast cancer health messages. J Cancer Educ. Winter. 1998;13(4):226-30. X-2, X-4. [pmid: 9883782].
3218 Rodney WM, Prislin MD, Orientale E, et al. Family practice obstetric ultrasound in an urban community health center. Birth outcomes and examination accuracy of the initial 227 cases. J Fam Pract. Feb. 1990;30(2):163-8. X-2, X-4, X-6. [pmid: 2405093].
3219 Rodrigue JR, Cornell DL, Kaplan B, et al. Patients' willingness to talk to others about living kidney donation. Prog Transplant. Mar. 2008;18(1):25-31. X-2, X-4. [pmid: 18429579].
3220 Rodriguez EM, Bowie JV, Frattaroli S, et al. A qualitative exploration of the community partner experience in a faith-based breast cancer educational intervention. Health Educ Res. Oct. 2009;24(5):760-71. X-2, X-4, X-6. [pmid: 19307318].
3221 Rodriguez F, Joynt KE, Lopez L, et al. Readmission rates for Hispanic Medicare beneficiaries with heart failure and acute myocardial infarction. American Heart Journal. Aug. 2011;162(2):254-U73. X-2, X-4. [pmid: 21835285].
3222 Rodriguez HP, Chen J, Rodriguez MA. A national study of problematic care experiences among Latinos with diabetes. J Health Care Poor Underserved. Nov. 2010;21(4):1152-68. X-2. [pmid: 21099068].
3223 Rodriguez KL, Appelt CJ, Switzer GE, et al. “They diagnosed bad heart”: a qualitative exploration of patients' knowledge about and experiences with heart failure. Heart Lung. Jul-Aug. 2008;37(4):257-65. X-2, X-4, X-6. [pmid: 18620101].
3224 Rodriguez-Saldana J, Rosales-Campos AC, Rangel Leon CB, et al. Quality of previous diabetes care among patients receiving services at ophthalmology hospitals in Mexico. Rev Panam Salud Publica. Dec. 2010;28(6):440-5. X-2, X-3, X-4, X-6. [pmid: 21308170].
3225 Roe MT, Chen AY, Riba AL, et al. Impact of congestive heart failure in patients with non-ST-segment elevation acute coronary syndromes. Am J Cardiol. Jun. 15. 2006;97(12):1707-12. X-2, X-6. [pmid: 16765118].
3226 Roetzheim RG, Christman LK, Jacobsen PB, et al. A randomized controlled trial to increase cancer screening among attendees of community health centers. Ann Fam Med. Jul-Aug. 2004;2(4):294-300. X-9. [pmid: 15335126].
3227 Roetzheim RG, Christman LK, Jacobsen PB, et al. Long-term results from a randomized controlled trial to increase cancer screening among attendees of community health centers. Ann Fam Med. Mar-Apr. 2005;3(2):109-14. X-6, X-9. [pmid: 15798035].
3228 Rogers AE, Addington-Hall JM, Abery AJ, et al. Knowledge and communication difficulties for patients with chronic heart failure: qualitative study. BMJ. Sep. 9. 2000;321(7261):605-7. X-2, X-4, X-6. [pmid: 10977838].
3229 Rogers MA, Small D, Buchan DA, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial. Ann Intern Med. Jun. 5. 2001;134(11):1024-32. X-6, X-7. [pmid: 11388815].
3230 Rogulj ZM, Baloevic E, Dogas Z, et al. Family medicine practice and research: survey of physicians' attitudes towards scientific research in a post-communist transition country. Wien Klin Wochenschr. 2007;119(5-6):164-9. X-2, X-3, X-4, X-5, X-6. [pmid: 17427019].
3231 Rohrbaugh MJ, Mehl MR, Shoham V, et al. Prognostic Significance of Spouse We Talk in Couples Coping With Heart Failure. Journal of Consulting and Clinical Psychology. Oct. 2008;76(5):781-9. X-2, X-4. [pmid: 18837595].
3232 Rohrer JE, Anderson GJ, Furst JW. Obesity and pre-hypertension in family medicine: implications for quality improvement. BMC Health Serv Res. 2007;7:212. X-2, X-4, X-6. [pmid: 18154676].
3233 Roizen M, Rodriguez S, Bauer G, et al. Initial validation of the Argentinean Spanish version of the PedsQL (TM) 4.0 Generic Core Scales in children and adolescents with chronic diseases: acceptability and comprehensibility in low-income settings. Health and Quality of Life Outcomes. Aug. 2008:6. X-2, X-3, X-4, X-5. [pmid: 18208616].
3234 Rollman BL, Hanusa BH, Belnap BH, et al. Race, quality of depression care, and recovery from major depression in a primary care setting. General Hospital Psychiatry. Nov-Dec. 2002;24(6):381-90. X-2. [pmid: 12490339].
3235 Roman SH, Chassin MR. Windows of opportunity to improve diabetes care when patients with diabetes are hospitalized for other conditions. Diabetes Care. Aug. 2001;24(8):1371-6. X-6, X-9. [pmid: 11473072].
3236 Romano PS, Zhou H. Do well-publicized risk-adjusted outcomes reports affect hospital volume?. Med Care. Apr. 2004;42(4):367-77. X-6, X-7, X-9. [pmid: 15076814].
3237 Romero AA, Duarte-Gardea M, Ortiz M, et al. Bone mineral density and body mass index of Mexican American women. Hispanic Health Care International. 2005;3(1):9-14. X-2, X-5.
3238 Rong Y, Turnbull F, Patel A, et al. Clinical pathways for acute coronary syndromes in China: protocol for a hospital quality improvement initiative. Crit Pathw Cardiol. Sep. 2010;9(3):134-9. X-1, X-2, X-3, X-4, X-6. [pmid: 20802266].
3239 Rooks RN, Simonsick EM, Klesges LM, et al. Racial disparities in health care access and cardiovascular disease indicators in Black and White older adults in the Health ABC Study. J Aging Health. Sep. 2008;20(6):599-614. X-2, X-4. [pmid: 18625758].
3240 Rosal MC, Benjamin EM, Pekow PS, et al. Opportunities and challenges for diabetes prevention at two community health centers. Diabetes Care. Feb. 2008;31(2):247-54. X-2, X-4, X-6. [pmid: 17989311].
3241 Rosal MC, Carbone ET, Goins KV. Use of cognitive interviewing to adapt measurement instruments for low-literate Hispanics. Diabetes Educ. Nov-Dec. 2003;29(6):1006-17. X-2, X-4. [pmid: 14692374].
3242 Rosal MC, Goins KV, Carbone ET, et al. Views and preferences of low-literate Hispanics regarding diabetes education: results of formative research. Health Educ Behav. Jun. 2004;31(3):388-405. X-2, X-4. [pmid: 15155047].
3243 Rosal MC, Ockene IS, Restrepo A, et al. Randomized trial of a literacy-sensitive, culturally tailored diabetes self-management intervention for low-income latinos: latinos en control. Diabetes Care. Apr. 2011;34(4):838-44. X-9. [pmid: 21378213].
3244 Rosal MC, Olendzki B, Reed GW, et al. Diabetes self-management among low-income Spanish-speaking patients: a pilot study. Ann Behav Med. Jun. 2005;29(3):225-35. X-4. [pmid: 15946117].
3245 Rosal MC, White MJ, Borg A, et al. Translational research at community health centers: challenges and successes in recruiting and retaining low-income Latino patients with type 2 diabetes into a randomized clinical trial. Diabetes Educ. Sep-Oct. 2010;36(5):733-49. X-2, X-7, X-9, X-10. [pmid: 20729512].
3246 Rosal MC, White MJ, Restrepo A, et al. Design and methods for a randomized clinical trial of a diabetes self-management intervention for low-income Latinos: Latinos en Control. BMC Med Res Methodol. 2009;9:81. X-9. [pmid: 20003208].
3247 Rosato R, Sacerdote C, Pagano E, et al. Appropriateness of early breast cancer management in relation to patient and hospital characteristics: a population based study in Northern Italy. Breast Cancer Res Treat. Sep. 2009;117(2):349-56. X-2, X-3, X-4, X-6. [pmid: 19051008].
3248 Rose D, Garwick A. Urban American Indian family caregivers' perceptions of barriers to management of childhood asthma. J Pediatr Nurs. Feb. 2003;18(1):2-11. X-2, X-4. [pmid: 12610782].
3249 Rose DE, Tisnado DM, Malin JL, et al. Use of Interpreters by Physicians Treating Limited English Proficient Women with Breast Cancer: Results from the Provider Survey of the Los Angeles Women's Health Study. Health Services Research. Feb. 2010;45(1):172-94. X-2, X-4. [pmid: 19878346].
3250 Rose G, Gilbert TE, Thame M, et al. Asthma clinic attendance improves quality of life of Jamaican asthmatic children and their parents. Ann Trop Paediatr. Sep. 2009;29(3):203-8. X-2, X-3, X-6. [pmid: 19689862].
3251 Rose M, Fliege H, Hildebrandt M, et al. The network of psychological variables in patients with diabetes and their importance for quality of life and metabolic control. Diabetes Care. Jan. 2002;25(1):35-42. X-2, X-4, X-6. [pmid: 11772898].
3252 Rosen CM, Rodriguez L. The Inner-City Asthma Intervention asthma counselor program: a collaborative model between physician and social worker to help empower families. Ann Allergy Asthma Immunol. Jul. 2006;97(1 Suppl 1):S16-9. X-1, X-2, X-4, X-6. [pmid: 16892766].
3253 Rosenblatt RA, Baldwin LM, Chan L, et al. Improving the quality of outpatient care for older patients with diabetes: Lessons from a comparison of rural and urban communities. The Journal of Family Practice. Aug. 2001;50(8):676-80. X-2, X-4, X-6. [pmid: 11509161].
3254 Rosenfeld L, Rudd R, Emmons KM, et al. Beyond reading alone: the relationship between aural literacy and asthma management. Patient Educ Couns. Jan. 2011;82(1):110-6. X-2, X-4. [pmid: 20399060].
3255 Rosenstein AH. Utilization review. Health economics and cost-effective resource management. Qual Assur Util Rev. Fall. 1991;6(3):85-90. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 1824449].
3256 Rosenzweig M, Brufsky A, Rastogi P, et al. The attitudes, communication, treatment, and support intervention to reduce breast cancer treatment disparity. Oncol Nurs Forum. Jan. 1. 2011;38(1):85-9. X-4. [pmid: 21186164].
3257 Rosenzweig MQ, Wiehagen T, Brufsky A, et al. The unique perspective of illness among women with metastatic breast cancer according to race and income. Journal of Hospice & Palliative Nursing. 2009. Jan-Feb. 2009;11(1):27-40. X-2, X-4.
3258 Rosland AM, Heisler M, Choi HJ, et al. Family influences on self-management among functionally independent adults with diabetes or heart failure: do family members hinder as much as they help?. Chronic Illn. Mar. 2010;6(1):22-33. X-2, X-4. [pmid: 20308348].
3259 Rosland AM, Piette JD, Choi H, et al. Family and friend participation in primary care visits of patients with diabetes or heart failure: patient and physician determinants and experiences. Med Care. Jan. 2011;49(1):37-45. X-2, X-4. [pmid: 21102357].
3260 Rosland A-M, Kieffer E, Israel B, et al. When is social support important? The association of family support and professional support with specific diabetes self-management behaviors. Journal of General Internal Medicine. Dec. 2008;23(12):1992-9. X-2, X-4. [pmid: 18855075].
3261 Ross Barnett J, Pearce J, Howes P. ‘Help, educate, encourage?’: Geographical variations in the provision and utilisation of diabetes education in New Zealand. Soc Sci Med. Sep. 2006;63(5):1328-43. X-2, X-3, X-4, X-6. [pmid: 16704889].
3262 Ross CJ, Williams BA, Low G, et al. Perceptions about self-management among people with severe asthma. J Asthma. Apr. 2010;47(3):330-6. X-2, X-4, X-6. [pmid: 20394519].
3263 Ross LF. Convening a 407 panel for research not otherwise approvable: “Precursors to diabetes in Japanese American youth” as a case study. Kennedy Inst Ethics J. Jun. 2004;14(2):165-86. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15281188].
3264 Rossiter LF, Whitehurst-Cook MY, Small RE, et al. The impact of disease management on outcomes and cost of care: a study of low-income asthma patients. Inquiry. Summer. 2000;37(2):188-202. X-9. [pmid: 10985112].
3265 Rost K, Dickinson LM, Fortney J, et al. Clinical improvement associated with conformance to HEDIS-based depression care. Ment Health Serv Res. Jun. 2005;7(2):103-12. X-2, X-4, X-6. [pmid: 15974156].
3266 Rost K, Fortney J, Coyne J. The relationship of depression treatment quality indicators to employee absenteeism. Ment Health Serv Res. Sep. 2005;7(3):161-9. X-2, X-4, X-6. [pmid: 16194001].
3267 Rost K, Nutting P, Smith J, et al. Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. J Gen Intern Med. Mar. 2001;16(3):143-9. X-6. [pmid: 11318908].
3268 Rost K, Smith JL, Dickinson M. The effect of improving primary care depression management on employee absenteeism and productivity. A randomized trial. Med Care. Dec. 2004;42(12):1202-10. X-6. [pmid: 15550800].
3269 Rosvall M, Ohlsson H, Hansen O, et al. Auditing patient registration in the Swedish quality register for acute coronary syndrome. Scand J Public Health. Jul. 2010;38(5):533-40. X-2, X-3, X-4, X-6. [pmid: 20406796].
3270 Roter DL, Stashefsky-Margalit R, Rudd R. Current perspectives on patient education in the US. Patient Education and Counseling. Jul. 2001;44(1):79-86. X-1, X-2, X-4, X-5, X-6. [pmid: 11390163].
3271 Roth DM, Mbizvo MT. Promoting safe motherhood in the community: the case for strategies that men. Afr J Reprod Health. Aug. 2001;5(2):10-21. X-1, X-2, X-3, X-4, X-6. [pmid: 12471909].
3272 Roth MT, Watson LC, Esserman DA, et al. Methodology of a Pilot Study to Improve the Quality of Medication Use in Older Adults: Enhancing Quality in Psychiatry Using Pharmacists (EQUIPP). American Journal of Geriatric Pharmacotherapy. Dec. 2009;7(6):362-72. X-2, X-5, X-6. [pmid: 20129257].
3273 Roth RS, Horowitz K, Bachman JE. Chronic myofascial pain: knowledge of diagnosis and satisfaction with treatment. Arch Phys Med Rehabil. Aug. 1998;79(8):966-70. X-2, X-4, X-5, X-6. [pmid: 9710171].
3274 Rothman R, Malone R, Bryant B, et al. The relationship between literacy and glycemic control in a diabetes disease-management program. Diabetes Educ. Mar-Apr. 2004;30(2):263-73. X-4, X-9. [pmid: 15095516].
3275 Rothman RL, DeWalt DA, Malone R, et al. Influence of patient literacy on the effectiveness of a primary care-based diabetes disease management program. JAMA. Oct. 13. 2004;292(14):1711-6. X-4. [pmid: 15479936].
3276 Rothman RL, Malone R, Bryant B, et al. A randomized trial of a primary care-based disease management program to improve cardiovascular risk factors and glycated hemoglobin levels in patients with diabetes. Am J Med. Mar. 2005;118(3):276-84. X-6. [pmid: 15745726].
3277 Rothman RL, Malone R, Bryant B, et al. The Spoken Knowledge in Low Literacy in Diabetes scale: a diabetes knowledge scale for vulnerable patients. Diabetes Educ. Mar-Apr. 2005;31(2):215-24. X-2, X-4. [pmid: 15797850].
3278 Rothman RL, Malone R, Bryant B, et al. The spoken knowledge in low literacy in diabetes scale - A diabetes knowledge scale for vulnerable patients. Diabetes Educator. Mar-Apr. 2005;31(2):215-24. X-14. [pmid: 15797850].
3279 Rothman RL, Mulvaney S, Elasy TA, et al. Self-management behaviors, racial disparities, and glycemic control among adolescents with type 2 diabetes. Pediatrics. Apr. 2008;121(4):e912-9. X-2, X-4. [pmid: 18381520].
3280 Roubideaux Y, Buchwald D, Beals J, et al. Measuring the quality of diabetes care for older american indians and alaska natives. Am J Public Health. Jan. 2004;94(1):60-5. X-2, X-4. [pmid: 14713699].
3281 Roubideaux Y, Noonan C, Goldberg JH, et al. Relation between the level of American Indian and Alaska Native diabetes education program services and quality-of-care indicators. Am J Public Health. Nov. 2008;98(11):2079-84. X-2, X-3, X-4. [pmid: 18511737].
3282 Roubidoux MA. Breast cancer detective: A computer game to teach breast cancer screening to Native American patients. Journal of Cancer Education. Spr. 2005;20(1):87-91. X-1, X-2, X-4, X-9, X-10. [pmid: 15916527].
3283 Rowe R. Breast cancer education program targets African American women. Am Nurse. Jul-Aug. 1995;27(5):30. X-1, X-6, X-7, X-9. [pmid: 7653908].
3284 Rowland JH, Meyerowitz BE, Crespi CM, et al. Addressing intimacy and partner communication after breast cancer: a randomized controlled group intervention. Breast Cancer Res Treat. Nov. 2009;118(1):99-111. X-2, X-4, X-6. [pmid: 19390963].
3285 Rowlands IJ, Lee C. ‘The silence was deafening’: social and health service support after miscarriage. Journal of Reproductive & Infant Psychology. 2010;28(3):274-86. X-2, X-3, X-4, X-6.
3286 Roy A, Downes MJ, Wisnivesky JP. Comprehensive environmental management of asthma and pediatric preventive care. Pediatr Allergy Immunol. May. 2011;22(3):277-82. X-6, X-7, X-9. [pmid: 21457334].
3287 Roy T, Lloyd CE. Development of audio methods of data collection in Bangladesh. Diversity in Health & Social Care. 2008;5(3):187-98. X-2, X-3, X-4.
3288 Royak-Schaler R, Blocker DE, Yali AM, et al. Breast and colorectal cancer risk communication approaches with low-income African-American and Hispanic women: implications for healthcare providers. J Natl Med Assoc. May. 2004;96(5):598-608. X-2, X-4. [pmid: 15160974].
3289 Royak-Schaler R, Lemkau JP, Ahmed SM. Discussing breast cancer risk in primary care. J Am Med Womens Assoc. Spring. 2002;57(2):115-6. X-1, X-2, X-3, X-4, X-6. [pmid: 11991420].
3290 Royer M, Castelo-Branco C, Blumel JE, et al. The US National Cholesterol Education Programme Adult Treatment Panel III (NCEP ATP III): prevalence of the metabolic syndrome in postmenopausal Latin American women. Climacteric. Apr. 2007;10(2):164-70. X-2, X-3, X-4, X-6. [pmid: 17453865].
3291 Rozen P, Liphshitz I, Barchana M. The changing epidemiology of colorectal cancer and its relevance for adapting screening guidelines and methods. Eur J Cancer Prev. Jan. 2011;20(1):46-53. X-2, X-3, X-4, X-6. [pmid: 21102339].
3292 Rozen P, Samuel Z, Brazowski E, et al. An audit of familial juvenile polyposis at the Tel Aviv Medical Center: demographic, genetic and clinical features. Fam Cancer. 2003;2(1):1-7. X-2, X-3, X-4, X-5. [pmid: 14574161].
3293 Rubin J, Kirchner K, Ray R, et al. Demographic factors associated with dialysis technique failures among patients undergoing continuous ambulatory peritoneal dialysis. Arch Intern Med. Jun. 1985;145(6):1041-4. X-2, X-4. [pmid: 4004428].
3294 Rucker-Whitaker C, Flynn KJ, Kravitz G, et al. Understanding African-American participation in a behavioral intervention: results from focus groups. Contemp Clin Trials. Jun. 2006;27(3):274-86. X-2, X-4. [pmid: 16427365].
3295 Rudd RE, Zobel EK, Fanta CH, et al. Asthma: in plain language. Health Promot Pract. Jul. 2004;5(3):334-40. X-1, X-7, X-9. [pmid: 15228789].
3296 Ruggiero L, Glasgow R, Dryfoos JM, et al. Diabetes self-management. Self-reported recommendations and patterns in a large population. Diabetes Care. Apr. 1997;20(4):568-76. X-2, X-4. [pmid: 9096982].
3297 Ruggiero L, Moadsiri A, Butler P, et al. Supporting diabetes self-care in underserved populations: a randomized pilot study using medical assistant coaches. Diabetes Educ. Jan-Feb. 2010;36(1):127-31. X-4. [pmid: 20185612].
3298 Rujiwatthanakorn D, Panpakdee O, Malathum P, et al. Effectiveness of a self-management program for Thais with essential hypertension. Pacific Rim International Journal of Nursing Research. 2011;15(2):97-109. X-3, X-4.
3299 Runck B. NIMH to launch major campaign on recognition and treatment of depression. Hosp Community Psychiatry. Aug. 1986;37(8):779-80. 88. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 3015762].
3300 Runions J. A program for psychological and social enhancement during rehabilitation after myocardial infarction. Heart Lung. Mar. 1985;14(2):117-25. X-1, X-6, X-7, X-9. [pmid: 3844391].
3301 Ruppar TM. Randomized pilot study of a behavioral feedback intervention to improve medication adherence in older adults with hypertension. Journal of Cardiovascular Nursing. Nov-Dec. 2010;25(6):470-9. X-4, X-6. [pmid: 20856132].
3302 Russell D. A queer practice. Aust Fam Physician. Jan-Feb. 2004;33(1-2):9-10. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 14988948].
3303 Russell KM, Champion VL, Monahan PO, et al. Randomized trial of a lay health advisor and computer intervention to increase mammography screening in African American women. Cancer Epidemiol Biomarkers Prev. Jan. 2010;19(1):201-10. X-9. [pmid: 20056639].
3304 Ruthven L. Will NCQA/HEDIS take health care to the promised land?. Manag Care Interface. Dec. 2000;13(12):62-3. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11141725].
3305 Ryan AM, Gee GC, Griffith D. The effects of perceived discrimination on diabetes management. Journal of Health Care for the Poor and Underserved. Feb. 2008;19(1):149-63. X-2, X-4. [pmid: 18263991].
3306 Ryan AM, Gee GC, Laflamme DF. The Association between self-reported discrimination, physical health and blood pressure: findings from African Americans, Black immigrants, and Latino immigrants in New Hampshire. J Health Care Poor Underserved. May. 2006;17(2 Suppl):116-32. X-2, X-4. [pmid: 16809879].
3307 Ryan GW, Martinez H, Pelto GH. Methodological issues for eliciting local signs/symptoms/illness terms associated with acute respiratory illnesses. Arch Med Res. Autumn. 1996;27(3):359-65. X-1, X-2, X-4, X-5, X-6. [pmid: 8854396].
3308 Ryan S. Chronic obstructive pulmonary disease: boosting quality of life. Community Nurse. Apr. 2000;6(3):31-2. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12778504].
3309 Rydman RJ, Sonenthal K, Tadimeti L, et al. Evaluating the outcome of two teaching methods of breath actuated inhaler in an inner city asthma clinic. J Med Syst. Oct. 1999;23(5):349-56. X-6, X-7, X-9. [pmid: 10587915].
3310 Rygg LO, Rise MB, Lomundal B, et al. Reasons for participation in group-based type 2 diabetes self-management education. A qualitative study. Scand J Public Health. Dec. 2010;38(8):788-93. X-2, X-3, X-4, X-6. [pmid: 20833706].
3311 Saaddine JB, Cadwell B, Gregg EW, et al. Improvements in diabetes processes of care and intermediate outcomes: United States, 1988-2002. Ann Intern Med. Apr. 4. 2006;144(7):465-74. X-2, X-4. [pmid: 16585660].
3312 Saaddine JB, Engelgau MM, Beckles GL, et al. A diabetes report card for the United States: quality of care in the 1990s. Ann Intern Med. Apr. 16. 2002;136(8):565-74. X-2, X-4. [pmid: 11955024].
3313 Saad-Harfouche FG, Jandorf L, Gage E, et al. Esperanza y Vida: training lay health advisors and cancer survivors to promote breast and cervical cancer screening in Latinas. J Community Health. Apr. 2011;36(2):219-27. X-2, X-4. [pmid: 20711645].
3314 Saad-Harfouche FG, Jandorf L, Gage E, et al. Esperanza y vida: Training lay health advisors and cancer survivors to promote breast and cervical cancer screening in Latinas. Journal of Community Health: The Publication for Health Promotion and Disease Prevention. Apr. 2011;36(2):219-27. X-2, X-4, X-5, X-6. [pmid: 20711645].
3315 Saastad E, Vangen S, Froen JF. Suboptimal care in stillbirths - a retrospective audit study. Acta Obstet Gynecol Scand. 2007;86(4):444-50. X-2, X-3, X-4, X-6. [pmid: 17486466].
3316 Sackoff J, McFarland J, Su S, et al. Prophylaxis for opportunistic infections among HIV-infected patients receiving medical care. J Acquir Immune Defic Syndr Hum Retrovirol. Dec. 1. 1998;19(4):387-92. X-6, X-7, X-9. [pmid: 9833748].
3317 Sacksteder P, Schatell D. The Renaissance in renal rehabilitation: 2001. Part II Nephrol News Issues. Oct. 2001;15(11):61-8. X-1, X-2, X-4, X-5, X-6. [pmid: 12098985].
3318 Sadler GR, Dong HS, Ko CM, et al. Vietnamese American women: breast cancer knowledge, attitudes, and screening adherence. Am J Health Promot. Mar-Apr. 2001;15(4):211-4. ii. X-2, X-4. [pmid: 11349339].
3319 Sadler GR, Gonzalez J, Mumman M, et al. Adapting a program to inform African American and Hispanic American women about cancer clinical trials. J Cancer Educ. Jun. 2010;25(2):142-5. X-7, X-9. [pmid: 20146043].
3320 Sadler GR, Hung J, Beerman PR, et al. Then and now: comparison of baseline breast cancer screening rates at 2 time intervals. J Cancer Educ. 2009;24(1):4-9. X-2, X-4. [pmid: 19259858].
3321 Sadler GR, Ryujin LT, Ko CM, et al. Korean women: breast cancer knowledge, attitudes and behaviors. BMC Public Health. 2001;1:7. X-2, X-4. [pmid: 11553321].
3322 Sadler GR, Thomas AG, Yen JY, et al. Breast cancer education program based in Asian grocery stores. J Cancer Educ. Fall. 2000;15(3):173-7. X-6, X-7, X-9. [pmid: 11019767].
3323 Sadler GR, Wang K, Wang M, et al. Chinese women: behaviors and attitudes toward breast cancer education and screening. Womens Health Issues. Jan-Feb. 2000;10(1):20-6. X-2, X-3, X-4. [pmid: 10697465].
3324 Sadler GR, York C, Madlensky L, et al. Health parties for African American study recruitment. J Cancer Educ. Summer. 2006;21(2):71-6. X-5, X-7, X-8, X-9, X-10. [pmid: 17020516].
3325 Sahip Y, Turan JM. Education for expectant fathers in workplaces in Turkey. J Biosoc Sci. Nov. 2007;39(6):843-60. X-3, X-5. [pmid: 17537276].
3326 Sailly JC, Lenne X, Bercez C, et al. Costs of hospitalization for severe acute asthma of patients not treated according to guidelines and recommendations. French prospective study of 169 cases. Eur J Health Econ. Jun. 2005;6(2):94-101. X-2, X-3, X-4, X-6. [pmid: 15761774].
3327 Sakagami T, Okumiya K, Ishine M, et al. Comprehensive geriatric assessment for community-dwelling elderly in Asia compared with those in Japan: II. Hongchon in Korea. Geriatrics & Gerontology International. 2005;5(2):107-14. X-2, X-3, X-4, X-5.
3328 Sakraida TJ, Robinson MV. Health literacy self-management by patients with type 2 diabetes and stage 3 chronic kidney disease. West J Nurs Res. Aug. 2009;31(5):627-47. X-2, X-4. [pmid: 19390053].
3329 Salas Zapata C, Grisales Romero H. Calidad de vida y factores asociados en mujeres con cancer de mama en Antioquia, Colombia. Revista Panamericana de Salud Publica. 2010;28(1):9-18. X-2, X-3, X-4, X-6. [pmid: 20857015].
3330 Saleh SS, Phillips KT, Schootman M, et al. Evaluation of Medicaid status, race, and urbanicity as risk factors for asthma hospitalization. Texas Journal of Rural Health. 2001;19(1):49-56. X-2, X-4.
3331 Salomone M, Canavese C, Bergamo D, et al. Guidelines audit may overcome disparities in health care: experience of an Italian region. J Nephrol. May-Jun. 2006;19(3):296-302. X-3. [pmid: 16874688].
3332 Salonen JT, Hamynen H, Heinonen OP. Impact of a health education program and other factors on stopping smoking after heart attack. Scand J Soc Med. 1985;13(3):103-8. X-3. [pmid: 4023664].
3333 Salt A, Redshaw M. Neurodevelopmental follow-up after preterm birth: follow up after two years. Early Hum Dev. Mar. 2006;82(3):185-97. X-2, X-4, X-5. [pmid: 16530991].
3334 Salto LM, Cordero-MacIntyre Z, Beeson L, et al. En Balance participants decrease dietary fat and cholesterol intake as part of a culturally sensitive Hispanic diabetes education program. Diabetes Educ. Mar-Apr. 2011;37(2):239-53. X-4. [pmid: 21343598].
3335 Salvalaggio G, Kelly L, Minore B. Perspectives on health: experiences of First Nations dialysis patients relocated from remote communities for treatment. Canadian Journal of Rural Medicine. 2003. Winter. 2003;8(1):19-24. X-2, X-3, X-4.
3336 Samal D, Greisenegger S, Auff E, et al. The relation between knowledge about hypertension and education in hospitalized patients with stroke in Vienna. Stroke. Apr. 2007;38(4):1304-8. X-2, X-3, X-4, X-6. [pmid: 17322074].
3337 Samir A, Nour W. Self-management among Egyptian heart failure patients. Int J Nurs Pract. Jun. 2011;17(3):221-30. X-2, X-4. [pmid: 21605261].
3338 Samuel-Hodge CD, DeVellis RF, Ammerman A, et al. Reliability and validity of a measure of perceived diabetes and dietary competence in African American women with type 2 diabetes. Diabetes Educ. Nov-Dec. 2002;28(6):979-88. X-2, X-4. [pmid: 12526638].
3339 Samuel-Hodge CD, Headen SW, Skelly AH, et al. Influences on day-to-day self-management of type 2 diabetes among African-American women: spirituality, the multicaregiver role, and other social context factors. Diabetes Care. Jul. 2000;23(7):928-33. X-2, X-4. [pmid: 10895842].
3340 Samuel-Hodge CD, Keyserling TC, France R, et al. A church-based diabetes self-management education program for African Americans with type 2 diabetes. Prev Chronic Dis. Jul. 2006;3(3):A93. X-7, X-9. [pmid: 16776894].
3341 Samuel-Hodge CD, Keyserling TC, Park S, et al. A randomized trial of a church-based diabetes self-management program for African Americans with type 2 diabetes. Diabetes Educ. May-Jun. 2009;35(3):439-54. X-9. [pmid: 19383882].
3342 Samuel-Hodge CD, Skelly AH, Headen S, et al. Familial roles of older African-American women with type 2 diabetes: testing of a new multiple caregiving measure. Ethn Dis. Summer. 2005;15(3):436-43. X-2, X-4. [pmid: 16108304].
3343 Samuel-Hodge CD, Watkins DC, Rowell KL, et al. Coping styles, well-being, and self-care behaviors among African Americans with type 2 diabetes. Diabetes Educ. May-Jun. 2008;34(3):501-10. X-2, X-4. [pmid: 18535323].
3344 Samuels-Dennis J. Employment status, depressive symptoms, and the mediating/moderating effects of single mothers' coping repertoire. Public Health Nurs. Nov-Dec. 2007;24(6):491-502. X-2, X-4, X-5. [pmid: 17973726].
3345 Sanchez CD, Newby LK, McGuire DK, et al. Diabetes-related knowledge, atherosclerotic risk factor control, and outcomes in acute coronary syndromes. Am J Cardiol. Jun. 1. 2005;95(11):1290-4. X-2, X-4, X-6. [pmid: 15904631].
3346 Sanchez I. Implementation of a diabetes self-management education program in primary care for adults using shared medical appointments. The Diabetes Educator. May-Jun. 2011;37(3):381-91. X-6, X-9. [pmid: 21454887].
3347 Sanchez-Martinez M, Otero A. Factors associated with cell phone use in adolescents in the community of Madrid (Spain). Cyberpsychol Behav. Apr. 2009;12(2):131-7. X-2, X-3, X-4, X-5, X-6. [pmid: 19072078].
3348 Sanders KM, Satyvavolu A. Improving blood pressure control in diabetes: limitations of a clinical reminder in influencing physician behavior. J Contin Educ Health Prof. Winter. 2002;22(1):23-32. X-6. [pmid: 12004637].
3349 Sanders T, Harrison S. Professional legitimacy claims in the multidisciplinary workplace: the case of heart failure care. Sociol Health Illn. Mar. 2008;30(2):289-308. X-2, X-3, X-4. [pmid: 18290937].
3350 Sanders Thompson VL, Cavazos-Rehg PA, Jupka K, et al. Evidential preferences: cultural appropriateness strategies in health communications. Health Educ Res. Jun. 2008;23(3):549-59. X-2, X-4. [pmid: 17631608].
3351 Santati S, Ratinhorn A, Christian B. Parents' experiences in asthma attack prevention: struggling to take control. Thai Journal of Nursing Research. 2003;7(3):186-98. X-2, X-4, X-6.
3352 Santati S, Wittaya-sooporn J, Hanucharurnkul S, et al. Asthma management abilities causal model: an empirical test among parent caregivers of the pre-school asthmatic children. Thai Journal of Nursing Research. 2006;10(2):98-112. X-2, X-3, X-4, X-6.
3353 Santos PR. Correlation between coping style and quality of life among hemodialysis patients from a low-income area in Brazil. Hemodial Int. Jul. 2010;14(3):316-21. X-2, X-3, X-4. [pmid: 20491971].
3354 Santoyo-Olsson J, Cabrera J, Freyre R, et al. An innovative multiphased strategy to recruit underserved adults into a randomized trial of a community-based diabetes risk reduction program. Gerontologist. Jun. Suppl 1. 2011;51:S82-93. X-9. [pmid: 21565823].
3355 Saounatsou M. Relation between response to illness and compliance in haemodialysis patients. EDTNA ERCA J. Oct-Dec. 1999;25(4):32-4. X-6, X-7, X-9. [pmid: 10827597].
3356 Sarfaty M, Feng S. Choice of screening modality in a colorectal cancer education and screening program for the uninsured. J Cancer Educ. Spring. 2006;21(1):43-9. X-7, X-9. [pmid: 16918290].
3357 Sarkadi A, Rosenqvist U. Social network and role demands in women's Type 2 diabetes: A model. Health Care for Women International. Sep-Nov. 2002;23(6-7):600-11. X-2, X-4, X-6. [pmid: 12418982].
3358 Sarkar U, Fisher L, Schillinger D. Is self-efficacy associated with diabetes self-management across race/ethnicity and health literacy?. Diabetes Care. Apr. 2006;29(4):823-9. X-2, X-4. [pmid: 16567822].
3359 Sarkar U, Karter AJ, Liu JY, et al. The literacy divide: health literacy and the use of an internet-based patient portal in an integrated health system-results from the diabetes study of northern California (DISTANCE). J Health Commun. Suppl 2. 2010;15:183-96. X-14. [pmid: 20845203].
3360 Sarkar U, Karter AJ, Liu JY, et al. The Literacy Divide: Health Literacy and the Use of an Internet-Based Patient Portal in an Integrated Health SystemResults from the Diabetes Study of Northern California (DISTANCE). Journal of Health Communication. 2010;15:183-96. X-6, X-7, X-9. [pmid: 20845203].
3361 Sarkar U, Karter AJ, Liu JY, et al. Hypoglycemia is more common among type 2 diabetes patients with limited health literacy: the Diabetes Study of Northern California (DISTANCE). J Gen Intern Med. Sep. 2010;25(9):962-8. X-2, X-4. [pmid: 20480249].
3362 Sarkar U, Piette JD, Gonzales R, et al. Preferences for self-management support: findings from a survey of diabetes patients in safety-net health systems. Patient Educ Couns. Jan. 2008;70(1):102-10. X-2, X-4. [pmid: 17997264].
3363 Sarkar U, Schillinger D, Lopez A, et al. Validation of Self-Reported Health Literacy Questions Among Diverse English and Spanish-Speaking Populations. Journal of General Internal Medicine. Mar. 2011;26(3):265-71. X-2, X-4, X-5. [pmid: 21057882].
3364 Sarkisian CA, Brusuelas RJ, Steers WN, et al. For the patient. Managing diabetes with cultural sensitivity and self-empowerment. Ethn Dis. Spring. 2005;15(2):351. X-1, X-6, X-7, X-9. [pmid: 15825982].
3365 Sarkisian CA, Brusuelas RJ, Steers WN, et al. Using focus groups of older African Americans and Latinos with diabetes to modify a self-care empowerment intervention. Ethn Dis. Spring. 2005;15(2):283-91. X-2, X-4. [pmid: 15825975].
3366 Sarrell EM, Mandelberg A, Cohen HA, et al. Compliance of primary care doctors with asthma guidelines and related education programs: the employment factor. Isr Med Assoc J. Jun. 2002;4(6):403-6. X-2, X-3, X-4, X-6. [pmid: 12073408].
3367 Satish S, Markides KS, Zhang D, et al. Factors influencing unawareness of hypertension among older Mexican Americans. Prev Med. Sep-Oct. 1997;26(5 Pt 1):645-50. X-2, X-4. [pmid: 9327472].
3368 Saunders LD, Irwig LM, Gear JS, et al. A randomized controlled trial of compliance improving strategies in Soweto hypertensives. Med Care. Jul. 1991;29(7):669-78. X-9. [pmid: 2072772].
3369 Savic G, Charlifue S, Glass C, et al. British Ageing with SCI Study: changes in physical and psychosocial outcomes over time. Topics in Spinal Cord Injury Rehabilitation. 2010. Winter. 2010;15(3):41-53. X-2, X-3, X-4, X-5, X-6.
3370 Saville SK, Wetta-Hall R, Hawley SR, et al. An assessment of a pilot asthma education program for childcare workers in a high-prevalence county. Respir Care. Dec. 2008;53(12):1691-6. X-6, X-7, X-9. [pmid: 19025704].
3371 Savoca MR, Miller CK, Ludwig DA. Food habits are related to glycemic control among people with type 2 diabetes mellitus. J Am Diet Assoc. Apr. 2004;104(4):560-6. X-2, X-4. [pmid: 15054341].
3372 Savoca MR, Miller CK, Quandt SA. Profiles of people with type 2 diabetes mellitus: the extremes of glycemic control. Soc Sci Med. Jun. 2004;58(12):2655-66. X-2, X-4. [pmid: 15081213].
3373 Sawyer RG, Pinciaro PJ, Anderson-Sawyer A. Pregnancy testing and counseling: a university health center's 5-year experience. J Am Coll Health. Mar. 1998;46(5):221-5. X-2, X-4, X-6. [pmid: 9558821].
3374 Sawyer SM, Farrant B, Cerritelli B, et al. A survey of sexual and reproductive health in men with cystic fibrosis: new challenges for adolescent and adult services. Thorax. Apr. 2005;60(4):326-30. X-2, X-4, X-6. [pmid: 15790989].
3375 Sawyer SM, Phelan PD, Bowes G. Reproductive health in young women with cystic fibrosis: knowledge, behavior and attitudes. J Adolesc Health. Jul. 1995;17(1):46-50. X-2, X-3, X-4. [pmid: 7578163].
3376 Sawyer SM, Tully MA, Colin AA. Reproductive and sexual health in males with cystic fibrosis: a case for health professional education and training. J Adolesc Health. Jan. 2001;28(1):36-40. X-2, X-4. [pmid: 11137904].
3377 Saxena S, Car J, Eldred D, et al. Practice size, caseload, deprivation and quality of care of patients with coronary heart disease, hypertension and stroke in primary care: national cross-sectional study. BMC Health Serv Res. 2007;7:96. X-2, X-3, X-4. [pmid: 17597518].
3378 Scala M. Medicare preventive services. Issue Brief Cent Medicare Educ. 2001;2(5):1-8. X-1, X-2, X-4, X-6. [pmid: 11859898].
3379 Scanlon K, Wood A. Breast cancer awareness in Britain: are there differences based on ethnicity?. Diversity in Health & Social Care. 2005;2(3):211-21. X-2, X-3, X-4.
3380 Scaramuzza A, De Palma A, Mameli C, et al. Adolescents with type 1 diabetes and risky behaviour. Acta Paediatr. Aug. 2010;99(8):1237-41. X-2, X-3, X-4. [pmid: 20377535].
3381 3382. Scarfone RJ, Zorc JJ, Capraro GA. Patient self-management of acute asthma: adherence to national guidelines a decade later. Pediatrics. Dec. 2001;108(6):1332-8. X-2, X-4, X-6. [pmid: 11731656].
3382 Schatell D, Wise M, Klicko K, et al. In-center hemodialysis patients' use of the internet in the United States: a national survey. Am J Kidney Dis. Aug. 2006;48(2):285-91. X-2, X-4, X-6. [pmid: 16860195].
3383 Schatz M, Gibbons C, Nelle C, et al. Impact of a care manager on the outcomes of higher risk asthmatic patients: a randomized controlled trial. J Asthma. Apr. 2006;43(3):225-9. X-6, X-9. [pmid: 16754526].
3384 Schechter MS. Non-genetic influences on CF lung disease: the role of sociodemographic characteristics, environmental exposures and healthcare interventions. Pediatr Pulmonol Suppl. 2004;26:82-5. X-1, X-6, X-7, X-9. [pmid: 15029607].
3385 Schechter MS, McColley SA, Silva S, et al. Association of socioeconomic status with the use of chronic therapies and healthcare utilization in children with cystic fibrosis. J Pediatr. Nov. 2009;155(5):634-9. e1. 4. X-2, X-4. [pmid: 19608199].
3386 Schectman JM, Nadkarni MM, Voss JD. The association between diabetes metabolic control and drug adherence in an indigent population. Diabetes Care. Jun. 2002;25(6):1015-21. X-2. [pmid: 12032108].
3387 Schectman JM, Schorling JB, Voss JD. Appointment adherence and disparities in outcomes among patients with diabetes. J Gen Intern Med. Oct. 2008;23(10):1685-7. X-2, X-4. [pmid: 18661189].
3388 Schenker Y, Stewart A, Na B, et al. Depressive Symptoms and Perceived Doctor-Patient Communication in the Heart and Soul Study. Journal of General Internal Medicine. May. 2009;24(5):550-6. X-2, X-4. [pmid: 19274477].
3389 Schensul JJ, Radda K, Coman E, et al. Multi-level intervention to prevent influenza infections in older low income and minority adults. American Journal of Community Psychology. Jun. 2009;43(3-4):313-29. X-5. [pmid: 19387822].
3390 Schensul JJ, Robison J, Reyes C, et al. Building interdisciplinary/intersectoral research partnerships for community-based mental health research with older minority adults. Am J Community Psychol. Sep. 2006;38(1-2):79-93. X-1, X-6, X-7, X-9. [pmid: 16909316].
3391 Schiel R, Bocklitz G, Braun A, et al. Cognitive function and quality of diabetes care in patients with Type-2-diabetes mellitus in general practitioner practice. Eur J Med Res. Sep. 29. 2003;8(9):419-27. X-2, X-3, X-4. [pmid: 14555298].
3392 Schiel R, Muller UA. Intensive or conventional insulin therapy in type 2 diabetic patients? A population-based study on metabolic control and quality of life (The JEVIN-trial). Exp Clin Endocrinol Diabetes. 1999;107(8):506-11. X-3, X-4. [pmid: 10612481].
3393 Schifano P, Scarinci M, Borgia P, et al. Analysis of the recourse to conservative surgery in the treatment of breast tumors. Tumori. Mar-Apr. 2002;88(2):131-6. X-3, X-6, X-7, X-9. [pmid: 12088253].
3394 Schillinger D, Barton LR, Karter AJ, et al. Does literacy mediate the relationship between education and health outcomes? A study of a low-income population with diabetes. Public Health Reports. May-Jun. 2006;121(3):245-54. X-6, X-7, X-9. [pmid: 16640146].
3395 Schillinger D, Bindman A, Wang F, et al. Functional health literacy and the quality of physician-patient communication among diabetes patients. Patient Educ Couns. Mar. 2004;52(3):315-23. X-2, X-4. [pmid: 14998602].
3396 Schillinger D, Grumbach K, Piette J, et al. Association of health literacy with diabetes outcomes. JAMA. Jul. 24-31. 2002;288(4):475-82. X-2, X-4. [pmid: 12132978].
3397 Schillinger D, Hammer H, Wang F, et al. Seeing in 3-D: examining the reach of diabetes self-management support strategies in a public health care system. Health Educ Behav. Oct. 2008;35(5):664-82. X-4, X-9. [pmid: 17513690].
3398 Schillinger D, Handley M, Wang F, et al. Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial. Diabetes Care. Apr. 2009;32(4):559-66. X-9. [pmid: 19131469].
3399 Schillinger D, Piette J, Grumbach K, et al. Closing the loop: physician communication with diabetic patients who have low health literacy. Arch Intern Med. Jan. 13. 2003;163(1):83-90. X-6, X-7, X-9. [pmid: 12523921].
3400 Schirmer J. High-risk diabetic pregnancy and work: two hard-to-reconcile circumstances. Revista Panamericana de Salud Pública. 1997;2(6):408-14. X-2, X-3, X-4, X-6.
3401 Schlichting JA, Quinn MT, Heuer LJ, et al. Provider perceptions of limited health literacy in community health centers. Patient Education and Counseling. Dec. 2007;69(1-3):114-20. X-2, X-4, X-5. [pmid: 17889494].
3402 Schlundt DG, Franklin MD, Patel K, et al. Religious affiliation, health behaviors and outcomes: Nashville REACH 2010. Am J Health Behav. Nov-Dec. 2008;32(6):714-24. X-2, X-4, X-5, X-6. [pmid: 18442350].
3403 Schlundt DG, Greene C, Reid R, et al. An evaluation of the Nashville REACH 2010 community health screening strategy. J Ambul Care Manage. Apr-Jun. 2006;29(2):151-61. X-6, X-7, X-9. [pmid: 16552324].
3404 Schlundt DG, Mushi C, Larson CO, et al. Use of innovative technologies in the evaluation of Nashville's REACH 2010 community action plan: reducing disparities in cardiovascular disease and diabetes in the African American community. J Ambul Care Manage. Jul. 2001;24(3):51-60. X-1, X-6, X-7, X-9. [pmid: 11433556].
3405 Schlundt DG, Niebler S, Brown A, et al. Disparities in smoking: data from the Nashville REACH 2010 project. J Ambul Care Manage. Apr-Jun. 2007;30(2):150-8. X-2, X-4. [pmid: 17495684].
3406 Schmitt J, Balser M, Reif W. Verification of medical guidelines in KI V. Stud Health Technol Inform. 2008;139:253-62. X-2, X-3, X-4, X-6. [pmid: 18806334].
3407 Schmitt MR, Miller MJ, Harrison DL, et al. Communicating non-steroidal anti-inflammatory drug risks: Verbal counseling, written medicine information, and patients' risk awareness. Patient Education and Counseling. Jun. 2011;83(3):391-7. X-2, X-4, X-5. [pmid: 21129892].
3408 Schnall R, Currie LM, Jia H, et al. Effect of nurse reminder on depression screening rates in racial/ethnic minorities. AMIA Annu Symp Proc. 2008:1125. X-7, X-9. [pmid: 18998860].
3409 Schnall R, Currie LM, Jia H, et al. Predictors of depression screening rates of nurses receiving a personal digital assistant-based reminder to screen. J Urban Health. Jul. 2010;87(4):703-12. X-6, X-9, X-11. [pmid: 20549570].
3410 Schneider B, Martin S, Heinemann L, et al. Interrelations between diabetes therapy, self-monitoring of blood glucose, blood glucose and non-fatal or fatal endpoints in patients with type 2 diabetes / results of a longitudinal cohort study (ROSSO 5). Arzneimittelforschung. 2007;57(12):762-9. X-2, X-3, X-4, X-6. [pmid: 18380408].
3411 Schneider EC, Cleary PD, Zaslavsky AM, et al. Racial disparity in influenza vaccination: does managed care narrow the gap between African Americans and whites?. JAMA. Sep. 26. 2001;286(12):1455-60. X-2, X-5. [pmid: 11572737].
3412 Schneider EC, Zaslavsky AM, Epstein AM. Racial disparities in the quality of care for enrollees in medicare managed care. JAMA. Mar. 13. 2002;287(10):1288-94. X-2, X-4. [pmid: 11886320].
3413 Schneider RH, Alexander CN, Staggers F, et al. A randomized controlled trial of stress reduction in African Americans treated for hypertension for over one year. Am J Hypertens. Jan. 2005;18(1):88-98. X-6, X-7, X-9. [pmid: 15691622].
3414 Schneider RH, Staggers F, Alxander CN, et al. A randomised controlled trial of stress reduction for hypertension in older African Americans. Hypertension. Nov. 1995;26(5):820-7. X-7, X-9. [pmid: 7591024].
3415 Schneider TR, Salovey P, Apanovitch AM, et al. The effects of message framing and ethnic targeting on mammography use among low-income women. Health Psychol. Jul. 2001;20(4):256-66. X-7, X-9. [pmid: 11515737].
3416 Schnipper JL, Roumie CL, Cawthon C, et al. Rationale and design of the Pharmacist Intervention for Low Literacy in Cardiovascular Disease (PILL-CVD) study. Circ Cardiovasc Qual Outcomes. Mar. 2010;3(2):212-9. X-1, X-6, X-9. [pmid: 20233982].
3417 Schoenbaum M, Kelleher K, Lave JR, et al. Exploratory evidence on the market for effective depression care in Pittsburgh. Psychiatr Serv. Apr. 2004;55(4):392-5. X-2, X-4, X-6. [pmid: 15067150].
3418 Schoenbaum M, Unutzer J, McCaffrey D, et al. The effects of primary care depression treatment on patients' clinical status and employment. Health Serv Res. Oct. 2002;37(5):1145-58. X-6, X-9. [pmid: 12479490].
3419 Schoenbaum M, Unutzer J, Sherbourne C, et al. Cost-effectiveness of practice-initiated quality improvement for depression: results of a randomized controlled trial. JAMA. Sep. 19. 2001;286(11):1325-30. X-6, X-9. [pmid: 11560537].
3420 Schoenberg NE, Amey CH, Coward RT. Diabetes knowledge and sources of information among African American and white older women. Diabetes Educ. May-Jun. 1998;24(3):319-24. X-2, X-4. [pmid: 9677949].
3421 Schoenberg NE, Bardach SH, Manchikanti KN, et al. Appalachian residents' experiences with and management of multiple morbidity. Qual Health Res. May. 2011;21(5):601-11. X-2, X-4. [pmid: 21263063].
3422 Schoenberg NE, Drew EM, Stoller EP, et al. Situating stress: lessons from lay discourses on diabetes. Med Anthropol Q. Jun. 2005;19(2):171-93. X-2, X-4. [pmid: 15974326].
3423 Schoenberg NE, Drungle SC. Barriers to non-insulin dependent diabetes mellitus (NIDDM) self-care practices among older women. J Aging Health. Nov. 2001;13(4):443-66. X-2, X-4. [pmid: 11813736].
3424 Schoenberg NE, Stoller EP, Kart CS, et al. Complementary and alternative medicine use among a multiethnic sample of older adults with diabetes. J Altern Complement Med. Dec. 2004;10(6):1061-6. X-2, X-4. [pmid: 15674002].
3425 Schoenberg NE, Traywick LS, Jacobs-Lawson J, et al. Diabetes self-care among a multiethnic sample of older adults. J Cross Cult Gerontol. Dec. 2008;23(4):361-76. X-2, X-4. [pmid: 18369715].
3426 Schokker MC, Keers JC, Bouma J, et al. The impact of social comparison information on motivation in patients with diabetes as a function of regulatory focus and self-efficacy. Health Psychol. Jul. 2010;29(4):438-45. X-6, X-7, X-9. [pmid: 20658832].
3427 Schokker MC, Links TP, Bouma J, et al. The role of overprotection by the partner in coping with diabetes: A moderated mediation model. Psychology & Health. Jan. 2011;26(1):95-111. X-2, X-4. [pmid: 20204978].
3428 Schonlau M, Mangione-Smith R, Chan KS, et al. Evaluation of a quality improvement collaborative in asthma care: does it improve processes and outcomes of care?. Ann Fam Med. May-Jun. 2005;3(3):200-8. X-6. [pmid: 15928222].
3429 Schootman M, Myers-Geadelmann J, Fuortes L. Factors associated with adequacy of diagnostic workup after abnormal breast cancer screening results. J Am Board Fam Pract. Mar-Apr. 2000;13(2):94-100. X-2, X-4, X-6. [pmid: 10764189].
3430 Schraer CD, Mayer AM, Vogt AM, et al. The Alaska Native diabetes program. Int J Circumpolar Health. Nov. 2001;60(4):487-94. X-2, X-4. [pmid: 11768423].
3431 Schrag SJ, Arnold KE, Mohle-Boetani JC, et al. Prenatal screening for infectious diseases and opportunities for prevention. Obstet Gynecol. Oct. 2003;102(4):753-60. X-2, X-4. [pmid: 14551005].
3432 Schreiner DT, Petrusa ER, Rettie CS, et al. Improving compliance with preventive medicine procedures in a house staff training program. South Med J. Dec. 1988;81(12):1553-7. X-6. [pmid: 3201302].
3433 Schultz J, Joish V. Costs associated with changes in antidepressant treatment in a managed care population with major depressive disorder. Psychiatr Serv. Dec. 2009;60(12):1604-11. X-2, X-4. [pmid: 19952150].
3434 Schultz N, Farrell P. Enhancing power and educating: urban aboriginal family caregivers' perspectives of caring for a child who has chronic renal failure. CANNT Journal. 1998;8(3):18-24. X-3, X-4, X-6, X-7, X-9. [pmid: 9807322].
3435 Schwartz MD, Benkendorf J, Lerman C, et al. Impact of educational print materials on knowledge, attitudes, and interest in BRCA1/BRCA2: testing among Ashkenazi Jewish women. Cancer. Aug. 15. 2001;92(4):932-40. X-6, X-7, X-9. [pmid: 11550168].
3436 Schwartz MD, Rimer BK, Daly M, et al. A randomized trial of breast cancer risk counseling: the impact on self-reported mammography use. Am J Public Health. Jun. 1999;89(6):924-6. X-6, X-7, X-9. [pmid: 10358689].
3437 Schwartzberg JG, Cowett A, VanGeest J, et al. Communication techniques for patients with low health literacy: A survey of physicians, nurses, and pharmacists. American Journal of Health Behavior. Special Issue: Health literacy. Sep-Oct. 2007;31(Suppl1):S96-S104. X-2, X-4, X-5. [pmid: 17931143].
3438 Scisney-Matlock M, Glazewki L, McClerking C, et al. Development and evaluation of DASH diet tailored messages for hypertension treatment. Appl Nurs Res. May. 2006;19(2):78-87. X-4. [pmid: 16728291].
3439 Scisney-Matlock M, Grand A, Steigerwalt SP, et al. Reliability and reproducibility of clinic and home blood pressure measurements in hypertensive women according to age and ethnicity. Blood Press Monit. Apr. 2009;14(2):49-57. X-2, X-4. [pmid: 19305185].
3440 Scisney-Matlock M, Watkins K. Examination of factor structure of the cognitive representations of hypertension scale for ethnic equivalence. Ethn Dis. Winter. 1999;9(1):33-47. X-2, X-4, X-6. [pmid: 10355473].
3441 Scott D, French S, Rudy G. Whitiora--a bridge to good health for South Auckland diabetics. N Z Hosp. Nov-Dec. 1987;39(8):19-20. 2. X-3. [pmid: 10286524].
3442 Scott P. Lay beliefs and the management of disease amongst West Indians with diabetes. Health & Social Care in the Community. 1998;6(6):407-19. X-2, X-3, X-4. [pmid: 11560610].
3443 Scott TL, Gazmararian JA, Williams MV, et al. Health literacy and preventive health care use among Medicare enrollees in a managed care organization. Med Care. May. 2002;40(5):395-404. X-2, X-4. [pmid: 11961474].
3444 Scupholme A, DeJoseph J, Strobino DM, et al. Nurse-midwifery care to vulnerable populations. Phase I: Demographic characteristics of the National CNM Sample. J Nurse Midwifery. Sep-Oct. 1992;37(5):341-8. X-2, X-4, X-5. [pmid: 1403179].
3445 Sealy PA, Fraser J, Simpson JP, et al. Community awareness of postpartum depression. J Obstet Gynecol Neonatal Nurs. Mar-Apr. 2009;38(2):121-33. X-2, X-3, X-4, X-5. [pmid: 19323709].
3446 Searle J. Fearing the worst--why do pregnant women feel ‘at risk’?. Aust N Z J Obstet Gynaecol. Aug. 1996;36(3):279-86. X-2, X-3, X-4. [pmid: 8883751].
3447 Sears SR, Stanton AL, Kwan L, et al. Recruitment and retention challenges in breast cancer survivorship research: results from a multisite, randomized intervention trial in women with early stage breast cancer. Cancer Epidemiol Biomarkers Prev. Oct. 2003;12(10):1087-90. X-6, X-7, X-9. [pmid: 14578147].
3448 Secrest AM, Costacou T, Gutelius B, et al. Associations between socioeconomic status and major complications in type 1 diabetes: the Pittsburgh epidemiology of diabetes complication (EDC) Study. Ann Epidemiol. May. 2011;21(5):374-81. X-2. [pmid: 21458731].
3449 Seeherunwong A, Boontong T, Sindhu S, et al. Self-regaining from loss of self-worth: a substantive theory of recovering from depression of middle-aged Thai women [corrected]. [published erratum appears in THAI J NURS RES 2003 Jan-Mar 7 1 no pagination]. Thai Journal of Nursing Research. 2002;6(4):186-99. X-2, X-3, X-4, X-6.
3450 Segal DL, Lebenson S, Coolidge FL. Global self-rated health status predicts reasons for living among older adults. Clinical Gerontologist. 2008;31(4):122-32. X-2, X-4, X-6.
3451 Segrin C, Badger T, Dorros SM, et al. Interdependent anxiety and psychological distress in women with breast cancer and their partners. Psychooncology. Jul. 2007;16(7):634-43. X-2, X-4. [pmid: 17094160].
3452 Segura JM, Castells X, Casamitjana M, et al. A randomized controlled trial comparing three invitation strategies in a breast cancer screening program. Preventive Medicine: An International Journal Devoted to Practice and Theory. Oct. 2001;33(4):325-32. X-3, X-6. [pmid: 11570837].
3453 Sehgal AR. Impact of quality improvement efforts on race and sex disparities in hemodialysis. JAMA. Feb. 26. 2003;289(8):996-1000. X-12. [pmid: 12597751].
3454 Sehgal AR, Leon JB, Siminoff LA, et al. Improving the quality of hemodialysis treatment: a community-based randomized controlled trial to overcome patient-specific barriers. JAMA. Apr. 17. 2002;287(15):1961-7. X-6. [pmid: 11960538].
3455 Seicean S, Seicean A. Insomnia in adult Latino immigrants in the United States. Hispanic Health Care International. 2010;8(4):227-34. X-2, X-4, X-5.
3456 Seid M, Opipari-Arrigan L, Gelhard LR, et al. Barriers to Care Questionnaire: Reliability, Validity, and Responsiveness to Change Among Parents of Children With Asthma. Academic Pediatrics. Mar-Apr. 2009;9(2):106-13. X-2, X-4. [pmid: 19329101].
3457 Seid M, Varni JW, Gidwani P, et al. Problem-solving skills training for vulnerable families of children with persistent asthma: report of a randomized trial on health-related quality of life outcomes. J Pediatr Psychol. Nov. 2010;35(10):1133-43. X-7, X-9. [pmid: 20061311].
3458 Seidel MC, Powell RO, Zgibor JC, et al. Translating the Diabetes Prevention Program into an urban medically underserved community: a nonrandomized prospective intervention study. Diabetes Care. Apr. 2008;31(4):684-9. X-6, X-7, X-9. [pmid: 18252904].
3459 Selby JV, Swain BE, Gerzoff RB, et al. Understanding the gap between good processes of diabetes care and poor intermediate outcomes: Translating research into action for diabetes (TRIAD). Medical Care. Dec. 2007;45(12):1144-53. X-6, X-7, X-9. [pmid: 18007164].
3460 Selig S, Tropiano E, Greene-Moton E. Teaching cultural competence to reduce health disparities. Health Promot Pract. Jul. 2006;7(3 Suppl):247S-55S. X-1, X-2, X-4, X-5. [pmid: 16760244].
3461 Seligman HK, Davis TC, Schillinger D, et al. Food insecurity is associated with hypoglycemia and poor diabetes self-management in a low-income sample with diabetes. J Health Care Poor Underserved. Nov. 2010;21(4):1227-33. X-2, X-4. [pmid: 21099074].
3462 Seligman HK, Wallace AS, DeWalt DA, et al. Facilitating Behavior change with low-literacy patient education materials. American Journal of Health Behavior. Sep-Oct. 2007;31:S69-S78. X-1, X-6, X-7, X-9. [pmid: 17931139].
3463 Seligman HK, Wang FF, Palacios JL, et al. Physician notification of their diabetes patients' limited health literacy. A randomized, controlled trial. J Gen Intern Med. Nov. 2005;20(11):1001-7. X-9. [pmid: 16307624].
3464 Sentell TL, Ratcliff-Baird B. Literacy and comprehension of Beck Depression Inventory response alternatives. Community Ment Health J. Aug. 2003;39(4):323-31. X-2, X-3, X-10. [pmid: 12908646].
3465 Sequist TD, Adams A, Zhang F, et al. Effect of quality improvement on racial disparities in diabetes care. Arch Intern Med. Mar. 27. 2006;166(6):675-81. X-11, X-12. [pmid: 16567608].
3466 Sequist TD, Fitzmaurice GM, Marshall R, et al. Physician performance and racial disparities in diabetes mellitus care. Arch Intern Med. Jun. 9. 2008;168(11):1145-51. X-2, X-4. [pmid: 18541821].
3467 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. Jul-Aug. 2005;12(4):431-7. X-6. [pmid: 15802479].
3468 Serber ER, Finch NJ, Leman RB, et al. Disparities in preferences for receiving support and education among patients with implantable cardioverter defibrillators. Pacing Clin Electrophysiol. Mar. 2009;32(3):383-90. X-2, X-4, X-5. [pmid: 19272070].
3469 Sessa A, Abbate R, Di Giuseppe G, et al. Knowledge, attitudes, and preventive practices about colorectal cancer among adults in an area of Southern Italy. BMC Cancer. 2008;8:171. X-2, X-3, X-4, X-6. [pmid: 18547435].
3470 Sewitch MJ, Fournier C, Ciampi A, et al. Adherence to colorectal cancer screening guidelines in Canada. BMC Gastroenterol. 2007;7:39. X-2, X-3, X-4, X-6. [pmid: 17910769].
3471 Sexton MB, Byrd MR, O'Donohue WT, et al. Web-based treatment for infertility-related psychological distress. Arch Womens Ment Health. Aug. 2010;13(4):347-58. X-4, X-5, X-6. [pmid: 20127127].
3472 Shackelford J, Bachman JH. A comparison of an individually tailored and a standardized asthma self-management education. American Journal of Health Education. 2009. Jan-Feb. 2009;40(1):23-9. X-4, X-6.
3473 Shacter HE, Shea JA, Akhabue E, et al. A qualitative evaluation of racial disparities in glucose control. Ethn Dis. Spring. 2009;19(2):121-7. X-2, X-4. [pmid: 19537221].
3474 Shadmi E, Admi H, Ungar L, et al. Cancer care at the hospital–community interface: Perspectives of patients from different cultural and ethnic groups. Patient Education and Counseling. Apr. 2010;79(1):106-11. X-2, X-3, X-4, X-5. [pmid: 19709845].
3475 Shaefer SJ, Hutchins E, Buckley K. A process to address disparities in rates of sudden infant death syndrome. Manag Care Interface. Nov. 2004;17(11):19-24. X-5. [pmid: 15573800].
3476 Shah BR, Booth GL. Predictors and effectiveness of diabetes self-management education in clinical practice. Patient Educ Couns. Jan. 2009;74(1):19-22. X-2, X-3. [pmid: 18805668].
3477 Shah BR, Manuel DG. Self-reported diabetes is associated with self-management behaviour: a cohort study. BMC Health Serv Res. 2008;8:142. X-2, X-4. [pmid: 18606004].
3478 3479. Shah LC, West P, Bremmeyr K, et al. Health Literacy Instrument in Family Medicine: The “Newest Vital Sign” Ease of Use and Correlates. Journal of the American Board of Family Medicine. Mar-Apr. 2010;23(2):195-203. X-2, X-4. [pmid: 20207930].
3479 Shah R, Wang Y, Masoudi FA, et al. Sex and racial differences in outcomes and guideline-based management of troponin-only-positive acute myocardial infarction in older persons. Am J Geriatr Cardiol. Mar-Apr. 2007;16(2):97-105. X-2, X-4. [pmid: 17380619].
3480 Shah SM, Carey IM, DeWilde S, et al. Trends and inequities in beta-blocker prescribing for heart failure. Br J Gen Pract. Dec. 2008;58(557):862-9. X-2, X-3, X-4. [pmid: 19068160].
3481 Shah SS, Lutfiyya MN, McCullough JE, et al. Who is providing and who is getting asthma patient education: An analysis of 2001 National Ambulatory Medical Care Survey data. Health Education Research. Oct. 2008;23(5):803-13. X-2, X-4. [pmid: 17984294].
3482 Shah T, Aronow WS, Peterson SJ, et al. Diagnosis, treatment, and referral of hypertension or prehypertension in an emergency department after an educational program: preliminary results. J Clin Hypertens (Greenwich). Jun. 2011;13(6):413-5. X-6, X-7, X-9. [pmid: 21649840].
3483 Shah ZC, Huffman FG. Depression among Hispanic women with type 2 diabetes. Ethn Dis. Autumn. 2005;15(4):685-90. X-2, X-4. [pmid: 16259494].
3484 Shaheen NJ, Green B, Medapalli RK, et al. The perception of cancer risk in patients with prevalent Barrett's esophagus enrolled in an endoscopic surveillance program. Gastroenterology. Aug. 2005;129(2):429-36. X-2, X-4, X-5. [pmid: 16083700].
3485 Shakoor-Abdullah B, Kotchen JM, Walker WE, et al. Incorporating socio-economic and risk factor diversity into the development of an African-American community blood pressure control program. Ethn Dis. Autumn. 1997;7(3):175-83. X-2, X-4. [pmid: 9467699].
3486 Shames RS, Sharek P, Mayer M, et al. Effectiveness of a multicomponent self-management program in at-risk, school-aged children with asthma. Ann Allergy Asthma Immunol. Jun. 2004;92(6):611-8. X-7, X-9. [pmid: 15237762].
3487 Shane-McWhorter L, Oderda GM. Providing diabetes education and care to underserved patients in a collaborative practice at a utah community health center. Pharmacotherapy. Jan. 2005;25(1):96-109. X-4, X-9. [pmid: 15767225].
3488 Shani M, Nakar S, Lustman A, et al. Patient characteristics correlated with quality indicator outcomes in diabetes care. Br J Gen Pract. Sep. 2010;60(578):655-9. X-2, X-3, X-4. [pmid: 20849693].
3489 Shannon JJ, Catrambone CD, Coover L. Targeting improvements in asthma morbidity in Chicago: a 10-year retrospective of community action. Chest. Nov. 2007;132(5 Suppl):866S-73S. X-1, X-7, X-9. [pmid: 17998352].
3490 Shapiro A, Gracy D, Quinones W, et al. Putting guidelines into practice: improving documentation of pediatric asthma management using a decision-making tool. Arch Pediatr Adolesc Med. May. 2011;165(5):412-8. X-6, X-9. [pmid: 21536955].
3491 Shapiro HR. Prenatal education in the work place. AWHONNS Clin Issues Perinat Womens Health Nurs. 1993;4(1):113-21. X-13. [pmid: 8472042].
3492 Shapiro LD, Thompson D, Calhoun E. Sustaining a safety net breast and cervical cancer detection program. J Health Care Poor Underserved. May. 2006;17(2 Suppl):20-30. X-1, X-2, X-4. [pmid: 16809873].
3493 Sharis PJ, Cannon CP, Rogers WJ, et al. Predictors of mortality, coronary angiography, and revascularization in unstable angina pectoris and acute non-ST elevation myocardial infarction (the TIMI III Registry). Am J Cardiol. Nov. 15. 2002;90(10):1154-6. X-2, X-4. [pmid: 12423724].
3494 Sharkey C, Gourishankar S. Transplant Friends: an interactive education program for patients awaiting kidney transplantation. Transplant Proc. Nov. 2003;35(7):2405-6. X-3, X-5, X-6. [pmid: 14611970].
3495 Sharp BA, Meikle SF, James MD, et al. NHQR/NHDR measures for women of reproductive age. Med Care. Mar. 2005;43(3 Suppl):I64-71. X-2, X-4, X-5. [pmid: 15746593].
3496 Shaw BR, Han JY, Baker T, et al. How women with breast cancer learn using interactive cancer communication systems. Health Educ Res. Feb. 2007;22(1):108-19. X-6, X-7, X-9. [pmid: 16829544].
3497 Shaw BR, Han JY, Hawkins RP, et al. Communicating about self and others within an online support group for women with breast cancer and subsequent outcomes. Journal of Health Psychology. Oct. 2008;13(7):930-9. X-2, X-4, X-6. [pmid: 18809644].
3498 Shaw SJ, Huebner C, Armin J, et al. The Role of Culture in Health Literacy and Chronic Disease Screening and Management. Journal of Immigrant and Minority Health. Dec. 2009;11(6):460-7. X-1, X-2, X-3, X-4, X-5. [pmid: 18379877].
3499 Shaw-Perry M, Horner C, Trevino RP, et al. NEEMA: a school-based diabetes risk prevention program designed for African-American children. J Natl Med Assoc. Apr. 2007;99(4):368-75. X-7, X-9. [pmid: 17444425].
3500 Shaya FT, Shin JY, Mullins D, et al. Medicaid managed care: disparities in the use of thiazolidinediones compared with metformin. J Natl Med Assoc. Apr. 2005;97(4):493-7. X-2, X-4, X-5. [pmid: 15868769].
3501 Shea S, Weinstock RS, Starren J, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus. J Am Med Inform Assoc. Jan-Feb. 2006;13(1):40-51. X-6, X-7, X-9. [pmid: 16221935].
3502 Shea S, Weinstock RS, Teresi JA, et al. A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus: 5 year results of the IDEATel study. J Am Med Inform Assoc. Jul-Aug. 2009;16(4):446-56. X-6, X-7, X-9. [pmid: 19390093].
3503 Sheares BJ, Du Y, Vazquez TL, et al. Use of written treatment plans for asthma by specialist physicians. Pediatr Pulmonol. Apr. 2007;42(4):348-56. X-2, X-4, X-6. [pmid: 17352397].
3504 Shegog R, Bartholomew LK, Gold RS, et al. Asthma management simulation for children: translating theory, methods, and strategies to effect behavior change. Simul Healthc. Fall. 2006;1(3):151-9. X-1, X-2, X-4. [pmid: 19088584].
3505 Sheikh K, Bullock CM, Jiang Y, et al. Adherence to guidelines for and disparities in diabetes care utilization in Medicaid children. J Pediatr Endocrinol Metab. Apr. 2008;21(4):349-58. X-2, X-4. [pmid: 18556966].
3506 3507. Sheley JF. Inadequate transfer of breast cancer self-detection technology. Am J Public Health. Nov. 1983;73(11):1318-20. X-2, X-4. [pmid: 6625041].
3507 Shen N, Mayo NE, Scott SC, et al. Factors associated with pattern of care before surgery for breast cancer in Quebec between 1992 and 1997. Med Care. Dec. 2003;41(12):1353-66. X-2, X-3, X-4. [pmid: 14668668].
3508 Shepherd JH, McInerney PA. Knowledge of breast cancer in women in Sierra Leone. Curationis. Aug. 2006;29(3):70-7. X-2, X-3, X-4. [pmid: 17131611].
3509 Shepherd M, Hattersley A, Ellard S. Integration of the MODY link nurse project: 20-month evaluation. Journal of Diabetes Nursing. 2005;9(2):47-52. X-3, X-4, X-6.
3510 Sheppard VB, Figueiredo M, Canar J, et al. Latina a Latina: developing a breast cancer decision support intervention. Psychooncology. Apr. 2008;17(4):383-91. X-2, X-4. [pmid: 17628037].
3511 Sherbourne CD, Wells KB, Duan N, et al. Long-term effectiveness of disseminating quality improvement for depression in primary care. Arch Gen Psychiatry. Jul. 2001;58(7):696-703. X-6, X-9. [pmid: 11448378].
3512 Sherrod RA, Richardson S. Using a case management model to implement a faith-based initiative: addressing breast cancer in a rural African American population. Lippincotts Case Manag. Nov-Dec. 2003;8(6):241-5. X-6, X-7, X-9. [pmid: 14646781].
3513 Shibusawa T, Chen S. Determinants of depressive symptoms among Japanese elders receiving care from spouses, daughters and daughters-in-law. Clinical Gerontologist. 2003;26(1/2):31-42. X-2, X-3, X-4, X-6.
3514 Shieh C, McDaniel A, Ke I. Information-seeking and its predictors in low-income pregnant women. J Midwifery Womens Health. Sep-Oct. 2009;54(5):364-72. X-2, X-4. [pmid: 19720337].
3515 Shields MC, Griffin KW, McNabb WL. The effect of a patient education program on emergency room use for inner-city children with asthma. Am J Public Health. Jan. 1990;80(1):36-8. X-6, X-9. [pmid: 2293801].
3516 Shiffman RN, Michel G, Essaihi A, et al. Bridging the guideline implementation gap: a systematic, document-centered approach to guideline implementation. J Am Med Inform Assoc. Sep-Oct. 2004;11(5):418-26. X-2, X-4, X-5, X-6. [pmid: 15187061].
3517 Shigaki C, Kruse RL, Mehr D, et al. Motivation and diabetes self-management. Chronic Illn. Sep. 2010;6(3):202-14. X-2, X-4, X-6. [pmid: 20675362].
3518 3519. Shimony A, Zahger D, Ilia R, et al. Impact of the community's socioeconomic status on characteristics and outcomes of patients undergoing percutaneous coronary intervention. Int J Cardiol. Oct. 29. 2010;144(3):379-82. X-2, X-3, X-4. [pmid: 19446896].
3519 3520. Shobhana R, Begum R, Snehalatha C, et al. Patients' adherence to diabetes treatment. J Assoc Physicians India. Dec. 1999;47(12):1173-5. X-2, X-4. [pmid: 11225220].
3520 Shobhana R, Indira P, Ramachandran A, et al. Effectiveness of patient education in a multilingual, multiliterate population. J Med Assoc Thai. Mar. Suppl 2. 1987;70:219-22. X-9. [pmid: 3598435].
3521 Shokar NK, Carlson CA, Weller SC. Factors associated with racial/ethnic differences in colorectal cancer screening. J Am Board Fam Med. Sep-Oct. 2008;21(5):414-26. X-2, X-4. [pmid: 18772296].
3522 Shone LP, Conn KM, Sanders L, et al. The role of parent health literacy among urban children with persistent asthma. Patient Educ Couns. Jun. 2009;75(3):368-75. X-2, X-4. [pmid: 19233588].
3523 Shortridge EF, James CV. Marriage and end-stage renal disease: implications for African Americans. Journal of Family Issues. 2010;31(9):1230-49. X-6, X-7, X-9.
3524 Shrank WH, Parker R, Davis T, et al. Rationale and design of a randomized trial to evaluate an evidence-based prescription drug label on actual medication use. Contemporary Clinical Trials. Nov. 2010;31(6):564-71. X-1, X-6, X-9. [pmid: 20647058].
3525 Shue CK, O'Hara LLS, Marini D, et al. Diabetes and low-health literacy: A preliminary outcome report of a mediated intervention to enhance patient-physician communication. Communication Education. Jul. 2010;59(3):360-73. X-6, X-7, X-9.
3526 Shuldham C, Theaker C, Jaarsma T, et al. Evaluation of the European Heart Failure Self-care Behaviour Scale in a United Kingdom population. Journal of Advanced Nursing. Oct. 2007;60(1):87-95. X-2, X-3, X-4, X-6. [pmid: 17824943].
3527 Sidora-Arcoleo K, Feldman J, Serebrisky D, et al. Validation of the Asthma Illness Representation Scale (AIRS). J Asthma. Feb. 2010;47(1):33-40. X-2, X-4. [pmid: 20100018].
3528 Sidora-Arcoleo KJ, Feldman J, Serebrisky D, et al. Validation of the Asthma Illness Representation Scale-Spanish (AIRS-S). J Asthma. May. 2010;47(4):417-21. X-2, X-4. [pmid: 20528596].
3529 Sidorov J, Shull R, Tomcavage J, et al. Does diabetes disease management save money and improve outcomes? A report of simultaneous short-term savings and quality improvement associated with a health maintenance organization-sponsored disease management program among patients fulfilling health employer data and information set criteria. Diabetes Care. Apr. 2002;25(4):684-9. X-2, X-4, X-6. [pmid: 11919125].
3530 Siegal R. Sex and flowers: a patient's guide. Nephrol News Issues. Nov. 1999;13(11):39. X-1, X-6, X-7, X-9. [pmid: 10865627].
3531 Siega-Riz AM, Adair LS, Hobel CJ. Institute of Medicine maternal weight gain recommendations and pregnancy outcome in a predominantly Hispanic population. Obstet Gynecol. Oct. 1994;84(4):565-73. X-2, X-4. [pmid: 8090394].
3532 Siegel B, Bear D, Andres E, et al. Measuring equity: an index of health care disparities. Qual Manag Health Care. Apr-Jun. 2009;18(2):84-90. X-2, X-4, X-5, X-6. [pmid: 19369851].
3533 Sieverding M, Matterne U, Ciccarello L. Gender differences in FOBT use: evidence from a large German survey. Z Gastroenterol. Apr. Suppl 1. 2008;46:S47-51. X-2, X-3, X-4. [pmid: 18368645].
3534 Sifri R, Wender R, Lieberman D, et al. Developing a quality screening colonoscopy referral system in primary care practice: a report from the national colorectal cancer roundtable. CA Cancer J Clin. Jan-Feb. 2010;60(1):40-9. X-1, X-2, X-3, X-4, X-6. [pmid: 20023050].
3535 Sigfrid LA, Turner C, Crook D, et al. Using the UK primary care Quality and Outcomes Framework to audit health care equity: preliminary data on diabetes management. J Public Health (Oxf). Sep. 2006;28(3):221-5. X-2, X-3, X-4. [pmid: 16809789].
3536 Silka L, Toof R, Grigg-Saito D. Eight Americas: differences in Asian communities are important. PLoS Med. Jan. 2007;4(1):e41. X-1, X-2, X-4. [pmid: 17411315].
3537 Silva JK, Kaholokula JK, Ratner R, et al. Ethnic differences in perinatal outcome of gestational diabetes mellitus. Diabetes Care. Sep. 2006;29(9):2058-63. X-2, X-4. [pmid: 16936153].
3538 Silva M, Munoz L, Diaz T, et al. Epidemiological characterization of pediatric patients with status asthmaticus admitted to intensive care units. Bol Asoc Med P R. Apr-Jun. 2009;101(2):17-20. X-2, X-3, X-4. [pmid: 19954095].
3539 Silva R, Thomas M, Caetano R, et al. Preventing low birth weight in Illinois: outcomes of the family case management program. Matern Child Health J. Nov. 2006;10(6):481-8. X-5, X-7, X-9, X-11. [pmid: 16865536].
3540 Silveira CD, Araujo Fde B, Pereira LF, et al. Evaluation of the treatment provided to patients with asthma by the Brazilian Unified Health Care System. J Bras Pneumol. Jul. 2009;35(7):628-34. X-2, X-3, X-4. [pmid: 19669000].
3541 Silverman BG, Moidu K, Clemente BE, et al. HOLON: a Web-based framework for fostering guideline applications. Proc AMIA Annu Fall Symp. 1997:374-8. X-2, X-4, X-5, X-6. [pmid: 9357651].
3542 Siminoff LA, Graham GC, Gordon NH. Cancer communication patterns and the influence of patient characteristics: disparities in information-giving and affective behaviors. Patient Educ Couns. Sep. 2006;62(3):355-60. X-2, X-4. [pmid: 16860520].
3543 Simmons D, Fleming C, Voyle J, et al. A pilot urban church-based programme to reduce risk factors for diabetes among Western Samoans in New Zealand. Diabet Med. Feb. 1998;15(2):136-42. X-3. [pmid: 9507914].
3544 Simmons D, Gatland BA, Leakehe L, et al. Ethnic differences in diabetes care in a multiethnic community in New Zealand. Diabetes Res Clin Pract. Oct. 1996;34(Suppl):S89-93. X-2, X-3, X-4. [pmid: 9015676].
3545 Simmons D, Peng A, Cecil A, et al. The personal costs of diabetes: a significant barrier to care in South Auckland. N Z Med J. Oct. 8. 1999;112(1097):383-5. X-2, X-3, X-4. [pmid: 10587070].
3546 Simmons D, Shaw L, Kenealy T, et al. Ethnic differences in diabetes knowledge and education: the South Auckland Diabetes Survey. N Z Med J. May. 25. 1994;107(978):197-200. X-2, X-3, X-4. [pmid: 8196864].
3547 Simmons D, Voyle JA. Reaching hard-to-reach, high-risk populations: Piloting a health promotion and diabetes disease prevention programme on an urban marae in New Zealand. Health Promotion International. Mar. 2003;18(1):41-50. X-3, X-7, X-9. [pmid: 12571091].
3548 Simon HK. Caregiver knowledge and delivery of a commonly prescribed medication (albuterol) for children. Arch Pediatr Adolesc Med. Jun. 1999;153(6):615-8. X-2, X-4. [pmid: 10357303].
3549 Simon MA, Cofta-Woerpel L, Randhawa V, et al. Using the word ‘cancer’ in communication about an abnormal Pap test: Finding common ground with patient-provider communication. Patient Education and Counseling. Oct. 2010;81(1):106-12. X-2, X-4, X-5. [pmid: 20060255].
3550 Simon MS, Gimotty PA, Moncrease A, et al. The effect of patient reminders on the use of screening mammography in an urban health department primary care setting. Breast Cancer Res Treat. Jan. 2001;65(1):63-70. X-6, X-9. [pmid: 11245341].
3551 Simonds VW, Rudd RE, Sequist TD, et al. An assessment of printed diabetes-prevention materials available to a Northern Plains tribe. J Health Commun. Apr. 2011;16(4):431-47. X-2, X-4. [pmid: 21271427].
3552 Simonian K, Brown SE, Sanders DB, et al. Breast health information: messages that appeal to young women and older women of color. J Cancer Educ. Winter. 2004;19(4):232-6. X-2, X-4. [pmid: 15725642].
3553 Simonian K, Brown SE, Sanders DB, et al. Promoting breast cancer screening to women of color. Nurse Pract. Mar. 2004;29(3):45-6. X-1, X-6, X-7, X-9. [pmid: 15021506].
3554 Simons LA, Tett S, Simons J, et al. Multiple medication use in the elderly. Use of prescription and non-prescription drugs in an Australian community setting. Med J Aust. Aug. 17. 1992;157(4):242-6. X-2, X-3, X-4, X-5, X-6. [pmid: 1435439].
3555 Simpson SH, Farris KB, Johnson JA, et al. Using focus groups to identify barriers to drug use in patients with congestive heart failure. Pharmacotherapy. Jul. 2000;20(7):823-9. X-2, X-4. [pmid: 10907972].
3556 Sin MK, Kang DH, Weaver M. Relationships of asthma knowledge, self-management, and social support in African American adolescents with asthma. Int J Nurs Stud. Mar. 2005;42(3):307-13. X-2, X-4. [pmid: 15708017].
3557 Sinclair AJ, Girling AJ, Bayer AJ. Cognitive dysfunction in older subjects with diabetes mellitus: impact on diabetes self-management and use of care services. All Wales Research into Elderly (AWARE) Study. Diabetes Res Clin Pract. Dec. 2000;50(3):203-12. X-2, X-3, X-4. [pmid: 11106835].
3558 Singh M, Singh G. Assessment of mental health status of middle-aged female school teachers of Varanasi City. Internet Journal of Health. 2006;5(1):10p. X-2, X-3, X-4, X-6.
3559 Singh N, Sidawy AN, DeZee KJ, et al. Factors associated with early failure of infrainguinal lower extremity arterial bypass. J Vasc Surg. Mar. 2008;47(3):556-61. X-2, X-4. [pmid: 18295106].
3560 Singleton JA, Santibanez TA, Wortley PM. Influenza and Pneumococcal Vaccination of Adults Aged ≥65: Racial/Ethnic Differences. American Journal of Preventive Medicine. Dec. 2005;29(5):412-20. X-2, X-4. [pmid: 16376704].
3561 Sinorita H, Saadah, Jazakillah S. Effects of dietary pattern and education on glycemic control in patients with type 2 diabetes mellitus at Dr. Sardjito Central General Hospital, Yogyakarta. Acta Med Indones. Apr. 2008;40(2):55-8. X-2, X-3, X-4. [pmid: 18560024].
3562 Siomos EE, Newsom RS, Camponeschi J, et al. A statewide collaboration to monitor diabetes quality improvement among Wisconsin health plans. Am J Manag Care. May. 2005;11(5):332-6. X-6, X-7, X-9. [pmid: 15898222].
3563 Siripitayakunkit A, Hanucharurnkul S, Melkus GDE, et al. Factors contributing to integrating lifestyle in Thai women with type 2 diabetes. Thai Journal of Nursing Research. 2008;12(3):166-77. X-2, X-3, X-4, X-6.
3564 Siriwardena AN, Middlemass JB, Ward K, et al. Drivers for change in primary care of diabetes following a protected learning time educational event: interview study of practitioners. BMC Med Educ. 2008;8:4. X-2, X-3, X-4. [pmid: 18205947].
3565 Sisk JE, Hebert PL, Horowitz CR, et al. Effects of nurse management on the quality of heart failure care in minority communities: a randomized trial. Ann Intern Med. Aug. 15. 2006;145(4):273-83. X-9. [pmid: 16908918].
3566 Sisk JE, Hebert PL, Horowitz CR, et al. Effects of nurse management on the quality of heart failure care in minority communities - A randomized trial. Annals of Internal Medicine. Aug. 2006;145(4):273-83. X-14. [pmid: 16908918].
3567 Sisk JE, Horowitz CR, Wang JJ, et al. The success of recruiting minorities, women, and elderly into a randomized controlled effectiveness trial. Mt Sinai J Med. Jan-Feb. 2008;75(1):37-43. X-2, X-4. [pmid: 18306248].
3568 Sixta CS, Ostwald S. Texas-Mexico border intervention by promotores for patients with type 2 diabetes. Diabetes Educ. Mar-Apr. 2008;34(2):299-309. X-9. [pmid: 18375779].
3569 Skaer TL, Robison LM, Sclar DA, et al. Financial incentive and the use of mammography among Hispanic migrants to the United States. Health Care Women Int. Jul-Aug. 1996;17(4):281-91. X-7. [pmid: 8850763].
3570 Skaer TL, Sclar DA, Robison LM, et al. Trends in the rate of depressive illness and use of antidepressant pharmacotherapy by ethnicity/race: an assessment of office-based visits in the United States, 1992-1997. Clin Ther. Dec. 2000;22(12):1575-89. X-2, X-4. [pmid: 11192148].
3571 Skelding PC, Majumdar SR, Kleinman K, et al. Clinical and nonclinical correlates of adherence to prescribing guidelines for hypertension in a large managed care organization. J Clin Hypertens (Greenwich). Jun. 2006;8(6):414-9. X-2, X-4. [pmid: 16760680].
3572 Skelly AH, Carlson J, Leeman J, et al. Controlled trial of nursing interventions to improve health outcomes of older African American women with type 2 diabetes. Nurs Res. Nov-Dec. 2009;58(6):410-8. X-9. [pmid: 19851122].
3573 Skelly AH, Dougherty M, Gesler WM, et al. African American beliefs about diabetes. West J Nurs Res. Feb. 2006;28(1):9-29. discussion 30-41. X-2, X-4. [pmid: 16676724].
3574 Skelly AH, Marshall JR, Haughey BP, et al. Self-efficacy and confidence in outcomes as determinants of self-care practices in inner-city, African-American women with non-insulin-dependent diabetes. Diabetes Educ. Jan-Feb. 1995;21(1):38-46. X-2, X-4. [pmid: 7835203].
3575 Skelly AH, Samuel-Hodge C, Elasy T, et al. Development and testing of culturally sensitive instruments for African American women with type 2 diabetes. Diabetes Educ. Sep-Oct. 2000;26(5):769-74. 76. 7. X-6, X-7, X-9. [pmid: 11140006].
3576 Skemp MM, Peltier JW, Cochran C. Bridging the gap. Relationship marketing breathes new life into neglected populations. Mark Health Serv. Summer. 2003;23(2):26-31. X-1, X-6, X-7, X-9. [pmid: 12800625].
3577 Skinner CS, Schildkraut JM, Berry D, et al. Pre-counseling education materials for BRCA testing: does tailoring make a difference?. Genet Test. Summer. 2002;6(2):93-105. X-2, X-5. [pmid: 12215248].
3578 Skinner CS, Strecher VJ, Hospers H. Physicians' recommendations for mammography: do tailored messages make a difference?. Am J Public Health. Jan. 1994;84(1):43-9. X-9. [pmid: 8279610].
3579 Skinner CS, Sykes RK, Monsees BS, et al. Learn, share, and live: breast cancer education for older, urban minority women. Health Educ Behav. Feb. 1998;25(1):60-78. X-9. [pmid: 9474500].
3580 Skinner TC, Hampson SE. Personal models of diabetes in relation to self-care, well-being, and glycemic control. A prospective study in adolescence. Diabetes Care. May. 2001;24(5):828-33. X-2, X-3, X-4, X-6. [pmid: 11347738].
3581 Skolnick AH, Alexander KP, Chen AY, et al. Characteristics, management, and outcomes of 5,557 patients age > or =90 years with acute coronary syndromes: results from the CRUSADE Initiative. J Am Coll Cardiol. May. 1. 2007;49(17):1790-7. X-6. [pmid: 17466230].
3582 Sleath B, Ayala GX, Davis S, et al. Child- and caregiver-reported problems and concerns in using asthma medications. J Asthma. Aug. 2010;47(6):633-8. X-2, X-4. [pmid: 20632916].
3583 Sleath B, Ayala GX, Gillette C, et al. Provider demonstration and assessment of child device technique during pediatric asthma visits. Pediatrics. Apr. 2011;127(4):642-8. X-2, X-4, X-6. [pmid: 21444594].
3584 Sleeper EJ, Ariza AJ, Binns HJ. Do hospitalized pediatric patients have weight and blood pressure concerns identified?. J Pediatr. Feb. 2009;154(2):213-7. X-2, X-4, X-5. [pmid: 18835489].
3585 Sloan FA, Brown DS, Carlisle ES, et al. Monitoring visual status: why patients do or do not comply with practice guidelines. Health Serv Res. Oct. 2004;39(5):1429-48. X-2, X-4. [pmid: 15333116].
3586 Sloan FA, Padron NA, Platt AC. Preferences, beliefs, and self-management of diabetes. Health Serv Res. Jun. 2009;44(3):1068-87. X-2, X-4. [pmid: 19674433].
3587 Sloan FA, Trogdon JG, Curtis LH, et al. The effect of dementia on outcomes and process of care for Medicare beneficiaries admitted with acute myocardial infarction. J Am Geriatr Soc. Feb. 2004;52(2):173-81. X-2, X-4, X-7. [pmid: 14728624].
3588 Sloane D, Nascimento L, Flynn G, et al. Assessing resource environments to target prevention interventions in community chronic disease control. J Health Care Poor Underserved. May. 2006;17(2 Suppl):146-58. X-2, X-4. [pmid: 16809881].
3589 Sloane DC, Diamant AL, Lewis LB, et al. Improving the nutritional resource environment for healthy living through community-based participatory research. J Gen Intern Med. Jul. 2003;18(7):568-75. X-2, X-5. [pmid: 12848840].
3590 Smaldone A, Ganda OP, McMurrich S, et al. Should group education classes be separated by type of diabetes?. Diabetes Care. Jul. 2006;29(7):1656-8. X-6, X-7, X-9. [pmid: 16801595].
3591 Small LF. Quality-of-life experiences from the perspective of patients receiving haemodialysis for chronic renal failure. Health SA Gesondheid. 2010;15(1):187-93. X-2, X-3, X-4, X-6.
3592 Smellie WS, Lowrie R, Wilkinson E. A laboratory based intervention to improve appropriateness of lipid tests and audit cholesterol lowering in primary care. BMJ. Nov. 24. 2001;323(7323):1224-7. X-3, X-5. [pmid: 11719414].
3593 Smellie WSA, Robson CA. Use of a parallel clinical advisory service to support lipid lowering in primary care. Quality in Primary Care. 2003;11(3):199-203. X-3, X-5, X-6.
3594 Smeulders ES, van Haastregt JC, Ambergen T, et al. Heart failure patients with a lower educational level and better cognitive status benefit most from a self-management group programme. Patient Educ Couns. Nov. 2010;81(2):214-21. X-3, X-6. [pmid: 20153132].
3595 Smide B, Ekman L, Wikblad K. Diabetes self-care and educational needs in Tanzanian and Swedish diabetic patients: a cross-cultural study. Trop Doct. Oct. 2002;32(4):212-6. X-2, X-3, X-4. [pmid: 12405300].
3596 Smith C, Ryan A. Change for Life/Cambia tu vida: A health promotion program based on the stages of change model for African descendent and Latino adults in New Hampshire. Prev Chronic Dis. Jul. 2006;3(3):A105. X-7. [pmid: 16776866].
3597 Smith ED, Merritt SL, Patel MK. Church-based education: an outreach program for African Americans with hypertension. Ethn Health. Aug. 1997;2(3):243-53. X-9. [pmid: 9426988].
3598 Smith J, Jackson G, Orr-Walker B, et al. A population-based approach to the estimation of diabetes prevalence and health resource utilisation. N Z Med J. Mar. 5. 2010;123(1310):62-73. X-2, X-3, X-4. [pmid: 20360780].
3599 Smith JL, Rost KM, Nutting PA, et al. Resolving disparities in antidepressant treatment and quality-of-life outcomes between uninsured and insured primary care patients with depression. Med Care. Sep. 2001;39(9):910-22. X-4. [pmid: 11502949].
3600 Smith JL, Rost KM, Nutting PA, et al. Impact of ongoing primary care intervention on long term outcomes in uninsured and insured patients with depression. Med Care. Dec. 2002;40(12):1210-22. X-4. [pmid: 12458303].
3601 Smith JP. Nature and causes of trends in male diabetes prevalence, undiagnosed diabetes, and the socioeconomic status health gradient. Proc Natl Acad Sci U S A. Aug. 14. 2007;104(33):13225-31. X-2, X-4. [pmid: 17698965].
3602 Smith JR, Mildenhall S, Noble M, et al. Clinician-assessed poor compliance identifies adults with severe asthma who are at risk of adverse outcomes. J Asthma. Jul-Aug. 2005;42(6):437-45. X-2, X-3, X-4. [pmid: 16293538].
3603 Smith MD, McGhan WF. Attacking expenditures for asthma. Bus Health. Apr. 1997;15(4):67-8. 70. X-1, X-6, X-7, X-9. [pmid: 10166794].
3604 Smith NL, Chen L, Au DH, et al. Cardiovascular risk factor control among veterans with diabetes: the ambulatory care quality improvement project. Diabetes Care. May. Suppl 2. 2004;27:B33-8. X-2, X-4, X-6. [pmid: 15113780].
3605 Smith RA, Cokkinides V, Eyre HJ. Cancer screening in the United States, 2007: a review of current guidelines, practices, and prospects. CA Cancer J Clin. Mar-Apr. 2007;57(2):90-104. X-1, X-2, X-4, X-5, X-6. [pmid: 17392386].
3606 Smith SK, Trevena L, Nutbeam D, et al. Information needs and preferences of low and high literacy consumers for decisions about colorectal cancer screening: utilizing a linguistic model. Health Expect. Jun. 2008;11(2):123-36. X-2, X-4. [pmid: 18494957].
3607 Smith SK, Trevena L, Simpson JM, et al. A decision aid to support informed choices about bowel cancer screening among adults with low education: randomised controlled trial. BMJ. 2010;341:c5370. X-3. [pmid: 20978060].
3608 Smith SL, Tessaro IA. Cultural perspectives on diabetes in an Appalachian population. Am J Health Behav. Jul-Aug. 2005;29(4):291-301. X-2, X-4. [pmid: 16006226].
3609 Smith SM, Mitchell C, Bowler SD, et al. The health behaviour and clinical characteristics of ambulance users with acute asthma. Emerg Med J. Mar. 2009;26(3):187-92. X-2, X-4, X-6. [pmid: 19234010].
3610 Smith SR. Disabled newborns and the federal child abuse amendments: tenuous protection. Hastings Law J. May. 1986;37(5):765-825. X-1, X-5. [pmid: 11655856].
3611 Smith SR, Jaffe DM, Highstein G, et al. Asthma coaching in the pediatric emergency department. Acad Emerg Med. Aug. 2006;13(8):835-9. X-4. [pmid: 16825669].
3612 Smith WJ. “Inevitable” assisted suicide?: don't bet your life. Hum Life Rev. Spring. 1997;23(2):61-74. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11656680].
3613 Smith-Bindman R, Quale C, Chu PW, et al. Can Medicare billing claims data be used to assess mammography utilization among women ages 65 and older?. Med Care. May. 2006;44(5):463-70. X-2, X-4. [pmid: 16641665].
3614 Smolders M, Laurant M, Verhaak P, et al. Which physician and practice characteristics are associated with adherence to evidence-based guidelines for depressive and anxiety disorders?. Med Care. Mar. 2010;48(3):240-8. X-2, X-4. [pmid: 20125045].
3615 So SS, G. Matters of the heart: Patients' adjustment to life following a cardiac crisis. Psychology & Health. 2011;26:83-100. X-2, X-4, X-6. [pmid: 21337261].
3616 So WK-w, Kai-chow C, Chan CW-h, et al. Age-Related Differences in the Quality of Life of Chinese Women Undergoing Adjuvant Therapy for Breast Cancer. Research in Gerontological Nursing. 2011;4(1):19-26. X-2. [pmid: 21210577].
3617 Sobel RM, Paasche-Orlow MK, Waite KR, et al. Asthma 1-2-3: a low literacy multimedia tool to educate African American adults about asthma. J Community Health. Aug. 2009;34(4):321-7. X-7, X-9. [pmid: 19353250].
3618 Sokal R. A critical review of the literature on the uptake of cervical and breast screening in British South Asian women. Quality in Primary Care. 2010;18(4):251-61. X-1, X-2, X-3, X-4, X-6.
3619 Solberg LI, Kottke TE, Brekke ML, et al. Failure of a continuous quality improvement intervention to increase the delivery of preventive services. A randomized trial. Eff Clin Pract. May-Jun. 2000;3(3):105-15. X-6. [pmid: 11182958].
3620 Son SH, Morrison FJ. The Nature and Impact of Changes in Home Learning Environment on Development of Language and Academic Skills in Preschool Children. Developmental Psychology. Sep. 2010;46(5):1103-18. X-2, X-4, X-5, X-6. [pmid: 20822226].
3621 Sonel AF, Good CB, Mulgund J, et al. Racial variations in treatment and outcomes of black and white patients with high-risk non-ST-elevation acute coronary syndromes: insights from CRUSADE (Can Rapid Risk Stratification of Unstable Angina Patients Suppress Adverse Outcomes With Early Implementation of the ACC/AHA Guidelines?). Circulation. Mar. 15. 2005;111(10):1225-32. X-2, X-4. [pmid: 15769762].
3622 Song HJ, Han HR, Lee JE, et al. Translating current dietary guidelines into a culturally tailored nutrition education program for Korean American immigrants with type 2 diabetes. Diabetes Educ. Sep-Oct. 2010;36(5):752-61. X-4. [pmid: 20651099].
3623 Song M, Choe MA, Kim KS, et al. An evaluation of Web-based education as an alternative to group lectures for diabetes self-management. Nurs Health Sci. Sep. 2009;11(3):277-84. X-3, X-4. [pmid: 19689636].
3624 Song M, Lee CS. Diabetes self-care maintenance, comorbid conditions and perceived health. European Diabetes Nursing. 2009;6(2):65-8. X-2, X-4, X-6.
3625 Song MK, Donovan HS, Piraino BM, et al. Effects of an intervention to improve communication about end-of-life care among African Americans with chronic kidney disease. Appl Nurs Res. May. 2010;23(2):65-72. X-4. [pmid: 20420992].
3626 Song MK, Ward SE, Happ MB, et al. Randomized controlled trial of SPIRIT: an effective approach to preparing African-American dialysis patients and families for end of life. Res Nurs Health. Jun. 2009;32(3):260-73. X-6, X-7, X-9. [pmid: 19205027].
3627 Song MS, Kim HS. Effect of the diabetes outpatient intensive management programme on glycaemic control for type 2 diabetic patients. J Clin Nurs. Jul. 2007;16(7):1367-73. X-3, X-4. [pmid: 17584356].
3628 Song YM, Byeon JJ. Excess mortality from avoidable and non-avoidable causes in men of low socioeconomic status: a prospective study in Korea. J Epidemiol Community Health. Mar. 2000;54(3):166-72. X-2, X-3, X-4. [pmid: 10746109].
3629 Sonksen P, Harris A, Jarman B. Perceived strategic and practical problems in the use of information technology for quality improvement in diabetes care in the United Kingdom. Diabete Metab. 1993;19(1 Pt 2):80-8. X-1, X-2, X-3, X-4. [pmid: 8314432].
3630 Sood N, Treglia M, Obenchain RL, et al. Determinants of antidepressant treatment outcome. Am J Manag Care. Dec. 2000;6(12):1327-36. X-2, X-4, X-6. [pmid: 11151810].
3631 Sorensen L, Gavier M, Helleso R. Latina breast cancer survivors informational needs: information partners. Stud Health Technol Inform. 2009;146:727. X-7, X-9. [pmid: 19592948].
3632 Sotiropoulos A, Skliros EA, Tountas C, et al. Risk factors for severe hypoglycaemia in type 2 diabetic patients admitted to hospital in Piraeus, Greece. East Mediterr Health J. May. 2005;11(3):485-9. X-2, X-3, X-4. [pmid: 16602470].
3633 Soumerai SB, Mah C, Zhang F, et al. Effects of health maintenance organization coverage of self-monitoring devices on diabetes self-care and glycemic control. Arch Intern Med. Mar. 22. 2004;164(6):645-52. X-6, X-7, X-9. [pmid: 15037493].
3634 Sousa VD, Zanetti ML, Zauszniewski JA, et al. Psychometric properties of the Portuguese version of the Depressive Cognition Scale in Brazilian adults with diabetes mellitus. J Nurs Meas. 2008;16(2):125-35. X-2, X-3, X-4, X-6. [pmid: 18939717].
3635 Souza JP, Sousa MH, Parpinelli MA, et al. Self-reported maternal morbidity and associated factors among Brazilian women. Rev Assoc Med Bras. May-Jun. 2008;54(3):249-55. X-2, X-3, X-4. [pmid: 18604404].
3636 Sowattanangoon N, Kotchabhakdi N, Petrie KJ. The influence of Thai culture on diabetes perceptions and management. Diabetes Res Clin Pract. Jun. 2009;84(3):245-51. X-2, X-3, X-4. [pmid: 19285741].
3637 Spady DW, Saunders LD, Bamforth F. Who gets missed: coverage in a provincial newborn screening program for metabolic disease. Pediatrics. Aug. 1998;102(2):e21. X-2, X-3, X-4, X-5, X-6. [pmid: 9685466].
3638 Speight J, Bradley C. The ADKnowl: identifying knowledge deficits in diabetes care. Diabet Med. Aug. 2001;18(8):626-33. X-2, X-4, X-6. [pmid: 11553199].
3639 Spence NJ. The long-term consequences of childbearing: physical and psychological well-being of mothers in later life. Research on Aging. 2008;30(6):722-51. X-2, X-4, X-5. [pmid: 19122886].
3640 Spencer MS, Kieffer EC, Sinco BR, et al. Diabetes-specific emotional distress among African Americans and Hispanics with type 2 diabetes. J Health Care Poor Underserved. May. 2006;17(2 Suppl):88-105. X-2, X-4. [pmid: 16809877].
3641 Spettell CM, Wall TC, Allison J, et al. Identifying physician-recognized depression from administrative data: consequences for quality measurement. Health Serv Res. Aug. 2003;38(4):1081-102. X-2, X-4, X-6. [pmid: 12968818].
3642 Spiegel J, Love AS, Wood PR, et al. The Inner-City Asthma Intervention: description of a community-based implementation of an evidence-based approach to asthma management. Ann Allergy Asthma Immunol. Jul. 2006;97(1 Suppl 1):S6-10. X-2. [pmid: 16892764].
3643 Spong CY, Guillermo L, Kuboshige J, et al. Recurrence of gestational diabetes mellitus: identification of risk factors. Am J Perinatol. Jan. 1998;15(1):29-33. X-2, X-4. [pmid: 9475684].
3644 Spurrier NJ, Staugas R, Sawyer MG, et al. Health-service use by children with asthma over a 6-month period. J Paediatr Child Health. Jan-Feb. 2003;39(1):15-21. X-2, X-4, X-6. [pmid: 12542806].
3645 St Pierre M. Diversity in delivery: the Medicare home health benefit. Caring. Dec. 1996;15(12):10-4. X-1, X-2, X-4, X-5, X-6, X-7, X-8. [pmid: 10162617].
3646 Stableford S, Mettger W. Plain language: A strategic response to the health literacy challenge. Journal of Public Health Policy. 2007;28(1):71-93. X-1, X-2, X-3, X-4, X-5. [pmid: 17363939].
3647 Stacy R, Torrence WA, Mitchell CR. Perceptions of knowledge, beliefs, and barriers to colorectal cancer screening. J Cancer Educ. 2008;23(4):238-40. X-2, X-4. [pmid: 19058073].
3648 Stafford L, Judd F. What do women with gestational trophoblastic disease understand about the condition?. Int J Gynecol Cancer. Jan. 2011;21(1):161-6. X-2, X-3, X-4, X-5, X-6. [pmid: 21178576].
3649 Stallwood L. Relationship between caregiver knowledge and socioeconomic factors on glycemic outcomes of young children with diabetes. J Spec Pediatr Nurs. Jul. 2006;11(3):158-65. X-2, X-4. [pmid: 16774526].
3650 Stang A, Moebus S, Dragano N, et al. Baseline recruitment and analyses of nonresponse of the Heinz Nixdorf Recall Study: identifiability of phone numbers as the major determinant of response. Eur J Epidemiol. 2005;20(6):489-96. X-2, X-3, X-4, X-5, X-6. [pmid: 16121757].
3651 Stanton WR, Fisher KJ, Balanda KP, et al. Patient reports of health education activities in a public hospital. Aust Health Rev. 1995;18(2):85-100. X-2, X-3, X-4, X-5. [pmid: 10144340].
3652 Stapleton DR, Gurrin LC, Zubrick SR, et al. What do children with cystic fibrosis and their parents know about nutrition and pancreatic enzymes?. J Am Diet Assoc. Dec. 2000;100(12):1494-500. X-2, X-3, X-4. [pmid: 11138442].
3653 Starmer AJ, Duby JC, Slaw KM, et al. Pediatrics in the year 2020 and beyond: preparing for plausible futures. Pediatrics. Nov. 2010;126(5):971-81. X-1, X-2, X-4, X-5, X-6. [pmid: 20956424].
3654 Starostina EG, Antsiferov M, Galstyan GR, et al. Effectiveness and cost-benefit analysis of intensive treatment and teaching programmes for type 1 (insulin-dependent) diabetes mellitus in Moscow--blood glucose versus urine glucose self-monitoring. Diabetologia. Feb. 1994;37(2):170-6. X-3. [pmid: 8163051].
3655 States RA, Susman WM, Riquelme LF, et al. Community health education: reaching ethnically diverse elders. J Allied Health. Winter. 2006;35(4):215-22. X-9. [pmid: 17243436].
3656 Stead MJ, Wallis MG, Wheaton ME. Improving uptake in non-attenders of breast screening: selective use of second appointment. J Med Screen. 1998;5(2):69-72. X-3. [pmid: 9718524].
3657 Stein K, Zhao L, Crammer C, et al. Prevalence and sociodemographic correlates of beliefs regarding cancer risks. Cancer. Sep. 2007;110(5):1139-48. X-2, X-4, X-5. [pmid: 17657733].
3658 Steinbrook R. Closing the affordability gap for drugs in low-income countries. N Engl J Med. Nov. 15. 2007;357(20):1996-9. X-1, X-6, X-7, X-9. [pmid: 18003957].
3659 Steiner JF, Prochazka AV. The assessment of refill compliance using pharmacy records: Methods, validity, and applications. Journal of Clinical Epidemiology. Jan. 1997;50(1):105-16. X-2, X-4, X-5, X-6. [pmid: 9048695].
3660 Steinke EE, Mosack V, Wright DW, et al. Risk factors as predictors of sexual activity in heart failure. Dimens Crit Care Nurs. May-Jun. 2009;28(3):123-9. quiz 30-1. X-2, X-4. [pmid: 19387276].
3661 Stelger G, Samkoff J, Karoullas J. A program of interventions designed to increase mammography rates in women ages 50 years and older for an underserved racial minority. J Health Hum Serv Adm. Winter. 2003;26(3):336-49. X-7, X-9. [pmid: 15704637].
3662 Stephens MR, Gaskell AL, Gent C, et al. Prospective randomised clinical trial of providing patients with audiotape recordings of their oesophagogastric cancer consultations. Patient Educ Couns. Aug. 2008;72(2):218-22. X-4, X-5, X-6. [pmid: 18513915].
3663 Stephens TT, Braithwaite R, Cozza S. Knowledge of prophylaxis treatment therapy among HIV-positive prisoners. AIDS Care. Oct. 1999;11(5):547-54. X-2, X-4, X-5. [pmid: 10755030].
3664 Sterling YM, Peterson JW. Characteristics of African American women caregivers of children with asthma. MCN Am J Matern Child Nurs. Jan-Feb. 2003;28(1):32-8. X-2, X-4. [pmid: 12514354].
3665 Stern MP. Epidemiology of diabetes and coronary heart disease among Mexican-. Americans Trans Assoc Life Insur Med Dir Am. 1985;67:79-90. X-1, X-6, X-7, X-9. [pmid: 4071889].
3666 Stevens KA, Pavlides C. Individualized prenatal nursing care of pregnant adolescents makes a difference. J Obstet Gynecol Neonatal Nurs. Nov-Dec. 1989;18(6):521-2. X-6, X-9. [pmid: 2600690].
3667 Stevens PE, Tomson CR. Guidelines in the United kingdom and how they are used. Clin J Am Soc Nephrol. Dec. Suppl 1. 2009;4:S23-9. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19996002].
3668 Stevenson FA, Kerr C, Murray E, et al. Information from the Internet and the doctor-patient relationship: the patient perspective--a qualitative study. BMC Fam Pract. 2007;8:47. X-2, X-4. [pmid: 17705836].
3669 Stewart A, Rao J, Osho-Williams G, et al. Audit of primary care angina management in Sandwell, England. Journal of the Royal Society for the Promotion of Health. 2002;122(2):112-7. X-2, X-3, X-4. [pmid: 12134762].
3670 Steyn M, Steyn K. Media use and preference related to coronary heart disease of the coloured population of the Cape Peninsula. The CRISIC study. Curationis. Jul. 1989;12(1-2):22-5. X-2, X-4. [pmid: 2791169].
3671 Stiles PG, Boothroyd RA, Dhont K, et al. Adherence to practice guidelines, clinical outcomes, and costs among Medicaid enrollees with severe mental illnesses. Eval Health Prof. Mar. 2009;32(1):69-89. X-7, X-9. [pmid: 19164300].
3672 Stingone JA, Claudio L. Disparities in allergy testing and health outcomes among urban children with asthma. J Allergy Clin Immunol. Oct. 2008;122(4):748-53. X-2, X-4. [pmid: 19014766].
3673 Stingone JA, Claudio L. Components of recommended asthma care and the use of long-term control medication among urban children with asthma. Med Care. Sep. 2009;47(9):940-7. X-2, X-4. [pmid: 19704351].
3674 Stockdale SE, Lagomasino IT, Siddique J, et al. Racial and ethnic disparities in detection and treatment of depression and anxiety among psychiatric and primary health care visits, 1995-2005. Med Care. Jul. 2008;46(7):668-77. X-2, X-4. [pmid: 18580385].
3675 Stone MA, Patel N, Daly H, et al. Using qualitative research methods to inform the development of a modified version of a patient education module for non-English speakers with type 2 diabetes: experience from an action research project in two South Asian populations in the UK. Diversity in Health & Social Care. 2008;5(3):199-206. X-2, X-3, X-4.
3676 Stone MA, Patel N, Drake L, et al. Making education in diabetes culturally appropriate for patients. Practice Nursing. 2006;17(12):621-5. X-1, X-2, X-3, X-4.
3677 Stout JW, White LC, Rogers LT, et al. The Asthma Outreach Project: a promising approach to comprehensive asthma management. J Asthma. 1998;35(1):119-27. X-4. [pmid: 9513591].
3678 Strating MMH, van Duijn MAJ, van Schuur WH, et al. The differential effects of rheumatoid arthritis on distress among patients and partners. Psychology & Health. 2007;22(3):361-79. X-2, X-4, X-5, X-6.
3679 Stratton BF, Nicholson ME, Olsen LK, et al. Breast self-examination proficiency: attitudinal, demographic, and behavioral characteristics. Journal of Women's Health. 1994;3(3):185-95. X-2, X-4, X-6.
3680 Straube BM. Commentary. The imperatives for change in the US health care payment and delivery systems are clear. Adv Chronic Kidney Dis. Jan. 2008;15(1):7-9. X-1, X-2, X-4. [pmid: 18155103].
3681 Street RL, Slee C, Kalauokalani DK, et al. Improving physician-patient communication about cancer pain with a tailored education-coaching intervention. Patient Education and Counseling. Jul. 2010;80(1):42-7. X-6, X-9. [pmid: 19962845].
3682 Street RL Jr., Van Order A, Bramson R, et al. Preconsultation education promoting breast cancer screening: does the choice of media make a difference?. J Cancer Educ. Fall. 1998;13(3):152-61. X-6, X-7, X-9. [pmid: 10898560].
3683 Street RL Jr., Voigt B, Geyer C Jr., et al. Increasing patient involvement in choosing treatment for early breast cancer. Cancer. Dec. 1. 1995;76(11):2275-85. X-4. [pmid: 8635032].
3684 Stroebe W, Abakoumkin G, Stroebe M. Beyond depression: yearning for the loss of a loved one. Omega: Journal of Death & Dying. 2010;61(2):85-101. X-2, X-4, X-5, X-6.
3685 Stroebel RJ, Gloor B, Freytag S, et al. Adapting the chronic care model to treat chronic illness at a free medical clinic. J Health Care Poor Underserved. May. 2005;16(2):286-96. X-6, X-7, X-9. [pmid: 15937392].
3686 Strom CM. Population-based carrier screening and prenatal diagnosis. MLO Med Lab Obs. Aug. 2004;36(8):12-7. quiz 20-1. X-1, X-6, X-7, X-9. [pmid: 15366363].
3687 Strom JL, Lynch CP, Egede LE. Rural/urban variations in diabetes self-care and quality of care in a national sample of US adults with diabetes. The Diabetes Educator. Mar-Apr. 2011;37(2):254-62. X-2, X-6. [pmid: 21289298].
3688 Strong M, Maheswaran R, Radford J. Socioeconomic deprivation, coronary heart disease prevalence and quality of care: a practice-level analysis in Rotherham using data from the new UK general practitioner Quality and Outcomes Framework. J Public Health (Oxf). Mar. 2006;28(1):39-42. X-2, X-3. [pmid: 16436452].
3689 Strulov A. The Western Galilee experience: reducing infant mortality in the Arab population. Isr Med Assoc J. Aug. 2005;7(8):483-6. X-2, X-3, X-4, X-5. [pmid: 16106770].
3690 Stryker JE, Emmons KM, Viswanath K. Uncovering differences across the cancer control continuum: a comparison of ethnic and mainstream cancer newspaper stories. Prev Med. Jan. 2007;44(1):20-5. X-2, X-4, X-6. [pmid: 16949141].
3691 Stuart B, Singhal PK, Magder LS, et al. How robust are health plan quality indicators to data loss? A Monte Carlo simulation study of pediatric asthma treatment. Health Serv Res. Dec. 2003;38(6 Pt 1):1547-61. X-2, X-4. [pmid: 14727787].
3692 Stuart GW, Laraia MT, Ornstein SM, et al. An interactive voice response system to enhance antidepressant medication compliance. Top Health Inf Manage. Jan-Mar. 2003;24(1):15-20. X-6, X-9. [pmid: 12674391].
3693 Su Y, Songwathana P, Naka K. Factor related to self-care among Chinese women with mastectomy in Beijing. Thai Journal of Nursing Research. 2006;10(4):252-63. X-2, X-3, X-4, X-6.
3694 Suarez L, Roche RA, Pulley LV, et al. Why a peer intervention program for Mexican-American women failed to modify the secular trend in cancer screening. Am J Prev Med. Nov-Dec. 1997;13(6):411-7. X-8, X-9. [pmid: 9415784].
3695 Subramanian K. The nature of social work services in a large public medical center serving an impoverished multicultural population. Soc Work Health Care. 2000;31(2):47-63. X-2, X-4, X-5. [pmid: 11081854].
3696 Subratty AH, Anathallee Y, Jowaheer V, et al. Quality of life of people with type 2 diabetes in Mauritius. Diabetes & Primary Care. 2003;5(4):183-6. X-2, X-4.
3697 Sudano JJ Jr., Baker DW. Antihypertensive medication use in Hispanic adults: a comparison with black adults and white adults. Med Care. Jun. 2001;39(6):575-87. X-2, X-4. [pmid: 11414262].
3698 Sudarsan NR, Jandorf L, Erwin DO. Multi-site implementation of health education programs for Latinas. J Community Health. Apr. 2011;36(2):193-203. X-7, X-9, X-10. [pmid: 20652382].
3699 Sudore RL, Landefeld CS, Perez-Stable EJ, et al. Unraveling the relationship between literacy, language proficiency, and patient-physician communication. Patient Education and Counseling. Jun. 2009;75(3):398-402. X-2, X-5. [pmid: 19442478].
3700 Sudore RL, Mehta KM, Simonsick EM, et al. Limited literacy in older people and disparities in health and healthcare access. Journal of the American Geriatrics Society. May. 2006;54(5):770-6. X-2, X-4. [pmid: 16696742].
3701 3702. Sukel MP, van de Poll-Franse LV, Nieuwenhuijzen GA, et al. Substantial increase in the use of adjuvant systemic treatment for early stage breast cancer reflects changes in guidelines in the period 1990-2006 in the southeastern Netherlands. Eur J Cancer. Sep. 2008;44(13):1846-54. X-2, X-3, X-6, X-7. [pmid: 18640030].
3702 Sulik GA. The balancing act: Care work for the self and coping with breast cancer. Gender & Society. Dec. 2007;21(6):857-77. X-2, X-4, X-6.
3703 Sullivan JD. The changing tide in ESRD care. Nephrol News Issues. Jul. 2010;24(8):247-8. X-1, X-6, X-7, X-9. [pmid: 20695319].
3704 Sullivan LM, Dukes KA, Harris L, et al. A COMPARISON OF VARIOUS METHODS OF COLLECTING SELF-REPORTED HEALTH OUTCOMES DATA AMONG LOW-INCOME AND MINORITY PATIENTS. Medical Care. Apr. 1995;33(4):AS183-AS94. X-2, X-7. [pmid: 7723446].
3705 Sullivan LV, Hicks P, Salazar G, et al. Patient beliefs and sense of control among Spanish-speaking patients with diabetes in northeast Colorado. Journal of Immigrant and Minority Health. Jun. 2010;12(3):384-9. X-2, X-4. [pmid: 19266283].
3706 Sullivan SD, Weiss KB, Lynn H, et al. The cost-effectiveness of an inner-city asthma intervention for children. J Allergy Clin Immunol. Oct. 2002;110(4):576-81. X-6, X-9. [pmid: 12373264].
3707 Sullivan-Bolyai S. Familias Apoyadas: Latino families supporting each other for diabetes care. J Pediatr Nurs. Dec. 2009;24(6):495-505. X-2, X-4. [pmid: 19931147].
3708 Sun P, Unger JB, Palmer PH, et al. Internet accessibility and usage among urban adolescents in Southern California: implications for web-based health research. Cyberpsychol Behav. Oct. 2005;8(5):441-53. X-2, X-4, X-5. [pmid: 16232037].
3709 Sundock J. Second phase of interim final regulations to Stark law clarifies issues for dialysis providers. Nephrol News Issues. May. 2004;18(6):47. X-1, X-2, X-3, X-4, X-6. [pmid: 15160421].
3710 Sung JF, Alema-Mensah E, Blumenthal DS. Inner-city African American women who failed to receive cancer screening following a culturally-appropriate intervention: the role of health insurance. Cancer Detect Prev. 2002;26(1):28-32. X-9. [pmid: 12088200].
3711 Sung JF, Blumenthal DS, Coates RJ, et al. Effect of a cancer screening intervention conducted by lay health workers among inner-city women. Am J Prev Med. Jan-Feb. 1997;13(1):51-7. X-9. [pmid: 9037342].
3712 Sung JF, Coates RJ, Williams JE, et al. Cancer screening intervention among black women in inner-city Atlanta--design of a study. Public Health Rep. Jul-Aug. 1992;107(4):381-8. X-9. [pmid: 1641433].
3713 Sunseri AJ, Alberti JM, Kent ND, et al. Reading, demographic, social and psychological factors related to pre-adolescent smoking and non-smoking behaviors and attitudes. J Sch Health. Apr. 1983;53(4):257-63. X-2, X-4, X-5. [pmid: 6552341].
3714 Sunsoa H. South Asian people with type 2 diabetes: a tool to assess learning. Diversity in Health & Social Care. 2008;5(1):43-53. X-2, X-3, X-4, X-6.
3715 Sutton D, Hollingdale R, Hart K. Questionnaire to evaluate and elucidate patients' perceptions of renal dietary advice. J Ren Care. Sep. 2008;34(3):143-50. X-2, X-4. [pmid: 18786081].
3716 Sutton DR, Taylor P, Earle K. Evaluation of PROforma as a language for implementing medical guidelines in a practical context. BMC Med Inform Decis Mak. 2006;6:20. X-2, X-4, X-6. [pmid: 16597341].
3717 Suwanno J, Petpichetchian W, Riegel B, et al. A model predicting health status of patients with heart failure. J Cardiovasc Nurs. Mar-Apr. 2009;24(2):118-26. X-2, X-3, X-4. [pmid: 19242277].
3718 Suwisith N, Hanucharurnkul S. An integrative review of breast cancer nursing studies in Thailand. Thai Journal of Nursing Research. 2006. Jan-Mar. 2006;10(1):1-17. X-1, X-2, X-3, X-4, X-6.
3719 Svensson J, Johannesen J, Mortensen HB, et al. Improved metabolic outcome in a Danish diabetic paediatric population aged 0-18 yr: results from a nationwide continuous Registration. Pediatr Diabetes. Nov. 2009;10(7):461-7. X-2, X-3, X-4. [pmid: 19175901].
3720 Svetkey LP, Erlinger TP, Vollmer WM, et al. Effect of lifestyle modifications on blood pressure by race, sex, hypertension status, and age. J Hum Hypertens. Jan. 2005;19(1):21-31. X-7. [pmid: 15385946].
3721 Svetkey LP, Simons-Morton D, Vollmer WM, et al. Effects of dietary patterns on blood pressure: subgroup analysis of the Dietary Approaches to Stop Hypertension (DASH) randomized clinical trial. Arch Intern Med. Feb. 8. 1999;159(3):285-93. X-7, X-9. [pmid: 9989541].
3722 Swami V, Loo P-W, Furnham A. Public knowledge and beliefs about depression among urban and rural Malays in Malaysia. International Journal of Social Psychiatry. Sep. 2010;56(5):480-96. X-2, X-3, X-4, X-6. [pmid: 19651692].
3723 Swan J, Breen N, Coates RJ, et al. Progress in cancer screening practices in the United States: results from the 2000 National Health Interview Survey. Cancer. Mar. 15. 2003;97(6):1528-40. X-2, X-4. [pmid: 12627518].
3724 Sweet L. Birth of a very low birth weight preterm infant and the intention to breastfeed ‘naturally’. Women Birth. Mar. 2008;21(1):13-20. X-2, X-3, X-4, X-5, X-6. [pmid: 18162451].
3725 Swenson SL, Rose M, Vittinghoff E, et al. The influence of depressive symptoms on clinician-patient communication among patients with type 2 diabetes. Medical Care. Mar. 2008;46(3):257-65. X-2, X-4. [pmid: 18388840].
3726 Swider SM, Martin M, Lynas C, et al. Project MATCH: training for a promotora intervention. Diabetes Educ. Jan-Feb. 2010;36(1):98-108. X-6, X-7, X-9. [pmid: 20008279].
3727 Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. Apr. 2001;24(4):619-24. X-6, X-7, X-9. [pmid: 11315819].
3728 Sword W, Watt S, Krueger P. Postpartum health, service needs, and access to care experiences of immigrant and Canadian-born women. J Obstet Gynecol Neonatal Nurs. Nov-Dec. 2006;35(6):717-27. X-2, X-3, X-4, X-5. [pmid: 17105636].
3729 Swords L, Hennessy E, Heary C. Adolescents' beliefs about sources of help for ADHD and depression. J Adolesc. Jun. 2011;34(3):485-92. X-2, X-4. [pmid: 20598740].
3730 Sykes DH, Hanley M, Boyle DM, et al. Work strain and the post-discharge adjustment of patients following a heart attack. Psychology & Health. 2000;15(5):609-23. X-3, X-6, X-7, X-9.
3731 Sylvia BM, McMullen P, Levine E, et al. Prenatal care needs, availability, accessibility, use, and satisfaction: A comparison of military women within and outside the continental United States. Military Medicine. May. 2001;166(5):443-8. X-2, X-3, X-4, X-6. [pmid: 11370210].
3732 Szilagyi PG, Bordley C, Vann JC, et al. Effect of patient reminder/recall interventions on immunization rates: A review. JAMA. Oct. 11. 2000;284(14):1820-7. X-1, X-2, X-4. [pmid: 11025835].
3733 Szilagyi PG, Holl JL, Rodewald LE, et al. Evaluation of New York State's Child Health Plus: children who have asthma. Pediatrics. Mar. 2000;105(3 Suppl E):719-27. X-7, X-9. [pmid: 10699150].
3734 Szilagyi PG, Shone LP, Holl JL, et al. Evaluation of New York State's Child Health Plus: methods. Pediatrics. Mar. 2000;105(3 Suppl E):697-705. X-6, X-7, X-9. [pmid: 10699147].
3735 Szromba C. Palliative care in patients with CKD. Nephrol Nurs J. Sep-Oct. 2007;34(5):551-2. X-1, X-6, X-7, X-9. [pmid: 18041458].
3736 Szwajcer A, Hannan R, Donoghue J, et al. Evaluating key dimensions of the breast care nurse role in Australia. Cancer Nurs. Jan-Feb. 2004;27(1):79-84. X-2, X-3, X-4. [pmid: 15108955].
3737 Taggart M. The attitudes and activities of registered nurses towards health promotion and patient education in the emergency department. NENA Outlook. 2009;32(1):15-9. X-2, X-3, X-4, X-5, X-6.
3738 Taggart VS, Bush PJ, Zuckerman AE, et al. A process evaluation of the District of Columbia “Know Your Body”. project. J Sch Health. Feb. 1990;60(2):60-6. X-4, X-6, X-7, X-8, X-9, X-10.
3739 Tahirovic H, Toromanovic A. Glycemic control in diabetic children: role of mother's knowledge and socioeconomic status. Eur J Pediatr. Aug. 2010;169(8):961-4. X-2, X-3, X-4. [pmid: 20169449].
3740 Taiwo JO. Oral health education needs of diabetic patients in Ibadan. Afr J Med Med Sci. Sep-Dec. 2000;29(3-4):269-74. X-2, X-3, X-4, X-6. [pmid: 11714004].
3741 Takahashi M, Ohno S, Inoue H, et al. Impact of breast cancer diagnosis and treatment on women's sexuality: a survey of Japanese patients. Psychooncology. Sep. 2008;17(9):901-7. X-2, X-3, X-4, X-6. [pmid: 18074406].
3742 Tak-Ying Shiu A, Kwan JJ, Wong RY. Social stigma as a barrier to diabetes self-management: implications for multi-level interventions. J Clin Nurs. Jan. 2003;12(1):149-50. X-1, X-2, X-4. [pmid: 12519263].
3743 Tan JT, Bagnell M, Morgan JW, et al. The identification and treatment of isolated tumor cells reflect disparities in the delivery of breast cancer care. Am J Surg. Oct. 2009;198(4):508-10. X-2, X-4. [pmid: 19800457].
3744 Tan MY, Magarey J. Self-care practices of Malaysian adults with diabetes and suboptimal glycaemic control. Patient Educ Couns. Aug. 2008;72(2):252-67. X-2, X-3, X-4, X-6. [pmid: 18467068].
3745 Tan NC, Chow MH, Goh P, et al. Primary care doctors' practice in the management of adult asthma patients. Singapore Med J. Feb. 2002;43(2):061-6. X-2, X-3, X-4, X-6. [pmid: 11993891].
3746 Tan NC, Khin LW, Pagi R. Home blood-pressure monitoring among hypertensive patients in an Asian population. J Hum Hypertens. Jul. 2005;19(7):559-64. X-2, X-3, X-4. [pmid: 15944723].
3747 T'Ang J, Chan C, Chan NF, et al. A survey of elderly diabetic patients attending a community clinic in Hong Kong. Patient Educ Couns. Mar. 1999;36(3):259-70. X-2, X-3, X-4, X-6. [pmid: 14528561].
3748 Tang TS, Brown MB, Funnell MM, et al. Social support, quality of life, and self-care behaviors among African Americans with type 2 diabetes. The Diabetes Educator. Mar-Apr. 2008;34(2):266-76. X-2, X-4. [pmid: 18375776].
3749 Tang TS, Funnell MM, Brown MB, et al. Self-management support in “real-world” settings: an empowerment-based intervention. Patient Educ Couns. May. 2010;79(2):178-84. X-4, X-9. [pmid: 19889508].
3750 Tang TS, Gillard ML, Funnell MM, et al. Developing a new generation of ongoing: Diabetes self-management support interventions: a preliminary report. Diabetes Educ. Jan-Feb. 2005;31(1):91-7. X-4, X-9. [pmid: 15779250].
3751 Tang TS, Stansfield RB, Oh M, et al. Patient-provider perceptions of diabetes and its impact on self-management: a comparison of African-American and White patients. Diabet Med. Mar. 2008;25(3):341-8. X-2, X-4. [pmid: 18307461].
3752 Tang YH, Pang SM, Chan MF, et al. Health literacy, complication awareness, and diabetic control in patients with type 2 diabetes mellitus. J Adv Nurs. Apr. 2008;62(1):74-83. X-2, X-3, X-4. [pmid: 18352966].
3753 Tangri N, Moorthi R, Tighiouhart H, et al. Variation in fistula use across dialysis facilities: is it explained by case-mix?. Clin J Am Soc Nephrol. Feb. 2010;5(2):307-13. X-2, X-4, X-6. [pmid: 20056763].
3754 Tanihara S, Ojima T, Nakamura Y, et al. Association between health-related knowledge and the awareness of blood pressure readings. Japan Lifestyle Monitoring Study Group. J Epidemiol. Aug. 1999;9(4):245-53. X-2, X-3, X-4. [pmid: 10510582].
3755 Tanjasiri SP, Sablan-Santos L, Merrill V, et al. Promoting breast cancer screening among Chamorro women in Southern California. Journal of Cancer Education. Jan. 2008;23(1):10-7. X-6, X-9. [pmid: 18444041].
3756 Tanjasiri SP, Tran JH, Kagawa-Singer M, et al. Exploring access to cancer control services for Asian-American and Pacific Islander communities in Southern California. Ethn Dis. Summer. 2004;14(3 Suppl 1):S14-9. X-2, X-4. [pmid: 15682767].
3757 Tanjasiri SP, Tran JH, Palmer PH, et al. Network analysis of an organizational collaboration for Pacific Islander cancer control. J Health Care Poor Underserved. Nov. 2007;18(4 Suppl):184-96. X-2, X-4, X-5. [pmid: 18065859].
3758 Tao LS, Hart P, Edwards E, et al. Treatment of difficult-to-control blood pressure in a multidisciplinary clinic at a public hospital. J Natl Med Assoc. Apr. 2003;95(4):263-9. X-6. [pmid: 12749616].
3759 Taplin SH, Haggstrom D, Jacobs T, et al. Implementing colorectal cancer screening in community health centers: addressing cancer health disparities through a regional cancer collaborative. Med Care. Sep. 2008;46(9 Suppl 1):S74-83. X-6, X-9, X-11. [pmid: 18725837].
3760 Taplin SH, Ichikawa L, Buist DS, et al. Evaluating organized breast cancer screening implementation: the prevention of late-stage disease?. Cancer Epidemiol Biomarkers Prev. Feb. 2004;13(2):225-34. X-2, X-4, X-6. [pmid: 14973097].
3761 Tara S, Agrawal CS, Agrawal A. Validating breast self examination as screening modalities for breast cancer in eastern region of Nepal: a population based study. Kathmandu Univ Med J (KUMJ). Jan-Mar. 2008;6(1):89-93. X-2, X-3. [pmid: 18604121].
3762 Tatis V, Remache D, DiMango E. Results of a culturally directed asthma intervention program in an inner-city Latino community. Chest. Sep. 2005;128(3):1163-7. X-4, X-9. [pmid: 16162702].
3763 Tatum C, Wilson A, Dignan M, et al. Development and implementation of outreach strategies for breast and cervical cancer prevention among African American women. FoCaS Project Forsyth County Cancer Screening J Cancer Educ. Spring. 1997;12(1):43-50. X-4, X-9, X-10. [pmid: 9095440].
3764 Tavris D, Shoaibi A, Chen AY, et al. Gender differences in the treatment of non-ST-segment elevation myocardial infarction. Clin Cardiol. Feb. 2010;33(2):99-103. X-2. [pmid: 20186991].
3765 Taylor JY, Washington OGM, Artinian NT, et al. Urban hypertensive African American grandparents: stress, health, and implications of child care. Clinical Gerontologist. 2007;30(4):39-54. X-2, X-4. [pmid: 20514351].
3766 Taylor V, Thompson B, Lessler D, et al. A clinic-based mammography intervention targeting inner-city women. J Gen Intern Med. Feb. 1999;14(2):104-11. X-6, X-9. [pmid: 10051781].
3767 Taylor VM, Nguyen TT, Jackson JC, et al. Cervical Cancer Control Research in Vietnamese American Communities. Cancer Epidemiology Biomarkers & Prevention. Nov. 2008;17(11):2924-30. X-1, X-2, X-4, X-5. [pmid: 18990732].
3768 Tedesco MA, Di Salvo G, Caputo S, et al. Educational level and hypertension: how socioeconomic differences condition health care. J Hum Hypertens. Oct. 2001;15(10):727-31. X-2, X-3, X-4, X-6. [pmid: 11607804].
3769 Tejeda S, Thompson B, Coronado GD, et al. Celebremos la Salud: a community-based intervention for Hispanic and non-Hispanic white women living in a rural area. J Community Health. Feb. 2009;34(1):47-55. X-9, X-10. [pmid: 18821000].
3770 Telonidis JS, Lund DA, Caserta MS, et al. The effects of widowhood on disabled older women (the Women's Health and Aging Study). Omega: Journal of Death & Dying. 2004;50(3):217-35. X-2, X-5, X-6.
3771 TenHave TR, VanHorn B, Kumanyika S, et al. Literacy assessment in a cardiovascular nutrition education setting. Patient Education and Counseling. Jun. 1997;31(2):139-50. X-2, X-4. [pmid: 9216355].
3772 Teti DM, Black MM, Viscardi R, et al. Intervention with African American premature infants: four-month results of an early intervention program. Journal of Early Intervention. 2009;31(2):146-66. X-5.
3773 Thackeray R, Merrill RM, Neiger BL. Disparities in diabetes management practice between racial and ethnic groups in the United States. Diabetes Educ. Jul-Aug. 2004;30(4):665-75. X-2, X-4. [pmid: 15669782].
3774 Thamer M, Ray NF, Richard C, et al. Excluded from universal coverage: ESRD patients not covered by Medicare. Health Care Financ Rev. Winter. 1995;17(2):123-46. X-1, X-2, X-4, X-6. [pmid: 10157372].
3775 Thanasilp S, Rujkorakarn D, Hanucharunkul S, et al. Effectiveness of a symptom management program on symptom status and quality of life among persons with pneumocystis carinii pneumonia. Thai Journal of Nursing Research. 2002;6(2):1-10. X-3, X-4, X-5, X-6.
3776 Theisen V, Duquette D, Kardia S, et al. Blood Pressure Sunday: introducing genomics to the community through family history. Prev Chronic Dis. Apr. 2005;2(2):A23. X-4, X-8, X-9, X-10. [pmid: 15888234].
3777 Thind A, Hoq L, Diamant A, et al. Satisfaction with care among low-income women with breast cancer. Journal of Women's Health. Jan. 2010;19(1):77-86. X-2, X-4. [pmid: 20088662].
3778 Thom DH, Tirado MD, Woon TL, et al. Development and evaluation of a cultural competency training curriculum. BMC Med Educ. 2006;6:38. X-7, X-9. [pmid: 16872504].
3779 Thomas B, Stamler LL, Lafreniere KD, et al. Breast health educational interventions. Changes in beliefs and practices of working women. AAOHN J. Oct. 2002;50(10):460-7. X-4, X-6. [pmid: 12400230].
3780 Thomas EA. Diabetes at work: a grounded-theory pilot study. AAOHN J. May. 2011;59(5):213-20. X-2, X-4. [pmid: 21534493].
3781 Thomas KL, Hernandez AF, Dai D, et al. Association of race/ethnicity with clinical risk factors, quality of care, and acute outcomes in patients hospitalized with heart failure. Am Heart J. Apr. 2011;161(4):746-54. X-6, X-7, X-9. [pmid: 21473975].
3782 Thomas LA, Supiano KP, Chasco EE, et al. Smoking cessation programs for seniors: a group model that works. Clinical Gerontologist. 2009;32(1):118-25. X-4, X-5, X-6.
3783 Thomas PD, Miceli R. Evaluation of the “Know Your Health” program for type 2 diabetes mellitus and hypertension in a large employer group. Am J Manag Care. Dec. 2006;12(Spec no.):SP33-9. X-6. [pmid: 17173490].
3784 Thomas SB, Sansing VV, Davis A, et al. Racial differences in the association between self-rated health status and objective clinical measures among participants in the BARI 2D trial… Bypass Angioplasty Revascularization Investigation 2 Diabetes. American Journal of Public Health. 2010;100(S1):S269-76. X-2. [pmid: 20147671].
3785 Thombs BD, Arthurs E, El-Baalbaki G, et al. Risk of bias from inclusion of patients who already have diagnosis of or are undergoing treatment for depression in diagnostic accuracy studies of screening tools for depression: systematic review. British Medical Journal. Aug. 2011:343. X-1, X-2, X-4, X-6. [pmid: 21852353].
3786 Thompson AL, Collins MA, Downey MC, et al. Prevalence and severity of hypertension in a dental hygiene clinic. J Contemp Dent Pract. 2007;8(3):13-20. X-2, X-4, X-6. [pmid: 17351677].
3787 Thompson BL, O'Connor P, Boyle R, et al. Measuring clinical performance: comparison and validity of telephone survey and administrative data. Health Serv Res. Aug. 2001;36(4):813-25. X-2, X-4, X-6. [pmid: 11508641].
3788 Thompson DR, Cordle CJ. Support of wives of myocardial infarction patients. J Adv Nurs. Mar. 1988;13(2):223-8. X-2, X-4, X-6. [pmid: 3372897].
3789 Thompson DR, Meddis R. Wives' responses to counselling early after myocardial infarction. J Psychosom Res. 1990;34(3):249-58. X-4, X-6. [pmid: 2341994].
3790 Thompson HS, Edwards T, Erwin DO, et al. Training lay health workers to promote post-treatment breast cancer surveillance in African American breast cancer survivors: development and implementation of a curriculum. J Cancer Educ. 2009;24(4):267-74. X-2, X-3, X-4. [pmid: 19838883].
3791 Thompson HS, Wahl E, Fatone A, et al. Enhancing the readability of materials describing genetic risk for breast cancer. Cancer Control. Jul-Aug. 2004;11(4):245-53. X-2, X-4, X-6. [pmid: 15284716].
3792 Thompson JR, Horton C, Flores C. Advancing diabetes self-management in the Mexican American population: a community health worker model in a primary care setting. Diabetes Educ. Jun. Suppl 6. 2007;33:159S-65S. X-4, X-9. [pmid: 17620396].
3793 Thompson VL, Kalesan B, Wells A, et al. Comparing the use of evidence and culture in targeted colorectal cancer communication for African Americans. Patient Educ Couns. Dec. 2010;81(Suppl):S22-33. X-9. [pmid: 20702056].
3794 Thompson VLS, Cavazos-Rehg P, Tate KY, et al. Cancer information seeking among African Americans. Journal of Cancer Education. Apr-Jun. 2008;23(2):92-101. X-2, X-4. [pmid: 18569244].
3795 Thompson W, Wang H, Xie M, et al. Assessing Quality of Diabetes Care by Measuring Longitudinal Changes in Hemoglobin A1c in the Veterans Health Administration. Health Services Research. Dec. 2005;40(6,part1):1818-35. X-2, X-4, X-6. [pmid: 16336550].
3796 Thomson MD, Hoffman-Goetz L. Cancer information comprehension by English-as-a-second-language immigrant women. J Health Commun. Jan. 2011;16(1):17-33. X-2, X-3, X-4. [pmid: 21120740].
3797 Thongsuksai P, Chongsuvivatwong V. Sriplung H. Delay in breast cancer care: a study in Thai women. Med Care. Jan. 2000;38(1):108-14. X-2, X-3, X-4, X-6. [pmid: 10630725].
3798 Thoolen B, de Ridder D, Bensing J, et al. Beyond Good Intentions: the development and evaluation of a proactive self-management course for patients recently diagnosed with type 2 diabetes. Health Educ Res. Feb. 2008;23(1):53-61. X-6. [pmid: 17289660].
3799 Thoolen B, De Ridder D, Bensing J, et al. Effectiveness of a self-management intervention in patients with screen-detected type 2 diabetes. Diabetes Care. Nov. 2007;30(11):2832-7. X-6. [pmid: 17666461].
3800 Thoonen BP, Schermer TR, Akkermans RP, et al. Willingness of patients to perform self-management of asthma and the role of inhaled steroids. Scand J Prim Health Care. Mar. 2002;20(1):60-4. X-9, X-10. [pmid: 12086288].
3801 Thornhill-Joynes M, Moore M. Minorities and ESRD. Early identification of renal disease among African-Americans: a continuing problem. Nephrol News Issues. Nov. 1995;9(11):16-8. X-1, X-2, X-4. [pmid: 8538798].
3802 Thorup OA Jr., Bodkin CJ, Pinkerton JV, et al. Medical Center Hour: teenage pregnancy. Va Med. Feb. 1988;115(2):71-5. X-13. [pmid: 3348052].
3803 Thrasher JF, Cummings KM, Michalek AM, et al. Colorectal cancer screening among individuals with and without a family history. J Public Health Manag Pract. Mar. 2002;8(2):1-9. X-2, X-6. [pmid: 11889847].
3804 Thuler LC, Freitas HG. Evaluation of a community-based intervention to enhance breast cancer screening practices in Brazil. J Eval Clin Pract. Dec. 2008;14(6):1012-7. X-3, X-4, X-6. [pmid: 18759754].
3805 Thyne SM, Rising JP, Legion V, et al. The Yes We Can Urban Asthma Partnership: a medical/social model for childhood asthma management. J Asthma. Nov. 2006;43(9):667-73. X-6, X-7, X-9. [pmid: 17092847].
3806 Tiddens HA. Introduction: striving for excellence: optimising CF patient care today. J Cyst Fibros. Jun. Suppl 1. 2009;8:S1. X-1, X-2, X-3, X-4, X-6. [pmid: 19460680].
3807 Tiernan J, Briggs CD, Irving GR, et al. Evaluation of the introduction of a standardised protocol for the staging and follow-up of colorectal cancer on resection rates for liver metastases. Ann R Coll Surg Engl. Apr. 2010;92(3):225-30. X-2, X-3, X-4, X-6. [pmid: 20223052].
3808 Tieu Y, Konnert C, Wang J. Depression literacy among older Chinese immigrants in Canada: a comparison with a population-based survey. Int Psychogeriatr. Dec. 2010;22(8):1318-26. X-2, X-3, X-4. [pmid: 20813076].
3809 Tighe M, Molassiotis A, Morris J, et al. Coping, meaning and symptom experience: a narrative approach to the overwhelming impacts of breast cancer in the first year following diagnosis. Eur J Oncol Nurs. Jul. 2011;15(3):226-32. X-2, X-3, X-4, X-6. [pmid: 21511530].
3810 Tilbury F. Ethical dilemmas: principles and practice in research with African refugees. Monash Bioeth Rev. Jan. 2006;25(1):75-84. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 16832950].
3811 Tillmann V, Adojaan B, Shor R, et al. Physical development in Estonian children with type 1 diabetes. Diabet Med. Jan. 1996;13(1):97-101. X-2, X-3, X-4. [pmid: 8741820].
3812 Tinkelman DG, McClure DL, Lehr TL, et al. Relationships between self-reported asthma utilization and patient characteristics. J Asthma. Dec. 2002;39(8):729-36. X-2, X-4. [pmid: 12507193].
3813 Tjia J, Briesacher BA. Prescription drug benefits and use of guideline recommended medications by elderly Medicare beneficiaries with diabetes mellitus. J Am Geriatr Soc. Oct. 2008;56(10):1879-86. X-2, X-4, X-6. [pmid: 18771456].
3814 Tluczek A, Orland KM, Nick SW, et al. Newborn screening: an appeal for improved parent education. J Perinat Neonatal Nurs. Oct-Dec. 2009;23(4):326-34. X-2, X-4, X-5, X-6. [pmid: 19915416].
3815 To T, Wang C, Dell S, et al. Risk factors for repeat adverse asthma events in children after visiting an emergency department. Ambul Pediatr. Sep-Oct. 2008;8(5):281-7. X-2, X-3, X-4. [pmid: 18922500].
3816 Tobe SW, Pylypchuk G, Wentworth J, et al. Effect of nurse-directed hypertension treatment among First Nations people with existing hypertension and diabetes mellitus: the Diabetes Risk Evaluation and Microalbuminuria (DREAM 3) randomized controlled trial. CMA J. Apr. 25. 2006;174(9):1267-71. X-7, X-9. [pmid: 16595786].
3817 Tobin CT. Highlights from the salary survey of diabetes educators 2008. Diabetes Educ. Nov-Dec. 2009;35(6):931-3. X-1, X-2, X-3, X-4, X-6. [pmid: 19915090].
3818 Tod AM, Read C, Lacey A, et al. Barriers to uptake of services for coronary heart disease: qualitative study. BMJ. Jul. 28. 2001;323(7306):214. X-2, X-3, X-4, X-6. [pmid: 11473916].
3819 Todd L, Harvey E, Hoffman-Goetz L. Predicting breast and colon cancer screening among English-as-a-second-language older Chinese immigrant women to Canada. J Cancer Educ. Mar. 2011;26(1):161-9. X-2, X-3, X-4. [pmid: 20625870].
3820 Todd L, Hoffman-Goetz L. Predicting health literacy among English-as-a-second-Language older Chinese immigrant women to Canada: comprehension of colon cancer prevention information. J Cancer Educ. Jun. 2011;26(2):326-32. X-2, X-3, X-4. [pmid: 20852979].
3821 Tokkaya S, Karayurt O. Adaptation of the Information and Support Needs Questionnaire into Turkish to use in women with primary relatives with breast cancer. Cancer Nurs. Mar-Apr. 2010;33(2):119-26. X-2, X-3, X-4, X-6. [pmid: 20142747].
3822 Tomio J, Toyokawa S, Tanihara S, et al. Quality of care for diabetes patients using National Health Insurance claims data in Japan. Journal of Evaluation in Clinical Practice. Dec. 2010;16(6):1164-9. X-2, X-3, X-4, X-6. [pmid: 20698921].
3823 Toobert DJ, Strycker LA, Barrera M Jr., et al. Outcomes from a multiple risk factor diabetes self-management trial for Latinas: inverted exclamation markViva Bien!. Ann Behav Med. Jun. 2011;41(3):310-23. X-9. [pmid: 21213091].
3824 Toobert DJ, Strycker LA, Glasgow RE, et al. If you build it, will they come? Reach and Adoption associated with a comprehensive lifestyle management program for women with type 2 diabetes. Patient Education and Counseling. Oct-Nov. 2002;48(2):99-105. X-1, X-2, X-4, X-6. [pmid: 12401412].
3825 Toussaint C. Socioeconomic problems of chronic renal failure: general conclusions. Contrib Nephrol. 1989;71:172-7. X-1, X-2, X-6. [pmid: 2805697].
3826 Trapp M, Barton S, Morgan H, et al. Self-administration of drugs for cystic fibrosis. Prof Nurse. Dec. 1998;14(3):199-203. X-1, X-2, X-4, X-6. [pmid: 10095691].
3827 Tregonning PB, Simmons D, Fleming C. A community diabetes educator course for the unemployed in South Auckland, New Zealand. Diabetes Educ. Jan-Feb. 2001;27(1):94-100. X-3, X-4, X-6. [pmid: 11912620].
3828 Trento M, Passera P, Bajardi M, et al. Lifestyle intervention by group care prevents deterioration of Type II diabetes: a 4-year randomized controlled clinical trial. Diabetologia. Sep. 2002;45(9):1231-9. X-3, X-4, X-6. [pmid: 12242455].
3829 Trento M, Passera P, Tomalino M, et al. Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care. Jun. 2001;24(6):995-1000. X-6. [pmid: 11375359].
3830 Trento M, Trinetta A, Kucich C, et al. Carbohydrate counting improves coping ability and metabolic control in patients with Type 1 diabetes managed by Group Care. J Endocrinol Invest. Feb. 2011;34(2):101-5. X-4. [pmid: 20440106].
3831 Trevena LJ, Irwig L, Barratt A. Randomized trial of a self-administered decision aid for colorectal cancer screening. J Med Screen. 2008;15(2):76-82. X-3, X-6, X-7, X-9, X-10. [pmid: 18573775].
3832 Trevino RP, Pugh JA, Hernandez AE, et al. Bienestar: a diabetes risk-factor prevention program. J Sch Health. Feb. 1998;68(2):62-7. X-5, X-9. [pmid: 9571575].
3833 Trief PM, Morin PC, Izquierdo J, et al. Marital quality and diabetes outcomes: the IDEATel Project. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2006;24(3):318-31. X-2, X-6.
3834 Trief PM, Ploutz-Snyder R, Britton KD, et al. The relationship between marital quality and adherence to the diabetes care regimen. Ann Behav Med. Jun. 2004;27(3):148-54. X-2, X-4, X-6. [pmid: 15184090].
3835 Trinacty CM, Adams AS, Soumerai SB, et al. Racial differences in long-term self-monitoring practice among newly drug-treated diabetes patients in an HMO. J Gen Intern Med. Nov. 2007;22(11):1506-13. X-2, X-4. [pmid: 17763913].
3836 Trinacty CM, Adams AS, Soumerai SB, et al. Racial differences in long-term adherence to oral antidiabetic drug therapy: a longitudinal cohort study. BMC Health Serv Res. 2009;9:24. X-2, X-4. [pmid: 19200387].
3837 Trinh LT, Michael John D, Byles J. Antenatal care adequacy in three provinces of Vietnam: Long An, Ben Tre, and Quang Ngai. Public Health Rep. Jul-Aug. 2006;121(4):468-75. X-2, X-3, X-5, X-6. [pmid: 16827450].
3838 Tripathy P, Nair N, Barnett S, et al. Effect of a participatory intervention with women's groups on birth outcomes and maternal depression in Jharkhand and Orissa, India: a cluster-randomised controlled trial. Lancet. Apr. 3. 2010;375(9721):1182-92. X-3. [pmid: 20207411].
3839 Trivedi AN, Grebla RC, Wright SM, et al. Despite improved quality of care in the Veterans Affairs health system, racial disparity persists for important clinical outcomes. Health Aff (Millwood). Apr. 2011;30(4):707-15. X-11. [pmid: 21471492].
3840 Trivedi AN, Zaslavsky AM, Schneider EC, et al. Trends in the quality of care and racial disparities in Medicare managed care. N Engl J Med. Aug. 18. 2005;353(7):692-700. X-2, X-4. [pmid: 16107622].
3841 Trivedi MH, Daly EJ, Kern JK, et al. Barriers to implementation of a computerized decision support system for depression: an observational report on lessons learned in “real world” clinical settings. Bmc Medical Informatics and Decision Making. Jan. 2009:9. X-2, X-4, X-5, X-6. [pmid: 19183479].
3842 Trobs M, Renner T, Scherer G, et al. Nutrition, antioxidants, and risk factor profile of nonsmokers, passive smokers and smokers of the Prevention Education Program (PEP) in Nuremberg, Germany. Prev Med. Jun. 2002;34(6):600-7. X-2, X-3, X-6. [pmid: 12052020].
3843 Trock B, Rimer BK, King E, et al. Impact of an HMO-based intervention to increase mammography utilization. Cancer Epidemiol Biomarkers Prev. Mar-Apr. 1993;2(2):151-6. X-9. [pmid: 8467250].
3844 Tromp M, Eskes M, Reitsma JB, et al. Regional perinatal mortality differences in the Netherlands---care is the question. Neonatal Intensive Care. 2009;22(5):51-6. X-2, X-3, X-4, X-5. [pmid: 19366460].
3845 Trotman BW, Boyce JG, Dajani EZ, et al. Highlights of the 14th Annual Scientific Meeting of the Association for Academic Minority Physicians, 2000. J Assoc Acad Minor Phys. Mar. 2001;12(1-2):95-7. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 11851198].
3846 Troxell H, Anderson J, Auld G, et al. Omega-3 for baby and me: material development for a WIC intervention to increase DHA intake during pregnancy. Matern Child Health J. Jun. 2005;9(2):189-97. X-2, X-4, X-6. [pmid: 15965625].
3847 Truncali A, Dumanovsky T, Stollman H, et al. Keep on Track: A Volunteer-Run Community-Based Intervention to Lower Blood Pressure in Older Adults. Journal of the American Geriatrics Society. Jun. 2010;58(6):1177-83. X-4, X-6, X-8, X-9. [pmid: 20722849].
3848 Tsai YF, Wong TK, Tsai HH, et al. Self-worth therapy for depressive symptoms in older nursing home residents. J Adv Nurs. Dec. 2008;64(5):488-94. X-3, X-4, X-6. [pmid: 19146517].
3849 Tseng CL, Sambamoorthi U, Rajan M, et al. Are there gender differences in diabetes care among elderly Medicare enrolled veterans?. J Gen Intern Med. Mar. Suppl 3. 2006;21:S47-53. X-2, X-4. [pmid: 16637945].
3850 Tseng CW, Tierney EF, Gerzoff RB, et al. Race/ethnicity and economic differences in cost-related medication underuse among insured adults with diabetes: the Translating Research Into Action for Diabetes Study. Diabetes Care. Feb. 2008;31(2):261-6. X-2, X-4. [pmid: 18000177].
3851 Tseng WH, Stevenson TR, Canter RJ, et al. Sacramento area breast cancer epidemiology study: use of postmastectomy breast reconstruction along the rural-to-urban continuum. Plast Reconstr Surg. Dec. 2010;126(6):1815-24. X-2, X-4, X-6. [pmid: 21124121].
3852 Tu SP, Taylor V, Yasui Y, et al. Promoting culturally appropriate colorectal cancer screening through a health educator: a randomized controlled trial. Cancer. Sep. 1. 2006;107(5):959-66. X-7, X-9. [pmid: 16865681].
3853 Tu SP, Taylor V, Yasui Y, et al. Promoting culturally appropriate colorectal cancer screening through a health educator - A randomized controlled trial. Cancer. Sep. 2006;107(5):959-66. X-14. [pmid: 16865681].
3854 Tu SP, Yip MP, Chun A, et al. Development of intervention materials for individuals with limited English proficiency: lessons learned from “Colorectal Cancer Screening in Chinese Americans”. Med Care. Sep. 2008;46(9 Suppl 1):S51-61. X-1, X-2, X-4. [pmid: 18725834].
3855 Tuchsen F, Endahl LA. Increasing inequality in ischaemic heart disease morbidity among employed men in Denmark 1981-1993: the need for a new preventive policy. Int J Epidemiol. Aug. 1999;28(4):640-4. X-2, X-3, X-4. [pmid: 10480690].
3856 Tudiver F, Wolff LT, Morin PC, et al. Primary care providers' perceptions of home diabetes telemedicine care in the IDEATel project. J Rural Health. Winter. 2007;23(1):55-61. X-2, X-4, X-6. [pmid: 17300479].
3857 Tumiel-Berhalter L, Zayas LE. Lay experiences and concerns with asthma in an urban Hispanic community. J Natl Med Assoc. Jun. 2006;98(6):875-80. X-2, X-4. [pmid: 16775908].
3858 Tumiel-Berhalter LM, McLaughlin-Diaz V, Vena J, et al. Building community research capacity: process evaluation of community training and education in a community-based participatory research program serving a predominantly Puerto Rican community. Prog Community Health Partnersh. Spring. 2007;1(1):89-97. X-1, X-2, X-4, X-5, X-6. [pmid: 19649164].
3859 Turenne MN, Hirth RA, Pan Q, et al. Using knowledge of multiple levels of variation in care to target performance incentives to providers. Medical Care. Feb. 2008;46(2):120-6. X-2, X-4, X-5, X-6. [pmid: 18219239].
3860 Turnin MC, Bourgeois O, Cathelineau G, et al. Multicenter randomized evaluation of a nutritional education software in obese patients. Diabetes Metab. Apr. 2001;27(2 Pt 1):139-47. X-3, X-5, X-6. [pmid: 11353880].
3861 Turpin R, Jungkind K, Salvucci L. The HEDIS performance NAVIGATOR for controlling high blood pressure: a resource to assist health plans improve patient adherence. Dis Manag. Spring. 2003;6(1):43-51. X-1, X-2, X-4, X-6. [pmid: 12899567].
3862 Two Feathers J, Kieffer EC, Palmisano G, et al. Racial and Ethnic Approaches to Community Health (REACH) Detroit partnership: improving diabetes-related outcomes among African American and Latino adults. Am J Public Health. Sep. 2005;95(9):1552-60. X-4, X-9. [pmid: 16051927].
3863 Ucan O, Ovayolu N. Relationship between diabetes mellitus, hypertension and obesity, and health-related quality of life in Gaziantep, a central south-eastern city in Turkey. Journal of Clinical Nursing. 2010;19(17/18):2511-9. X-2, X-3, X-4. [pmid: 20920079].
3864 Udayaraj UP, Ben-Shlomo Y, Roderick P, et al. Ethnicity, socioeconomic status, and attainment of clinical practice guideline standards in dialysis patients in the United kingdom. Clin J Am Soc Nephrol. May. 2009;4(5):979-87. X-2, X-3, X-4. [pmid: 19357243].
3865 Udell JA, Juurlink DN, Kopp A, et al. Inequitable distribution of implantable cardioverter defibrillators in Ontario. Int J Technol Assess Health Care. Summer. 2007;23(3):354-61. X-2, X-3, X-4. [pmid: 17579939].
3866 Uebelacker LA, Courtnage ES, Whisman MA. Correlates of depression and marital dissatisfaction: perceptions of marital communication style. Journal of Social & Personal Relationships. 2003;20(6):757-69. X-2, X-4, X-6.
3867 Ueland AS, Hornung PA, Greenwald B. Colorectal cancer prevention and screening: a Health Belief Model-based research study to increase disease awareness. Gastroenterol Nurs. Sep-Oct. 2006;29(5):357-63. X-2, X-4. [pmid: 17038836].
3868 Ueunten A, Shovic A. Patient education. Improving albumin levels in peritoneal dialysis patients. J Ren Nutr. Apr. 2003;13(2):105-8. X-1, X-6, X-7, X-9. [pmid: 12671827].
3869 Ugarriza DN, Schmidt L. Telecare for women with postpartum depression. J Psychosoc Nurs Ment Health Serv. Jan. 2006;44(1):37-45. X-4, X-6. [pmid: 16475443].
3870 Uitewaal PJ, Voorham AJ, Bruijnzeels MA, et al. No clear effect of diabetes education on glycaemic control for Turkish type 2 diabetes patients: a controlled experiment in general practice. Neth J Med. Dec. 2005;63(11):428-34. X-3. [pmid: 16397311].
3871 Ulbricht C, Chao W, Costa D, et al. An evidence-based systematic review of green-lipped mussel (Perna canaliculus) by the Natural Standard Research Collaboration. Journal of Dietary Supplements. 2009;6(1):54-90. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 22435354].
3872 Underwood SM. African-American women and breast cancer. Nurs Spectr (Wash D C). Feb. 23. 1998;8(4):14-5. X-1, X-2, X-3, X-4. [pmid: 10542686].
3873 Underwood SM. Breast cancer screening among African American women: addressing the needs of African American women with known and no known risk factors. J Natl Black Nurses Assoc. Spring. 1999;10(1):46-55. X-2. [pmid: 10188430].
3874 Underwood SM, Canales M, Powe BD, et al. Expanding and strengthening research focused on breast cancer in African American women: building upon what is known. JOCEPS: The Journal of Chi Eta Phi Sorority. 2005;51(1):2-24. X-1, X-2, X-4.
3875 Underwood SM, Dobson A. Promoting breast health among African American women in community-based settings: identifying good, better and best practices. JOCEPS: The Journal of Chi Eta Phi Sorority. 2004;50(1):1-8. X-1, X-2, X-4.
3876 Underwood SM, Richards K, Bradley PK, et al. Pilot study of the breast cancer experiences of African American women with a family history of breast cancer: implications for nursing practice. ABNF J. Summer. 2008;19(3):107-13. X-2, X-7, X-10. [pmid: 18717210].
3877 Unruh HK, Bowen DJ, Meischke H, et al. Women's approaches to the use of new technology for cancer risk information. Women Health. 2004;40(1):59-78. X-2, X-4, X-6. [pmid: 15778132].
3878 Urbán R, Kugler G, Oláh A, et al. Smoking and education: Do psychosocial variables explain the relationship between education and smoking behavior?. Nicotine & Tobacco Research. Aug. 2006;8(4):565-73. X-2, X-4, X-6. [pmid: 16920654].
3879 Urbanus-van Laar JJ, de Koning JS, Klazinga NS, et al. Suboptimal asthma care for immigrant children: results of an audit study. BMC Health Serv Res. 2008;8:22. X-2, X-3, X-4. [pmid: 18218104].
3880 Ussher M, Ibrahim S, Reid F, et al. Psychosocial correlates of health literacy among older patients with coronary heart disease. J Health Commun. Oct. 2010;15(7):788-804. X-2, X-4. [pmid: 21104506].
3881 Utz SW, Steeves RH, Wenzel J, et al. “Working hard with it”: self-management of type 2 diabetes by rural African Americans. Fam Community Health. Jul-Sep. 2006;29(3):195-205. X-2, X-4. [pmid: 16775469].
3882 Utz SW, Williams IC, Jones R, et al. Culturally tailored intervention for rural African Americans with type 2 diabetes. The Diabetes Educator. Sep-Oct. 2008;34(5):854-65. X-4, X-9, X-10. [pmid: 18832290].
3883 Uwakwe R, Ibeh CC, Modebe AI, et al. The epidemiology of dependence in older people in Nigeria: prevalence, determinants, informal care, and health service utilization. A 10/66 dementia research group cross-sectional survey. J Am Geriatr Soc. Sep. 2009;57(9):1620-7. X-2, X-3, X-4, X-5, X-6. [pmid: 19682135].
3884 Uziel Y, Friedland O, Jaber L, et al. Living with children with growing pains: how does it affect the parents?. Journal of Musculoskeletal Pain. 2007;15(2):19-23. X-2, X-4, X-5, X-6.
3885 Uzun S, Kara B, Yokusoglu M, et al. The assessment of adherence of hypertensive individuals to treatment and lifestyle change recommendations. Anadolu Kardiyol Derg. Apr. 2009;9(2):102-9. X-2, X-4. [pmid: 19357051].
3886 Vaananen MH, Lyles A, Airaksinen M. The symptom mitigation path of mobile community residents: Community pharmacy's role. Health Policy. Jan. 2009;89(1):14-25. X-2, X-3, X-4, X-5, X-6. [pmid: 18534711].
3887 Vadaparampil ST, Quinn G, Malo TL, et al. Knowledge about hereditary colorectal cancer among colorectal cancer survivors. Genet Test Mol Biomarkers. Oct. 2010;14(5):603-9. X-2, X-4, X-6. [pmid: 20722496].
3888 Vadheim LM, McPherson C, Kassner DR, et al. Adapted diabetes prevention program lifestyle intervention can be effectively delivered through telehealth. Diabetes Educ. Jul-Aug. 2010;36(4):651-6. X-4, X-6. [pmid: 20534873].
3889 Vahabi M. Knowledge of breast cancer and screening practices. Health Education Journal. 2005;64(3):218-28. X-2, X-3, X-4, X-6.
3890 Vahabi M. Verbal versus numerical probabilities: does format presentation of probabilistic information regarding breast cancer screening affect women's comprehension?. Health Education Journal. 2010;69(2):150-63. X-6, X-7, X-9.
3891 Valdez A, Banerjee K, Ackerson L, et al. A multimedia breast cancer education intervention for low-income Latinas. J Community Health. Feb. 2002;27(1):33-51. X-7, X-9. [pmid: 11845940].
3892 Valdez A, Banerjee K, Fernandez M, et al. Impact of a multimedia breast cancer education intervention on use of mammography by low-income Latinas. J Cancer Educ. Winter. 2001;16(4):221-4. X-9. [pmid: 11848671].
3893 van Bruggen R, Gorter KJ, Stolk RP, et al. Implementation of locally adapted guidelines on type 2 diabetes. Fam Pract. Dec. 2008;25(6):430-7. X-3, X-6, X-9. [pmid: 18718886].
3894 van de Sande M, Dippenaar H, Rutten GE. The relationship between patient education and glycaemic control in a South African township. Prim Care Diabetes. Jun. 2007;1(2):87-91. X-2, X-3, X-4. [pmid: 18632025].
3895 van Dellen QM, van Aalderen WM, Bindels PJ, et al. Asthma beliefs among mothers and children from different ethnic origins living in Amsterdam, the Netherlands. BMC Public Health. 2008;8:380. X-2, X-3, X-4. [pmid: 18980690].
3896 van den Hazel P, Zuurbier M, Babisch W, et al. Today's epidemics in children: possible relations to environmental pollution and suggested preventive measures. Acta Paediatr Suppl. Oct. 2006;95(453):18-25. X-1, X-2, X-3, X-4, X-6. [pmid: 17000565].
3897 van den Nieuwenhof L, Schermer T, Heins M, et al. Tracing uncontrolled asthma in family practice using a mailed asthma control questionnaire. Ann Fam Med. Jan-Feb. Suppl 1. 2008;6:S16-22. X-2, X-3, X-4, X-6. [pmid: 18195302].
3898 van der Pol M, Cairns J. Predicting attendance for breast screening using routinely collected data. Health Care Manag Sci. Nov. 2003;6(4):229-36. X-2, X-4. [pmid: 14686629].
3899 Van Hoof TJ, Ho SY, Curry M, et al. Opportunities to improve colorectal cancer screening in Connecticut through Medicare claims data. Conn Med. Feb. 2011;75(2):69-82. X-2, X-4, X-6. [pmid: 21476376].
3900 Van Hoof TJ, Mahier SE, Barr JK, et al. The Equity and Quality (EQual) Health-Care Project: A Connecticut Health Foundation initiative with Qualidigm. Conn Med. May. 2010;74(5):295-7. X-1, X-6, X-7, X-9. [pmid: 20509420].
3901 van Ittersum MW, van Wilgen CP, Hilberdink WK, et al. Illness perceptions in patients with fibromyalgia. Patient Educ Couns. Jan. 2009;74(1):53-60. X-2, X-3, X-4, X-5, X-6. [pmid: 18815004].
3902 van Loon A, van Schaik DJ, Dekker JJ, et al. Effectiveness of an intercultural module added to the treatment guidelines for Moroccan and Turkish patients with depressive and anxiety disorders. BMC Psychiatry. 2011;11:13. X-3. [pmid: 21247455].
3903 Van Minnen K, Davis WA, Bruce DG, et al. Accuracy, determinants, and consequences of body weight self-perception in type 2 diabetes: the Fremantle Diabetes Study. J Diabetes Complications. Jan-Feb. 2011;25(1):1-6. X-2, X-3, X-4, X-6. [pmid: 20045657].
3904 Van Rooijen AJ, Rheeder P, Eales CJ, et al. Effect of exercise versus relaxation on health-related quality of life in black females with type 2 diabetes mellitus. South African Journal of Physiotherapy. 2005;61(3):7. X-3.
3905 Van Scoyoc EE, DeWalt DA. Interventions to improve diabetes outcomes for people with low literacy and numeracy: a systematic literature review. Diabetes Spectrum. 2010;23(4):228-37. X-1, X-2, X-3, X-4, X-6.
3906 Van Servellen G, Brown JS, Lombardi E, et al. Health literacy in low-income Latino men and women receiving antiretroviral therapy in community-based treatment centers. Aids Patient Care and Stds. Jun. 2003;17(6):283-98. X-2, X-4, X-5. [pmid: 12880492].
3907 Van Voorhees BW, Walters AE, Prochaska M, et al. Reducing health disparities in depressive disorders outcomes between non-Hispanic Whites and ethnic minorities: a call for pragmatic strategies over the life course. Med Care Res Rev. Oct. 2007;64(5 Suppl):157S-94S. X-1, X-2, X-3, X-4. [pmid: 17766647].
3908 van Vuuren PAC, Kagan SH, Chalian AA. Geriatric otolaryngology toolbox: What you and your nurse can do to improve outcomes for older adults. Ent-Ear Nose & Throat Journal. Oct. 2009;88(10):1162-+. X-1, X-2, X-4, X-5, X-6. [pmid: 19826998].
3909 Van Winter JT, Harmon MC, Atkinson EJ, et al. Young Moms' Clinic: a multidisciplinary approach to pregnancy education in teens and in young single women. J Pediatr Adolesc Gynecol. Feb. 1997;10(1):28-33. X-6, X-9. [pmid: 9061632].
3910 Vannoy SD, Fancher T, Meltvedt C, et al. Suicide Inquiry in Primary Care: Creating Context, Inquiring, and Following Up. Annals of Family Medicine. Jan-Feb. 2010;8(1):33-9. X-2, X-4, X-6. [pmid: 20065276].
3911 Vargas PA, Robles E, Harris J, et al. Using information technology to reduce asthma disparities in underserved populations: a pilot study. J Asthma. Oct. 2010;47(8):889-94. X-2, X-4. [pmid: 20846082].
3912 Varma R, Aronow WS, Gandelman G, et al. Prevalence of adequate control of increased serum low-density lipoprotein cholesterol in self-pay or Medicare patients versus Medicaid or private insurance patients followed in a University General Medicine Clinic. Am J Cardiol. Jan. 15. 2005;95(2):269-70. X-2, X-4. [pmid: 15642567].
3913 Vasconcelos FF, de Araujo TL, Moreira TMM, et al. Association among nursing diagnoses, demographic variables, and clinical characteristics of patients with high blood pressure. Acta Paulista de Enfermagem. 2007;20(3):326-32. X-2, X-3, X-4, X-6.
3914 Vassiliadou A, Toulia G, Stamatopoulou E, et al. Sexual activity cardiological survey among Greek cardiologists. Health Science Journal. 2008. Jan-Mar. 2008;2(1):25-32. X-2, X-3, X-4, X-5, X-6.
3915 Vaughan C, Reddy P, Dunbar J. From rural beginnings to statewide roll-out: Evaluation of facilitator training for a group-based diabetes prevention program. Aust J Rural Health. Apr. 2010;18(2):59-65. X-4, X-6. [pmid: 20398045].
3916 Vedavanam S, Steel N, Broadbent J, et al. Recorded quality of care for depression in general practice: an observational study. Br J Gen Pract. Feb. 2009;59(559):e32-7. X-2, X-3, X-4, X-6. [pmid: 19192365].
3917 Vederhus BJ, Markestad T, Eide GE, et al. Health related quality of life after extremely preterm birth. Neonatal Intensive Care. 2010;23(7):35-40. X-2, X-3, X-4, X-5, X-6. [pmid: 20492724].
3918 Vehko T, Manderbacka K, Arffman M, et al. Increasing resources effected equity in access to revascularizations for patients with diabetes. Scand Cardiovasc J. Aug. 2010;44(4):237-44. X-2, X-3, X-4. [pmid: 20586656].
3919 Vehko T, Manderbacka K, Arffman M, et al. Changing patterns of secondary preventive medication among newly diagnosed coronary heart disease patients with diabetes in Finland: a register-based study. Scand J Public Health. May. 2010;38(3):317-24. X-2, X-3, X-4. [pmid: 20228159].
3920 Velsor-Friedrich B, Pigott T. Srof B. A practitioner-based asthma intervention program with African American inner-city school children. J Pediatr Health Care. May-Jun. 2005;19(3):163-71. X-4, X-6. [pmid: 15867832].
3921 Velsor-Friedrich B, Pigott TD, Louloudes A. The effects of a school-based intervention on the self-care and health of African-American inner-city children with asthma. J Pediatr Nurs. Aug. 2004;19(4):247-56. X-7, X-9. [pmid: 15308974].
3922 Velsor-Friedrich B, Pigott TD, et al. Srof B, The asthma belief survey: development and testing. J Nurs Meas. Spring-Summer. 2004;12(1):7-19. X-2, X-4, X-6. [pmid: 15916316].
3923 Venkatappa S, Oehlert WH, Nguyen L, et al. Screening mammography for Oklahoma Medicare beneficiaries: a national priority for quality improvement. J Okla State Med Assoc. Oct. 2002;95(10):655-60. X-2, X-4. [pmid: 12420415].
3924 Venkataraman V, Nolph KD. Socioeconomic aspects of peritoneal dialysis in North America: role of non medical factors in the choice of dialysis. Perit Dial Int. Suppl 2. 1999;19:S419-22. X-1, X-2, X-3, X-4, X-6. [pmid: 10406557].
3925 Vergili JM, Wolf RL. Nutrition practices of renal dietitians in hemodialysis centers throughout the United States: a descriptive study. J Ren Nutr. Jan. 2010;20(1):8 e1-8 e16. X-2, X-4, X-6. [pmid: 19796966].
3926 Verma A, Birger R, Bhatt H, et al. Ethnic disparities in diabetes management: a 10-year population-based repeated cross-sectional study in UK primary care. J Public Health (Oxf). Jun. 2010;32(2):250-8. X-2, X-3, X-4. [pmid: 20064875].
3927 Vermeire PA, Rabe KF, Soriano JB, et al. Asthma control and differences in management practices across seven European countries. Respir Med. Mar. 2002;96(3):142-9. X-2, X-3, X-4, X-6. [pmid: 11905548].
3928 Vernon SW, Myers RE, Tilley BC, et al. Factors associated with perceived risk in automotive employees at increased risk of colorectal cancer. Cancer Epidemiol Biomarkers Prev. Jan. 2001;10(1):35-43. X-2, X-4, X-6. [pmid: 11205487].
3929 Vickrey BG, Strickland TL, Fitten LJ, et al. Ethnic variations in dementia caregiving from focus groups. Journal of Human Behavior in the Social Environment. 2007;15(2-3):233-49. X-2, X-4, X-5.
3930 Vidovich MI, Vasaiwala S, Cannon CP, et al. Association of insurance status with inpatient treatment for coronary artery disease: findings from the Get With the Guidelines program. Am Heart J. Jun. 2010;159(6):1026-36. X-11. [pmid: 20569716].
3931 Vidyullatha B. A study to assess the knowledge of mothers about risk factors of low birth weight. Nurs J India. Nov. 2003;94(11):249-50. X-2, X-4. [pmid: 15318845].
3932 Vileikyte L, Gonzalez JS, Leventhal H, et al. Patient Interpretation of Neuropathy (PIN) questionnaire: an instrument for assessment of cognitive and emotional factors associated with foot self-care. Diabetes Care. Dec. 2006;29(12):2617-24. X-2, X-3, X-4, X-6. [pmid: 17130194].
3933 Villanueva EV, Jones S, Nehill C, et al. The 2003 Australian Breast Health Survey: survey design and preliminary results. BMC Public Health. 2008;8:13. X-2, X-3, X-4, X-6. [pmid: 18194528].
3934 Vincent D. Culturally tailored education to promote lifestyle change in Mexican Americans with type 2 diabetes. J Am Acad Nurse Pract. Sep. 2009;21(9):520-7. X-4. [pmid: 19845810].
3935 Vincent D, Clark L, Zimmer LM, et al. Using focus groups to develop a culturally competent diabetes self-management program for Mexican Americans. Diabetes Educ. Jan-Feb. 2006;32(1):89-97. X-2, X-4. [pmid: 16439497].
3936 Vincent D, Hastings-Tolsma M, Park JH. Down the rabbit hole: examining outcomes of nurse midwifery care. J Nurs Care Qual. Oct-Dec. 2004;19(4):361-7. X-6, X-7, X-9. [pmid: 15535542].
3937 Vincent D, McEwen MM, Pasvogel A. The validity and reliability of a Spanish version of the summary of diabetes self-care activities questionnaire. Nurs Res. Mar-Apr. 2008;57(2):101-6. X-2, X-4, X-6. [pmid: 18347481].
3938 Vincent D, Pasvogel A, Barrera L. A feasibility study of a culturally tailored diabetes intervention for Mexican Americans. Biol Res Nurs. Oct. 2007;9(2):130-41. X-4. [pmid: 17909165].
3939 Vivian EM. Improving blood pressure control in a pharmacist-managed hypertension clinic. Pharmacotherapy. Dec. 2002;22(12):1533-40. X-4, X-6. [pmid: 12495164].
3940 Vivienne Wu SF, Courtney M, Edwards H, et al. Development and validation of the Chinese version of the Diabetes Management Self-efficacy Scale. Int J Nurs Stud. Apr. 2008;45(4):534-42. X-2, X-3, X-4, X-6. [pmid: 17055509].
3941 Voda SC. Improving diabetes education for minority-group members. Nursing. Jul. 2008;38(7):12-3. X-6, X-7, X-9, X-10. [pmid: 18580634].
3942 Vodoor M, Southwell YP, Grubin M, et al. The management of depression: the implications for managed care--roundtable discussion: Part 3. Manag Care Interface. Suppl B. 2000:26-32. X-1, X-2, X-3, X-4, X-6. [pmid: 11183022].
3943 Vogel DL, Wester SR, Larson LM, et al. An information-processing model of the decision to seek professional help. Professional Psychology-Research and Practice. Aug. 2006;37(4):398-406. X-1, X-2, X-3, X-4, X-5, X-6.
3944 Vollrath ME, Landolt MA, Gnehm HE, et al. Child and parental personality are associated with glycaemic control in Type 1 diabetes. Diabet Med. Sep. 2007;24(9):1028-33. X-2, X-4, X-6. [pmid: 17593242].
3945 Volpp KG, Buckley E. The effect of increases in HMO penetration and changes in payer mix on in-hospital mortality and treatment patterns for acute myocardial infarction. Am J Manag Care. Jul. 2004;10(7 Pt 2):505-12. X-2, X-4, X-6. [pmid: 15298238].
3946 Volpp KG, Williams SV, Pauly MV. Market reform in New Jersey and quality of care: a cautionary tale. LDI Issue Brief. Apr. 2003;8(7):1-4. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12828171].
3947 von Euler-Chelpin M, Olsen AH, Njor S, et al. Does educational level determine screening participation?. Eur J Cancer Prev. Jun. 2008;17(3):273-8. X-2, X-3, X-4, X-6. [pmid: 18414200].
3948 von Goeler DS, Rosal MC, Ockene JK, et al. Self-management of type 2 diabetes: a survey of low-income urban Puerto Ricans. Diabetes Educ. Jul-Aug. 2003;29(4):663-72. X-2, X-3, X-4, X-6. [pmid: 13677177].
3949 von Wagner C, Semmler C, Good A, et al. Health literacy and self-efficacy for participating in colorectal cancer screening: The role of information processing. Patient Educ Couns. Jun. 2009;75(3):352-7. X-2, X-3, X-4. [pmid: 19386461].
3950 Vorderstrasse AA. Cultural issues in diabetes. Dietary counseling for black patients. Adv NPs PAs. Nov. 2010;1(3):26-9. quiz 30. X-1, X-2, X-3, X-4, X-6. [pmid: 21291140].
3951 Vulic D, Lee BT, Dede J, et al. Extent of control of cardiovascular risk factors and adherence to recommended therapies in US multiethnic adults with coronary heart disease: from a 2005-2006 national survey. Am J Cardiovasc Drugs. 2010;10(2):109-14. X-2, X-4. [pmid: 20334448].
3952 Wacharasin C, Barnard KE, Spieker SJ. Factors affecting toddler cognitive development in low-income families: implications for practitioners. Infants & Young Children: An Interdisciplinary Journal of Special Care Practices. 2003;16(2):175-81. X-2, X-4, X-5.
3953 Wagner EH, Glasgow RE, Davis C, et al. Quality improvement in chronic illness care: a collaborative approach. Jt Comm J Qual Improv. Feb. 2001;27(2):63-80. X-4, X-6. [pmid: 11221012].
3954 Wagner EH, Grothaus LC, Sandhu N, et al. Chronic care clinics for diabetes in primary care: a system-wide randomized trial. Diabetes Care. Apr. 2001;24(4):695-700. X-6, X-9. [pmid: 11315833].
3955 Wagner J, Abbott G, Lacey K. Knowledge of heart disease risk among Spanish speakers with diabetes: The role of interpreters in the medical encounter. Ethnicity & Disease. Fal. 2005;15(4):679-84. X-2, X-4. [pmid: 16259493].
3956 Wagner J, Lacey K, Abbott G, et al. Knowledge of heart disease risk in a multicultural community sample of people with diabetes. Ann Behav Med. Jun. 2006;31(3):224-30. X-2, X-4. [pmid: 16700635].
3957 Wagner JA. Response shift and glycemic control in children with diabetes. Health Qual Life Outcomes. 2005;3:38. X-2, X-4, X-6. [pmid: 15955236].
3958 Wagner JA, Abbott GL, Heapy A, et al. Depressive symptoms and diabetes control in African Americans. J Immigr Minor Health. Feb. 2009;11(1):66-70. X-2, X-4. [pmid: 18470617].
3959 Wagner JA, Osborn CY, Mendenhall EA, et al. Beliefs about racism and health among African American women with diabetes: a qualitative study. J Natl Med Assoc. Mar. 2011;103(3):224-32. X-2, X-4. [pmid: 21528110].
3960 Wagner JA, Tennen H, Osborn CY. Lifetime depression and diabetes self-management in women with Type 2 diabetes: a case-control study. Diabet Med. Jun. 2010;27(6):713-7. X-2, X-4, X-6. [pmid: 20546294].
3961 Waite R, Calamaro C. Culture and depression: a case example of a young African American man. Perspect Psychiatr Care. Jul. 2009;45(3):232-8. X-1, X-2, X-3, X-4, X-6. [pmid: 19566696].
3962 Waite R, Killian P. Perspectives about depression: explanatory models among African-American women. Arch Psychiatr Nurs. Aug. 2009;23(4):323-33. X-2, X-4. [pmid: 19631110].
3963 Waitzfelder B, Gerzoff RB, Karter AJ, et al. Correlates of depression among people with diabetes: The Translating Research Into Action for Diabetes (TRIAD) study. Prim Care Diabetes. Dec. 2010;4(4):215-22. X-2, X-4, X-6. [pmid: 20832375].
3964 Walden CM, Still AT, Zinn B, et al. Perinatal effects of a pregnancy wellness program in the workplace. MCN Am J Matern Child Nurs. Nov-Dec. 1996;21(6):288-93. X-6, X-9. [pmid: 8952282].
3965 Waldkoetter RO, Sanders GO. Auditory brainwave stimulation in treating alcoholic depression. Percept Mot Skills. Feb. 1997;84(1):226. X-4, X-5, X-6. [pmid: 9132712].
3966 Walen HR, Oliver K, Groessl E, et al. Traumatic events, health outcomes, and health care use in patients with fibromyalgia. Journal of Musculoskeletal Pain. 2001;9(2):19-38. X-2, X-4, X-5, X-6.
3967 Waljee JF, Rogers MAM, Alderman AK. Decision aids and breast cancer: Do they influence choice for surgery and knowledge of treatment options?. Journal of Clinical Oncology. Mar. 2007;25(9):1067-73. X-1, X-2, X-3, X-4, X-6. [pmid: 17369570].
3968 Walker CC. An educational intervention for hypertension management in older African Americans. Ethn Dis. Spring-Summer. 2000;10(2):165-74. X-4. [pmid: 10892822].
3969 Walker D, Adebajo A, Heslop P, et al. Patient education in rheumatoid arthritis: the effectiveness of the ARC booklet and the mind map. Rheumatology (Oxford). Oct. 2007;46(10):1593-6. X-4, X-5. [pmid: 17767002].
3970 Walker DR, Stern PM, Landis DL. Examining healthcare disparities in a disease management population. Am J Manag Care. Feb. 2004;10(2 Pt 1):81-8. X-8. [pmid: 15011808].
3971 Walker E, Holman T, Busby D. Childhood sexual abuse, other childhood factors, and pathways to survivors' adult relationship quality. Journal of Family Violence. 2009;24(6):397-406. X-2, X-4, X-5, X-6.
3972 Walker EA. Characteristics of the adult learner. Diabetes Educator. Nov-Dec. 1999;25(6):16-24. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 10711081].
3973 Walker EA, Engel SS, Zybert PA. Dissemination of diabetes care guidelines: lessons learned from community health centers. Diabetes Educ. Jan-Feb. 2001;27(1):101-10. X-6, X-9. [pmid: 11912611].
3974 Walker EA, Stevens KA, Persaud S. Promoting diabetes self-management among African Americans: an educational intervention. J Health Care Poor Underserved. Aug. 2010;21(3 Suppl):169-86. X-7, X-9. [pmid: 20675953].
3975 Walker JG, Mackinnon AJ, Batterham P, et al. Mental health literacy, folic acid and vitamin B12, and physical activity for the prevention of depression in older adults: randomised controlled trial. Br J Psychiatry. Jul. 2010;197(1):45-54. X-6, X-9. [pmid: 20592433].
3976 Walker MS, Farria D, Schmidt M, et al. Educational intervention for women undergoing image-guided breast biopsy: results of a randomized clinical trial. Cancer Control. Oct. 2007;14(4):380-7. X-6, X-7, X-9. [pmid: 17914338].
3977 Wallace AS, Carlson JR, Malone RM, et al. The influence of literacy on patient-reported experiences of diabetes self-management support. Nurs Res. Sep-Oct. 2010;59(5):356-63. X-2, X-4. [pmid: 20808193].
3978 Wallace AS, Seligman HK, Davis TC, et al. Literacy-appropriate educational materials and brief counseling improve diabetes self-management. Patient Educ Couns. Jun. 2009;75(3):328-33. X-7, X-9, X-10, X-11. [pmid: 19167857].
3979 Wallace LS, Roskos SE, Weiss BD. Readability Characteristics of Consumer Medication Information for Asthma Inhalation Devices. Journal of Asthma. Jun-Jul. 2006;43(5):375-8. X-2, X-3, X-4, X-6. [pmid: 16801142].
3980 Wallen GR, Middleton KR, Rivera-Goba MV, et al. Validating English- and Spanish-language patient-reported outcome measures in underserved patients with rheumatic disease. Arthritis Research & Therapy. 2011;13(1). X-2, X-4, X-5, X-6. [pmid: 21208400].
3981 Waller B, Tzeng HM. Glycaemic index knowledge and use among African Americans with type 2 diabetes. J Adv Nurs. May. 2011;67(5):1102-8. X-2, X-4. [pmid: 21480960].
3982 Waller H, Eiser C, Knowles J, et al. Pilot study of a novel educational programme for 11-16 year olds with type 1 diabetes mellitus: the KICk-OFF course. Arch Dis Child. Nov. 2008;93(11):927-31. X-3, X-4, X-6. [pmid: 18676435].
3983 Waller J, McCaffery K, Wardle J. Measuring cancer knowledge: comparing prompted and unprompted recall. Br J Psychol. May. 2004;95(Pt 2):219-34. X-3, X-6. [pmid: 15142303].
3984 Wallhagen MI, Lacson M. Perceived control and psychosocial/physiological functioning in African American elders with type 2 diabetes. Diabetes Educ. Jul-Aug. 1999;25(4):568-75. X-2, X-4. [pmid: 10614261].
3985 Walsh JM, Salazar R, Nguyen TT, et al. Healthy colon, healthy life: a novel colorectal cancer screening intervention. Am J Prev Med. Jul. 2010;39(1):1-14. X-9. [pmid: 20547275].
3986 Walsh MN, Yancy CW, Albert NM, et al. Equitable improvement for women and men in the use of guideline-recommended therapies for heart failure: findings from IMPROVE HF. J Card Fail. Dec. 2010;16(12):940-9. X-7. [pmid: 21111983].
3987 Walter EB, Hellkamp AS, Goldberg KC, et al. Improving influenza vaccine coverage among asthmatics: a practice-based research network study. Journal of Clinical Outcomes Management. 2008;15(5):229-34. X-6, X-9.
3988 Walton J. Can a one-hour presentation make an impact on cultural awareness?. Nephrol Nurs J. Jan-Feb. 2011;38(1):21-30. quiz 1. X-5, X-7, X-9, X-10. [pmid: 21469551].
3989 Wang A, Wolf M, Carlyle R, et al. The North Carolina experience with the diabetes health disparities collaboratives. Jt Comm J Qual Saf. Jul. 2004;30(7):396-404. X-1, X-6, X-9. [pmid: 15279504].
3990 Wang CJ, McGlynn EA, Brook RH, et al. Quality-of-care indicators for the neurodevelopmental follow-up of very low birth weight children: Results of an expert panel process. Pediatrics. Jun. 2006;117(6):2080-92. X-2, X-4, X-5, X-6. [pmid: 16740851].
3991 Wang CY. The cross-cultural applicability of Orem's conceptual framework. J Cult Divers. Summer. 1997;4(2):44-8. X-2, X-3, X-4, X-6. [pmid: 9287595].
3992 Wang CY, Abbot L, Goodbody AK, et al. Ideal body image and health status in low-income Pacific Islanders. J Cult Divers. Spring. 2002;9(1):12-22. X-2, X-4. [pmid: 12046317].
3993 Wang CY, Chan SM. Culturally tailored diabetes education program for Chinese Americans: a pilot study. Nurs Res. Sep-Oct. 2005;54(5):347-53. X-4. [pmid: 16224321].
3994 Wang HH, Zhou J, Huang L, et al. Effects of nurse-delivered home visits combined with telephone calls on medication adherence and quality of life in HIV-infected heroin users in Hunan of China. Journal of Clinical Nursing. Feb. 2010;19(3-4):380-8. X-3, X-5, X-6. [pmid: 20500277].
3995 Wang J, Lai D. The relationship between mental health literacy, personal contacts and personal stigma against depression. Journal of Affective Disorders. Sep. 2008;110(1-2):191-6. X-2, X-3, X-4, X-6. [pmid: 18261806].
3996 Wang JH, Liang W, Schwartz MD, et al. Development and evaluation of a culturally tailored educational video: changing breast cancer-related behaviors in Chinese women. Health Educ Behav. Dec. 2008;35(6):806-20. X-7, X-9. [pmid: 17602099].
3997 Wang L, Li J. Role of educational intervention in the management of comorbid depression and hypertension. Blood Press. 2003;12(4):198-202. X-6, X-7, X-9. [pmid: 14596355].
3998 Wang LY, Zhong Y, Wheeler L. Asthma medication use in school-aged children. J Asthma. Sep. 2006;43(7):495-9. X-2, X-4. [pmid: 16939988].
3999 Wang PS, Patrick A, Avorn J, et al. The costs and benefits of enhanced depression care to employers. Arch Gen Psychiatry. Dec. 2006;63(12):1345-53. X-2, X-3, X-4, X-6. [pmid: 17146009].
4000 Wang TY, Chen AY, Roe MT, et al. Comparison of baseline characteristics, treatment patterns, and in-hospital outcomes of Asian versus non-Asian white Americans with non-ST-segment elevation acute coronary syndromes from the CRUSADE quality improvement initiative. Am J Cardiol. Aug. 1. 2007;100(3):391-6. X-2, X-4. [pmid: 17659915].
4001 Wang XJ, Fang C, Tan Y, et al. Evidence-Based Intervention to Reduce Access Barriers to Cervical Cancer Screening Among Underserved Chinese American Women. Journal of Womens Health. Mar. 2010;19(3):463-9. X-5. [pmid: 20156089].
4002 Wang Y, Wang QJ. The prevalence of prehypertension and hypertension among US adults according to the new joint national committee guidelines: new challenges of the old problem. Arch Intern Med. Oct. 25. 2004;164(19):2126-34. X-2, X-4. [pmid: 15505126].
4003 Wang Y, Wu D, Zhou Y, et al. Survey of blood pressure control status in patients with ischemic stroke or transient ischemic attack in China. Neurol Res. May. 2008;30(4):348-55. X-2, X-3, X-4, X-5, X-6. [pmid: 18544250].
4004 Wang Y, Zhang L, Li X, et al. Improvement of awareness, treatment and control of hypertension among chronic kidney disease patients in China from 1999 to 2005. Hypertens Res. Jun. 2009;32(6):444-9. X-2, X-3, X-4, X-6. [pmid: 19494816].
4005 Wanitkun N, Batterham R, Vichathai C, et al. Building equity in chronic disease management in Thailand: a whole-system provincial trial of systematic, pro-active chronic illness care. Chronic Illn. Mar. 2011;7(1):31-44. X-1, X-2, X-3. [pmid: 21343219].
4006 Wannapornsiri C, Sindhu S, Phancharoenworakul K, et al. Caring process of Thai women with breast cancer receiving chemotherapy. Thai Journal of Nursing Research. 2005;9(2):121-32. X-2, X-3, X-4, X-6.
4007 Wanzer MB, Wojtaszczyk AM, Schimert J, et al. Enhancing the oInformedo in Informed Consent: A Pilot Test of a Multimedia Presentation. Health Communication. 2010;25(4):365-74. X-4, X-5, X-6. [pmid: 20512718].
4008 Ward AJ, Coffey Kluhsman B, Lengerich EJ, et al. The impact of cancer coalitions on the dissemination of colorectal cancer materials to community organizations in rural Appalachia. Prev Chronic Dis. Apr. 2006;3(2):A55. X-6. [pmid: 16539796].
4009 Ward B, Bertera EM, Hoge P. Developing and evaluating a Spanish TEL-MED message on breast cancer. J Community Health. Apr. 1997;22(2):127-35. X-4. [pmid: 9149954].
4010 Wardle J, Williamson S, McCaffery K, et al. Increasing attendance at colorectal cancer screening: testing the efficacy of a mailed, psychoeducational intervention in a community sample of older adults. Health Psychol. Jan. 2003;22(1):99-105. X-6, X-7, X-9. [pmid: 12558207].
4011 Warren-Findlow J, Issel LM. Stress and coping in African American women with chronic heart disease: A cultural cognitive coping model. Journal of Transcultural Nursing. Jan. 2010;21(1):45-54. X-2, X-4. [pmid: 19826059].
4012 Warren-Findlow J, Seymour RB. Prevalence rates of hypertension self-care activities among African Americans. J Natl Med Assoc. Jun. 2011;103(6):503-12. X-2, X-4. [pmid: 21830634].
4013 Warren-Findlow J, Seymour RB, Shenk D. Intergenerational transmission of chronic illness self-care: results from the caring for hypertension in African American families study. Gerontologist. Feb. 2011;51(1):64-75. X-2, X-4. [pmid: 20864590].
4014 Warrier I, Du W, Natarajan G, et al. Patterns of drug utilization in a neonatal intensive care unit. J Clin Pharmacol. Apr. 2006;46(4):449-55. X-2, X-4, X-5. [pmid: 16554453].
4015 Washington EL, Shen JJ, Bell R, et al. Patterns of Hospital-Based Pediatric Care Across Diverse Ethnicities: The Case of Pneumonia. Journal of Health Care for the Poor and Underserved. Aug. 2004;15(3):462-73. X-2, X-4. [pmid: 15453181].
4016 Washington G, Wang-Letzkus MF. Self-care practices, health beliefs, and attitudes of older diabetic Chinese Americans. J Health Hum Serv Adm. Winter. 2009;32(3):305-23. X-2. [pmid: 20099582].
4017 Wasserfallen JB, Moinat M, Halabi G, et al. Satisfaction of patients on chronic haemodialysis and peritoneal dialysis. Swiss Med Wkly. Apr. 1. 2006;136(13-14):210-7. X-2, X-3, X-4, X-6. [pmid: 16633970].
4018 Waterhouse D. Vascular access: a role for a renal nurse clinician. EDTNA ERCA J. Apr-Jun. 2002;28(2):64-6. 9. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12216845].
4019 Watson WT, Gillespie C, Thomas N, et al. Small-group, interactive education and the effect on asthma control by children and their families. CMA J. Sep. 1. 2009;181(5):257-63. X-6, X-9. [pmid: 19687105].
4020 Watts KD, Schechter MS. Origins of outcome disparities in pediatric respiratory disease. Pediatr Ann. Dec. 2010;39(12):793-8. X-2. [pmid: 21162488].
4021 Watts M, Johnson IS. Screening for ischaemic heart disease risk factors at a health fair: low attendance by those at highest risk. J Epidemiol Community Health. Sep. 1989;43(3):234-6. X-2, X-3, X-4. [pmid: 2607301].
4022 Wearden AJ, Tarrier N, Davies R. Partners' expressed emotion and the control and management of type 1 diabetes in adults. J Psychosom Res. Aug. 2000;49(2):125-30. X-2, X-4, X-6. [pmid: 11068056].
4023 Webb KL, Dobson AJ, O'Connell DL, et al. Dietary compliance among insulin-dependent diabetics. J Chronic Dis. 1984;37(8):633-43. X-3, X-4, X-6. [pmid: 6746853].
4024 Webb M, Beckstead J, Meininger J, et al. Stress management for African American women with elevated blood pressure: a pilot study. Biol Res Nurs. Jan. 2006;7(3):187-96. X-4. [pmid: 16552946].
4025 Webber PA, Fox P, Zhang X, et al. An examination of differential follow-up rates in breast cancer screening. Journal of Community Health: The Publication for Health Promotion and Disease Prevention. Apr. 1996;21(2):123-32. X-2, X-4. [pmid: 8728360].
4026 Weber BE, Reilly BM. Enhancing mammography use in the inner city. A randomized trial of intensive case management. Arch Intern Med. Nov. 10. 1997;157(20):2345-9. X-6, X-9. [pmid: 9361575].
4027 Webster J, Linnane JW, Dibley LM, et al. Improving antenatal recognition of women at risk for postnatal depression. Aust N Z J Obstet Gynaecol. Nov. 2000;40(4):409-12. X-3, X-4, X-5, X-6. [pmid: 11194425].
4028 Wee HL, Li SC. Sociodemographic factors influencing the effectiveness of public health education - a comparison of two studies in Singapore. Ann Acad Med Singapore. Nov. 2007;36(11):958-61. X-2, X-3. [pmid: 18071609].
4029 Wei W, Sambamoorthi U, Olfson M, et al. Use of psychotherapy for depression in older adults. Am J Psychiatry. Apr. 2005;162(4):711-7. X-2, X-4, X-6. [pmid: 15800143].
4030 Weiler DM, Crist JD. Diabetes self-management in a Latino social environment. Diabetes Educ. Mar-Apr. 2009;35(2):285-92. X-2, X-4. [pmid: 19204101].
4031 Weiner M, Quwatli Z, Perkins AJ, et al. Limitation of a Single Clinical Data Source for Measuring Physicians' Performance on Quality Indicators. Journal of the American Geriatrics Society. Aug. 2006;54(8):1256-60. X-2, X-4. [pmid: 16913995].
4032 Weinmann S, Janssen B, Gaebel W. Guideline adherence in medication management of psychotic disorders: an observational multisite hospital study. Acta Psychiatr Scand. Jul. 2005;112(1):18-25. X-2, X-4, X-5, X-6. [pmid: 15952941].
4033 Weinrich SP, Weinrich MC, Boyd MD, et al. Teaching older adults by adapting for aging changes. Cancer Nurs. Dec. 1994;17(6):494-500. X-6, X-9. [pmid: 7529659].
4034 Weinrich SP, Weinrich MC, Stromborg MF, et al. Using elderly educators to increase colorectal cancer screening. Gerontologist. Aug. 1993;33(4):491-6. X-6, X-9. [pmid: 8375677].
4035 Weinstock LM, Whisman MA. The self-verification model of depression and interpersonal rejection in heterosexual dating relationships. Journal of Social and Clinical Psychology. Apr. 2004;23(2):240-59. X-2, X-4, X-6.
4036 Weinstock RS, Teresi JA, Goland R, et al. Glycemic control and health disparities in older ethnically diverse underserved adults with diabetes: five-year results from the Informatics for Diabetes Education and Telemedicine (IDEATel) study. Diabetes Care. Feb. 2011;34(2):274-9. X-7. [pmid: 21270184].
4037 Weiss BD, Francis L, Senf JH, et al. Literacy education as treatment for depression in patients with limited literacy and depression: a randomized controlled trial. J Gen Intern Med. Aug. 2006;21(8):823-8. X-4. [pmid: 16881941].
4038 Weiss BD, Reed RL, Kligman EW. LITERACY SKILLS AND COMMUNICATION METHODS OF LOW-INCOME OLDER PERSONS. Patient Education and Counseling. May. 1995;25(2):109-19. X-2, X-4, X-5. [pmid: 7659623].
4039 Weiss JJ, Mulder CL, Antoni MH, et al. Effects of a supportive-expressive group intervention on long-term psychosocial adjustment in HIV-infected gay men. Psychother Psychosom. May-Jun. 2003;72(3):132-40. X-4, X-5, X-6. [pmid: 12707480].
4040 Weiss KB, Shannon JJ, Sadowski LS, et al. The burden of asthma in the Chicago community fifteen years after the availability of national asthma guidelines: the design and initial results from the CHIRAH study. Contemp Clin Trials. May. 2009;30(3):246-55. X-6, X-7, X-9. [pmid: 19470314].
4041 Weiss RB, Rifkin RM, Stewart FM, et al. High-dose chemotherapy for high-risk primary breast cancer: an on-site review of the Bezwoda study. Lancet. Mar. 18. 2000;355(9208):999-1003. X-2, X-3, X-4, X-6. [pmid: 10768448].
4042 Weissenberger C, Jonassen S, Beranek-Chiu J, et al. Breast cancer: patient information needs reflected in English and German web sites. Br J Cancer. Oct. 18. 2004;91(8):1482-7. X-2, X-3, X-4, X-6. [pmid: 15467771].
4043 Weissman MM, Neria Y, Gameroff MJ, et al. Positive screens for psychiatric disorders in primary care: a long-term follow-up of patients who were not in treatment. Psychiatr Serv. Feb. 2010;61(2):151-9. X-2, X-4. [pmid: 20123820].
4044 Welch G, Schwartz CE, Santiago-Kelly P, et al. Disease-related emotional distress of Hispanic and non-Hispanic type 2 diabetes patients. Ethnicity & Disease. Sum. 2007;17(3):541-7. X-2. [pmid: 17985511].
4045 Welch JL, Siek KA, Connelly KH, et al. Merging health literacy with computer technology: self-managing diet and fluid intake among adult hemodialysis patients. Patient Educ Couns. May. 2010;79(2):192-8. X-1, X-2, X-4. [pmid: 19796911].
4046 Welch VL, Oster NV, Gazmararian JA, et al. Impact of a Diabetes Disease Management Program by Race and Ethnicity. Disease Management & Health Outcomes. 2006;14(4):245-52. X-8.
4047 Welch VL, VanGeest JB, Caskey R. Time, Costs, and Clinical Utilization of Screening for Health Literacy: A Case Study Using the Newest Vital Sign (NVS) Instrument. Journal of the American Board of Family Medicine. May-Jun. 2011;24(3):281-9. X-2, X-5, X-6, X-9, X-10. [pmid: 21551400].
4048 Welkenhuysen M, Evers-Kiebooms G. The reactions of general practitioners, nurses and midwives in Flanders concerning breast cancer risks in a high-risk situation. Community Genet. 2003;6(4):206-13. X-2, X-3, X-4, X-6. [pmid: 15331866].
4049 Wells KB, Norquist G, Benjamin B, et al. Quality of antidepressant medications prescribed at discharge to depressed elderly patients in general medical hospitals before and after prospective payment system. General Hospital Psychiatry. Jan. 1994;16(1):4-15. X-2, X-4, X-6. [pmid: 8039682].
4050 Wells KB, Rogers WH, Davis LM, et al. Quality of care for depressed elderly pre-post prospective payment system: Differences in response across treatment settings. Medical Care. Mar. 1994;32(3):257-76. X-2, X-4, X-6. [pmid: 8145602].
4051 Wells KB, Rogers WH, Davis LM, et al. Quality of care for hospitalized depressed elderly patients before and after implementation of the Medicare Prospective Payment System. The American Journal of Psychiatry. Dec. 1993;150(12):1799-805. X-2, X-4, X-6. [pmid: 8238633].
4052 Wells KB, Schoenbaum M, Unutzer J, et al. Quality of care for primary care patients with depression in managed care. Arch Fam Med. Nov-Dec. 1999;8(6):529-36. X-2, X-4, X-6. [pmid: 10575393].
4053 Wells KB, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. Jan. 12. 2000;283(2):212-20. X-6. [pmid: 10634337].
4054 Wells KB, Tang L, Miranda J, et al. The effects of quality improvement for depression in primary care at nine years: Results from a randomized, controlled group-level trial. Health Services Research. Dec. 2008;43(6):1952-74. X-6, X-9. [pmid: 18522664].
4055 Wells-Federman C, Arnstein P, Caudill-Slosberg M. Comparing patients with fibromyalgia and chronic low back pain participating in an outpatient cognitive-behavioral treatment program. Journal of Musculoskeletal Pain. 2003;11(3):5-12. X-5, X-6.
4056 Wen LK, Parchman ML, Shepherd MD. Family support and diet barriers among older Hispanic adults with type 2 diabetes. Fam Med. Jun. 2004;36(6):423-30. X-2, X-4. [pmid: 15181555].
4057 Wen LK, Shepherd MD, Parchman ML. Family support, diet, and exercise among older Mexican Americans with type 2 diabetes. Diabetes Educ. Nov-Dec. 2004;30(6):980-93. X-2, X-4. [pmid: 15641619].
4058 Wendel CS, Shah JH, Duckworth WC, et al. Racial and ethnic disparities in the control of cardiovascular disease risk factors in Southwest American veterans with type 2 diabetes: the Diabetes Outcomes in Veterans Study. BMC Health Serv Res. 2006;6:58. X-2, X-4. [pmid: 16716235].
4059 Wenger RD. Does the U.S. have the best health care system in the world?. Bull Am Coll Surg. Jul. 2009;94(7):8-15. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19718966].
4060 Werner RM, Asch DA, Polsky D. Racial profiling: the unintended consequences of coronary artery bypass graft report cards. Circulation. Mar. 15. 2005;111(10):1257-63. X-7. [pmid: 15769766].
4061 Werner RM, Bradlow ET, Asch DA. Does hospital performance on process measures directly measure high quality care or is it a marker of unmeasured care?. Health Services Research. 2008;43(5 Part 1):1464-84. X-6, X-7, X-9. [pmid: 22568614].
4062 West DS, Greene P, Pulley L, et al. Stepped-care, community clinic interventions to promote mammography use among low-income rural African American women. Health Educ Behav. Aug. 2004;31(4 Suppl):29S-44S. X-9. [pmid: 15296690].
4063 Wheeler K, Crawford R, McAdams D, et al. Inpatient to outpatient transfer of care in urban patients with diabetes: patterns and determinants of immediate postdischarge follow-up. Arch Intern Med. Feb. 23. 2004;164(4):447-53. X-2, X-4, X-6. [pmid: 14980997].
4064 Wheeler LA, Wheeler ML, Ours P, et al. Evaluation of computer-based diet education in persons with diabetes mellitus and limited educational background. Diabetes Care. Nov-Dec. 1985;8(6):537-44. X-4. [pmid: 3908024].
4065 White AD, Folsom AR, Chambless LE, et al. Community surveillance of coronary heart disease in the Atherosclerosis Risk in Communities (ARIC) Study: methods and initial two years' experience. J Clin Epidemiol. Feb. 1996;49(2):223-33. X-2, X-4. [pmid: 8606324].
4066 White C, Gallagher P. Effect of patient coping preferences on quality of life following renal transplantation. J Adv Nurs. Nov. 2010;66(11):2550-9. X-2, X-3, X-4, X-5, X-6. [pmid: 20722812].
4067 White J, Gray R, Jones M. The development of the serious mental illness physical Health Improvement Profile. J Psychiatr Ment Health Nurs. Jun. 2009;16(5):493-8. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19538607].
4068 White RO, DeWalt DA, Malone RM, et al. Leveling the field: addressing health disparities through diabetes disease management. Am J Manag Care. Jan. 2010;16(1):42-8. X-4, X-9. [pmid: 20148604].
4069 White RO, Osborn CY, Gebretsadik T, et al. Development and Validation of a Spanish Diabetes-Specific Numeracy Measure: DNT-15 Latino. Diabetes Technology & Therapeutics. Sep. 2011;13(9):893-8. X-2, X-4. [pmid: 21714674].
4070 White WB. Assessment of patients with office hypertension by 24-hour noninvasive ambulatory blood pressure monitoring. Arch Intern Med. Nov. 1986;146(11):2196-9. X-2, X-4, X-6. [pmid: 3778049].
4071 Whittaker R, Bramley D, Wells S, et al. Will a web-based cardiovascular disease (CVD) risk assessment programme increase the assessment of CVD risk factors for Maori?. N Z Med J. 2006;119(1238):U2077. X-2, X-4, X-6. [pmid: 16868574].
4072 Whittemore R, Jaser S, Guo J, et al. A conceptual model of childhood adaptation to type 1 diabetes. Nurs Outlook. Sep-Oct. 2010;58(5):242-51. X-1, X-2, X-3, X-4, X-6. [pmid: 20934079].
4073 Whyte S, Penny C, Phelan M, et al. Quality of diabetes care in patients with schizophrenia and bipolar disorder: cross-sectional study. Diabet Med. Dec. 2007;24(12):1442-8. X-2, X-3, X-4, X-6. [pmid: 18042084].
4074 Widerman E. Knowledge, interests and educational needs of adults diagnosed with cystic fibrosis after age 18. J Cyst Fibros. Jun. 2003;2(2):97-104. X-2, X-4, X-5, X-6. [pmid: 15463857].
4075 Widga AC, Lewis NM. Defined, in-home, prenatal nutrition intervention for low-income women. J Am Diet Assoc. Sep. 1999;99(9):1058-62. quiz 63-4, 175. X-4. [pmid: 10491673].
4076 Wiehagen T, Caito NM, Thompson VS, et al. Applying projective techniques to formative research in health communication development. Health Promot Pract. Apr. 2007;8(2):164-72. X-2, X-4. [pmid: 17003247].
4077 Wierenga ME, Wuethrich KL. Diabetes program attrition: Differences between two cultural groups. Health Values: The Journal of Health Behavior, Education & Promotion. May-Jun. 1995;19(3):12-21. X-10.
4078 Wigg DS, Shapiro J, Perley MJ, et al. Patient and spouse expectations of and reactions to continuous subcutaneous insulin infusion (CSII) therapy: case report. Diabetes Educ. Spring. 1986;12(2):141-4. X-1, X-2, X-3, X-4, X-6. [pmid: 3634699].
4079 Wiist WH, Flack JM. A church-based cholesterol education program. Public Health Rep. Jul-Aug. 1990;105(4):381-8. X-5, X-8, X-9. [pmid: 2116640].
4080 Wijeratne C, Harris P. Late life depression and dementia: a mental health literacy survey of Australian general practitioners. Int Psychogeriatr. Apr. 2009;21(2):330-7. X-2, X-3, X-4, X-6. [pmid: 19138460].
4081 Wilf-Miron R, Galai N, Gabali A, et al. Organisational efforts to improve quality while reducing healthcare disparities: the case of breast cancer screening among Arab women in Israel. Qual Saf Health Care. Oct. 2010;19(5):e36. X-3. [pmid: 20558476].
4082 Wilkin HA, Valente TW, Murphy S, et al. Does entertainment-education work with Latinos in the United States? Identification and the effects of a telenovela breast cancer storyline. J Health Commun. Jul-Aug. 2007;12(5):455-69. X-7, X-9. [pmid: 17710596].
4083 Wilkinson AV, Vasudevan V, Honn SE, et al. Sociodemographic characteristics, health beliefs, and the accuracy of cancer knowledge. Journal of Cancer Education. Jan. 2009;24(1):58-64. X-2, X-4. [pmid: 19259867].
4084 Wilkinson E, Randhawa G, Rehman T, et al. The impact of quality improvement initiatives on diabetes care among South Asian people. Diabetes & Primary Care. 2011;13(2):90. X-3, X-7, X-9.
4085 Williams B, Mukhopadhyay S, Dowell J, et al. Problems and solutions: accounts by parents and children of adhering to chest physiotherapy for cystic fibrosis. Disabil Rehabil. Jul. 30. 2007;29(14):1097-105. X-2, X-4, X-5, X-6. [pmid: 17612996].
4086 Williams CD, Adams-Campbell LL. Addictive behaviors and depression among African Americans residing in a public housing community. Addict Behav. Jan-Feb. 2000;25(1):45-56. X-2, X-4. [pmid: 10708318].
4087 Williams D. Acute bronchospasm from the patient's perspective: role of patient education. Pharmacotherapy. Sep. 2006;26(9 Pt 2):193S-9S. X-1, X-2, X-3, X-4, X-6. [pmid: 16945066].
4088 Williams GC, Freedman ZR, Deci EL. Supporting autonomy to motivate patients with diabetes for glucose control. Diabetes Care. Oct. 1998;21(10):1644-51. X-2, X-4, X-6. [pmid: 9773724].
4089 Williams IC, Utz SW, Jones R, et al. Recruitment of rural African Americans for research projects: lessons learned. Southern Online Journal of Nursing Research. 2011;11(1):17p. X-4, X-5.
4090 Williams J, Klinepeter K, Palmes G, et al. Use of an electronic record audit to enhance mental health training for pediatric residents. Teach Learn Med. Fall. 2007;19(4):357-61. X-5, X-6. [pmid: 17935465].
4091 Williams JH, Auslander WF, de Groot M, et al. Cultural relevancy of a diabetes prevention nutrition program for African American women. Health Promot Pract. Jan. 2006;7(1):56-67. X-1, X-2, X-3, X-4, X-6. [pmid: 16410421].
4092 Williams JH, Belle GA, Houston C, et al. Process evaluation methods of a peer-delivered health promotion program for African American women. Health Promotion Practice. 2001;2(2):135-42. X-4, X-5.
4093 Williams JW, Bhogte M, Flinn JF. Meeting the needs of primary care physicians: A guide to content for programs on depression. International Journal of Psychiatry in Medicine. 1998;28(1):123-36. X-1, X-2, X-4. [pmid: 9617652].
4094 Williams JW, Noel PH, Cordes JA, et al. Is this patient clinically depressed?. Jama-Journal of the American Medical Association. Mar. 2002;287(9):1160-70. X-1, X-2, X-3, X-4, X-6. [pmid: 11879114].
4095 Williams KP, Mabiso A, Todem D, et al. Differences in knowledge of breast cancer screening among African American, Arab American, and Latina women. Prev Chronic Dis. Jan. 2011;8(1):A20. X-7, X-9, X-10. [pmid: 21159232].
4096 Williams KP, Mullan PB, Fletcher F. Working with African American women to develop a cancer literacy assessment tool. J Cancer Educ. Winter. 2007;22(4):241-4. X-2, X-4. [pmid: 18067436].
4097 Williams ML, Hill G, Jackson M. The impact of an acute myocardial infarction guideline and pathway on racial outcomes at a university hospital. Ethn Dis. Summer. 2006;16(3):653-8. X-11, X-12. [pmid: 16937601].
4098 Williams ML, Morris MT 2nd, Ahmad U, et al. Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center. Ethn Dis. Winter. 2002;12(1):S1-58-62. X-2, X-4, X-7. [pmid: 11913623].
4099 Williams MV, Baker DW, Honig EG, et al. Inadequate literacy is a barrier to asthma knowledge and self-care. Chest. Oct. 1998;114(4):1008-15. X-2, X-4. [pmid: 9792569].
4100 Williams MV, Baker DW, Parker RM, et al. Relationship of functional health literacy to patients' knowledge of their chronic disease. A study of patients with hypertension and diabetes. Arch Intern Med. Jan. 26. 1998;158(2):166-72. X-2, X-4. [pmid: 9448555].
4101 Williams-Brown S, Baldwin DM, Bakos A. Storytelling as a method to teach African American women breast health information. J Cancer Educ. Winter. 2002;17(4):227-30. X-2, X-4. [pmid: 12556061].
4102 Willig JH, Westfall AO, Allison J, et al. Nucleoside reverse-transcriptase inhibitor dosing errors in an outpatient HIV clinic in the electronic medical record era. Clin Infect Dis. Sep. 1. 2007;45(5):658-61. X-2, X-4, X-5. [pmid: 17683005].
4103 Willis MA, Davis M, Cairns NU, et al. Inter-agency collaboration: teaching breast self-examination to black women. Oncol Nurs Forum. Mar-Apr. 1989;16(2):171-7. X-1, X-2, X-4. [pmid: 2928267].
4104 Wilmoth MC, Coleman EA, Wahab HT. Initial validation of the symptom cluster of fatigue, weight gain, psychologic distress and altered sexuality. Southern Online Journal of Nursing Research. 2009;9(3):7p. X-2, X-4, X-6.
4105 Wilson E, Wardle EV, Chandel P, et al. Diabetes education: an Asian perspective. Diabet Med. Mar. 1993;10(2):177-80. X-9. [pmid: 8458197].
4106 Wilson EA, Park DC, Curtis LM, et al. Media and memory: the efficacy of video and print materials for promoting patient education about asthma. Patient Educ Couns. Sep. 2010;80(3):393-8. X-6. [pmid: 20688454].
4107 Wilson EA, Wolf MS, Curtis LM, et al. Literacy, cognitive ability, and the retention of health-related information about colorectal cancer screening. J Health Commun. Suppl 2. 2010;15:116-25. X-2, X-4. [pmid: 20845198].
4108 Wilson FL, Baker LM, Nordstrom CK, et al. Using the teach-back and Orem's Self-care Deficit Nursing theory to increase childhood immunization communication among low-income mothers. Issues in Comprehensive Pediatric Nursing. Mar. 2008;31(1):7-22. X-4. [pmid: 18300059].
4109 Wilson N, Daley C. Staff development story. Health literacy: promoting the health professionals' role. J Nurses Staff Dev. Nov-Dec. 2009;25(6):319-20. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19955982].
4110 Wilson SR, Scamagas P, Grado J, et al. The Fresno Asthma Project: a model intervention to control asthma in multiethnic, low-income, inner-city communities. Health Educ Behav. Feb. 1998;25(1):79-98. X-1, X-3, X-4, X-6. [pmid: 9474501].
4111 Wilson SR, Yamada EG, Sudhakar R, et al. A controlled trial of an environmental tobacco smoke reduction intervention in low-income children with asthma. Chest. Nov. 2001;120(5):1709-22. X-6, X-9. [pmid: 11713157].
4112 Wilson TE, Fraser-White M, Feldman J, et al. Hair salon stylists as breast cancer prevention lay health advisors for African American and Afro-Caribbean women. Journal of Health Care for the Poor and Underserved. Feb. 2008;19(1):216-26. X-7, X-9. [pmid: 18263997].
4113 Winget M, Hossain S, Yasui Y, et al. Characteristics of patients with stage III colon adenocarcinoma who fail to receive guideline-recommended treatment. Cancer. Oct. 15. 2010;116(20):4849-56. X-2, X-3, X-4. [pmid: 20578180].
4114 Winkelmayer WC, Owen W Jr., Glynn RJ, et al. Preventive Health Care Measures Before and After Start of Renal Replacement Therapy. Journal of General Internal Medicine. Aug. 2002;17(8):588-95. X-2, X-4. [pmid: 12213139].
4115 Winkelstein ML, Quartey R, Pham L, et al. Asthma education for rural school nurses: resources, barriers, and outcomes. J Sch Nurs. Jun. 2006;22(3):170-7. X-6. [pmid: 16704287].
4116 Winkleby MA, Flora JA, Kraemer HC. A community-based heart disease intervention: predictors of change. Am J Public Health. May. 1994;84(5):767-72. X-6, X-7, X-9. [pmid: 8179046].
4117 Winocour PH, Gosden C, Walton C, et al. Association of British Clinical Diabetologists (ABCD) and Diabetes-UK survey of specialist diabetes services in the UK, 2006. 1. The consultant physician perspective. Diabet Med. Jun. 2008;25(6):643-50. X-2, X-3, X-4, X-6. [pmid: 18544101].
4118 Winston CA, Mims AD, Leatherwood KA. Increasing pneumococcal vaccination in managed care through telephone outreach. Am J Manag Care. Oct. 2007;13(10):581-8. X-9. [pmid: 17927463].
4119 Winterfeld A, Longshore A. Diabetes: rising rates, disability and death. NCSL Legisbrief. Oct. 2006;14(41):1-2. X-1, X-2, X-3, X-4, X-6. [pmid: 17044158].
4120 Wintergerst KA, Hinkle KM, Barnes CN, et al. The impact of health insurance coverage on pediatric diabetes management. Diabetes Res Clin Pract. Oct. 2010;90(1):40-4. X-2, X-4. [pmid: 20630611].
4121 Wisdom K, Neighbors K, Williams VH, et al. Recruitment of African Americans with type 2 diabetes to a randomized controlled trial using three sources. Ethn Health. Nov. 2002;7(4):267-78. X-2, X-4, X-10. [pmid: 12772546].
4122 Wise M, Han JY, Shaw B, et al. Effects of using online narrative and didactic information on healthcare participation for breast cancer patients. Patient Educ Couns. Mar. 2008;70(3):348-56. X-7. [pmid: 18201859].
4123 Wise M, Pulvermacher A, Shanovich KK, et al. Using action research to implement an integrated pediatric asthma case management and eHealth intervention for low-income families. Health Promot Pract. Nov. 2010;11(6):798-806. X-1, X-2, X-4, X-10. [pmid: 19515862].
4124 Wisnivesky JP, Kattan M, Evans D, et al. Assessing the relationship between language proficiency and asthma morbidity among inner-city asthmatics. Med Care. Feb. 2009;47(2):243-9. X-2, X-4. [pmid: 19169126].
4125 Wisnivesky JP, Lorenzo J, Lyn-Cook R, et al. Barriers to adherence to asthma management guidelines among inner-city primary care providers. Ann Allergy Asthma Immunol. Sep. 2008;101(3):264-70. X-2, X-4. [pmid: 18814449].
4126 Wissow LS, Kimel MBD. Assessing provider-patient-parent communication in the pediatric emergency department. Ambulatory Pediatrics. Jul-Aug. 2002;2(4):323-9. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 12135407].
4127 Wissow LS, Roter D, Bauman LJ, et al. Patient-provider communication during the emergency department care of children with asthma The National Cooperative Inner-City Asthma Study, National Institute of Allergy and Infectious Diseases, NIH, Bethesda, MD. Med Care. Oct. 1998;36(10):1439-50. X-2, X-4, X-6. [pmid: 9794338].
4128 Witt K, Knudsen E, Ditlevsen S, et al. Academic detailing has no effect on prescribing of asthma medication in Danish general practice: a 3-year randomized controlled trial with 12-monthly follow-ups. Fam Pract. Jun. 2004;21(3):248-53. X-3, X-6. [pmid: 15128684].
4129 4130. Wittich AR, Mangan J, Grad R, et al. Pediatric asthma: Caregiver health literacy and the clinician's perception. Journal of Asthma. Jan-Feb. 2007;44(1):51-5. X-2, X-4. [pmid: 17365205].
4130 Wofford JL, Smith ED, Miller DP. The multimedia computer for office-based patient education: a systematic review. Patient Education and Counseling. Nov. 2005;59(2):148-57. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 16257619].
4131 Wolever RQ, Dreusicke M, Fikkan J, et al. Integrative health coaching for patients with type 2 diabetes: a randomized clinical trial. Diabetes Educ. Jul-Aug. 2010;36(4):629-39. X-4, X-6. [pmid: 20534872].
4132 Wolff BG. “Latch on to the affirmative: don't mess with Mr. In-Between”. Dis Colon Rectum. May. 2006;49(5):547-56. X-1, X-6, X-7, X-9. [pmid: 16598406].
4133 Wolff K, Cavanaugh K, Malone R, et al. The Diabetes Literacy and Numeracy Education Toolkit (DLNET): materials to facilitate diabetes education and management in patients with low literacy and numeracy skills. Diabetes Educ. Mar-Apr. 2009;35(2):233-6. 8. 41. 44. 5. X-1, X-2, X-3, X-4, X-6. [pmid: 19240246].
4134 Wolfklein GP. NEW ALZHEIMERS DRUG EXPANDS YOUR OPTIONS IN SYMPTOM MANAGEMENT. Geriatrics. Aug. 1993;48(8):26-&. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 8339940].
4135 Wolleswinkel-van den Bosch JH, Vredevoogd CB, Borkent-Polet M, et al. Substandard factors in perinatal care in The Netherlands: a regional audit of perinatal deaths. Acta Obstet Gynecol Scand. Jan. 2002;81(1):17-24. X-2, X-3, X-4, X-6. [pmid: 11942882].
4136 Wong FK, Lam YK, Poon A. Depression literacy among Australians of Chinese-speaking background in Melbourne. Australia BMC Psychiatry. 2010;10:7. X-2, X-3, X-4. [pmid: 20082724].
4137 Wong GC, Bernaards CA, Berman BA, et al. Do children with asthma and their parents agree on household ETS exposure? Implications for asthma management. Patient Educ Couns. Apr. 2004;53(1):19-25. X-2, X-4, X-6. [pmid: 15062900].
4138 Wong J, Wong S, Weerasinghe S, et al. Viewpoint. Building community partnerships for diabetes primary prevention: lessons learned. Clinical Governance: An International Journal. 2005;10(1):6-14. X-1, X-2, X-3, X-4, X-6.
4139 Wong ML, Ng TP, Hong CY, et al. Understanding asthma: patient survey. Ann Acad Med Singapore. Nov. 1994;23(6):861-5. X-2, X-3, X-4, X-6. [pmid: 7741500].
4140 Wong WS, Fielding R. A longitudinal analysis of patient satisfaction and subsequent quality of life in Hong Kong Chinese breast and nasopharyngeal cancer patients. Med Care. Aug. 2009;47(8):875-81. X-2, X-3, X-4, X-6. [pmid: 19584760].
4141 Wonghongkul T, Sawasdisingha P, Aree P, et al. Effect of educative -- supportive program on quality of life in breast cancer survivors. Thai Journal of Nursing Research. 2008;12(3):179-93. X-3, X-4, X-6.
4142 Wong-Kim E, Chilton JA, Goh SS, et al. Breast health issues of undocumented women in California and Texas. J Cancer Educ. Suppl 2. 2009;24:S64-7. X-1, X-7, X-9. [pmid: 20024832].
4143 Wongpiriyayothar A, Pothiban L, Liehr P, et al. Effects of home-based care program on symptom alleviation and well-being among persons with chronic heart failure. Thai Journal of Nursing Research. 2008. Jan-Mar. 2008;12(1):25-39. X-4, X-6.
4144 Woo K, Farber A, Doros G, et al. Evaluation of the efficacy of the transposed upper arm arteriovenous fistula: a single institutional review of 190 basilic and cephalic vein transposition procedures. J Vasc Surg. Jul. 2007;46(1):94-9. discussion 100. X-2, X-4, X-6. [pmid: 17543490].
4145 Wood DM, Hill D, Gunasekera A, et al. Is cocaine use recognised as a risk factor for acute coronary syndrome by doctors in the UK?. Postgrad Med J. May. 2007;83(979):325-8. X-2, X-3, X-4, X-5, X-6. [pmid: 17488862].
4146 Wood DM, Jones KD. Comparing NHANES data in the assessment of hypertension of African-Americans. Awareness, treatment and control of hypertension in an urban Maryland city. Md Med. Spring. 2002;3(2):57-9. X-2, X-4. [pmid: 12056231].
4147 Wood F, Jacobson S. Employee perceptions of diabetes education needs: a focus group study. AAOHN J. Oct. 2005;53(10):443-9. X-2, X-4, X-6. [pmid: 16255527].
4148 Wood FG, Jacobson S. Educating supervisors of employees with diabetes. AAOHN J. Jun. 2008;56(6):262-7. X-4, X-6. [pmid: 18604922].
4149 Wood MR, Price JH, Dake JA, et al. African American parents'/guardians' health literacy and self-efficacy and their child's level of asthma control. J Pediatr Nurs. Oct. 2010;25(5):418-27. X-2, X-4. [pmid: 20816565].
4150 Wood P, Tumiel-Berhalter L, Owen S, et al. Implementation of an asthma intervention in the inner city. Ann Allergy Asthma Immunol. Jul. 2006;97(1 Suppl 1):S20-4. X-4, X-7, X-10. [pmid: 16892767].
4151 Wood RY, Della-Monica NR. Promoting breast health: older women's perceptions of an innovative intervention to enhance screening. International Journal of Older People Nursing. 2006;1(2):75-84. X-4, X-6, X-7, X-9. [pmid: 20925733].
4152 Wood RY, Duffy ME. Video breast health kits: testing a cancer education innovation in older high-risk populations. J Cancer Educ. Summer. 2004;19(2):98-104. X-7. [pmid: 15456666].
4153 Wood RY, Duffy ME, Morris SJ, et al. The effect of an educational intervention on promoting breast self-examination in older African American and Caucasian women. Oncol Nurs Forum. Aug. 2002;29(7):1081-90. X-9. [pmid: 12183756].
4154 Woodard LD, Kressin NR, Petersen LA. Is lipid-lowering therapy underused by African Americans at high risk of coronary heart disease within the VA health care system?. Am J Public Health. Dec. 2004;94(12):2112-7. X-2, X-4. [pmid: 15569962].
4155 Woods E, Bhaumik U, Nethersole S, et al. Quality Improvement Evaluation of Community Asthma Initiative: One Year Follow-Up, Adolescent Findings and Two Year Cost Analysis. Journal of Adolescent Health. 2010;46(2, Supplement 1):S9-S. X-6.
4156 Woolfson P, Hood V, Secker-Walker R, et al. Mohawk English in the medical interview. Med Anthropol Q. Dec. 1995;9(4):503-9. X-1, X-2, X-4, X-5. [pmid: 8748476].
4157 Worden JK, Solomon LJ, Flynn BS, et al. A community-wide program in breast self-examination training and maintenance. Prev Med. May. 1990;19(3):254-69. X-6, X-9. [pmid: 2377588].
4158 Wray RJ, Buskirk TD, Jupka K, et al. Influenza vaccination concerns among older Blacks: A randomized controlled trial. American Journal of Preventive Medicine. May. 2009;36(5):429-34. X-5. [pmid: 19269130].
4159 Wray RJ, Jupka K, Ross W, et al. How can you improve vaccination rates among older African Americans? Patients want you to address their fear of drug interactions and allergic reactions. The Journal of Family Practice. Nov. 2007;56(11):925-9. X-2, X-4, X-5. [pmid: 17976341].
4160 Wright JA, Wallston KA, Elasy TA, et al. Development and results of a kidney disease knowledge survey given to patients with CKD. Am J Kidney Dis. Mar. 2011;57(3):387-95. X-2, X-4. [pmid: 21168943].
4161 Wright K, Jones L, Hogan V. A roadmap for authentic community/academic engagement for developing effective community preterm birth education. Ethn Dis. Winter. 2010;20(1 Suppl 2):S2-77-82. X-1, X-2, X-3, X-4, X-6. [pmid: 20629249].
4162 Wright RJ, Suglia SF, Levy J, et al. Transdisciplinary research strategies for understanding socially patterned disease: the Asthma Coalition on Community, Environment, and Social Stress (ACCESS) project as a case study. Cien Saude Colet. Nov-Dec. 2008;13(6):1729-42. X-1, X-2, X-3, X-4, X-6. [pmid: 18833350].
4163 Wu AC, Glauber J, Gay C, et al. Asthma self-assessment in a Medicaid population. BMC Public Health. 2009;9:244. X-6, X-9. [pmid: 19607719].
4164 Wu AC, Smith L, Bokhour B, et al. Racial/ethnic variation in parent perceptions of asthma. Ambulatory Pediatrics. Mar-Apr. 2008;8(2):89-97. X-2, X-4. [pmid: 18355737].
4165 Wu JR, Moser DK, Chung ML, et al. Predictors of medication adherence using a multidimensional adherence model in patients with heart failure. J Card Fail. Sep. 2008;14(7):603-14. X-2, X-4. [pmid: 18722327].
4166 Wu P, Hoven CW, Cohen P, et al. Factors associated with use of mental health services for depression by children and adolescents. Psychiatr Serv. Feb. 2001;52(2):189-95. X-2, X-4. [pmid: 11157117].
4167 Wu TY, Kao JY, Hsieh HF, et al. Effective colorectal cancer education for Asian Americans: a Michigan program. J Cancer Educ. Jun. 2010;25(2):146-52. X-7, X-9. [pmid: 20094825].
4168 Wu X, Richardson LC, Kahn AR, et al. Survival difference between non-Hispanic black and non-Hispanic white women with localized breast cancer: the impact of guideline-concordant therapy. J Natl Med Assoc. May. 2008;100(5):490-8. X-2, X-4. [pmid: 18507201].
4169 Wyatt G, Sikorskii A, Wills CE, et al. Complementary and alternative medicine use, spending, and quality of life in early stage breast cancer. Nurs Res. Jan-Feb. 2010;59(1):58-66. X-2, X-3, X-4, X-6. [pmid: 20010046].
4170 Wyatt SB, Akylbekova EL, Wofford MR, et al. Prevalence, awareness, treatment, and control of hypertension in the Jackson Heart Study. Hypertension. Mar. 2008;51(3):650-6. X-6, X-7, X-9. [pmid: 18268140].
4171 Wylie-Rosett J, Cypress M, Walker E, et al. Assessment of nutrition care provided to patients with diabetes in primary-care clinics. J Am Diet Assoc. Jul. 1992;92(7):854-6. X-2. [pmid: 1497752].
4172 Wylie-Rosett J, Engel S, D'Eramo G, et al. Delivery of diabetes care to low--income patients: assessment of a federally funded program. Diabetes Educ. Jul-Aug. 1989;15(4):366-9. X-6, X-7, X-9. [pmid: 2791863].
4173 Wynn TA, Taylor-Jones MM, Johnson RE, et al. Using community-based participatory approaches to mobilize communities for policy change. Family & Community Health. Suppl 1. 2011;34(S102):14. X-2, X-4. [pmid: 21160326].
4174 Xaba GL, Dewar SR. The health behaviour of Black insulin dependent diabetic patients. Curationis. Aug. 1991;14(2):17-9. X-2, X-4. [pmid: 1845618].
4175 Xu Y, Pan W, Liu H. Self-management practices of Chinese Americans with type 2 diabetes. Nurs Health Sci. Jun. 2010;12(2):228-34. X-2, X-4. [pmid: 20602696].
4176 Yaghoubian A, Lewis RJ, de Virgilio C. Can the National Kidney Foundation guidelines for first-time arteriovenous fistula creation be met in underserved end-stage renal disease patients?. Ann Vasc Surg. Jan. 2008;22(1):5-10. X-2, X-4. [pmid: 18083330].
4177 Yamagishi M, Kobayashi T, Nagami M, et al. Effect of web-based assertion training for stress management of Japanese nurses. J Nurs Manag. Sep. 2007;15(6):603-7. X-3, X-4, X-5, X-6. [pmid: 17688565].
4178 Yamashita T, Kart CS. Is diabetes-specific health literacy associated with diabetes-related outcomes in older adults?. J Diabetes. Jun. 2011;3(2):138-46. X-2, X-4. [pmid: 21599867].
4179 Yancy CW, Abraham WT, Albert NM, et al. Quality of care of and outcomes for African Americans hospitalized with heart failure: findings from the OPTIMIZE-HF (Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients With Heart Failure) registry. J Am Coll Cardiol. Apr. 29. 2008;51(17):1675-84. X-9. [pmid: 18436120].
4180 Yarnall KS, Rimer BK, Hynes D, et al. Computerized prompts for cancer screening in a community health center. J Am Board Fam Pract. Mar-Apr. 1998;11(2):96-104. X-2, X-4, X-6. [pmid: 9542701].
4181 Yates BC. The relationships among social support and short- and long-term recovery outcomes in men with coronary heart disease. Res Nurs Health. Jun. 1995;18(3):193-203. X-2, X-4, X-6. [pmid: 7754090].
4182 Yazdany J, Tonner C, Trupin L, et al. Provision of preventive health care in systemic lupus erythematosus: data from a large observational cohort study. Arthritis Res Ther. 2010;12(3):R84. X-2, X-4, X-5. [pmid: 20462444].
4183 Ye X, Gross CR, Schommer J, et al. Initiation of statins after hospitalization for coronary heart disease. J Manag Care Pharm. Jun. 2007;13(5):385-96. X-2, X-4, X-6. [pmid: 17605510].
4184 Yeates K, Houlden RL. Canadian Diabetes Association clinical practice guidelines for the treatment of diabetes mellitus and Native Canadians on Manitoulin Island. Canadian Journal of Diabetes Care. 1997;21(2):22-7. X-2, X-3, X-4.
4185 Yeboah-Korang A, Kleppinger A, Fortinsky RH. Racial and ethnic group variations in service use in a national sample of Medicare home health care patients with type 2 diabetes mellitus. J Am Geriatr Soc. Jun. 2011;59(6):1123-9. X-2, X-4. [pmid: 21649625].
4186 Yelland MJ, Schluter PJ. Defining worthwhile and desired responses to treatment of chronic low back pain. Pain Med. Jan-Feb. 2006;7(1):38-45. X-2, X-4, X-5, X-6. [pmid: 16533195].
4187 Yeo SG, Parker G, Yap HL, et al. Mental health literacy beliefs. A comparison of psychiatric trained nurses and enrolled nurses in Singapore. J Psychosoc Nurs Ment Health Serv. Mar. 2003;41(3):34-41. X-2, X-3, X-4. [pmid: 12643081].
4188 Yeom HE, Heidrich SM. Effect of perceived barriers to symptom management on quality of life in older breast cancer survivors. Cancer Nurs. Jul-Aug. 2009;32(4):309-16. X-2, X-4, X-6. [pmid: 19444083].
4189 Yeung A, Kam R. Ethical and cultural considerations in delivering psychiatric diagnosis: reconciling the gap using MDD diagnosis delivery in less-acculturated Chinese patients. Transcult Psychiatry. Dec. 2008;45(4):531-52. X-1, X-2, X-4. [pmid: 19091724].
4190 Yeung A, Kung WW, Chung H, et al. Integrating psychiatry and primary care improves acceptability to mental health services among Chinese Americans. Gen Hosp Psychiatry. Jul-Aug. 2004;26(4):256-60. X-4, X-9. [pmid: 15234819].
4191 Yeung A, Kung WW, Murakami JL, et al. Outcomes of recognizing depressed Chinese American patients in primary care. Int J Psychiatry Med. 2005;35(3):213-24. X-4. [pmid: 16480237].
4192 Yeung A, Overstreet KM, Albert EV. Current practices in depression care. J Contin Educ Health Prof. Fall;. Suppl 1. 2007;27:S9-17. X-1, X-2, X-4. [pmid: 18085581].
4193 Yi JK, Luong KN. Apartment-based breast cancer education program for low income Vietnamese American women. J Community Health. Oct. 2005;30(5):345-53. X-8. [pmid: 16175957].
4194 Yi JK, Swartz MD, Reyes-Gibby CC. English Proficiency, Symptoms, and Quality of Life in Vietnamese- and Chinese-American Breast Cancer Survivors. Journal of Pain and Symptom Management. Jul. 2011;42(1):83-92. X-2, X-4. [pmid: 21227634].
4195 Yildirim Y. Patterns of the use of complementary and alternative medicine in women with metastatic cancer. Cancer Nurs. May-Jun. 2010;33(3):194-200. X-2, X-4, X-6. [pmid: 20357652].
4196 Yin X, Savage C, Toobert D, et al. Adaptation and testing of instruments to measure diabetes self-management in people with type 2 diabetes in mainland China. J Transcult Nurs. Jul. 2008;19(3):234-42. X-2, X-3, X-4. [pmid: 18579863].
4197 Yoon DP, Lee EO. Religiousness/spirituality and subjective well-being among rural elderly Whites, African Americans, and Native Americans. Journal of Human Behavior in the Social Environment. 2004;10(1):191-211. X-2, X-4, X-5.
4198 Yoon R, McKenzie DK, Miles DA, et al. Characteristics of attenders and non-attenders at an asthma education programme. Thorax. Dec. 1991;46(12):886-90. X-2, X-4. [pmid: 1792635].
4199 Yoos HL, Kitzman H, Henderson C, et al. The impact of the parental illness representation on disease management in childhood asthma. Nurs Res. May-Jun. 2007;56(3):167-74. X-2, X-4. [pmid: 17495572].
4200 Yoos HL, Kitzman H, McMullen A, et al. The language of breathlessness: do families and health care providers speak the same language when describing asthma symptoms?. J Pediatr Health Care. Jul-Aug. 2005;19(4):197-205. X-2, X-4, X-6. [pmid: 16010258].
4201 Yoos HL, McMullen A. Symptom perception and evaluation in childhood asthma. Nurs Res. Jan-Feb. 1999;48(1):2-8. X-2, X-4. [pmid: 10029396].
4202 Yoos HL, McMullen A, Bezek S, et al. An asthma management program for urban minority children. J Pediatr Health Care. Mar-Apr. 1997;11(2):66-74. X-6, X-9. [pmid: 9155350].
4203 Yost SE, Srinivas T, Kaplan B. Ethical considerations regarding disparities pertaining to kidney transplant patients. Clin Pharmacol Ther. Aug. 2011;90(2):212-4. X-1, X-2, X-4. [pmid: 21772298].
4204 Young AH, Currie A. Physicians' knowledge of antidepressant withdrawal effects: a survey. J Clin Psychiatry. Suppl 7. 1997;58:28-30. X-2, X-4. [pmid: 9219491].
4205 Young AS, Klap R, Shoai R, et al. Persistent depression and anxiety in the united states: Prevalence and quality of care. Psychiatric Services. Dec. 2008;59(12):1391-8. X-2, X-4. [pmid: 19033165].
4206 Young GJ, Cohen BB. The process and outcome of hospital care for Medicaid versus privately insured hospital patients. Inquiry. Fall. 1992;29(3):366-71. X-2, X-4, X-5. [pmid: 1398905].
4207 Young GJ, Meterko M, Beckman H, et al. Effects of paying physicians based on their relative performance for quality. J Gen Intern Med. Jun. 2007;22(6):872-6. X-4, X-6, X-7. [pmid: 17443360].
4208 Young RF, Schwartz K, Booza J. Medical barriers to mammography screening of African American women in a high cancer mortality area: implications for cancer educators and health providers. J Cancer Educ. Jun. 2011;26(2):262-9. X-2, X-4. [pmid: 21210272].
4209 Young RF, Waller JB Jr., Smitherman H. A breast cancer education and on-site screening intervention for unscreened African American women. J Cancer Educ. Winter. 2002;17(4):231-6. X-4. [pmid: 12556062].
4210 Youssef RM, Moubarak II. Patterns and determinants of treatment compliance among hypertensive patients. East Mediterr Health J. Jul-Sep. 2002;8(4-5):579-92. X-2, X-4, X-6. [pmid: 15603041].
4211 Yu GC, Beresford R. Implementation of a chronic illness model for diabetes care in a family medicine residency program. J Gen Intern Med. Sep. Suppl 4. 2010;25:S615-9. X-4, X-6. [pmid: 20737237].
4212 Yu MY, Song L, Seetoo A, et al. Culturally competent training program: a key to training lay health advisors for promoting breast cancer screening. Health Educ Behav. Dec. 2007;34(6):928-41. X-2, X-4, X-10. [pmid: 17965228].
4213 Yuan ASV. Sibling relationships and adolescents' mental health: the interrelationship of structure and quality. Journal of Family Issues. 2009;30(9):1221-44. X-2, X-4, X-5, X-6.
4214 Yuen HK, Burik JK, Krause JS. Physical and psychosocial well-being among adults with spinal cord injury: the role of volunteer activities. Topics in Spinal Cord Injury Rehabilitation. 2004;9(4):19-25. X-2, X-4, X-5, X-6.
4215 Yuen HK, Huang P, Burik JK, et al. Impact of participating in volunteer activities for residents living in long-term-care facilities. American Journal of Occupational Therapy. Jan-Feb. 2008;62(1):71-6. X-5. [pmid: 18254433].
4216 Yun LS, Hassan Y, Aziz NA, et al. A comparison of knowledge of diabetes mellitus between patients with diabetes and healthy adults: a survey from north Malaysia. Patient Educ Couns. Dec. 2007;69(1-3):47-54. X-2, X-3, X-4, X-6. [pmid: 17720351].
4217 Yuval R, Halon DA, Lewis BS. Perceived disability and lifestyle modification following hospitalization for non-ST elevation versus ST elevation acute coronary syndromes: the patients' point of view. Eur J Cardiovasc Nurs. Dec. 2007;6(4):287-92. X-2, X-4. [pmid: 17449324].
4218 Zachariah R. Attachment, social support, life stress, and psychological well-being in pregnant low-income women: a pilot study. Clinical Excellence for Nurse Practitioners. 2004;8(2):60-7. X-2, X-4, X-5.
4219 Zambroski CH. Qualitative analysis.of living with heart failure. Heart & Lung. Jan-Feb. 2003;32(1):32-40. X-2, X-4, X-6. [pmid: 12571546].
4220 Zamora D, Gordon-Larsen P, He K, et al. Are the 2005 Dietary Guidelines for Americans Associated With reduced risk of type 2 diabetes and cardiometabolic risk factors? Twenty-year findings from the CARDIA study. Diabetes Care. May. 2011;34(5):1183-5. X-2, X-4. [pmid: 21478463].
4221 Zanetti ML, Otero LM, Biaggi MV, et al. Satisfaction of diabetes patients under follow-up in a diabetes education program. Rev Lat Am Enfermagem. Jul-Aug. 2007;15(4):583-9. X-2, X-3, X-4. [pmid: 17923974].
4222 Zapka JG, Chasan L, Barth R, et al. Emphasizing screening activities in a community health center: a case study of a breast cancer screening project. J Ambul Care Manage. Jan. 1992;15(1):38-47. X-1, X-6, X-7, X-9. [pmid: 10115228].
4223 Zapka JG, Harris DR, Hosmer D, et al. Effect of a community health center intervention on breast cancer screening among Hispanic American women. Health Serv Res. Jun. 1993;28(2):223-35. X-4, X-9. [pmid: 8514501].
4224 Zapka JG, Puleo E, Taplin SH, et al. Processes of care in cervical and breast cancer screening and follow-up--the importance of communication. Preventive Medicine: An International Journal Devoted to Practice and Theory. Jul. 2004;39(1):81-90. X-2, X-4. [pmid: 15207989].
4225 Zarb J. Correlates of depression in cognitively impaired hospitalized elderly referred for neuropsychological assessment. J Clin Exp Neuropsychol. Oct. 1996;18(5):713-23. X-2, X-3, X-4, X-6. [pmid: 8941856].
4226 Zayas LE, McLean D. Asthma patient education opportunities in predominantly minority urban communities. Health Educ Res. Dec. 2007;22(6):757-69. X-2, X-4. [pmid: 16896054].
4227 Zeh P. Delivering diabetes care to ethnic groups: a pilot general practice survey. Diabetes & Primary Care. 2010;12(5):11p. X-2, X-3, X-4.
4228 Zeitler P. Approach to the obese adolescent with new-onset diabetes. J Clin Endocrinol Metab. Dec. 2010;95(12):5163-70. X-1, X-2, X-4, X-6. [pmid: 21131537].
4229 Zgibor JC, Simmons D. Barriers to blood glucose monitoring in a multiethnic community. Diabetes Care. Oct. 2002;25(10):1772-7. X-2, X-3, X-4. [pmid: 12351476].
4230 Zhang JX, Huang ES, Drum ML, et al. Insurance status and quality of diabetes care in community health centers. Am J Public Health. Apr. 2009;99(4):742-7. X-2, X-4. [pmid: 18799773].
4231 Zhang W, Ayanian JZ, Zaslavsky AM. Patient characteristics and hospital quality for colorectal cancer surgery. Int J Qual Health Care. Feb. 2007;19(1):11-20. X-2, X-4. [pmid: 17000710].
4232 Zhao J, Ang Q, Wang J, et al. A comparative efficacy of fluoxetine and trazodone in depression with remarkable retardation and loss of energy: a randomized open-label trial. International Medical Journal. 2006;13(1):25-30. X-3, X-6, X-7.
4233 Zhao Y, Ash AS, Ellis RP, et al. Disease burden profiles: an emerging tool for managing managed care. Health Care Manag Sci. Aug. 2002;5(3):211-9. X-2, X-4. [pmid: 12363048].
4234 Zhong X, Tanasugarn C, Fisher EB, et al. Awareness and practices of self-management and influence factors among individuals with type 2 diabetes in urban community settings in Anhui Province, China. Southeast Asian J Trop Med Public Health. Jan. 2011;42(1):185-6. 47. 96. X-2, X-3, X-4, X-6. [pmid: 21323182].
4235 Zhou J, Enewold L, Peoples GE, et al. Colorectal, prostate, and skin cancer screening among Hispanic and White non-Hispanic men, 2000-2005. J Natl Med Assoc. Apr. 2011;103(4):343-50. X-7, X-9. [pmid: 21805813].
4236 Zickmund SL, Blasiole JA, Brase V, et al. Congestive heart failure patients report conflict with their physicians. J Card Fail. Sep. 2006;12(7):546-53. X-2, X-4. [pmid: 16952789].
4237 Ziemer DC, Berkowitz KJ, Panayioto RM, et al. A simple meal plan emphasizing healthy food choices is as effective as an exchange-based meal plan for urban African Americans with type 2 diabetes. Diabetes Care. Jun. 2003;26(6):1719-24. X-6, X-7, X-9. [pmid: 12766100].
4238 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. Mar. 13. 2006;166(5):507-13. X-6, X-9. [pmid: 16534036].
4239 Zikmund-Fisher BJ, Angott AM, Ubel PA. The benefits of discussing adjuvant therapies one at a time instead of all at once Breast Cancer Research and Treatment. Aug. 2011;129(1):79-87. X-6, X-7, X-9, X-10. [pmid: 20945090].
4240 Zikmund-Fisher BJ, Fagerlin A, Ubel PA. Risky feelings: Why a 6 risk of cancer does not always feel like 6. Patient Education and Counseling. Dec. 2010;81:S87-S93. X-1, X-2, X-4, X-5, X-6. [pmid: 20739135].
4241 Zikmund-Fisher BJ, Fagerlin A, Ubel PA. A Demonstration of “Less Can Be More” in Risk Graphics. Medical Decision Making. Nov-Dec. 2010;30(6):661-71. X-5, X-8, X-10. [pmid: 20375419].
4242 Zikmund-Fisher BJ, Ubel PA, Smith DM, et al. Communicating side effect risks in a tamoxifen prophylaxis decision aid: The debiasing influence of pictographs. Patient Education and Counseling. Nov. 2008;73(2):209-14. X-6, X-7, X-10. [pmid: 18602242].
4243 Zima BT, Hurlburt MS, Knapp P, et al. Quality of Publicly-Funded Outpatient Specialty Mental Health Care for Common Childhood Psychiatric Disorders in California. Journal of the American Academy of Child & Adolescent Psychiatry. Feb. 2005;44(2):130-44. X-2, X-4, X-5. [pmid: 15689726].
4244 Zimmerman BJ, Bonner S, Evans D, et al. Self-regulating childhood asthma: a developmental model of family change. Health Educ Behav. Feb. 1999;26(1):55-71. X-2, X-4, X-6. [pmid: 9952052].
4245 Zimmerman RK, Mieczkowski TA, Wilson SA. Immunization rates and beliefs among elderly patients of inner city neighborhood health centers. Health Promotion Practice. 2002;3(2):197-206. X-2, X-4.
4246 Zimmerman RK, Nowalk MP, Raymund M, et al. Tailored interventions to increase influenza vaccination in neighborhood health centers serving the disadvantaged. Am J Public Health. Oct. 2003;93(10):1699-705. X-5. [pmid: 14534225].
4247 Zimmerman RK, Nowalk MP, Tabbarah M, et al. Predictors of colorectal cancer screening in diverse primary care practices. BMC Health Serv Res. 2006;6:116. X-2, X-4. [pmid: 16970813].
4248 Zimmerman RK, Silverman M, Janosky JE, et al. A comprehensive investigation of barriers to adult immunization: a methods paper. J Fam Pract. Aug. 2001;50(8):703. X-1, X-2, X-4, X-5. [pmid: 11509165].
4249 Zink MR. Social support and knowledge level of the older adult homebound person with diabetes. Public Health Nurs. Aug. 1996;13(4):253-62. X-2, X-4, X-6. [pmid: 8828386].
4250 Zittel-Palamara K, Rockmaker JR, Schwabel KM, et al. Desired assistance versus care received for postpartum depression: access to care differences by race. Arch Womens Ment Health. Jun. 2008;11(2):81-92. X-2, X-4, X-5. [pmid: 18463943].
4251 Zook PM, Jordan C, Adams B, et al. Retention strategies and predictors of attrition in an urban pediatric asthma study. Clin Trials. Aug. 2010;7(4):400-10. X-2, X-4. [pmid: 20571137].
4252 Zorc JJ, Chew A, Allen JL, et al. Beliefs and barriers to follow-up after an emergency department asthma visit: a randomized trial. Pediatrics. Oct. 2009;124(4):1135-42. X-6, X-9. [pmid: 19786448].
4253 Zucker TL, Samuelson KW, Muench F, et al. The effects of respiratory sinus arrhythmia biofeedback on heart rate variability and posttraumatic stress disorder symptoms: a pilot study. Appl Psychophysiol Biofeedback. Jun. 2009;34(2):135-43. X-4, X-5, X-6. [pmid: 19396540].
4254 Zuckerman IH, Stuart B, Magder LS, et al. Adherence to asthma treatment guidelines among children in the Maryland Medicaid Program. Current Therapeutic Research. 2000;61(12):912-24. X-2, X-4.
4255 Zuidgeest MG, van Dijk L, Spreeuwenberg P, et al. What drives prescribing of asthma medication to children? A multilevel population-based study. Ann Fam Med. Jan-Feb. 2009;7(1):32-40. X-2, X-3, X-4. [pmid: 19139447].
4256 Zuniga GC, Hernandez T, Kirk S, et al. On linkages: a multi-institutional collaboration to develop asthma education for school settings in south Texas. Public Health Rep. Jan-Feb. 2011;126(1):139-44. X-8. [pmid: 21337940].
4257 Zust BL. Meaning of INSIGHT participation among women who have experienced intimate partner violence. Issues Ment Health Nurs. Aug-Sep. 2006;27(7):775-93. X-2, X-4, X-5. [pmid: 16849263].
4258 Zweifler M, Rodriguez E, Reilly J, et al. Breast reconstruction among inner city women with breast carcinoma. Ann Plast Surg. Jul. 2001;47(1):53-9. X-2, X-4, X-5. [pmid: 11756804].