# Applicability Tables

Table K-1 Applicability of evidence from cancer screening studies

Domain | Description of applicability of evidence
Population | Studies included patients cared for at community clinics in New York City, men treated at two Veterans Affairs clinics in Chicago, low-income primary care patients, men and women patients of a large urban primary care practice, and women enrolled in a large group model HMO in the northeastern US. As the populations were varied, study results may or may not be applicable to other areas.
Intervention | The studied interventions included provider education, audit and feedback, and patient education that was sensitive to low health literacy; mailed or telephone reminders to undergo screening; a targeted intervention by mail or mail intervention plus telephone reminders to encourage screening; patient navigator based education to undergo screening; and language-concordant patient education and care management. With the exception of mailed reminders (which were ineffective), these interventions required significant organizational resources to develop and implement and may not be feasible in other settings.
Comparators | The studies employed usual care as the comparator, which may differ in other settings.
Outcomes | Studies focused on process measures, namely, performance of breast, cervical, and colorectal cancer screening during follow-up. Included studies did not assess clinical outcomes, such as diagnosis of malignancies, leaving the long-term clinical impact unclear.
Setting | Studies were conducted in community clinics in New York City, VA clinics in Chicago, community health centers and public hospitals in Massachusetts, an academic primary care practice in Philadelphia, and a large group model HMO in the Northeast.

Table K-2 Applicability of evidence from cardiovascular disease studies

Domain | Description of applicability of evidence
Population | Studies of CAD risk factor control included men enrolled at clinical centers in 18 US cities and patients cared for at two university-affiliated primary care clinics in North Carolina. A study of AMI treatment included patients at academic and community hospitals in Michigan. The results of the latter two studies are applicable to ambulatory and hospitalized patients, respectively. However, the 18-city study, involving men only, has limited applicability to women.
Intervention | Interventions for CAD risk factor control included intensive patient education and self-management. The intervention for AMI treatment involved provider education, practice feedback, and a toolkit. The CAD risk factor interventions required significant institutional resources, and may or may not be feasible outside the research setting. The AMI intervention is part of a national guideline implementation initiative and has been applied in both research and clinical contexts.
Comparators | Usual care served as the comparator, which may differ in other settings.
Outcomes | Studies of CAD risk factor control reported intermediate clinical outcomes (blood pressure, cholesterol, smoking, weight). The study of AMI treatment assessed numerous process and utilization measures (prescription of evidence-based medications, smoking cessation counseling, use of the toolkit, echocardiography, cardiac catheterization, PCI, CABG), as well as proximal adverse clinical events (hypotension, shock, heart failure, pulmonary edema, stroke, renal insufficiency, bleeding). None of these studies reported subsequent health care utilization or longer-term clinical outcomes such as myocardial infarction (or reinfarction), or mortality, leaving the effect of the interventions on such issues unclear.
Setting | Among studies to improve CAD risk factor control, one was conducted in university-affiliated clinics; its results are applicable to academic primary care practices and may or may not be applicable to other outpatient primary care and subspecialty clinics. The other occurred in community clinics in 18 cities around the US, but enrolled patients between 1973 and 1975 and has limited applicability to present day practice. The AMI treatment intervention took place in academic and community hospitals, and is applicable to those settings.

Table K-3 Applicability of evidence from depression care studies

Domain | Description of applicability of evidence
Population | Two of the three studies focused on elderly patients in primary care. One included a range of ages in adulthood. All included both men and women and were racially diverse. Nonetheless, this represents a small proportion of the individuals who struggle with depression. It is unclear whether the observed results apply to apply to patient populations who receive their primary and mental health care outside of a managed care system, or to harder to reach individuals not receiving regular medical care. Given the settings in which the study took place, they also may not apply to vulnerable populations receiving care through public health systems.
Intervention | The intervention in all cases was some variation on a collaborative care model that included a care manager, usually a nurse. The interventions were all intensive in terms of demand on resources and required strong communication between care providers. One study had two interventions: one focused on providing training to the practice in medical management and one on therapy. Patients and their physicians, however, could also select any approach to managing their depression.
Comparators | All of the studies compared the intervention to usual care, although usual care was not ever completely described and therefore would be expected to vary.
Outcomes | Generally speaking, outcomes were appropriate and reflected those that would and could be used in practice. They included changes in depressive symptoms, incidence of probably depressive disorder, mental health related quality of life, functional impairment, and receipt of appropriate depression care.
Setting | All of the studies were conducted in primary care practices associated with larger healthcare organizations. It is unclear whether results would therefore apply to other settings, including individual practices without the resources of a larger organization, or assisted living facilities (pertinent because of the focus on the elderly population).

Table K-4 Applicability of evidence from diabetes care studies

Domain | Description of applicability of evidence
Population | Studies included people cared for by primary care clinicians in ambulatory health centers in eastern Massachusetts, diabetes disease management program members living in socioeconomic disparate areas throughout the U.S., and Medicare patients in New York State. Therefore, the results may or may not be applicable to other populations in other regions.
Intervention | Interventions evaluated included cultural competency training for clinicians and race-stratified performance reports with recommendations for Black diabetic patients, patient telephone reminders in Health Disparity Zones, defined as one with diabetes prevalence above the national average for minorities, and Medicare New York State Quality Improvement Organization (IPRO) multifaceted provider and community interventions. The interventions may not be available in other regions and settings, since they required significant programmatic and implementation resources.
Comparators | Comparators included usual care, process measures in Non-Health Disparity Zones; statewide interventions that IPRO implemented for the Physician Office Quality Improvement Project (POQIP). The usual care described in these studies may not be applicable to other settings and regions.
Outcomes | Studies reported surrogate clinical outcomes (HbA1c control), clinical risk factors for diabetes comorbidities (BP and lipid control), and process measures (HbA1c and LDL measurements). Duration of studies was generally 12 months. No studies reported any critically important clinical outcomes of diabetes such as death or micro-vascular and/or macro-vascular complications. Results from surrogate outcomes may not apply to important long-term clinical outcomes in people with diabetes.
Setting | Studies were conducted in ambulatory health centers in eastern Massachusetts, in diabetes disease management programs across the United States, and in New York state. As much of diabetes care is delivered in primary care ambulatory settings, the evidence would be applicable. However, specialty clinic settings were not reported and the evidence may not apply.