# Strength of Evidence for Outcomes

Table J1 Strength of evidence for outcomes in studies addressing disparities associated with race or ethnicity

Outcome/Intervention | Number of Studies (N) Study Design | Risk of Bias | Consistency | Directness | Precision | Overall SOE
Colorectal cancer screening
Multifaceted patient education/self management with limited language concordance and patient reminders | 1^1^ (465) RCT | High | Unknown | Indirect | Imprecise | Insufficient
Depression Severity Score (HSCL-20)
Collaborative care model plus clinical information tracking | 1^2^ (1748) RCT | High | Inconsistent | Direct | Imprecise | Insufficient
Mental Health Inventory
Collaborative care with medication adherance support. | 1^3^ (474) RCT | High | Inconsistent | Direct | Imprecise | Insufficient
Collaborative care with cognitive behavioral therapy | 1^3^ (474) RCT | High | Inconsistent | Direct | Imprecise | Insufficient
Depression symptoms
Collaborative care model | 1^4^ (396) RCT | Moderate | Inconsistent | Direct | Imprecise | Insufficient
Probable depressive disorder
Collaborative care with medication adherance support. | 2^5-7^ (1269) RCT | High | Inconsistent | Direct | Imprecise | Insufficient
Collaborative care with cognitive behavioral therapy | 2^5-7^ (1269) RCT | High | Inconsistent | Direct | Imprecise | Insufficient
Use of antidepressant medications
Collaborative care model plus clinical information tracking | 1^2^ (1748) RCT | High | Inconsistent | Indirect | Imprecise | Insufficient
Collaborative care model | 1^4^(396) RCT | Moderate | Inconsistent | Indirect | Imprecise | Insufficient
HbA1c goal <7% achieved
Patient education (cultural competency training) | 1^8^ (3773) RCT | Low | Unknown | Indirect | Imprecise | Insufficient
BP goal achieved
Patient education (cultural competency training) | 1^8^ (3773) RCT | Low | Unknown | Indirect | Imprecise | Insufficient
LDL cholesterol level goal achieved
Patient education (cultural competency training) | 1^8^ (3773) RCT | Low | Unknown | Indirect | Imprecise | Insufficient
HbA1c test
Patient reminder | 1^9^ (37425) Cohort | High | Unknown | Indirect | Imprecise | Insufficient
Lipid test
Multifaceted provider and community intervention | 1^10^ (28650) Cohort | Moderate | Unknown | Indirect | Imprecise | Insufficient
Smoking cessation
Patient education/self-management | 1^11^ (11392) Cohort | Moderate | Unknown | Indirect | Imprecise | Insufficient
Frequency of PCI, CABG, and cardiac catheterization
Multifaceted patient and provider education intervention and AMI GAP impementation | 1^12^ (2857) Cohort | High | Unknown | Indirect | Imprecise | Insufficient
Decreased systolic and diastolic blood pressure
Patient education/self-management | 1^13^ (636) RCT | Moderate | Unknown | Direct | Imprecise | Insufficient
Achieving diastolic blood pressure goal
Patient education/self-management | 1^11^ (11392) Cohort | Moderate | Unknown | Direct | Imprecise | Insufficient

Abbreviations: AMI=acute myocardial infarction; BP=blood pressure; GAP=American College of Cardiology's AMI Guidelines Applied in Practice; HbA1c=glycosylated hemoglobin; LDL=low density lipoprotein; PCI=percutaneous coronary intervention; RCT=randomized controlled trial; SOE=strength of evidence

Table J2 Strength of evidence for outcomes in studies addressing disparities associated with insurance status

Outcome/Intervention | Number of Studies (N) Study Design | Risk of Bias | Consistency | Directness | Precision | Overall SOE
Colorectal cancer screening
Multifaceted patient education/self management with limited language concordance and patient reminders | 1^1^ (465) RCT | High | Unknown | Indirect | Imprecise | Insufficient
Breast cancer screening
Patient reminder system plus scheduling | 1^14^ (3034) RCT | High | Unknown | Indirect | Precise | Insufficient

Abbreviations: RCT=randomized controlled trial; SOE=strength of evidence

Table J3 Strength of evidence for outcomes in studies addressing disparities associated with language

Outcome/Intervention | Number of Studies (N) Study Design | Risk of Bias | Consistency | Directness | Precision | Overall SOE
Colorectal cancer screening
Language concordant patient education/self-management | 1^15^ (1070) RCT | Moderate | Unknown | Indirect | Imprecise | Insufficient
Multifaceted patient education/self management with limited language concordance and patient reminders | 1^1^ (465) RCT | High | Unknown | Indirect | Imprecise | Insufficient
Breast cancer screening
Language concordant patient education/self-management | 1^15^ (1346) RCT | Moderate | Unknown | Indirect | Imprecise | Insufficient

Abbreviations: RCT=randomized controlled trial; SOE=strength of evidence

Table J4 Strength of evidence for outcomes in studies addressing disparities associated with health literacy

Outcome/Intervention | Number of Studies (N) Study Design | Risk of Bias | Consistency | Directness | Precision | Overall SOE
Colorectal cancer screening
Multifaceted patient and provider education and reminder intervention with audit and feedback | 1^16^ (1978) RCT | High | Unknown | Indirect | Imprecise | Insufficient

Abbreviations: RCT=randomized controlled trial; SOE=strength of evidence

Table J5 Strength of evidence for outcomes in studies addressing disparities associated with socioeconomic status

Outcome/Intervention | Number of Studies (N) Study Design | Risk of Bias | Consistency | Directness | Precision | Overall SOE
Use of antidepressant medications
Collaborative care model plus clinical information tracking | 1^17^(1801) RCT | Moderate | Inconsistent | Indirect | Precise | Insufficient
Collaborative care model | 1^4^(396) RCT | Moderate | Inconsistent | Indirect | Imprecise | Insufficient
Depression Severity Score (HSCL-20)
Collaborative care model plus clinical information tracking | 1^17^ (1801) RCT | Moderate | Inconsistent | Direct | Precise | Insufficient
HbA1c test
Patient reminder | 1^9^ (37425) Cohort | High | Unknown | Indirect | Imprecise | Insufficient

Abbreviations: HbA1c=glycosylated hemoglobin; RCT=randomized controlled trial; SOE=strength of evidence

Table J6 Strength of evidence for outcomes in studies addressing disparities associated with sex

Outcome/Intervention | Number of Studies (N) Study Design | Risk of Bias | Consistency | Directness | Precision | Overall SOE
Probable depressive disorder
Collaborative care with medication adherance support. | 1^18^ (1299) RCT | Moderate | Inconsistent | Direct | Imprecise | Insufficient
Collaborative care with cognitive behavioral therapy | 1^18^ (1299) RCT | Moderate | Inconsistent | Direct | Imprecise | Insufficient
Use of mental health services
Collaborative care with medication adherance support. | 1^18^ (1299) RCT | Moderate | Inconsistent | Indirect | Imprecise | Insufficient
Collaborative care with cognitive behavioral therapy | 1^18^ (1299) RCT | Moderate | Inconsistent | Indirect | Imprecise | Insufficient

Abbreviations: RCT=randomized controlled trial; SOE=strength of evidence

Table J7 Strength of evidence domains and domain definitions

Domain | Definition and elements | Score and application
Risk of bias | Risk of bias is the degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design (e.g., RCTs or observational studies); - Aggregate quality of the studies under consideration. Information for this determination comes from the rating of quality (good/fair/poor) done for individual studies | Use one of three levels of aggregate risk of bias:; - Low risk of bias; - Medium risk of bias; - High risk of bias
Consistency | The principal definition of consistency is the degree to which reported effect sizes from included studies appear to have the same direction of effect. This can be assessed through two main elements:; - Effect sizes have the same sign (that is, are on the same side of “no effect”); - The range of effect sizes is narrow. | Use one of three levels of consistency:; - Consistent (i.e., no inconsistency); - Inconsistent•; - Unknown or not applicable (e.g., single study)
Directness | The rating of directness relates to whether the evidence links the interventions directly to health outcomes. Evidence is indirect if:; - It uses intermediate or surrogate outcomes instead of health outcomes.; - It uses two or more bodies of evidence to compare interventions A and B. | Score dichotomously as one of two levels of directness:; - Direct; - Indirect
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome (i.e., for each outcome separately). | Score dichotomously as one of two levels of precision:; - Precise; - Imprecise

## References

1 Lasser KE, Murillo J, Lisboa S, et al. Colorectal cancer screening among ethnically diverse, low-income patients: a randomized controlled trial. Arch Intern Med. May. 23. 2011;171(10):906-12. [pmid: 21606094].
2 Arean PA, Ayalon L, Hunkeler E, et al. Improving depression care for older, minority patients in primary care. Med Care. Apr. 2005;43(4):381-90. [pmid: 15778641].
3 Wells KB, Sherbourne CD, Miranda J, et al. The cumulative effects of quality improvement for depression on outcome disparities over 9 years: results from a randomized, controlled group-level trial. Med Care. Nov. 2007;45(11):1052-9. [pmid: 18049345].
4 Bao Y, Alexopoulos GS, Casalino LP, et al. Collaborative depression care management and disparities in depression treatment and outcomes. Arch Gen Psychiatry. Jun. 2011;68(6):627-36. [pmid: 21646579].
5 Miranda J, Schoenbaum M, Sherbourne C, et al. Effects of primary care depression treatment on minority patients' clinical status and employment. Arch Gen Psychiatry. Aug. 2004;61(8):827-34. [pmid: 15289281].
6 Miranda J, Duan N, Sherbourne C, et al. Improving care for minorities: can quality improvement interventions improve care and outcomes for depressed minorities? Results of a randomized, controlled trial. Health Serv Res. Apr. 2003;38(2):613-30. [pmid: 12785564].
7 Wells K, Sherbourne C, Schoenbaum M, et al. Five-year impact of quality improvement for depression: results of a group-level randomized controlled trial. Arch Gen Psychiatry. Apr. 2004;61(4):378-86. [pmid: 15066896].
8 Sequist TD, Fitzmaurice GM, Marshall R, et al. Cultural competency training and performance reports to improve diabetes care for black patients: a cluster randomized, controlled trial. Ann Intern Med. Jan. 5. 2010;152(1):40-6. [pmid: 20048271].
9 Coberley CR, Puckrein GA, Dobbs AC, et al. Effectiveness of disease management programs on improving diabetes care for individuals in health-disparate areas. Dis Manag. Jun. 2007;10(3):147-55. [pmid: 17590145].
10 Mahotiere T, Ocepek-Welikson K, Daley MB, et al. A program to reduce the disparity in the rate of biennial lipid profiles between African-American and white Medicare beneficiaries with diabetes mellitus in New York City. J Community Health. Aug. 2006;31(4):263-88. [pmid: 16894826].
11 Connett JE, Stamler J. Responses of black and white males to the special intervention program of the Multiple Risk Factor Intervention Trial. Am Heart J. Sep. 1984;108(3 Pt 2):839-48. [pmid: 6475754].
12 Olomu AB, Grzybowski M, Ramanath VS, et al. Evidence of disparity in the application of quality improvement efforts for the treatment of acute myocardial infarction: the American College of Cardiology's Guidelines Applied in Practice Initiative in Michigan. Am Heart J. Mar. 2010;159(3):377-84. [pmid: 20211298].
13 Bosworth HB, Olsen MK, Grubber JM, et al. Racial differences in two self-management hypertension interventions. Am J Med. May. 2011;124(5):468 e1-8. [pmid: 21531237].
14 Barr JK, Franks AL, Lee NC, et al. A randomized intervention to improve ongoing participation in mammography. Am J Manag Care. Sep. 2001;7(9):887-94. [pmid: 11570022].
15 Beach ML, Flood AB, Robinson CM, et al. Can language-concordant prevention care managers improve cancer screening rates?. Cancer Epidemiol Biomarkers Prev. Oct. 2007;16(10):2058-64. [pmid: 17932353].
16 Ferreira MR, Dolan NC, Fitzgibbon ML, et al. Health care provider-directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial. J Clin Oncol. Mar. 1. 2005;23(7):1548-54. [pmid: 15735130].
17 Arean PA, Gum AM, Tang L, et al. Service use and outcomes among elderly persons with low incomes being treated for depression. Psychiatr Serv. Aug. 2007;58(8):1057-64. [pmid: 17664516].
18 Sherbourne CD, Weiss R, Duan N, et al. Do the effects of quality improvement for depression care differ for men and women? Results of a group-level randomized controlled trial. Med Care. Dec. 2004;42(12):1186-93. [pmid: 15550798].