# Evidence Table

Evidence Table I-1 Characteristics and outcomes from studies of quality improvement interventions addressing disparities in health outcomes