# Quality of Individual Studies

Table H-1 Quality assessment of randomized controlled trials of quality improvement interventions addressing disparities in health outcomes

Author, Year | Random Sequence Generation | Allocation Concealment | Selective Reporting | Other Bias | Blinding-Participants and Personnel | Blinding- Outcome Assessment | Incomplete Outcome Data | Quality Rating
Arean et al., 2005^1^ | Low | Low | Low | Low | Unclear | High | Unclear | Poor
Arean et al., 2007^2^ | Low | Low | Low | Low | Unclear | Low | Low | Fair
Bao et al., 2011^3^ | Low | Low | Low | Unclear | Low | High | Unclear | Fair
Barr et al., 2001^4^ | Unclear | Unclear | Low | Low | High | Unclear | Unclear | Poor
Beach et al., 2007^5^ | Low | Low | Low | High | Low | Low | Low | Fair
Bosworth et al., 2011^6^ | Low | Unclear | Low | Low | Low | Low | Low | Fair
Connett and Stamler,1984^7^ | Low | Low | Low | Low | Low | Unclear | Low | Fair
Ferreira et. al., 2005^8^ | Unclear | Unclear | Low | Low | High | High | Low | Poor
Lasser et al., 2011^9^ | Low | Low | Low | Low | High | Low | Low | Fair
Miranda et al., 2003^10^ | Low | Low | Low | Unclear | Low | High | Low | Fair
Miranda et al., 2004^11^ | Low | Low | Low | Unclear | Low | High | Low | Fair
Sequist et al., 2001^12^ | Low | Low | Low | Low | Low | Low | Low | Good
Sherbourne et al., 2004^13^ | Low | Low | Low | Unclear | Low | High | Low | Fair
Siddiqui et al., 2011^14^ | Unclear | Unclear | Low | Low | Low | Low | Unclear | Poor
Wells et al., 2004^15^ | Low | Low | Low | Unclear | Low | High | High | Poor
Wells et al., 2007^16^ | Low | Low | High | Unclear | Low | High | High | Poor

Table H-2 Quality assessment of observational studies of quality improvement interventions addressing disparities in health outcomes

Author, Year | Representativeness of exposed cohort | Selection of the nonexposed cohort | Ascertainment of exposure | Demonstration that outcome of interest was not present at start of study | Comparability of cohorts / controlling for confounders | Assessment of outcome | Appropriate duration of followup | Adequacy of followup of cohorts | Total Score | Quality rating
Coberley et al., 2007^17^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 7 | Good
Mahotiere et al., 2006^18^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 8 | Good
Olomu et al., 2010^19^ | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 0 | 6 | Fair

## References

1 Arean PA, Ayalon L, Hunkeler E, et al. Improving depression care for older, minority patients in primary care. Med Care. Apr. 2005;43(4):381-90. [pmid: 15778641].
2 Arean PA, Gum AM, Tang L, et al. Service use and outcomes among elderly persons with low incomes being treated for depression. Psychiatr Serv. Aug. 2007;58(8):1057-64. [pmid: 17664516].
3 Bao Y, Alexopoulos GS, Casalino LP, et al. Collaborative depression care management and disparities in depression treatment and outcomes. Arch Gen Psychiatry. Jun. 2011;68(6):627-36. [pmid: 21646579].
4 Barr JK, Franks AL, Lee NC, et al. A randomized intervention to improve ongoing participation in mammography. Am J Manag Care. Sep. 2001;7(9):887-94. [pmid: 11570022].
5 Beach ML, Flood AB, Robinson CM, et al. Can language-concordant prevention care managers improve cancer screening rates?. Cancer Epidemiol Biomarkers Prev. Oct. 2007;16(10):2058-64. [pmid: 17932353].
6 Bosworth HB, Olsen MK, Grubber JM, et al. Racial differences in two self-management hypertension interventions. Am J Med. May. 2011;124(5):468 e1-8. [pmid: 21531237].
7 Connett JE, Stamler J. Responses of black and white males to the special intervention program of the Multiple Risk Factor Intervention Trial. Am Heart J. Sep. 1984;108(3 Pt 2):839-48. [pmid: 6475754].
8 Ferreira MR, Dolan NC, Fitzgibbon ML, et al. Health care provider-directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial. J Clin Oncol. Mar. 1. 2005;23(7):1548-54. [pmid: 15735130].
9 Lasser KE, Murillo J, Lisboa S, et al. Colorectal cancer screening among ethnically diverse, low-income patients: a randomized controlled trial. Arch Intern Med. May. 23. 2011;171(10):906-12. [pmid: 21606094].
10 Miranda J, Duan N, Sherbourne C, et al. Improving care for minorities: can quality improvement interventions improve care and outcomes for depressed minorities? Results of a randomized, controlled trial. Health Serv Res. Apr. 2003;38(2):613-30. [pmid: 12785564].
11 Miranda J, Schoenbaum M, Sherbourne C, et al. Effects of primary care depression treatment on minority patients' clinical status and employment. Arch Gen Psychiatry. Aug. 2004;61(8):827-34. [pmid: 15289281].
12 Sequist TD, Fitzmaurice GM, Marshall R, et al. Cultural competency training and performance reports to improve diabetes care for black patients: a cluster randomized, controlled trial. Ann Intern Med. Jan. 5. 2010;152(1):40-6. [pmid: 20048271].
13 Sherbourne CD, Weiss R, Duan N, et al. Do the effects of quality improvement for depression care differ for men and women? Results of a group-level randomized controlled trial. Med Care. Dec. 2004;42(12):1186-93. [pmid: 15550798].
14 Siddiqui AA, Sifri R, Hyslop T, et al. Race and response to colon cancer screening interventions. Prev Med. Mar-Apr. 2011;52(3-4):262-4. [pmid: 21256149].
15 Wells K, Sherbourne C, Schoenbaum M, et al. Five-year impact of quality improvement for depression: results of a group-level randomized controlled trial. Arch Gen Psychiatry. Apr. 2004;61(4):378-86. [pmid: 15066896].
16 Wells KB, Sherbourne CD, Miranda J, et al. The cumulative effects of quality improvement for depression on outcome disparities over 9 years: results from a randomized, controlled group-level trial. Med Care. Nov. 2007;45(11):1052-9. [pmid: 18049345].
17 Coberley CR, Puckrein GA, Dobbs AC, et al. Effectiveness of disease management programs on improving diabetes care for individuals in health-disparate areas. Dis Manag. Jun. 2007;10(3):147-55. [pmid: 17590145].
18 Mahotiere T, Ocepek-Welikson K, Daley MB, et al. A program to reduce the disparity in the rate of biennial lipid profiles between African-American and white Medicare beneficiaries with diabetes mellitus in New York City. J Community Health. Aug. 2006;31(4):263-88. [pmid: 16894826].
19 Olomu AB, Grzybowski M, Ramanath VS, et al. Evidence of disparity in the application of quality improvement efforts for the treatment of acute myocardial infarction: the American College of Cardiology's Guidelines Applied in Practice Initiative in Michigan. Am Heart J. Mar. 2010;159(3):377-84. [pmid: 20211298].