# Thresholds for Quality Assessment

## Cochrane Risk of Bias (RoB) Tool for randomized controlled trials (RCTs)

Cochrane Collaboration uses strict criteria for the threshold: A good-quality study must meet all criteria (Low RoB). A fair-quality study does not meet, or it is not clear that it meets, at least one criterion, but it has no known important limitation that could invalidate its results (Moderate RoB). A poor-quality study has important limitations and/or at least one criterion not met (High RoB).

- If all criteria met (i.e., all elements are rated as “low” risk of bias) = Good Quality
- If 1 criteria not met or 2 criteria unclear, and the assessment that this was unlikely to have biased the outcome, and there is no known important limitation that could invalidate the results = Moderate RoB = Fair Quality
- If 1 criteria not met or 2 criteria unclear, and the assessment that this was likely to have biased the outcome, and there are important limitations that could invalidate the results = High RoB = Poor Quality
- If 2 or more criteria not met = High RoB = Poor Quality

Note: Using the Cochrane RoB Tool, it is possible for a criterion to be met, even when this element was technically not part of the method; for instance, a judgment that knowledge of the allocated interventions was adequately prevented, even though there was no blinding, but the review authors judge that the outcome and the outcome measurement are not likely to be influenced by lack of blinding.

## Newcastle-Ottawa Scale (N-O-S) for observational studies (e.g., cohort studies and case control studies)

The Newcastle-Ottawa Scale includes 3 categories, with a maximum of 9 points, based on:

Selection (maximum of 4 points)
1. Representativeness of the exposed cohort (one point)
2. Selection of the non exposed cohort (one point)
3. Ascertainment of exposure (one point)
4. Demonstration that outcome of interest was not present at start of study (one point)

Comparability (maximum of 2 points)
1. Comparability of cohorts on the basis of the design or analysis
  a. Study controls for age (one point)
  b. Study controls for any additional factor (one point)

Outcome (maximum of 3 points)
1. Assessment of outcome (one point)
2. Was follow-up long enough for outcomes to occur (one point)
3. Adequacy of follow up of cohorts (one point)

Scoring algorithm*

Quality rating | # Points in Selection Domain | # Points in Comparability Domain | # Points in Outcome Domain
Good | ≥3 | ≥2 | ≥2
Fair | 2 | ≥1 | ≥2
Poor | 0-1 | 0 | 0-1