# Literature Search Strategies

Database: PubMed

Search | Search terms | Search results
#1 | reminder systems[mh] OR guideline adherence[mh] OR medical audit[mh] OR interdisciplinary communication[mh] OR feedback[mh] OR nursing audit[mh] OR patient education as topic[mh] OR education, continuing[mh] OR health personnel/education[mh] OR health education[majr] OR “provider education” OR self care[mh] OR organizational innovation[mh] OR “self management” OR quality improvement[tiab] OR quality assurance, health care[mh] OR quality indicators, health care[mh] OR safety management[majr] OR patient safety[tiab] | 481284
#2 | health status disparities[mh] OR healthcare disparities[mh] OR minority health[mh] OR ethnic groups[mh] OR minority groups[mh] OR health literacy[mh] OR health literacy[tiab] OR numeracy[tiab] OR socioeconomic factors[mh] OR social class[mh] OR sexuality[mh] OR communication barriers[mh] OR translating[mh] OR language[mh:noexp] OR insurance coverage[mh] OR medically uninsured[mh] OR disparities[tiab] OR disparity[tiab] OR inequity[tiab] OR inequities[tiab] OR inequality[tiab] OR inequalities[tiab] | 475923
#3 | colorectal neoplasms[mh] OR breast neoplasms[mh] OR heart failure[mh] OR myocardial ischemia[mh] OR coronary disease[mh] OR diabetes mellitus[mh:noexp] OR diabetes mellitus, type 1[mh] OR diabetes mellitus, type 2[mh] OR hypertension[mh:noexp] OR pregnancy outcome[mh] OR birth weight[mh] OR premature birth[mh] OR infant mortality[mh] OR infant, low birth weight[mh] OR infant, premature[mh] OR depressive disorder[mh:noexp] OR depressive disorder, major[mh] OR depression[mh] OR asthma[mh] OR pneumonia[mh] OR pneumococcal vaccines[mh] OR cystic fibrosis[mh] OR kidney failure, chronic[mh] OR renal dialysis[mh] | 1517358
#4 | #1 AND #2 AND #3 AND eng[la] AND humans[mh] AND 1983:2011[dp] | 3616
#5 | #4 AND case reports[pt] | 44
#6 | #4 AND letter[pt] | 49
#7 | #4 AND review[pt] | 288
#8 | #4 AND editorial[pt] | 43
#9 | #4 AND comment[pt] | 74
#10 | #4 AND practice guideline[pt] | 16
#11 | #4 AND historical article[pt] | 11
#12 | #4 AND legal cases[pt] | 2
#13 | #4 AND news[pt] | 27
#14 | #4 AND newspaper article[pt] | 2
#15 | #4 AND meta-analysis[pt] | 15
#16 | #4 AND jsubsetk | 16
#17 | #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 | 507
#18 | #4 NOT #17 | 3109

Key: jsubsetk consumer health subset; [la] language; [mh] Medical Subject Heading; [mh:noexp] Medical Subject Heading, not including narrower terms; [pt] publication type; [tiab] title or abstract word

Database: CINAHL (EBSCOhost interface)

Search | Search terms | Search results
#1 | (MH “Quality Assurance”) OR (MH “Quality of Health Care”) OR (MH “Patient Safety”) OR (MH “Reminder Systems”) OR (MH “Health Education+”) OR (MH “Audit”) OR (MH “Feedback”) OR (MH “Self Care”) OR TX quality OR (MH “Education, Continuing”) OR (MH “Education, Medical, Continuing”) OR (MH “Education, Nursing, Continuing”) OR (MH “Quality Management, Organizational”) OR (MH “Organizational Change”) | 271475
#2 | (TX disparity OR disparities OR numeracy OR health literacy OR inequity OR inequities OR inequality OR inequalities) OR (MH “Minority Groups”) OR (MH “Socioeconomic Factors+”) OR (MH “Communication Barriers”) OR (MH “English as a Second Language”) OR (MH “Insurance, Health+”) OR (MH “GLBT Persons+”) OR (MH “Sexuality”) OR (MH “Bisexuality”) OR (MH “Homosexuality”) OR (MH “Medically Uninsured”) OR (MH “Ethnic Groups+”) | 241818
#3 | (MH “colorectal neoplasms+”) OR (MH “breast neoplasms+”) OR (MH “heart failure”) OR (MH “myocardial ischemia+”) OR (MH “diabetes mellitus, insulin-dependent”) OR (MH “diabetes mellitus, non-insulin-dependent”) OR (MH “hypertension”) OR (MH “infant, low birth weight”) OR (MH “infant, premature”) OR (MH “pregnancy outcomes”) OR (MH “infant mortality”) OR (MH “depression”) OR (MH “asthma”) OR (MH “pneumonia+”) OR (MH “pneumococcal vaccine”) OR (MH “cystic fibrosis”) OR (MH “kidney failure, chronic”) OR (MH “hemodialysis”)(MH “colorectal neoplasms+”) OR (MH “breast neoplasms+”) OR (MH “heart failure”) OR (MH “myocardial ischemia+”) OR (MH “diabetes mellitus, insulin-dependent”) OR (MH “diabetes mellitus, non-insulin-dependent”) OR (MH “hypertension”) OR (MH “infant, low birth weight”) OR (MH “infant, premature”) OR (MH “pregnancy outcomes”) OR (MH “infant mortality”) OR (MH “depression”) OR (MH “asthma”) OR (MH “pneumonia+”) OR (MH “pneumococcal vaccine”) OR (MH “cystic fibrosis”) OR (MH “kidney failure, chronic” | 208909
#4 | #1 AND #2 AND #3, limited to English, human, peer reviewed journals, research articles; MEDLINE articles excluded | 413
#5 | #4 AND (PT “abstract”) | 55
#6 | #4 AND (MH “case studies”) | 10
#7 | #4 AND (PT “commentary”) | 3
#8 | #4 AND (PT “editorial”) | 1
#9 | #4 AND (PT “letter”) | 1
#10 | #4 AND (PT “practice guidelines”) | 1
#11 | #4 AND (PT “proceedings”) | 1
#12 | #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 | 70
#13 | #4 NOT #12 | 343

Key: MH CINAHL medical subject heading; + explode term; PT publication type; TX text word

Database: PsycINFO (CSA interface)

Search | Search terms | Search results
#1 | DE=(quality of care OR clinical audits OR feedback OR knowledge of results OR client education OR continuing education OR decision support systems OR self care skills OR self management OR organizational innovation OR quality control OR safety OR “health education”) OR (reminder OR reminders), limited to 1980 -2011, journal article, English language, and human | 35168
#2 | DE=(health disparities OR racial and ethnic groups OR racial and ethnic differences OR health literacy OR minority groups OR english as a second language OR communication barriers OR language proficiency OR numerical ability OR “health insurance” or “employee health insurance” or “workers compensation insurance” or “fee for service” or “health maintenance organizations” or “medicaid” or “medicare” or “underinsured health insurance” or “uninsured health insurance” OR “transgender” or “transsexualism” OR “sexual orientation” or “bisexuality” or “heterosexuality” or “homosexuality” or “lesbianism” or “male homosexuality”) OR (disparity OR disparities OR inequity OR inequities OR inequality OR inequalities), limited to 1980 -2011, journal article, English language, and human | 80091
#3 | DE=(breast neoplasms OR hypertension OR pregnancy outcomes OR premature birth OR birth weight OR asthma OR pneumonia OR cystic fibrosis OR kidney diseases OR “heart disorders” or “angina pectoris” or “arrhythmias heart” or “bradycardia” or “fibrillation heart” or “tachycardia” or “coronary thromboses” or “myocardial infarctions” OR “diabetes” or “diabetes mellitus” OR “major depression” OR “depression emotion” OR “dialysis” or “hemodialysis”) OR (DE=(neoplasms) AND (DE=(colon disorders) OR colon OR colorectal)) OR (pneumococcal AND (vaccine OR vaccines OR vaccination OR vaccinated OR vaccinations)), limited to 1980 -2011, journal article, English language, and human | 80009
#4 | #1 AND #2 AND #3 | 391
#5 | PT=(edited book) or PT=(editorial) or PT=(electronic collection) or PT=(encyclopedia entry) or PT=(encyclopedia) or PT=(erratum/correction) or PT=(handbook/manual) or PT=(letter) or PT=(obituary) or PT=(publication information) or PT=(reference book) or PT=(reprint) or PT=(review-book) or PT=(review-media) or PT=(textbook/study guide) or PT=(dissertation) or PT=(review-software) or PT=(abstract collection) or PT=(authored book) or PT=(bibliography) or PT=(book) or PT=(chapter) or PT=(classic book) or PT=(column/opinion) or PT=(comment/reply) or PT=(conference proceedings) or PT=(dissertation abstract) | 1101
#6 | ME=(focus group OR interview OR literature review OR meta analysis OR nonclinical case study OR systematic review) | 94944
#7 | #4 NOT (#5 OR #6) | 336

Key: DE subject term; PT publication type; ME methodology

Database: Social Science Citation

Search | Search terms | Search results
#1 | TS=(health literacy OR (language AND (barrier* OR problem*)) OR English as a second language OR (health AND numeracy)) AND Language=(English) AND Document Type=(Article) | 11111
#2 | TS=(breast cancer OR colorectal cancer OR colon cancer OR diabetes OR heart failure OR coronary artery disease OR heart disease OR myocardial infarction OR myocardial ischemia OR hypertension OR hypertensive OR depression OR depressive disorder OR asthma OR cystic fibrosis OR pneumonia OR end stage renal disease OR (birthweight AND low) OR premature birth OR prematurity OR preterm birth) AND Language=(English) AND Document Type=(Article) | >100000
#3 | TS=(reminder OR reminders OR audit OR feedback OR patient education OR provider education OR self management OR quality OR patient safety) AND Language=(English) AND Document Type=(Article) | >100000
#4 | #1 AND #2 AND #3 , limited to articles with any US author affiliation | 280

Key: TS keyword