# Acronyms and Abbreviations

AA: African-American
ADA: American Diabetes Association
AHRQ: Agency for Healthcare Research and Quality
AMI: Acute myocardial infarction
BP: Blood pressure
CABG: Coronary artery bypass grafting
CAD: Coronary artery disease
CBT: Cognitive behavior therapy
CC: Collaborative care
CHD: Coronary heart disease
CI: Confidence interval
CQG: Closing the Quality Gap
CQI: Continuous Quality Improvement
CRC: Colorectal cancer
DBP: Diastolic blood pressure
DCM: Depression care manager
DCS: Depression care specialist
EPC: Evidence-based practice center
FADE: Quality improvement organizational model: Focus, Analyze, Develop, Execute, Evaluate
FFS: Fee-for-service
FOBT: Fecal occult blood test
FS/COL: Flexible sigmoidoscopy or colonoscopy
GAP: American College of Cardiology's AMI Guidelines Applied in Practice
GCC: Guideline concordant care
HbA1c: Glycosylated hemoglobin
HDL: High density lipoprotein
HDZ: Health disparity zone
HMO: Health maintenance organization
IMPACT: Improving mood-promoting access to collaborative treatment
IOM: Institute of Medicine
IPRO: Medicare quality improvement organization for the State of New York
KQ: Key question
LDL: Low density lipoprotein
MCO: Managed care organization
MCS-12: Mental health component scale
MDD: Major depressive disorder
mm Hg: Millimeter of mercury
mmol/L: Millimole per liter
MRFIT: Multiple risk factor intervention trial
N-O: Newcastle-Ottawa
NA: Not applicable
Non-HDZ: Non-health disparity zone
NP: Nurse practitioner
NR: Not reported
adjusted OR: Adjusted odds ratio
OR: Odds ratio
PA: Physician assistant
PCI: Percutaneous coronary intervention
PCS-12: Physical component score
PDSA: Plan, Do, Study, Act
PIC: Partners in care
PROSPECT: Prevention of Suicide in Primary Care Elderly
QI: Quality improvement
QI–Meds: Quality improvement-enhanced medication management
QI–Therapy: Quality improvement-enhanced therapy management
QoL: Quality of life
RCT: Randomized controlled trial
REALM: Rapid estimate of adult literacy in medicine
RoB: Risk of bias
SBP: Systolic blood pressure
SD: Standard deviation
SES: Socioeconomic status
TEP: Technical Expert Panel
TQM: Total quality management
UC: Usual care
VA: Veterans Affairs