# Acknowledgments

We are indebted to an exceptional group of colleagues who made this report possible. Each step of a systematic review draws on the skills and attention of an entire team. The authors gratefully acknowledge the following individuals for their contributions to this project:

Dr. Adeola Davis and Ms. Rachel Walden were instrumental in completing evidence tables.

Mr. Jeff Seroogy, Ms. Kathy Lee, Ms. Sanura Latham, and Mr. Yichuan Wang assisted with formatting tables and entering data.

Dr. Chandra Osborn and Ms. Kathryn McDonald offered key input and feedback on the protocol and conceptual framework for the report.

Ms. J. Nikki McKoy and Ms. Nila Sathe provided advice on formatting and organization of the report.