# References

1 Martin A, Lassman D, Whittle L, et al. Recession contributes to slowest annual rate of increase in health spending in five decades. Health Aff (Millwood). 2011;30(1):11-22. [pmid: 21209433].
2 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-45. [pmid: 12826639].
3 Jencks SF, Huff ED, Cuerdon T. Change in the quality of care delivered to Medicare beneficiaries, 1998-1999 to 2000-2001. JAMA. 2003;289(3):305-12. [pmid: 12525231].
4 Saaddine JB, Cadwell B, Gregg EW, et al. Improvements in diabetes processes of care and intermediate outcomes: United States, 1988-2002. Ann Intern Med. 2006;144(7):465-74. [pmid: 16585660].
5 Grant RW, Buse JB, Meigs JB. Quality of diabetes care in U.S. academic medical centers: low rates of medical regimen change. Diabetes Care. 2005;28(2):337-442. [pmid: 15677789].
6 Nolte E, McKee CM. Measuring the health of nations: updating an earlier analysis. [Erratum appears in Health Aff (Millwood) 2008 Mar-Apr;27(2):593]. Health Aff (Millwood). 2008;27(1):58-71. [pmid: 18180480].
7 Bodenheimer T. Primary care—will it survive?. N Engl J Med. 2006;355(9):861-4. [pmid: 16943396].
8 Agency for Healthcare Research and Quality. Patient Centered Medical Home Resource Center. Available at: http://pcmh.ahrq.gov/. January 24, 2011.
9 Scholle S, Torda P, Peikes D, et al. Engaging Patients and Families in the Medical Home. (Prepared by Mathematica Policy Research under Contract No. HHSA290200900019ITO2.) AHRQ Publication No. 10-0083-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2010.
10 Moreno L, Peikes D, Krilla A. Necessary But Not Sufficient: The HITECH Act and Health Information Technology's Potential to Build Medical Homes. (Prepared by Mathematica Policy Research under Contract No. HHSA290200900019ITO2.) AHRQ Publication No. 10-0080-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2010.
11 Stange KC, Nutting PA, Miller WL, et al. Defining and measuring the patient-centered medical home. J Gen Intern Med. 2010;25(6):601-12. [pmid: 20467909].
12 Sia C, Tonniges TF, Osterhus E, et al. History of the medical home concept. Pediatrics. 2004;113(5 Suppl):1473-8. [pmid: 15121914].
13 Kilo CM, Wasson JH. Practice redesign and the patient-centered medical home: history, promises, and challenges. Health Aff (Millwood). 2010;29(5):773-8. [pmid: 20439860].
14 Carrier E, Gourevitch MN, Shah NR. Medical homes: challenges in translating theory into practice. Med Care. 2009;47(7):714-22. [pmid: 19536005].
15 Wagner EH, Austin BT, Von Korff M. Organizing care for patients with chronic illness. Milbank Q. 1996;74(4):511-44. [pmid: 8941260].
16 Wagner EH, Glasgow RE, Davis C, et al. Quality improvement in chronic illness care: a collaborative approach. Jt Comm J Qual Improv. 2001;27(2):63-80. [pmid: 11221012].
17 McDonald KM, Sundaram V, Bravata DM, et al. Care Coordination. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9. (Prepared by the Stanford University-UCSF Evidence-based Practice Center under contract 290-02-0017). AHRQ Publication No. 04(07)-0051-7. Rockville, MD. Agency for Healthcare Research and Quality. June. 2007;7. [pmid: 20734531].
18 Adams SG, Smith PK, Allan PF, et al. Systematic review of the chronic care model in chronic obstructive pulmonary disease prevention and management. Arch Intern Med. 2007;167(6):551-61. [pmid: 17389286].
19 Bodenheimer T, Wagner EH, Grumbach K. Improving primary care for patients with chronic illness: the chronic care model, Part 2. JAMA. 2002;288(15):1909-14. [pmid: 12377092].
20 Coleman K, Austin BT, Brach C, et al. Evidence on the Chronic Care Model in the new millennium. Health Aff (Millwood). 2009;28(1):75-85. [pmid: 19124857].
21 Tsai AC, Morton SC, Mangione CM, et al. A meta-analysis of interventions to improve care for chronic illnesses. Am J Manag Care. 2005;11(8):478-88. [pmid: 16095434].
22 Vest JR, Bolin JN, Miller TR, et al. Medical homes: “where you stand on definitions depends on where you sit”. Med Care Res Rev. 2010;67(4):393-411. [pmid: 20448255].
23 Bodenheimer T, Grumbach K, Berenson RA. A lifeline for primary care. N Engl J Med. 2009;360(26):2693-6. [pmid: 19553643].
24 American Academy of Family Physicians (AAFP), American Academy of Pediatrics (AAP), American College of Physicians (ACP), et al. Joint Principles of the Patient-Centered Medical Home. February. 2007. Available at: www.aafp.org/online/etc/medialib/aafp_org/documents/policy/fed/jointprinciplespcmh0207.Par.0001.File.dat/022107medicalhome.pdf. November 7, 2011.
25 Shortell SM, Gillies R, Wu F. United States innovations in healthcare delivery. Public Health Rev. 2010;32(1):190-212.
26 Rittenhouse DR, Thom DH, Schmittdiel JA. Developing a policy-relevant research agenda for the patient-centered medical home: a focus on outcomes. J Gen Intern Med. 2010;25(6):593-600. [pmid: 20467908].
27 Crabtree BF, Chase SM, Wise CG, et al. Evaluation of patient centered medical home practice transformation initiatives. Med Care. 2011;49(1):10-6. [pmid: 21079525].
28 Piette J, Holtz B, Beard A, et al. Improving chronic illness care for veterans within the framework of the Patient-Centered Medical Home: experiences from the Ann Arbor Patient-Aligned Care Team Laboratory. Translational Behavioral Medicine. Published Online First on August 16, 2011. 1-9. [pmid: 24073022].
29 Coleman K, Mattke S, Perrault PJ, et al. Untangling practice redesign from disease management: how do we best care for the chronically ill?. Annu Rev Public Health. 2009;30:385-408. [pmid: 18925872].
30 Shojania KG, Ranji SR, McDonald KM, et al. Effects of quality improvement strategies for type 2 diabetes on glycemic control: a meta-regression analysis. JAMA. 2006;296(4):427-40. [pmid: 16868301].
31 Walsh JME, McDonald KM, Shojania KG, et al. Quality improvement strategies for hypertension management: a systematic review. Med Care. 2006;44(7):646-57. [pmid: 16799359].
32 Gilbody S, Whitty P, Grimshaw J, et al. Educational and organizational interventions to improve the management of depression in primary care: a systematic review. JAMA. 2003;289(23):3145-51. [pmid: 12813120].
33 Ouwens M, Wollersheim H, Hermens R, et al. Integrated care programmes for chronically ill patients: a review of systematic reviews. Int J Qual Health Care. 2005;17(2):141-6. [pmid: 15665066].
34 Shojania K, McDonald K, Wachter R, et al. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies, Volume 1 - Series Overview and Methodology. Technical Review 9. (Contract No. 290-02-0017 to the Stanford University-UCSF Evidence-based Practice Center). AHRQ Publication No. 04005101. Rockville, MD. Agency for Healthcare Research and Quality. August. 2004. [pmid: 20734525].
35 Agency for Healthcare Research and Quality. Closing the Quality Gap: Revisiting the State of the Science—Series Overview. June. 23. 2011. Available at: www.effectivehealthcare.ahrq.gov. March 13, 2012.
36 Hoff T. The patient-centered medical home: what we need to know more about. Med Care Res Rev. 2010;67(4):383-92. [pmid: 20519431].
37 Shortell SM, Gillies R, Siddique J, et al. Improving chronic illness care: a longitudinal cohort analysis of large physician organizations. Med Care. 2009;47(9):932-9. [pmid: 19648838].
38 Rittenhouse DR, Casalino LP, Shortell SM, et al. Small and medium-size physician practices use few patient-centered medical home processes. Health Aff (Millwood). 2011;30(8):1575-84. [pmid: 21719447].
39 McPherson M, Arango P, Fox H, et al. A new definition of children with special health care needs. Pediatrics. 1998;102(1 Pt 1):137-40. [pmid: 9714637].
40 Kilo CM. Improving care through collaboration. Pediatrics. 1999;103(1 Suppl E):384-93. [pmid: 9917480].
41 Solomon DH, Van Houten L, Glynn RJ, et al. Academic detailing to improve use of broad-spectrum antibiotics at an academic medical center. Arch Intern Med. 2001;161(15):1897-902. [pmid: 11493132].
42 Reeves BC, Deeks JJ, H JPT, et al. Chapter 13: Including nonrandomized studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2. [updated September 2009]. The Cochrane Collaboration. 2009. Available at: www.cochrane-handbook.org. February 7, 2011.
43 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: www.effectivehealthcare.ahrq.gov. October 31, 2011.
44 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. 2009;62(10):1006-12. [pmid: 19631508].
45 Chapman AL, Morgan LC, Gartlehner G. Semi-automating the manual literature search for systematic reviews increases efficiency. Health Information & Libraries Journal. 2010;27(1):22-7. [pmid: 20402801].
46 Bitton A, Martin C, Landon BE. A nationwide survey of patient centered medical home demonstration projects. J Gen Intern Med. 2010;25(6):584-92. [pmid: 20467907].
47 Homer CJ, Klatka K, Romm D, et al. A review of the evidence for the medical home for children with special health care needs. Pediatrics. 2008;122(4):e922-37. [pmid: 18829788].
48 Rosenthal TC. The medical home: growing evidence to support a new approach to primary care. Journal of the American Board of Family Medicine: JABFM. 2008;21(5):427-40. [pmid: 18772297].
49 Robert Graham Center. The Patient Centered Medical Home: History, Seven Core Features, Evidence and Transformational Change. 2007. Available at: www.graham-center.org/online/graham/home/publications/monographs-books/2007/rgcmo-medical-home.html. September 21, 2010.
50 Grumbach K, Bodenheimer T, Grundy P. The Outcomes of Implementing Patient-Centered Medical Home Interventions: A Review of the Evidence on Quality, Access and Costs from Recent Prospective Evaluation Studies. August. 2009. Available at: www.pcpcc.net/files/evidenceWEB%20FINAL%2010.16.09_1.pdf. September 21, 2010. 2009.
51 Ginsburg P, Maxfield M, O'Malley A, et al. Making Medical Homes Work: Moving from Concept to Practice. Policy Perspective: Insights into Health Policy Issues. Dec. 2008. Available at: http://hschange.org/CONTENT/1030/?. September 21, 2010.
52 DePalma JA. Evidence to support medical home concept for children with special health care needs. Home Health Care Management & Practice. 2007;19(6):473-5.
53 The World Bank. Country and lending groups. Available at: http://data.worldbank.org/about/country-classifications/country-and-lending-groups. March 18, 2011.
54 Viswanathan M, Berkman ND. Assessing the Risk of Bias and Precision of Observational Studies of Intervention or Exposures: Development, Validation, and Reliability Testing of the RTI Item Bank. (Prepared by RTI International–University of North Carolina Evidence-based Practice Center under Contract No. 290200710056I). Rockville, MD. Agency for Healthcare Research and Quality. In press.
55 Borenstein M, Hedges L, Higgins J, et al. Comprehensive Meta-analysis, Version 2. [software program]. Englewood, NJ. Biostat. 2005.
56 Miles MB, Huberman AM. Qualitative data analysis: an expanded sourcebook. 2nd edition. Thousand Oaks. Sage Publications. 1994.
57 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
58 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
59 Domino ME, Humble C, Lawrence WW Jr., et al. Enhancing the medical homes model for children with asthma. Med Care. 2009;47(11):1113-20. [pmid: 19786921].
60 Jaen CR, Crabtree BF, Palmer RF, et al. Methods for evaluating practice change toward a patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S9-20. S92. [pmid: 20530398].
61 Rosenthal MB, Beckman HB, Forrest DD, et al. Will the patient-centered medical home improve efficiency and reduce costs of care? A measurement and research agenda. Med Care Res Rev. 2010;67(4):476-84. [pmid: 20519426].
62 Jaen CR, Ferrer RL, Miller WL, et al. Patient outcomes at 26 months in the patient-centered medical home National Demonstration Project. Ann Fam Med. Suppl 1. 2010;8:S57-67. S92. [pmid: 20530395].
63 Reid RJ, Fishman PA, Yu O, et al. Patient-centered medical home demonstration: a prospective, quasi-experimental, before and after evaluation. Am J Manag Care. 2009;15(9):e71-87. [pmid: 19728768].
64 Farmer JE, Clark MJ, Drewel EH, et al. Consultative care coordination through the medical home for CSHCN: a randomized controlled trial. Matern Child Health J. Oct. 2011;15(7):1110-18. [pmid: 20721612].
65 Boult C, Reider L, Frey K, et al. Early effects of “Guided Care” on the quality of health care for multimorbid older persons: a cluster-randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2008;63(3):321-7. [pmid: 18375882].
66 Boyd CM, Boult C, Shadmi E, et al. Guided care for multimorbid older adults. Gerontologist. 2007;47(5):697-704. [pmid: 17989412].
67 Zuckerman B, Parker S, Kaplan-Sanoff M, et al. Healthy Steps: a case study of innovation in pediatric practice. Pediatrics. 2004;114(3):820-6. [pmid: 15342859].
68 Toseland RW, O'Donnell JC, Engelhardt JB, et al. Outpatient geriatric evaluation and management: is there an investment effect?. Gerontologist. 1997;37(3):324-32. [pmid: 9203756].
69 Boyd CM, Reider L, Frey K, et al. The effects of guided care on the perceived quality of health care for multi-morbid older persons: 18-month outcomes from a cluster-randomized controlled trial. J Gen Intern Med. 2010;25(3):235-42. [pmid: 20033622].
70 Toseland RW, O'Donnell JC, Engelhardt JB, et al. Outpatient geriatric evaluation and management. Results of a randomized trial. Med Care. 1996;34(6):624-40. [pmid: 8656727].
71 Reid RJ, Coleman K, Johnson EA, et al. The group health medical home at year two: cost savings, higher patient satisfaction, and less burnout for providers. Health Aff (Millwood). 2010;29(5):835-43. [pmid: 20439869].
72 Boyd CM, Shadmi E, Conwell LJ, et al. A pilot test of the effect of guided care on the quality of primary care experiences for multimorbid older adults. J Gen Intern Med. 2008;23(5):536-42. [pmid: 18266045].
73 Minkovitz CS, Strobino D, Mistry KB, et al. Healthy Steps for Young Children: sustained results at 5.5 years. Pediatrics. 2007;120(3):e658-68. [pmid: 17766506].
74 Wagner EH. Chronic disease management: what will it take to improve care for chronic illness?. Eff Clin Pract. 1998;1(1):2-4. [pmid: 10345255].
75 Glasgow RE, Wagner EH, Schaefer J, et al. Development and validation of the Patient Assessment of Chronic Illness Care (PACIC). Med Care. 2005;43(5):436-44. [pmid: 15838407].
76 Safran DG, Karp M, Coltin K, et al. Measuring patients' experiences with individual primary care physicians. Results of a statewide demonstration project. J Gen Intern Med. 2006;21(1):13-21. [pmid: 16423118].
77 Safran DG, Kosinski M, Tarlov AR, et al. The Primary Care Assessment Survey: tests of data quality and measurement performance. Med Care. 1998;36(5):728-39. [pmid: 9596063].
78 Nutting PA, Crabtree BF, Stewart EE, et al. Effect of facilitation on practice outcomes in the National Demonstration Project model of the patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S33-44. S92. [pmid: 20530393].
79 Masiach C, Jackson SA, Leither MP. Masiach Burnout Inventory Manual. 3rd ed. Mountain View, CA. Consulting Psychologists Press. 1996.
80 Marsteller JA, Hsu YJ, Reider L, et al. Physician satisfaction with chronic care processes: a cluster-randomized trial of guided care. Ann Fam Med. 2010;8(4):308-15. [pmid: 20644185].
81 Wise CG, Bahl V, Mitchell R, et al. Population-based medical and disease management: an evaluation of cost and quality. Dis Manag. 2006;9(1):45-55. [pmid: 16466341].
82 Schraeder C, Dworak D, Stoll JF, et al. Managing elders with comorbidities. J Ambul Care Manage. 2005;28(3):201-9. [pmid: 15968212].
83 Taplin S, Galvin MS, Payne T, et al. Putting population-based care into practice: real option or rhetoric?. J Am Board Fam Pract. 1998;11(2):116-26. [pmid: 9542703].
84 Peikes D, Chen A, Schore J, et al. Effects of care coordination on hospitalization, quality of care, and health care expenditures among Medicare beneficiaries: 15 randomized trials. JAMA. 2009;301(6):603-18. [pmid: 19211468].
85 Minkovitz CS, Hughart N, Strobino D, et al. A practice-based intervention to enhance quality of care in the first 3 years of life: the Healthy Steps for Young Children Program. JAMA. 2003;290(23):3081-91. [pmid: 14679271].
86 Dorr DA, Wilcox AB, Brunker CP, et al. The effect of technology-supported, multidisease care management on the mortality and hospitalization of seniors. J Am Geriatr Soc. 2008;56(12):2195-202. [pmid: 19093919].
87 Hebert R, Durand PJ, Dubuc N, et al. Frail elderly patients. New model for integrated service delivery. Can Fam Physician. 2003;49:992-7. [pmid: 12943358].
88 Sommers LS, Marton KI, Barbaccia JC, et al. Physician, nurse, and social worker collaboration in primary care for chronically ill seniors. Arch Intern Med. 2000;160(12):1825-33. [pmid: 10871977].
89 Ware JE Jr., Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992;30(6):473-83. [pmid: 1593914].
90 Stewart AL, Hays RD, Ware JE Jr. The MOS short-form general health survey. Reliability and validity in a patient population. Med Care. 1988;26(7):724-35. [pmid: 3393032].
91 Lorig K, Stewart A, Gonzalez VM, et al. Outcome Measures for Health Education and Other Healthcare Interventions. Thousand Oaks, CA. Sage Publications. 1996.
92 Steele GD, Haynes JA, Davis DE, et al. How Geisinger's advanced medical home model argues the case for rapid-cycle innovation. Health Aff (Millwood). 2010;29(11):2047-53. [pmid: 21041747].
93 Martin AB, Crawford S, Probst JC, et al. Medical homes for children with special health care needs: a program evaluation. J Health Care Poor Underserved. 2007;18(4):916-30. [pmid: 17982215].
94 Rubin CD, Sizemore MT, Loftis PA, et al. The effect of geriatric evaluation and management on Medicare reimbursement in a large public hospital: a randomized clinical trial. J Am Geriatr Soc. 1992;40(10):989-95. [pmid: 1401688].
95 Goetzel RZ, Ozminkowski RJ, Villagra VG, et al. Return on investment in disease management: a review. Health Care Financ Rev. 2005;26(4):1-19. [pmid: 17288065].
96 Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. 2011;171(5):460-6. [pmid: 21403043].
97 Gilfillan RJ, Tomcavage J, Rosenthal MB, et al. Value and the medical home: effects of transformed primary care. Am J Manag Care. 2010;16(8):607-14. [pmid: 20712394].
98 Sylvia ML, Griswold M, Dunbar L, et al. Guided care: cost and utilization outcomes in a pilot study. Dis Manag. 2008;11(1):29-36. [pmid: 18279112].
99 Steiner BD, Denham AC, Ashkin E, et al. Community care of North Carolina: improving care through community health networks. Ann Fam Med. 2008;6(4):361-7. [pmid: 18626037].
100 Dobson LA Jr., Hewson DL. Community care of North Carolina--an enhanced medical home model. N C Med J. 2009;70(3):219-24. [pmid: 19653605].
101 Leff B, Reider L, Frick KD, et al. Guided care and the cost of complex healthcare: a preliminary report. Am J Manag Care. 2009;15(8):555-9. [pmid: 19670959].
102 Farmer JE, Clark MJ, Sherman A, et al. Comprehensive primary care for children with special health care needs in rural areas. Pediatrics. 2005;116(3):649-56. [pmid: 16140704].
103 Palfrey JS, Sofis LA, Davidson EJ, et al. The Pediatric Alliance for Coordinated Care: evaluation of a medical home model. Pediatrics. 2004;113(5 Suppl):1507-16. [pmid: 15121919].
104 Rankin KM, Cooper A, Sanabria K, et al. Illinois medical home project: pilot intervention and evaluation. Am J Med Qual. 2009;24(4):302-9. [pmid: 19515943].
105 Treadwell J, Bean G, Warner W. Supporting disease management through intervention in the medical home. Prof Case Manag. 2009;14(4):192-7. [pmid: 19625938].
106 Chandler C, Barriuso P, Rozenberg-Ben-Dror K, et al. Pharmacists on a primary care team at a Veterans Affairs medical center. Am J Health Syst Pharm. 1997;54(11):1280-7. [pmid: 9179348].
107 Farris KB, Cote I, Feeny D, et al. Enhancing primary care for complex patients. Demonstration project using multidisciplinary teams. Can Fam Physician. 2004;50:998-1003. [pmid: 15317232].
108 Peleg R, Press Y, Asher M, et al. An intervention program to reduce the number of hospitalizations of elderly patients in a primary care clinic. BMC Health Serv Res. 2008;8:36. [pmid: 18254972].
109 Schifalacqua M, Hook M, O'Hearn P, et al. Coordinating the care of the chronically ill in a world of managed care. Nurs Adm Q. 2000;24(3):12-20. [pmid: 10986928].
110 Vedel I, De Stampa M, Bergman H, et al. A novel model of integrated care for the elderly: COPA Coordination of Professional Care for the Elderly. Aging Clin Exp Res. 2009;21(6):414-23. [pmid: 20154510].
111 Waxmonsky JA, Giese AA, McGinnis GF, et al. Colorado access' enhanced care management for high-cost, high-need Medicaid members: preliminary outcomes and lessons learned. J Ambul Care Manage. 2011;34(2):183-91. [pmid: 21415616].
112 Stroebel CK, McDaniel RR Jr., Crabtree BF, et al. How complexity science can inform a reflective process for improvement in primary care practices. Joint Commission Journal on Quality & Patient Safety. 2005;31(8):438-46. [pmid: 16156191].
113 Rhode Island Chronic Care Sustainability Initiative. DS Gifford (Primary Contact). Funding and/or Convening Orgs NR. Projected end date: 10/2011. Search source: PCPCCNET.
114 UnitedHealth Group PCMH Demonstration Program (Arizona). Eric Sullivan (Primary Contact). United Healthcare (Convening Org). Projected end date: 4/2012. Search source: PCPCCNET.
115 Maine Patient-Centered Medical Home Pilot. Lisa Letourneau (Primary Contact). Maine Quality Forum, Quality Counts, and Maine Health Management Coalition (Convening Org). Projected end date: 11/2012. Search source: PCPCCNET.
116 Alabama Health Improvement Initiative—Medical Home Pilot. Daniel Jackson (Primary Contact). Blue Cross Blue Shield of Alabama (Convening Org). Projected end date: 9/2012. Search source: PCPCCNET.
117 EmblemHealth Medical Home High Value Network Project (New York). William Gillespie (Primary Contact). EmblemHealth (Convening Org). Projected end date: 1/2010. Search source: PCPCCNET.
118 National Naval Medical Center Medical Home Program (Maryland). Kevin Dorrance (Primary Contact). National Naval Medical Center, Internal Medicine (Convening Org). Projected end date: NR. Search source: PCPCCNET.
119 TriHealth Physician Practices/Humana Patient-Centered Medical Home (Ohio). Chris Corbin (Primary Contact). Humana (Convening Org). Projected end date: 5/2011. Search source: PCPCCNET.
120 Queen City Physicians/Humana Patient-Centered Medical Home (Ohio). Chris Corbin (Primary Contact). Humana (Convening Org). Projected end date: 12/2010. Search source: PCPCCNET.
121 Metcare of Florida/Humana Patient-Centered Medical Home. Chris Corbin (Primary Contact). Humana (Convening Org). Projected end date: 11/2010. Search source: PCPCCNET.
122 WellStar Health System/Humana Patient-Centered Medical Home (Georgia). Chris Corbin (Primary Contact). Humana (Convening Org). Projected end date: NR. Search source: PCPCCNET.
123 Implementation and Impact of VA Patient-Centered Medical Home. Elizabeth Yano (Principal Investigator). U.S. Department of Veterans Affairs (Funding Institution). Projected end date: 9/2012. Search source: enGrant Scientific.
124 Multi-Method Evaluation of Physician Group Incentive Programs for PCMH Transition. Christopher Griffiths Wise (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 12/2011. Search source: enGrant Scientific.
125 Primary Care Transformation in a NCQA Certified Patient–Centered Medical Home. Ming Tai-Seale (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 7/2011. Search source: enGrant Scientific.
126 Informing Sound Policy: Linking Medical Home Measures and Child Health Outcomes. Nancy Swigonski (Primary Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 9/2013. Search source: enGrant Scientific.
127 Evaluating the Role of the Medical Home Model in the Successful Management of Diabetes. Gregory David Stevens (Principal Investigator). National Institute of Diabetes and Digestive and Kidney Diseases (Funding Institution). Projected end date: 1/2012. Search source: enGrant Scientific.
128 Evaluating Statewide Transformation of Primary Care to Medical Homes. Leif Solberg (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 8/2012. Search source: enGrant Scientific.
129 Understanding the Transformation Experiences of Small Practices with NCQA's Medical Home. Sarah Scholle (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 7/2012. Search source: enGrant Scientific.
130 Transforming Primary Care: Evaluating the Spread of Group Health's Medical Home. Robert Reid (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 6/2012. Search source: enGrant Scientific.
131 Transformed Primary Care—Care By Design. Michael Magill (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 6/2012. Search source: enGrant Scientific.
132 Transforming Primary Care Practice in North Carolina. Donahue, Katrina (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 7/2012. Search source: enGrant Scientific.
133 Evaluating Models of Medical Home Payment Within the Pennsylvania Chronic Care Initiative. MW Friedberg (Principal Investigator). The Commonwealth Fund (Funding Institution). Projected end date: 6/2013. Search source: The Commonwealth Fund.
134 Evaluating a Medical Home Demonstration in Colorado and Ohio. M Rosenthal (Principal Investigator). The Commonwealth Fund (Funding Institution). Projected end date: 6/2011. Search source: The Commonwealth Fund.
135 Evaluation of The Commonwealth Fund's Safety-Net Medical Home Initiative, Phase 2. MH Chin (Principal Investigator). The Commonwealth Fund (Funding Institution). Projected end date: 10/2013. Search source: The Commonwealth Fund.
136 What Makes Medical Homes Work: Lessons for Implementation and Spread. WF Stewart (Principal Investigator). The Commonwealth Fund (Funding Institution). Projected end date: 4/2012. Search source: The Commonwealth Fund.
137 Using Health Information Technology and Health Information Exchange to Help Physician Practices Improve Patient Care in Cincinnati. Trudi Matthews (Contact Person). Robert Wood Johnson Foundation Development Fund (Funding Org). Projected end date: 1/2012. Search source: Robert Wood Johnson Foundation.
138 Using Multi-Payer Payment Reform to Integrate Medical Home Concepts into Primary Care Practice in Washington State. Susanne Dade (Contact Person). Robert Wood Johnson Foundation Development Fund (Funding Source). Projected end date: 1/2012. Search source: Robert Wood Johnson Foundation.
139 The Medical HOME Study. ClinicalTrials.gov ID: NCT01228032. Robin Hill and Silke von Esenwein (Contact Persons). National Institute of Mental Health (Funding Org). Projected end date: 1/2015. Search source: ClinicalTrials.gov.
140 Evaluating the Effects of EHRs, P4P and Medical Home Redesign in the Hudson Valley. ClinicalTrials.gov ID: NCT00793065. Lisa Kern and Rainu Kaushal (Prinicipal Investigators). Weill Medical College, NY State Department of Health, and The Commonwealth Fund (Funding Orgs). Projected end date: 12/2011. Search source: ClinicalTrials.gov.
141 Multi-Payer Advanced Primary Care Practice (MAPCP) Demonstration. Alexander Dragatsi, Carol Callaghan, Ross Owen, Foster Gesten, Chris Collins, Ann Torregrossa, Tricia Leddy, and Craig Jones (Contact Persons). Centers for Medicaire & Medicaid Services (CMS; Funding Institution). Projected end date: 2014. Search source: CMS.
142 Patient Aligned Care Team (PACT) Demonstration Lab Initiative. Stephan Fihn (Primary Contact). U.S. Department of Veterans Affairs Health Services Research & Development (Funding Institution). Projected end date: NR. Search source: Personal contact.
143 Blue Cross Patient-Centered Medical Home Initiative Grows to Largest in Tennessee with 31 Sites. M Thompson-Danielson (Primary Contact). Blue Cross Blue Shield of Tennessee (Convening Org). Projected end date: NR. Search source: Review article (Bitton 2010).
144 Jackson GL, Powell AA, Ordin DL, et al. Developing and sustaining quality improvement partnerships in the VA: the Colorectal Cancer Care Collaborative. J Gen Intern Med. Suppl 1. 2010;25:38-43. [pmid: 20077150].
145 Nutting PA, Crabtree BF, Miller WL, et al. Journey to the patient-centered medical home: a qualitative analysis of the experiences of practices in the National Demonstration Project. Ann Fam Med. Suppl 1. 2010;8:S45-56. S92. [pmid: 20530394].
146 Centers for Medicare & Medicaid Services, Federally Qualified Health Center (FQHC), Advanced Primary Care Practice (APCP). Demonstration Frequently Asked Questions (FAQs). Available at: www.cms.gov/DemoProjectsEvalRpts/downloads/FQHC_APCP_Demo_FAQsOct2011.pdf. January 30, 2012.
147 Macinko J, Starfield B, Shi L. The contribution of primary care systems to health outcomes within Organization for Economic Cooperation and Development (OECD) countries, 1970-1998. Health Serv Res. 2003;38(3):831-65. [pmid: 12822915].
148 Jacobson D, Gance-Cleveland B. A systematic review of primary healthcare provider education and training using the Chronic Care Model for childhood obesity. Obes Rev. 2011;12(5):e244-56. [pmid: 20673280].
149 Lemmens KMM, Nieboer AP, Huijsman R. A systematic review of integrated use of disease-management interventions in asthma and COPD. Respir Med. 2009;103(5):670-91. [pmid: 19155168].
150 Epstein RM, Fiscella K, Lesser CS, et al. Why the nation needs a policy push on patient-centered health care. Health Aff (Millwood). 2010;29(8):1489-95. [pmid: 20679652].
151 Williams JW Jr., Gerrity M, Holsinger T, et al. Systematic review of multifaceted interventions to improve depression care. Gen Hosp Psychiatry. 2007;29(2):91-116. [pmid: 17336659].
152 Inglis SC, Clark RA, McAlister FA, et al. Structured telephone support or telemonitoring programmes for patients with chronic heart failure. Cochrane Database Syst Rev. 2010;(8):CD007228. [pmid: 20687083].
153 Peikes D, Zutshi A, Genevro J, et al. Early Evidence on the Patient-Centered Medical Home. Final Report (Prepared by Mathematica Policy Research, under Contract Nos. HHSA290200900019I/ HHSA29032002T and HHSA290200900019I/HHSA29032005T). AHRQ Publication No. 12-0020-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2012.
154 Peikes D, Zutshi A, Genevro JL, et al. Early evaluations of the medical home: building on a promising start. Am J Manag Care. 2012;18(2):105-16. [pmid: 22435838].
155 Peikes D, Dale S, Lundquist E, et al. Building the Evidence Base for the Medical Home: What Sample and Sample Size Do Studies Need?. White Paper (Prepared by Mathematica Policy Research under Contract No. HHSA290200900019I TO2). AHRQ Publication No. 11-0100-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2011.
156 McCulloch DK, Price MJ, Hindmarsh M, et al. A population-based approach to diabetes management in a primary care setting: early results and lessons learned. Eff Clin Pract. 1998;1(1):12-22. [pmid: 10345254].
157 Ralston JD, Martin DP, Anderson ML, et al. Group Health Cooperative's transformation toward patient-centered access. Med Care Res Rev. 2009;66(6):703-24. [pmid: 19549993].
158 Paulus RA, Davis K, Steele GD. Continuous innovation in health care: implications of the Geisinger experience. Health Aff (Millwood). 2008;27(5):1235-45. [pmid: 18780906].
159 James BC, Savitz LA. How Intermountain trimmed health care costs through robust quality improvement efforts. Health Aff (Millwood). 2011;30(6):1185-91. [pmid: 21596758].
160 Institute of Medicine Committee on Quality Health Care in America. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC. National Academy Press. 2001.
161 Glasziou P, Chalmers I, Altman DG, et al. Taking healthcare interventions from trial to practice. BMJ. 2010;341:c3852. [pmid: 20709714].
162 Wagner EH, Austin BT, Davis C, et al. Improving chronic illness care: translating evidence into action. Health Aff (Millwood). 2001;20(6):64-78. [pmid: 11816692].
163 Miller WL, Crabtree BF, Nutting PA, et al. Primary care practice development: a relationship-centered approach. Ann Fam Med. Suppl 1. 2010;8:S68-79. S92. [pmid: 20530396].
164 Damschroder LJ, Aron DC, Keith RE, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implementation Science. 2009;4:50. [pmid: 19664226].
165 Jackson GL, Krein SL, Alverson DC, et al. Defining core issues in utilizing information technology to improve access: evaluation and research agenda. J Gen Intern Med. Suppl 2. 2011;26:623-7. [pmid: 21989613].
166 Rubenstein LV, Pugh J. Strategies for promoting organizational and practice change by advancing implementation research. J Gen Intern Med. Suppl 2. 2006;21:S58-64. [pmid: 16637962].
167 Weiner BJ, Lewis MA, Linnan LA. Using organization theory to understand the determinants of effective implementation of worksite health promotion programs. Health Educ Res. 2009;24(2):292-305. [pmid: 18469319].
168 Harrison MI, Koppel R, Bar-Lev S. Unintended consequences of information technologies in health care--an interactive sociotechnical analysis. J Am Med Inform Assoc. 2007;14(5):542-9. [pmid: 17600093].
169 Powell AA, White KM, Partin MR, et al. Unintended consequences of implementing a national performance measurement system into local practice. J Gen Intern Med. Online First™. 13. October. 2011.
170 Yarnall KS, Pollak KI, Ostbye T, et al. Primary care: is there enough time for prevention?. Am J Public Health. 2003;93(4):635-41. [pmid: 12660210].
171 Stille C, Turchi RM, Antonelli R, et al. The family-centered medical home: specific considerations for child health research and policy. Academic Pediatrics. 2010;10(4):211-7. [pmid: 20605546].