# Introduction

## Background

The United States spends a greater proportion of its gross domestic product on health care than any other country in the world (17.6 percent in 2009),1 yet often fails to provide high-quality and efficient health care.2-6 U.S. health care has traditionally been based on a solid foundation of primary care to meet the majority of preventive, acute, and chronic health care needs of its population; however, the recent challenges facing health care in the United States have been particularly magnified within the primary care setting. Access to primary care is limited in many areas, particularly rural communities. Fewer U.S. physicians are choosing primary care as a profession, and satisfaction among primary care physicians has waned amid the growing demands of office-based practice.7 There has been growing concern that current models of primary care will not be sustainable for meeting the broad health care needs of the American population.

The patient-centered medical home (PCMH) is a model of primary care transformation that seeks to meet the variety of health care needs of patients and to improve patient and staff experiences, outcomes, safety, and system efficiency.8-11 The term “medical home” was first used by the American Academy of Pediatrics in 1967 to describe the concept of a single centralized source of care and medical record for children with special health care needs.12 The current concept of PCMH has been greatly expanded and is based on 40 years of previous efforts to redesign primary care to provide the highest quality of care possible.13,14 The chronic care model (CCM),15,16 a conceptual model for organizing chronic illness care that is associated with improved health outcomes, is the cornerstone of PCMH.17 Interventions based on CCM and focused on single conditions such as diabetes mellitus, asthma, chronic obstructive pulmonary disease, or depression have been shown to improve patient outcomes and/or quality of care.18-21 PCMH builds on this model and is intended to address the full range of patient-focused health care needs.8

As defined by physician and consumer groups, the core principles of the PCMH are: wide-ranging team-based care; patient-centered orientation toward the whole person; care that is coordinated across all elements of the health care system and the patient's community; enhanced access to care that utilizes alternative methods of communication; and a systems-based approach to quality and safety.9 While these principles are frequently cited in relation to PCMH, it should be recognized that specific PCMH definitions vary widely, reflecting the rapid expansion of the utilization of PCMH concepts in the last decade.22 As described in detail below, we based the operational definition of PCMH for this review on the definition outlined by the Agency for Healthcare Research and Quality (AHRQ).8

It has been hypothesized that comprehensive PCMH interventions hold promise as a pathway to improved primary health care quality, safety, efficiency, and effectiveness. The PCMH has also been described as a “lifeline for primary care” that has the potential to transform and increase the appeal and viability of primary care practice.23 Given the conceptual promise of PCMH, professional societies have endorsed the model,24 and payers (e.g., Medicare) and large health systems have begun to implement PCMH-based programs. These include health maintenance organizations (HMOs), networks of Medicaid providers, community health centers, private integrated delivery systems, private practices, the United States Department of Veterans Affairs (VA) health care system, and components of the Department of Defense military health care system.25-28 The goal is to improve the care of patients across the continuum of prevention and treatment of chronic and acute illness, while potentially improving both patient and provider experiences with the health care system. Further, it has been hypothesized that PCMH may introduce efficiencies in care that help contain rising health care costs.25

## Scope and Key Questions

### Scope of the Review

Individual elements of the PCMH are associated with improvements in selected outcomes for individual conditions.29-33 However, it is uncertain if primary care reorganization according to a comprehensive PCMH model (i.e., combining the use of PCMH components for multiple conditions) improves overall care processes and clinical outcomes. For this review, we examined the results of studies focusing on changing care for all or most patients served by a health care organization, not just a specific group of patients such as those with a given illness or set of illnesses.

As part of the Closing the Quality Gap: Revisiting the State of the Science series of Evidence-based Practice Center (EPC) reviews,34,35 the purpose of the systematic review is to identify completed and ongoing efforts to evaluate the comprehensive PCMH model, summarize current evidence for this model, and identify gaps in the evidence. Because the PCMH model is being implemented widely but the number of completed and published studies is expected to be small, the identification of ongoing studies is an important goal of this review. This “horizon scan” component of the review will help to identify forthcoming studies that may address gaps in the currently available evidence.

The PCMH is a cross-cutting topic, relevant to broad areas of health care and patient populations and we therefore anticipated important challenges for this review:

- Multiple definitions of the PCMH model have been proposed by various professional and patient organizations.22 Further, the agreed upon elements of the PCMH are expressed in general terms and are subject to different interpretations and operational definitions, particularly when applied to each unique delivery system.36-38 As a result, we have identified components of comprehensive PCMH interventions that must be present for studies to be included in this review. These components are based on the PCMH definition proposed by the Agency for Healthcare Research and Quality (AHRQ).8
- Based on a preliminary review of the literature, we anticipated few randomized controlled trials (RCTs) and a diverse range of study designs. Because RCTs, quasiexperimental designs, and observational designs vary in their risk of bias, we prioritized RCTs. However, we included other study designs when necessary.

For the purpose of this report, we created an operational definition for a PCMH intervention that is based on the AHRQ definition of PCMH.8 The operational definition requires a combination of components as follows: (1) team-based care; (2) having ≥ 2 of 4 elements focused on how to improve the entire organization of care (enhanced access, coordinated care, comprehensiveness, systems-based approach to improving quality and safety); (3) a sustained partnership; and (4) having an intervention that involves structural changes to the traditional practice. Specifics on these elements can be found in the PICOTS (Populations, Interventions, Comparators, Outcomes, Timing, Settings) section, below. This definition was applied for Key Questions (KQs) 1–3, below, for inclusion in the review. Intervention programs did not have to specifically identify themselves as a PCMH if they otherwise described the components required for inclusion. Because reports of ongoing studies for KQ 4 (horizon scan) often provided very limited detail on the intervention, we applied a more liberal definition, including any intervention that claimed to be testing a PCMH, regardless of the detail provided on the intervention.

### Key Questions

KQs 1–3 include published studies describing completed PCMH interventions, while KQ 4 is a “horizon scan” that addresses unpublished comparative studies now in progress.

- KQ 1: In published, primary care–based evaluations of comprehensive PCMH interventions, what are the effects of the PCMH on patient and staff experiences, process of care, clinical outcomes, and economic outcomes?
  a. Are specific PCMH components associated with greater effects on patient and staff experiences, process of care, clinical outcomes, and economic outcomes?
  b. Is implementation of comprehensive PCMH associated with unintended consequences (e.g., decrease in levels of indicated care for nonpriority conditions) or other harms?
- KQ 2: In published, primary care–based evaluations of comprehensive PCMH interventions, what individual PCMH components have been implemented?
- KQ 3: In published, primary care–based evaluations of comprehensive PCMH interventions, what financial models and implementation strategies have been used to support uptake?
- KQ 4: What primary care–based studies evaluating the effects of comprehensive PCMH interventions on patient and staff experiences, process of care, clinical outcomes, or economic outcomes are currently under way? In these ongoing studies, what are the study designs, PCMH components, comparators, settings, financial models, and outcomes to be evaluated?

### PICOTS Framework for the Key Questions

#### Populations

Populations included were:

1. Adult, primary care patients, selected to represent the practice rather than on the basis of a particular chronic illness
2. Children with special health care needs according to the Health Resources and Services Administration (HRSA) definition.39 The broad definition of children with special health care needs includes those who have or are at increased risk for chronic physical, developmental, behavioral, or emotional conditions that require health and related services of a type or amount beyond those required by children generally.

#### Interventions

The PCMH is a broad-based strategy aimed at improving chronic illness care or provision of preventive services. Using the AHRQ definition of the PCMH (items marked with an asterisk [*] below),8 we operationalized the concept of a PCMH intervention as a comprehensive intervention that includes items 1, 3, and 4, along with at least two elements of item 2. The comprehensive PCMH intervention is the combination of the components described below, not the individual components themselves.

The components are:

1. Team*-based care, defined as a team-based structure in which two or more clinicians work together to provide care. The team may be virtual.
2. The intervention includes ≥ 2 of the following 4 elements:
  a. Enhanced [underlined: access]* to care (e.g., advanced electronic communications such as Internet or telephone visits, open access scheduling, group visits, 24/7 coverage).
  b. [underlined: Coordinated]* care (care coordinated across settings such as inpatient and outpatient, or across specialty and nonspecialty care [such as mental health], or subspecialty medicine and primary care; care management; or referral tracking).
  c. [underlined: Comprehensiveness],* i.e., care that is accountable for addressing a large majority of personal health needs; (e.g., preventive care, acute care, chronic disease care, and mental health).
  d. [underlined: A systems-based approach to improving quality and safety]* (e.g., care planning process, evidence-based medicine/clinical guidelines, point-of-care resources, electronic prescribing, test-tracking, performance measurement, self-management support, accountability, and shared decisionmaking.
3. A sustained partnership* and personal relationship over time oriented towards the whole person* (e.g., designating a primary point of contact who coordinates care, a personal physician, and shared decisionmaking).
4. The intervention involves structural changes to the traditional practice, [underlined: reorganizing care delivery] (e.g., new personnel, new role definitions, functional linkages with community organizations and/or other health care entities such as hospitals, specialists or other service providers, and disease registries).

#### Comparators

1. Usual care.
2. Programs aimed at improving the quality of care, process outcomes, or clinical outcomes that do not meet the operational definition of a comprehensive PCMH intervention given above. These comparator programs may include some components of the PCMH model, but not enough to qualify as a comprehensive PCMH intervention.

#### Outcomes

KQ 1 PCMH interventions may lead to a variety of effects on the health care system and patient health status. We prioritized and abstracted a specific subset of these outcomes that had face validity and were reported across studies, and/or were collected using validated instruments or methods. These included:
  1. Patient experiences:
    a. Global/overall patient experiences
    b. Coordination of care
    c. Patient-provider interaction
  2. Staff experiences:
    a. Global/overall staff experiences
    b. Staff retention rates
    c. Staff burnout
  3. Process of care:
    a. Preventive services
    b. Chronic illness care services
  4. Clinical outcomes:
    a. Health status
    b. Laboratory tests
    c. Mortality
  5. Economic outcomes:
    a. Inpatient utilization
    b. Emergency department utilization
    c. Overall costs
  6. Unintended consequences or other harms
KQ 2 PCMH components as listed under “Interventions,” above. We describe the use of specific PCMH components and related activities reported in the reviewed studies, as follows:
  1. Team-based care (description, including disciplines represented)
  2. Enhanced access (description of components)
  3. Coordinated care (description of components)
  4. Comprehensiveness (yes/no)
  5. A systems-based approach to improving quality and safety (description of components)
  6. Sustained partnership (yes/no)
  7. Reorganizing care delivery (description of components)
KQ 3 1. Financial models (e.g., bundled payments, fee-for-service, performance-based incentives)
  2. System-change (e.g., Plan-Do-Study-Act cycles,40 academic detailing41), along with any theoretical basis provided
  3. Organizational learning strategies (e.g., quality improvement collaboratives40), and any theoretical basis provided for these strategies
KQ 4 Because KQ 4 is a horizon scan of ongoing studies, we anticipated that many study details would not be available, but we examined data sources for the following information:
  1. Study designs, including patient or cluster RCTs, nonrandomized clustered controlled trials, and controlled before-and-after studies
  2. PCMH components (as defined in intervention PICOTS) and comparators
  3. Settings (e.g., practice size, geographic location)
  4. Financial models (e.g., bundled payments, fee-for-service, performance-based incentives)
  5. Types of outcomes assessed:
    a. Patient experiences
    b. Staff experiences
    c. Process of care
    d. Clinical outcomes
    e. Economic outcomes

#### Timing

1. Studies had to have at least 6 months' longitudinal followup.

#### Settings

1. Primary care (i.e., we did not consider studies in specialty care settings such as infectious disease for patients with HIV/AIDS). Primary care includes:
  a. General internal medicine
  b. Family medicine
  c. Primary care pediatrics
  d. Primary care clinics directed by mid-level providers
  e. Terms commonly used for primary care outside the United States (e.g., general practice/practitioner)
2. KQ 4 was further restricted specifically to studies underway in the United States. We imposed this restriction on the horizon scan to identify ongoing studies that are most relevant to the U.S health care system and because we believed we would more reliably be able to identify studies conducted in the United States.

#### Type of Studies

The description below represents the types of studies that were eligible for inclusion in the report. Not all types were found as a result of the literature search.

1. KQ 1: We focused on studies of comprehensive PCMH interventions with a comparison group. Specific study designs are based on guidance from the Cochrane Effective Practice and Organisation of Care Review Group (EPOC) and include:42
  a. Patient or cluster RCTs
  b. Nonrandomized clustered controlled trials: an experimental study in which practices or clinicians are allocated to different interventions using methods that are not random
  c. Controlled before-and-after studies: A study in which observations are made before and after the implementation of an intervention, both in a group that receives the intervention and in a comparison group that does not. These studies include observational studies of “natural experiments.”
2. KQ 2–3: All of the designs listed above plus uncontrolled studies that include a pre- and postintervention assessment. We included uncontrolled studies for these questions because the aims of the questions are descriptive. By including uncontrolled studies, we were able to give a more comprehensive description of the PCMH components, financial models, and implementation strategies examined to date.
3. KQ 4: Same as KQ1. Because this question represents a “horizon scan” of ongoing and/or yet-to-be-published literature, we sought ongoing longitudinal studies, including pilot and demonstration projects, with a comparison group. Given the large number of organizations conducting ongoing evaluations of PCMH, we prioritized studies from major Federal funders (e.g. Centers for Medicare & Medicaid Services [CMS], AHRQ, VA) and large studies from non-Federal funders that are most likely to yield high quality data and address gaps in existing evidence.

### Analytic Framework

Figure 1 shows the analytic framework for this review.

Figure 1 Analytic framework

Notes: KQ = Key Question; PCMH = patient-centered medical home

Iillustrates how we hypothesized the potential mechanism by which comprehensive PCMH interventions (the combination of PCMH elements taken as a group, not just the individual components) and their comparators may impact outcomes of interest (KQ 1), including patient and staff experiences, process of care, clinical outcomes, and economic outcomes. This hypothesis motivated the search for potentially relevant published literature. In addition, we searched the literature to determine if there have been any reports of an association between PCMH and unintended consequences or other harms. The individual components of PCMH and their incorporation and/or implementation in PCMH evaluations were examined (KQ 2), as well as the financial models and system change or organizational learning strategies used to support uptake (KQ 3). Finally, the figure illustrates the way in which the above-mentioned outcomes and moderators were identified in ongoing studies (KQ 4).

The figure illustrates how we hypothesized the potential mechanism by which comprehensive PCMH interventions (the combination of PCMH elements taken as a group, not just the individual components) and their comparators may impact outcomes of interest (KQ 1), including patient and staff experiences, process of care, clinical outcomes, and economic outcomes. This hypothesis motivated the search for potentially relevant published literature. In addition, we searched the literature to determine if there have been any reports of an association between PCMH and unintended consequences or other harms. The individual components of PCMH and their incorporation and/or implementation in PCMH evaluations were examined (KQ 2), as well as the financial models and system change or organizational learning strategies used to support uptake (KQ 3). Finally, the figure illustrates the way in which the above-mentioned outcomes and moderators were identified in ongoing studies (KQ 4).