# Peer Reviewers

Mac Baird, M.D.

Professor of Family Medicine and Community Health

University of Minnesota

Minneapolis, MN

Michael S. Barr, M.D., M.B.A.

Senior Vice President, American College of Physicians

Philadelphia, PA

Matthew Burke, M.D.

Bureau of Primary Health Care

Health Resources and Services Administration

Rockville, MD

C. Annette DuBard, M.D., M.P.H.

Director of Informatics, Quality, and Evaluation

North Carolina Community Care Networks, Inc.

Raleigh, NC

Suzanne Goodwin, Ph.D.

Project Officer, Centers for Medicare & Medicaid Services

Baltimore, MD

Christopher L. Hunter, Ph.D.

Program Manager, Behavioral Health in Primary Care

Falls Church, VA

Eugenie M. Komives, M.D.

Vice President and Senior Medical Director

Blue Cross Blue Shield of North Carolina

Chapel Hill, NC

Marie Y. Mann, M.D., M.P.H.

Health Resources and Services Administration

Rockville, MD

Christopher Stille, M.D., M.P.H.

Professor of Pediatrics

University of Colorado

Denver, CO