# Technical Expert Panel

Frank V. deGruy, III, M.D., M.S.F.M.

Department of Family Medicine

University of Colorado

Aurora, CO

Lisa Rubenstein, M.D., M.P.S.H.

Professor of Medicine, UCLA

Director, VA Health Services Research and Development

Los Angeles, CA

Sarah H. Scholle, Dr.P.H., M.P.H.

National Committee for Quality Assurance

Washington, DC

Kathleen R. Stevens, Ed.D., R.N.

Professor and Director, Academic Center for Evidence-based Nursing

University of Texas Health Science Center

San Antonio, TX