# Discussion

Although few studies have evaluated the effects of the medical home specifically, a moderately well-developed series of trials and observational studies have tested interventions meeting the functional definition of the medical home. Most of these evaluations focused on older adults with multiple chronic conditions. The effects across a range of important outcomes (Key Question [KQ] 1) are summarized in Table 22.^57^ In brief, there is moderately strong evidence that the medical home has a small positive impact on patient experiences and small to moderate positive effects on preventive care services. Staff experiences are also improved by a small to moderate degree (low strength of evidence [SOE]), but no study reported effects on staff retention. Current evidence is insufficient to determine effects on clinical and most economic outcomes. We judged the strength of evidence as low for an association between PCMH and lower healthcare utilization (combination of inpatient and primarily emergency department utilization), but estimated effects were imprecise. Further, we did not find evidence of an effect of PCMH on total costs. Given the relatively small number of studies directly evaluating the medical home, and the evolving approaches to designing and implementing the medical home model, these findings should be considered preliminary.

Table 22 Summary of the strength of evidence for KQ 1

Outcome [SOE & Magnitude of Effect^a,b,c^] | Number of Studies (Subjects) | SOE Domain–Risk of Bias: Study Design/ Quality | SOE Domain–Consistency | SOE Domain–Directness | SOE Domain–Precision | Effect Estimate (Range or 95% CI)
Patient Experiences [Moderate SOE: small positive effects] | 5 (6,884) | RCT/Fair | Consistent | Direct | Precise | ES median (range): 0.27 (-0.36 to 0.42)
Patient Experiences [Moderate SOE: small positive effects] | 2 (3,513) | Observational/Fair | Inconsistent | Direct | Precise | ES:^d^ +0.13
Staff Experiences [Low SOE: small to moderate positive effects] | 2 (NR) | RCT/Fair | Inconsistent | Some indirectness | Imprecise | ES median (range): 0.18 (0.14 to 0.87)
Staff Experiences [Low SOE: small to moderate positive effects] | 1 (82) | Observational/Fair | Unknown | Direct | Imprecise | ES median (range): 0.49 (0.32 to 0.61)
Process of Care for Preventive Services [Moderate SOE: small to moderate positive effects] | 3 (8,377) | RCT/Fair | Consistent | Direct | Precise | RD median (range): 1.3% (-0.4% to +7.7%)
Process of Care for Preventive Services [Moderate SOE: small to moderate positive effects] | 2 (57,832) | Observational/Fair | Consistent | Direct | Precise | RD median (range): 14.2% (5.6% to 20.6%)
Process of Care for Chronic Illness Care Services [Insufficient] | 2 (4,640) | RCT/Fair | Inconsistent | Some indirectness | Precise | RD median (range): 6.6% (0.2% to 20.8%)
Process of Care for Chronic Illness Care Services [Insufficient] | 3 (455,832) | Observational/Fair | Seriously inconsistent | Some indirectness | Precise | RD median (range): 7.1% (7.1% to 21.4%)
Clinical Outcomes: Biophysical Markers, Health Status, Mortality [Insufficient] | 3 (2,586) | RCT/Good | Consistent | Some indirectness | Imprecise | Not reliably estimated
Clinical Outcomes: Biophysical Markers, Health Status, Mortality [Insufficient] | 3 (58,393) | Observational/Poor | Consistent | Some indirectness | Imprecise | Not reliably estimated
Economic Outcomes: Hospital Inpatient Admissions, ED Visits, Total Costs^e^ [Low SOE for Lower ED visits in older adults and no reduction in admissions; insufficient for total costs in adults; insufficient for all economic outcomes in children] | 5 (8,001) | RCT/Fair | Consistent | Some indirectness | Imprecision | Admissions: RR 0.96 (95% CI, 0.84 to 1.10) in adults; ED visits: RR 0.81 (95% CI, 0.67 to 0.98) in adults; total costs: no summary estimate
| 6 (229,883) | Observational/Fair | Consistent | Direct | Precise | Admissions: RD median (range): -0.2% (1.4% to -8.9%); ED visits: RD median (range): -1.2% (3.1% to -8.3%); total costs: no summary estimate
Unintended Consequences or Other Harms [Insufficient] | 0 | NA | NA | NA | NA | No estimate

a SOE ratings are provided for outcomes overall (incorporating evidence from all studies), while magnitude-of-effect estimates are provided for RCTs vs. observational studies. The effect size for economic outcomes represents a summary estimate of effect from meta-analysis. Other effect sizes are presented as the range across individual studies.

b In one study,60 a program of facilitated PCMH (intervention) was compared with providing practices with information on PCMH but not facilitating the implementation (control). This study generally showed no differences on the key outcomes addressed. Both arms implemented components of the PCMH model, and this may be why there were no significant differences between them.

c The small number of studies conducted among children precluded formal comparison with studies conducted in adults. However, results in these two populations were generally congruent.

d The effect size for one of the two available observational studies could not be calculated with available information.72 As a result, an effect size median and range could not be calculated.

e Two of the 13 studies that reported economic outcomes—one RCT94 and on observational study81—reported only total costs and so did not inform the summary effect estimates reported in this table.

Notes: CI = confidence interval; ED = emergency department; ES = effect size; KQ = Key Question; NA = not applicable; NR = not reported; RCT = randomized controlled trial; RD = risk difference; RR = risk ratio; SMD = standardized mean difference; SOE = strength of evidence

Rating the SOE for this body of evidence was challenging because the range of study designs, populations, and outcomes precluded quantitative summaries for most outcomes. We thus did not have the usual quantitative tools that are part of meta-analyses for assessing consistency and precision.

## Key Findings and Strength of Evidence

### KQ 1 Effects of PCMH Interventions

Table 22 summarizes the strength of evidence for various outcomes evaluated for KQ 1. Note that the information summarized relates to comprehensive patient-centered medical home (PCMH) and comprehensive functional PCMH interventions. It is uncertain whether particular PCMH components (e.g., enhanced access) or the particular methods used to implement those components (e.g., telephone visits) are associated with greater effects than usual primary care.

### KQ 2 PCMH Components Implemented

A summary of the most important findings for KQs 2–4 is provided in Table 23.

Table 23 Summary of findings for KQs 2–4

KQ2 – PCMH Components Implemented
Variability in components: Although most studies reported implementing most of the seven major medical home domains, studies varied considerably in their approach to implementing major components (e.g., variable approaches to enhancing access to care).
Evaluation of specialty care: Few medical home studies directly address medical specialty care (n = 6) or mental health specialty care (n = 3).
KQ3 – Financial Models and Implementation Strategies
Financial models: Few medical home studies (n = 11) provided detailed information about the financial models used to support the medical home. Financial models described included enhanced fee-for-service, additional per-member per-month payments, stipends to support aspects of the intervention, and payments linked to quality and efficiency targets.
Organizational implementation strategies: Audit and feedback were the most commonly used specific strategies to implement the medical home, described in 13 studies.
Organizational learning strategies: Learning collaboratives and collaborative program planning were the most commonly used organizational learning strategies, described in 19 studies.
KQ4 – Horizon Scan of Ongoing PCMH Studies
Ongoing studies: A relatively large number of studies evaluating the medical home are scheduled to conclude within the next 2 years. However, only 2 of the 31 studies are RCTs. Most studies report planned outcomes of: patient or staff experiences, process of care outcomes, and economic outcomes. These studies appear to have the potential for improving our understanding and the strength of evidence for a range of important outcomes.

Notes: KQ = Key Question; PCMH = patient-centered medical home; RCT = randomized controlled trial

For KQ 2, 21 of 27 studies described interventions that included all 7 major PCMH components. Studies varied greatly in the number and types of approaches used to implement these core components; overall, 51 different strategies or approaches were used. PCMH studies used a greater number of strategies than did functional PCMH studies. Most studies addressed chronic illness, preventive care needs, and acute care needs; used multidisciplinary teams; and coordinated care transitions. Over three-quarters reported adding new staff. All but three studies used strategies to enhance access, but no single strategy was employed by a majority of studies. Identifying high-risk patients and using evidence-based clinical guidelines, performance monitoring, and electronic health records were the most commonly used approaches to improving quality and safety.

### KQ 3 Financial Models and Implementation Strategies

Implementation of PCMH requires significant restructuring for most primary care practices. Recognizing the increased range of services required and the cost of implementation, some definitions of the medical home include a financial component, but this was not a requirement for inclusion in our review. Among the 27 included studies, only 11 described aspects of their financial model. These studies used a variety of methods to fund PCMH implementation, including receipt of external study funding, capitation payments or salaried providers, or a hybrid approach.

While it is likely that both organizational learning and implementation strategies are necessary for implementation of complex interventions,16,144 we recognize that there can be significant overlap in these concepts. The most commonly employed organizational learning strategy, used in a majority of studies (n = 19), was either a formal learning collaborative or collaborative program planning forums for practice team members to learn about PCMH or its components. For implementation, over one-half of studies used audit and feedback, usually employing quality improvement methodology. The largest trial of PCMH found that facilitated PCMH was associated with better staff experience than nonfacilitated PCMH,78 which qualitatively was shown to be important for PCMH implementation.145 This may indicate that the impact of PCMH on practices may go beyond simply having the identified elements in place. The process of facilitation may also represent an important part of the process for making PCMH successful.

### KQ 4 Horizon Scan of Ongoing PCMH Studies

We identified 31 ongoing studies evaluating the medical home. Only two of these are randomized controlled trials (RCTs). Most studies report plans to evaluate patient or staff experiences, process of care outcomes, and economic outcomes. Many studies also plan qualitative and quantitative assessments of implementation to better understand how care can be successfully transformed according to this model. These studies appear to be broadly representative of the U.S. health care system, both in geography and in the complexity of private and public health care payers and delivery networks. The cooperation of many of these evaluation projects with commercial insurers is particularly encouraging given the importance of implementing medical homes in a way that is financially sustainable for payers and providers alike. Most of these studies will be complete within the next 2 years, which means that the extant literature will grow significantly in the near future.

There are many ongoing PCMH demonstration projects that were not included in this horizon scan. Some of these are large and may contribute important information, such as the CMS Federally Qualified Health Center Advanced Primary Care Practice Demonstration, which plans to include 500 health centers and almost 200,000 Medicare beneficiaries.146 However, we chose to include only those studies that specified a comparator group for evaluating the PCMH. Many of the excluded demonstration projects may in fact include appropriate comparators to determine the impact of PCMH, but did not provide this detail in the limited grey literature available to us. Because of this limitation, we believe the number of studies reporting the impact of the PCMH in the next few years will exceed the list catalogued in the horizon scan.

## Findings in Relationship to What Is Already Known

The PCMH model is built on a solid research foundation, including findings that greater access to primary care is associated with better population health outcomes and lower costs.147 The chronic care model (CCM),15,16 a conceptual model for organizing chronic illness care, is the cornerstone of the medical home model. In adults, interventions based on the CCM have been shown to improve health outcomes across a range of chronic conditions, including congestive heart failure, diabetes mellitus, and major depression.17 In children and adolescents, the CCM is associated with better outcomes for obesity148 and asthma.149 However, these studies typically focused on single chronic conditions. By contrast, this review evaluated PCMH interventions that were more broadly conceptualized and tested in more general populations.

For our review, we evaluated the effects of interventions designed to improve care for all or most patients served by a health care organization, not just a specific group of patients such as those with a given illness or set of illnesses. Compared with narrative reviews of PCMH,50,150 or reviews of selected components of the medical home,47 our results suggest less certainty about the benefits of the PCMH. These narrative reviews often included a broader range of study designs, including designs with a higher risk of bias, than did our review. Compared with systematic reviews of care models tested for single diseases,17,151,152 our review is generally consistent with the findings of improvements in patient experiences, but contrasts with these reviews in finding insufficient evidence for improved clinical outcomes. A recent systematic evaluation of 14 higher quality medical home studies covering 12 separate interventions153,154 found similar results to our review, concluding that: (1) there were some positive effects for quality, costs, and patient/family experience, and a few negative effects on costs and many inconclusive results; (2) the model is rapidly evolving; and (3) PCMH is a promising innovation, but stronger evaluations are needed to guide model development and implementation. In a related work,155 the same research group found that extant studies are underpowered for some key outcomes, particularly economic outcomes. Our review adds new information by showing some support for positive effects on staff experiences, and by providing detailed descriptions of the components implemented and the financial models and implementation strategies used to facilitate adoption. Our review is also consistent with a previous horizon scan46 showing that a wide range of ongoing studies are evaluating the medical home, with the potential to address important gaps in evidence.

## Applicability to Primary Care in the United States

Overall, studies tended to focus on specific populations of patients (e.g., older adults, children with special health care needs). Many included priority populations as identified by the Agency for Healthcare Research and Quality (AHRQ) or the Institute of Medicine (IOM), but applicability to broader, generally healthier primary care populations is uncertain. Most studies tested an intervention that met the AHRQ definition of PCMH but were not an explicit test of the medical home. Further, these “functional PCMH” studies had fewer strategies for implementing the core components of PCMH than studies explicitly evaluating PCMH. Therefore, these studies collectively may be a less robust test of PCMH and less applicable than ongoing studies of PCMH. With one important exception, controlled studies included for KQ 1 evaluated the effect of PCMH interventions against usual care. The American Academy of Family Physicians National Demonstration Project (AAFP NDP), a multicenter RCT, compared facilitated verses nonfacilitated implementation of the PCMH.60 This study demonstrated that motivated practices, even without expert facilitation, can implement the key elements of the PCMH model of care.

Among comparative studies, we abstracted outcomes in five broad domains. Collectively, these studies evaluated a broad range of clinical and economic outcomes. However, studies did not report unintended consequences or effects on staff retention; few reported a comprehensive set of outcome measures; and the longest followup was 2 years. Some outcomes (e.g., mortality, overall costs) may require larger and longer-term studies to show an effect.

Most comparative studies were fielded in integrated delivery systems (9 of 17 studies included in KQ1). Many of these health care systems have lengthy histories of extensive quality improvement programs.156-159 For example, the CCM, which forms much of the basis of current PCMH definitions, was developed at the Group Health Cooperative of Puget Sound.74 Two studies included in KQ 1 were conducted at Group Health.63,83 Practices participating in the large AAFP-NDP had a mean of 46 percent of the model components in place at baseline (range 20 percent to 70 percent).62 Studies conducted in organizations that are early adopters or with multiple PCMH components already in place may have limited the observed effects of the PCMH intervention. It is possible that greater differences in various outcomes may be seen if the PCMH model were evaluated in organizations with fewer PCMH components in place or with a less robust history of quality improvement efforts.

## Implications for Clinical and Policy Decisionmaking

Despite the fact that the United States spends a greater proportion of its gross domestic product on health care than any other country in the world (17.6% in 2009),1 it frequently falls short on measures of quality and efficiency.2-6 The PCMH is a model of primary care transformation that seeks to meet the variety of patient health care needs and improve patient and staff experiences, health outcomes, safety, and system efficiency.8-11 Based largely on studies of programs aimed at improving care for patients with chronic illnesses,20 numerous large organizations have begun to implement PCMH. Some have described PCMH as having the potential to redefine primary care and transform the organization of health care in the United States.

PCMH interventions are associated with improvements in both patient and staff experiences and preventive care processes. For policymakers concerned about the sustained viability of primary care, these results are encouraging. However, for chronic illness care and clinical outcomes, we were unable to estimate intervention effects due to the small number of studies and the varied outcome measures used. Moreover, there is insufficient evidence to determine the effects on most economic outcomes. Two recent evaluations of PCMH implementation in two highly regarded health care systems point to reduced inpatient and emergency department utilization, but these results were not reflected in reduced total cost.71,97 Two studies reporting significant cost differences actually pointed generally towards higher costs. This was related to having increased access to services59 and/or reduced program fees.59,84 Lowering costs or improving outcomes can increase the value of health care. The improvements in patient experience and preventive care suggest that PCMH may increase value, but until better data are available for effects on chronic illness care, clinical outcomes, and total costs, this value metric will remain uncertain.

For some organizations, the conceptual promise of PCMH, coupled with the current positive but limited evidence, will be sufficient to proceed with implementation. Which strategies are the most promising to implement and how should implementation be facilitated? Published studies of PCMH interventions by definition have similar broad components (e.g., teams, enhanced access, coordinated care, a comprehensive focus, system-based approaches to improving quality and safety, sustained partnerships, and reorganization of care); however, precise components of care vary widely. As a result, one organization's version of PCMH may not look like another organization's version. We were not able to identify specific PCMH components that were associated with greater effects, but our descriptions of the range of strategies employed, helps to answer the “What is possible?” question. From a practical perspective, payers may require a medical home designation that meets requirements by NCQA or other certifying bodies. The processes used to actually implement the PCMH components were often not well described. As a result, we do not yet know details about “the best way” to implement PCMH. However, complex interventions and practice transformation do not happen spontaneously; they require support and a viable financial structure. Most studies included in our review used structured implementation approaches.

Finally, the 31 ongoing studied identified through the KQ 4 horizon scan, most to be completed within the next 2 years, have great potential to add to our understanding of the impact of PCMH. These second-generation studies have the potential to show greater impacts than has been reported in the literature published to date.

## Limitations of the Review Process

The PCMH is a model of care with considerable flexibility, not a narrowly defined intervention or manualized protocol. Further, multiple definitions of the PCMH model have been proposed by various professional and patient organizations.22 We developed an operational definition, derived from the AHRQ definition of the medical home,8 which does not require an enhanced payment model, to identify eligible interventions. Because we used the AHRQ definition, our review was more inclusive of studies that tested the critical principles that embody the IOM concept of patient-centered care.160 However, greater inclusivity came with the trade-off of greater variability in study interventions. The general nature of the intervention also complicated our literature search, given the potential for relevant studies that did not use the term “medical home” and the lack of MeSH terms for this topic. An additional challenge was identifying relevant non-RCTs since search filters for these study designs are not as well-developed or as well-validated as for RCTs.

There is no standard nomenclature for many of the concepts that form part of the definition of the medical home or for the methods used for implementing programs designed to operationalize these concepts. This lack of standard definitions also leads to a wide variety of measures for PCMH components. The lack of standardized nomenclature and measures is a particular issue for studies seeking to describe quality improvement approaches or financial models used to implement PCMH. Similarly, some specific PCMH features (e.g., electronic health record) could fit into more than one PCMH component. The lack of a standard nomenclature and the often sparse reporting of interventions made uniform data abstraction and classification of intervention components particularly challenging.

Heterogeneity in study designs, populations, and outcomes meant that standard quantitative summary methods were generally not possible. Much of this variability is appropriate. For example, studies included different populations (e.g. adults, children). The needs of these patients differ, as do the locations in which they are often treated. Further, there is no consensus on what types of outcomes should be addressed when determining if PCMH “works.” We also faced difficulties in implementing our planned qualitative cross-case analysis to determine components and approaches most associated with benefit. There were simply too few studies for each outcome to complete this planned analysis.

The variable number of publications per study, some using multiple publications and others using only a single publication to describe the intervention, may have limited the description of the different PCMH components, financial models, and leaning and implementation strategies. Queries to study authors may have reduced missing information, but may also have introduced recall bias.

Finally, the horizon scan conducted for KQ 4 has important limitations. Many of the included citations provided only sparse detail on the population, design, and outcomes, which limited our ability to completely evaluate each PCMH project. This may have led to the exclusion of studies that would have met our criteria had they reported sufficient detail. Even among the included studies, the paucity of detail carries with it the risk of misclassification, with the likely bias toward underrepresentation of the full study detail.

## Limitations of the Evidence Base

Only 6 of the 27 studies included in this review evaluated an intervention that was explicitly developed using current definitions of PCMH, and only 2 of these 6 were RCTs. Across all studies, only six were judged to be good quality. Some of the limitations that led to lower quality ratings were failure to account for clustering within practices and/or the organization in the analyses, lack of clear eligibility criteria, lack of blinding when assessing outcomes, and clinical outcome measures of uncertain validity.

As described above, PCMH is a flexible model of care as opposed to a more discrete intervention such as a drug or device. Given this flexibility, detailed descriptions are particularly important, but study descriptions were often inadequate to fully characterize the intervention, much less permit replication. Complex interventions like PCMH will likely require separate publications to fully describe the intervention. We encourage editors to support this practice and authors to consider recommendations for intervention reporting such as described by Glasziou et al.161

Relatively few studies reported outcomes for any of the five outcome domains used in this report. More than one-third of studies reported outcomes for one domain, only two reported outcomes across four domains, and no study reported results in all five domains. We did not expect that individual studies would report the entire range of outcomes; such studies would likely require a prohibitive level of resources. However, the lack of more comprehensive outcomes, combined with the wide variability in outcome measures, limited our ability to draw strong conclusions about the effectiveness of PCMH. Most of the 31 ongoing studies identified through the horizon scan intend to collect outcomes pertaining to patient or staff experiences, processes of care, and economic outcomes. However, only one-third of these studies reported an intention to report clinical outcomes. To the degree that effects on clinical outcomes are needed for policymaking, the ongoing research may not adequately address this specific gap in evidence.

The process used to implement PCMH was often not described or was described at only a superficial level. As a result, there is limited guidance on the best way for organizations to go about putting PCMH into place. Other studies have shown that complex organizational change is difficult to implement. More complete descriptions of the methods used to implement change and planned analyses to evaluate the most effective strategies are needed.

## Research Gaps

The horizon scan conducted for this review identified 31 ongoing PCMH studies that are broadly representative of the U.S. health care system, both in geography and in the complexity of private and public health care payers and delivery networks. Many of these studies are being done in cooperation with payer organizations, and most are expected to be completed in the next 2 years. As a result, the evidence base related to PCMH will soon be greatly expanded. We encourage investigators to report the interventions in detail, adjust for clustering when appropriate, report meaningful quality indicators for chronic illness (both processes and clinical outcomes), and provide data related to the impact of PCMH on staff. If researchers clearly link intervention components to the core components of PCMH, this could greatly improve our understanding of the conceptual basis for interventions tested and ultimately the key features of successful models. Finally, we encourage long-term followup of results. Outcomes examined in this report rarely had followup periods longer than 2 years.

In addition to a lack of data on key outcomes addressed in KQ 1, there is an important lack of evidence concerning how programs need to be implemented if there is to be a genuine opportunity to affect outcomes. Broad changes in organizations likely require a combination of factors, such as practice guidelines to indicate aspects of high-quality care, system changes such as the PCMH to provide a roadmap for how to organize care, organizational learning strategies (e.g., learning collaboratives), and change models (e.g., Plan-Do-Study-Act cycles) to put changes into place.144,162 As described in the analysis of KQ 3, even basic descriptions of these aspects of interventions are often not provided in the published literature. While the AAFP NDP study, which specifically compared implementation strategies, used a variety of quantitative and qualitative methods to examine these issues,60,145,163 other studies generally have not done so. We encourage the explicit use of techniques of implementation research to examine the process of putting PCMH into place, aspects of the interventions that may affect effectiveness, and micro- and macro-level organizational and policy factors (e.g., readiness to implement PCMH, organizational structure, governance, organizational culture, and healthcare market environment) that influence both implementation and effectiveness of PCMH and its components.164-167

Although ongoing studies have the potential to fill important gaps, the lack of detail contained in published research plans generates uncertainty about how well these studies will address these gaps. We therefore describe a series of research priorities in what follows.

### Missing Outcomes

The strength of evidence was judged to be low or insufficient for most outcomes. Studies that address quality indicators for chronic illness care and clinical outcomes (e.g., symptom status or functional status) are urgently needed. Because PCMH is oriented towards broad populations of patients and not focused on specific illnesses, the impact on chronic illness could be attenuated. Cluster randomized controlled trials would provide the strongest evidence for effects on these outcomes, but given their high costs, quasiexperimental designs may be more feasible and could yield valuable data. Within the context of a trial, assessing unintended consequences or other potential harms would provide important new information. Unintended consequences have been observed with other quality improvement innovations,168,169 and considering the significant time demands required to provide guideline-concordant care,170 it is possible that unintended consequences of PCMH may emerge. Evaluators should also carefully consider the outcomes most relevant to the population studied, particularly considering differences in the emphasis of the medical home and relevant outcomes for pediatric versus adult populations.171 For example, developmental outcomes, effects on family, school performance and school absences may be particularly important in pediatric studies.

Observational and mixed-methods designs can also provide valuable evidence, particularly with regards to real-world effects of PCMH. These designs might be particularly valuable for assessing effects on staff retention and economic outcomes. Economic outcomes reported to date focus on per-patient utilization and/or costs. This is a viewpoint that may be most helpful to payer organizations. Information on the impact of PCMH on practice costs and patient out-of-pocket costs would provide an additional important perspective on economic outcomes.

### Most Important PCMH Components

We were unable to determine the PCMH components most associated with benefit. Understanding the “active ingredients” of PCMH is important to help practices with limited resources realize the greatest return on investment and to assist organizations developing certifying standards for medical home practices. Observational studies from natural experiments, comparing differing levels and different approaches to PCMH, could address this gap. In addition, as the evidence base grows, an updated systematic review could be valuable. For this latter approach to succeed, studies will need to report the details of the PCMH intervention and ideally use a more consistent set of outcome measures and nomenclature for PCMH components and measures of PCMH components. These common measures and definitions will further allow for estimates of the “dose” of the PCMH intervention (i.e., degree to which PCMH concepts are implemented).

### Most Effective Implementation Approaches

PCMH is a complex intervention that will require substantial changes to most practices. Understanding the level of support needed to implement and sustain the model, including the necessary financial context, is critical to any long-term success. Our horizon scan identified a number of studies that planned formative evaluations to identify factors associated with successful implementation. Additional studies that examine long-term sustainability are needed.

### Effects of PCMH in More Representative Populations

Most PCMH studies were conducted in older adults with multiple chronic health conditions or in children with special health care needs. Studies that examine the effects in more broadly representative primary care samples are needed to fully understand the impact of this care model. Because PCMH has the potential to reduce heath disparities, evaluating effects in important subgroups (e.g., socioeconomically disadvantaged) will be important.

## Conclusions

Published studies of PCMH often have similar broad interventions; however, precise components of care vary widely. The interventions tested—both PCMH and functional PCMH interventions—appear to be associated with improvements in both patient and staff experiences and potentially care processes. However, there is insufficient evidence to determine the effects on clinical or most economic outcomes. Current ongoing studies identified through the horizon scan have potential to greatly expand the evidence base relating to PCMH.

In conclusion, the PCMH model is a conceptually sound approach to organizing patient care and appears to hold promise, especially for improving the experiences of patients and staff involved in the health care system. Evidence points to the possibility of improved care processes. If ongoing and future studies indicate that these improvements translate into improved clinical outcomes or economic benefit, the health care value would be increased.