# Characteristics of Included Studies (KQ 4)

Table J1 Characteristics of ongoing or planned studies evaluating PCMH

Study Title | Projected End Date | Funding Source | Health Care Delivery Organization | Location | Number of Patients^a^ | Number of Clinics | Number of Providers
WellStar Health System/Humana Patient-Centered Medical Home1 | NR | NR | Insurance organization: Humana | Georgia | 720 | 2 | 12
Metcare of Florida/Humana Patient-Centered Medical Home2 | 11/2010 | NR | Insurance organization: Humana | Florida | NR | 9 | 17
Queen City Physicians/Humana Patient-Centered Medical Home3 | 12/2010 | NR | Insurance organization: Humana | Ohio | 5200 | 4 | 18
TriHealth Physician Practices/Humana Patient-Centered Medical Home4 | 5/2011 | NR | Insurance organization: Humana | Ohio | 1100 | 1 | 8
Using Multi–Payer Payment Reform to Integrate Medical Home Concepts into Primary Care Practice in Washington State5 | 1/2012 | RWJ | NR | Washington | NR | NR | NR
Transforming Primary Care Practice in North Carolina6 | 7/2012 | AHRQ | NR | North Carolina | NR | 12 | NR
National Naval Medical Center Medical Home Program7 | NR | NR | Federal (U.S.): Department of Defense | Maryland | 22,500 | 1 | 25
EmblemHealth Medical Home High Value Network Project8 (planned as an RCT) | 1/2010 | NR | Insurance organization: EmblemHealth | New York | 12,000 | 33 | 159
Alabama Health Improvement Initiative—Medical Home Pilot9 | 9/2012 | NR | Insurance organization: Blue Cross Blue Shield of Alabama | Alabama | NR | 14 | 70
Maine Patient-Centered Medical Home Pilot10 | 11/2012 | NR | MaineCare(Medicaid); Maine Health Management Coalition Maine Quality Forum | Maine | 30,000 to 50,000 | 26 | 221
Transformed Primary Care—Care By Design11 | 6/2012 | AHRQ | Multidisciplinary, University–owned primary care practices | Utah | NR | 10 | NR
Using Health Information Technology and Health Information Exchange to Help Physician Practices Improve Patient Care in Cincinnati12 | 1/2012 | RWJ | Multipayer | Ohio | 30,000 | 11 | 40
Evaluating the Effects of EHRs, P4P and Medical Home Redesign in the Hudson Valley13 | 12/2011 | Weill Medical College; NY State Dept of Health; The Commonwealth Fund | Taconic Independent Practice Association | New York (Hudson Valley) | 250,000 | 13 | 210
The Medical HOME Study14 (planned as an RCT) | 1/2015 | NIMH | Community Mental Health Centers | Georgia | 300 | NR | NR
Transforming Primary Care: Evaluating the Spread of Group Health's Medical Home15 | 6/2012 | AHRQ | Group model health maintenance organization (HMO): Group Health | Washington | NR | 9 for qualitative outcomes; NR for other outcomes | NR
Understanding the Transformation Experiences of Small Practices with NCQA's Medical Home16 | 7/2012 | AHRQ | Multiple primary care clinics across the country | Multistate | NR | 300 | NR
Evaluating Statewide Transformation of Primary Care to Medical Homes17 | 8/2012 | AHRQ | All primary care in the state of Minnesota | Minnesota | 2,000,000 | 180 | 1500
Evaluating the Role of the Medical Home Model in the Successful Management of Diabetes18 | 1/2012 | NIH (NIDDK) | NR | California | NR | NR | NR
UnitedHealth Group PCMH Demonstration Program (Arizona)19 | 4/2012 | United Health Insurance | Insurance organization: United Health | Arizona | 14,000 | 7 | 25
Informing Sound Policy: Linking Medical Home Measures and Child Health Outcomes20 | 9/2013 | AHRQ | Indiana patient care network of pediatric practices | Indiana | NR | NR | NR
Primary Care Transformation in a NCQA Certified Patient-Centered Medical Home21 | 7/2011 | AHRQ | Palo Alto Medical Foundation | California | NR | NR | NR
Multi-Method Evaluation of Physician Group Incentive Programs for PCMH Transformation22 | 12/2011 | AHRQ | Insurance organization: BCBS of Michigan's | Michigan | 1,700,000 | NR | 7618
Implementation and Impact of VA Patient-Centered Medical Home 23 | 9/2012 | VA HSRD | Federal (U.S.): Department of Veterans Affairs | Multistate | NR | > 200 | NR
What Makes Medical Homes Work: Lessons for Implementation and Spread24 | 4/2012 | The Commonwealth Fund | Group model health maintenance organization (HMO): Geisinger | Pennsylvania | 50,000 | 26 | 110
Evaluation of The Commonwealth Fund's Safety-Net Medical Home Initiative, Phase 2^25^ | 10/2013 | The Commonwealth Fund | Network of safety–net clinics | Multistate | NR | 68 | NR
Evaluating a Medical Home Demonstration in Colorado and Ohio26 | 6/2011 | The Commonwealth Fund | Collaborative of five of the nation's leading insurers (unnamed) | Multistate | NR | NR | NR
Evaluating Models of Medical Home Payment Within the Pennsylvania Chronic Care Initiative27 | 6/2013 | The Commonwealth Fund | Partnership of multiple health insurers | Pennsylvania | 1093246 | 170 | 780
Rhode Island Chronic Care Sustainability Initiative28 | 10/2011 | NR | Unnamed commercial insurers and stand–alone primary care provider | Rhode Island | 46,000 | 13 | 66
Blue Cross Blue Shield Patient-Centered Medical Home Initiative (Tennessee)29 | NR | NR | Insurance organization: Blue Cross Blue Shield | Tennessee | 25,000 | 31 | NR
VA PACT Demonstration Lab Initiative30 | NR | VA HSR&D | Federal (U.S.): Department of Veterans Affairs | Multistate | NR | NR | NR
Multi-Payer Advanced Primary Care Practice (MAPCP) Demonstration31 | 2014 | CMS | Multiple participating practices across 8 states | Multistate | 150,000 | 1200 | NR

a The number of patients may mean the number of covered lives potentially eligible, or the number of patients specifically participating in the project.

Abbreviations: AHRQ = Agency for Healthcare Research and Quality; CMS = Centers for Medicare & Medicaid Services; EHR = electronic health record; HMO = health maintenance organization; HSR&D = Health Services Research & Development Service; NCQA = National Committee for Quality Assurance; NIDDK = National Institute of Diabetes and Digestive and Kidney Diseases; NIH = National Institutes of Health; NIMH = National Institute of Mental Health; NR = not reported; P4P = pay for performance; PACT = Patient Aligned Care Team; PCMH = patient-centered medical home; RCT = randomized controlled trial; RWJ = Robert Wood Johnson Foundation; VA = United States Department of Veterans Affairs

## References

1 WellStar Health System/Humana Patient-Centered Medical Home (Georgia). Chris Corbin (Primary Contact). Humana (Convening Org). Projected end date: NR. Search source: PCPCCNET.
2 Metcare of Florida/Humana Patient-Centered Medical Home. Chris Corbin (Primary Contact). Humana (Convening Org). Projected end date: 11/2010. Search source: PCPCCNET.
3 Queen City Physicians/Humana Patient-Centered Medical Home (Ohio). Chris Corbin (Primary Contact). Humana (Convening Org). Projected end date: 12/2010. Search source: PCPCCNET.
4 TriHealth Physician Practices/Humana Patient-Centered Medical Home (Ohio). Chris Corbin (Primary Contact). Humana (Convening Org). Projected end date: 5/2011. Search source: PCPCCNET.
5 Using Multi-Payer Payment Reform to Integrate Medical Home Concepts into Primary Care Practice in Washington State. Susanne Dade (Contact Person). Robert Wood Johnson Foundation Development Fund (Funding Source). Projected end date: 1/2012. Search source: Robert Wood Johnson Foundation.
6 Transforming Primary Care Practice in North Carolina. Donahue, Katrina (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 7/2012. Search source: enGrant Scientific.
7 National Naval Medical Center Medical Home Program (Maryland). Kevin Dorrance (Primary Contact). National Naval Medical Center, Internal Medicine (Convening Org). Projected end date: NR. Search source: PCPCCNET.
8 EmblemHealth Medical Home High Value Network Project (New York). William Gillespie (Primary Contact). EmblemHealth (Convening Org). Projected end date: 1/2010. Search source: PCPCCNET.
9 Alabama Health Improvement Initiative—Medical Home Pilot. Daniel Jackson (Primary Contact). Blue Cross Blue Shield of Alabama (Convening Org). Projected end date: 9/2012. Search source: PCPCCNET.
10 Maine Patient-Centered Medical Home Pilot. Lisa Letourneau (Primary Contact). Maine Quality Forum, Quality Counts, and Maine Health Management Coalition (Convening Org). Projected end date: 11/2012. Search source: PCPCCNET.
11 Transformed Primary Care—Care By Design. Michael Magill (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 6/2012. Search source: enGrant Scientific.
12 Using Health Information Technology and Health Information Exchange to Help Physician Practices Improve Patient Care in Cincinnati. Trudi Matthews (Contact Person). Robert Wood Johnson Foundation Development Fund (Funding Org). Projected end date: 1/2012. Search source: Robert Wood Johnson Foundation.
13 Evaluating the Effects of EHRs, P4P and Medical Home Redesign in the Hudson Valley. ClinicalTrials.gov ID: NCT00793065. Lisa Kern and Rainu Kaushal (Prinicipal Investigators). Weill Medical College, NY State Department of Health, and The Commonwealth Fund (Funding Orgs). Projected end date: 12/2011. Search source: ClinicalTrials.gov.
14 The Medical HOME Study. ClinicalTrials.gov ID: NCT01228032. Robin Hill and Silke von Esenwein (Contact Persons). National Institute of Mental Health (Funding Org). Projected end date: 1/2015. Search source: ClinicalTrials.gov.
15 Transforming Primary Care: Evaluating the Spread of Group Health's Medical Home. Robert Reid (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 6/2012. Search source: enGrant Scientific.
16 Understanding the Transformation Experiences of Small Practices with NCQA's Medical Home. Sarah Scholle (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 7/2012. Search source: enGrant Scientific.
17 Evaluating Statewide Transformation of Primary Care to Medical Homes. Leif Solberg (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 8/2012. Search source: enGrant Scientific.
18 Evaluating the Role of the Medical Home Model in the Successful Management of Diabetes. Gregory David Stevens (Principal Investigator). National Institute of Diabetes and Digestive and Kidney Diseases (Funding Institution). Projected end date: 1/2012. Search source: enGrant Scientific.
19 UnitedHealth Group PCMH Demonstration Program (Arizona). Eric Sullivan (Primary Contact). United Healthcare (Convening Org). Projected end date: 4/2012. Search source: PCPCCNET
20 Informing Sound Policy: Linking Medical Home Measures and Child Health Outcomes. Nancy Swigonski (Primary Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 9/2013. Search source: enGrant Scientific.
21 Primary Care Transformation in a NCQA Certified Patient–Centered Medical Home. Ming Tai-Seale (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 7/2011. Search source: enGrant Scientific.
22 Multi-Method Evaluation of Physician Group Incentive Programs for PCMH Transition. Christopher Griffiths Wise (Principal Investigator). Agency for Health Care Research and Quality (Funding Institution). Projected end date: 12/2011. Search source: enGrant Scientific.
23 Implementation and Impact of VA Patient-Centered Medical Home. Elizabeth Yano (Principal Investigator). U.S. Department of Veterans Affairs (Funding Institution). Projected end date: 9/2012. Search source: enGrant Scientific.
24 What Makes Medical Homes Work: Lessons for Implementation and Spread. WF Stewart (Principal Investigator). The Commonwealth Fund (Funding Institution). Projected end date: 4/2012. Search source: The Commonwealth Fund.
25 Evaluation of The Commonwealth Fund's Safety-Net Medical Home Initiative, Phase 2. MH Chin (Principal Investigator). The Commonwealth Fund (Funding Institution). Projected end date: 10/2013. Search source: The Commonwealth Fund.
26 Evaluating a Medical Home Demonstration in Colorado and Ohio. M Rosenthal (Principal Investigator). The Commonwealth Fund (Funding Institution). Projected end date: 6/2011. Search source: The Commonwealth Fund.
27 Evaluating Models of Medical Home Payment Within the Pennsylvania Chronic Care Initiative. MW Friedberg (Principal Investigator). The Commonwealth Fund (Funding Institution). Projected end date: 6/2013. Search source: The Commonwealth Fund
28 Rhode Island Chronic Care Sustainability Initiative. DS Gifford (Primary Contact). Funding and/or Convening Orgs NR. Projected end date: 10/2011. Search source: PCPCCNET.
29 Blue Cross Patient-Centered Medical Home Initiative Grows to Largest in Tennessee with 31 Sites. M Thompson-Danielson (Primary Contact). Blue Cross Blue Shield of Tennessee (Convening Org). Projected end date: NR. Search source: Blue Cross Blue Shield Association.
30 Patient Aligned Care Team (PACT) Demonstration Lab Initiative. Stephan Fihn (Primary Contact). U.S. Department of Veterans Affairs Health Services Research & Development (Funding Institution). Projected end date: NR. Search source: Personal contact.
31 Multi-Payer Advanced Primary Care Practice (MAPCP) Demonstration. Alexander Dragatsi, Carol Callaghan, Ross Owen, Foster Gesten, Chris Collins, Ann Torregrossa, Tricia Leddy, and Craig Jones (Contact Persons). Centers for Medicaire & Medicaid Services (CMS; Funding Institution). Projected end date: 2014. Search source: CMS.