# Characteristics of Included Studies (KQs 2–3 Only)

Table I1 Characteristics of included studies (KQs 2–3 only)

Study | Country; Organization | Explicitly PCMH?; Intervention Components | Practices (n) | Subjects
Farmer, 2005^1^ | U.S.A. Other: University-affiliated PC clinics | Yes; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (3) Usual care (n/a) | CSHCN – 51 Practice staff – NR
Palfrey, 2004^2,3^ | U.S.A. Other: Pediatric Alliance for Coordinated Care | Yes; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (6) Usual care (n/a) | CSHCN – 150 Practice staff – NR
Rankin, 2009^4^ | U.S.A. Stand-alone PC provider | Yes; 1. Quality included; 2. Coordinated care; 3. Sustained partnership; 4. Comprehensive; 5. Enhanced access | Intervention (6) Usual care (n/a) | CSHCN – 47 Practice staff – NR
Treadwell, 2009^5^ | U.S.A. Stand-alone PC provider: 47 PC practices | Yes; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (47) Usual care (NR) | Children with asthma, DM, or ADHD – Practice Staff - NR
Chandler, 1997^6^ | U.S.A. Federal (U.S.) – Department of Veterans Affairs; Other: Northwestern Memorial Hospital | No; 1. Coordinated care; 2. Team; 3. Sustained partnership; 4. Comprehensive; 5. Enhanced access; 6. Structural changes | Intervention (2) Usual care (n/a) | Adults – 16,000 Practice staff – 3
Farris, 2004^7^ | Canada Government-operated Health System outside U.S.; Private delivery, but government funded health care system | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (6) Usual care (n/a) | Adults with chronic illness – 199 Practice staff – NR
Peleg, 2008^8^ | Israel Non U.S. Government: Israel – PC clinic | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (1) Usual care (n/a) | Older adults – 4620 Practice staff – NR
Schifalacqua, 2000^9^ | U.S.A. Integrated delivery system: Aurora Health Care of WI | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (NR) Usual care (n/a) | Older adults at medium to high health risk – NR Practice staff – NR
Vedel, 2009^10^ | Paris, France Non U.S. Government: French Health Care System | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (NR) Usual care (2) | Older adults with chronic illness – 100 Practice staff – NR
Waxmonsky, 2011^11^ | U.S.A. Colorado Access | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (NR) Usual care (n/a) | Adults – 3314 Practice staff - 14

Abbreviations: ADHD = attention deficit hyperactivity disorder; CSHCN = children with special health care needs; DM = diabetes mellitus; KQ = key question; n/a = not applicable; NR = not reported; PC = primary care; PCMH = patient-centered medical home; RCT = randomized controlled trial

## References

1 Farmer JE, Clark MJ, Sherman A, et al. Comprehensive primary care for children with special health care needs in rural areas. Pediatrics. 2005;116(3):649-56. [pmid: 16140704].
2 Palfrey JS, Sofis LA, Davidson EJ, et al. The Pediatric Alliance for Coordinated Care: evaluation of a medical home model. Pediatrics. 2004;113(5 Suppl):1507-16. [pmid: 15121919].
3 Samuels RC, Liu J, Sofis LA, et al. Immunizations in children with special health care needs in a medical home model of care. Matern Child Health J. 2008;12(3):357-62. [pmid: 17578657].
4 Rankin KM, Cooper A, Sanabria K, et al. Illinois medical home project: pilot intervention and evaluation. Am J Med Qual. 2009;24(4):302-9. [pmid: 19515943].
5 Treadwell J, Bean G, Warner W. Supporting disease management through intervention in the medical home. Prof Case Manag. 2009;14(4):192-7. [pmid: 19625938].
6 Chandler C, Barriuso P, Rozenberg-Ben-Dror K, et al. Pharmacists on a primary care team at a Veterans Affairs medical center. Am J Health Syst Pharm. 1997;54(11):1280-7. [pmid: 9179348].
7 Farris KB, Cote I, Feeny D, et al. Enhancing primary care for complex patients. Demonstration project using multidisciplinary teams. Can Fam Physician. 2004;50:998-1003. [pmid: 15317232].
8 Peleg R, Press Y, Asher M, et al. An intervention program to reduce the number of hospitalizations of elderly patients in a primary care clinic. BMC Health Serv Res. 2008;8:36. [pmid: 18254972].
9 Schifalacqua M, Hook M, O'Hearn P, et al. Coordinating the care of the chronically ill in a world of managed care. Nurs Adm Q. 2000;24(3):12-20. [pmid: 10986928].
10 Vedel I, De Stampa M, Bergman H, et al. A novel model of integrated care for the elderly: COPA, Coordination of Professional Care for the Elderly. Aging Clin Exp Res. 2009;21(6):414-23. [pmid: 20154510].
11 Waxmonsky JA, Giese AA, McGinnis GF, et al. Colorado access' enhanced care management for high-cost, high-need Medicaid members: preliminary outcomes and lessons learned. J Ambul Care Manage. 2011;34(2):183-91. [pmid: 21415616].