# Characteristics of Included Studies (KQs 1–3, Observational Studies)

Table H1 Characteristics of included studies (KQ1, observational studies)

Study | Country; Organization | Explicitly PCMH?; Intervention Components | Practices (n) | Subjects | Outcomes Reported; Followup Period^a^ | Study Quality
Domino, 2009^1^ | U.S.A. Other: State-wide medical home network | Yes; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (NR) Usual care (NR) | Children with asthma – 207,439 Practice staff – NR | Process of care Economic Monthly estimates based on 4 years of data | Good
Martin, 2007^2^ | U.S.A. Stand-alone primary care provider: Family practice | Yes; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (1) Usual care (NR) | CSHCN – 199 Practice staff - NR | Economic 2 years | Fair; – Possible selection bias; – Possible detection bias
Reid, 2009^3-5^ | U.S.A. HMO: Group Health Cooperative of Puget Sound | Yes; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (1) Usual care (19) | Adults – 3353 Practice staff – 82 | Patient experiences Staff experiences Process of care Economic 2 years | Fair; – Possible selection bias; – Possible detection bias
Steele, 2010^6,7^ | U.S.A. HMO: Geisinger | Yes; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (11) Usual care (75) | Older adults with chronic illness – 15,310 Practice staff – NR | Economic 1 year | Moderate risk of bias; – Possible detection bias
Boyd, 2007^8-10^ | U.S.A. Integrated delivery system Health plan for military retirees; Other: University affiliated community PC practices | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (1) Usual care (1) | Older adults with chronic illness – 150 Practice staff – 2 | Patient experiences Economic 6 months | Fair; – Possible selection bias; – Possible attrition bias; – Analysis not adjusted for clustering
Dorr, 2008^11,12^ | U.S.A. Integrated delivery system: Intermountain Group Health | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (7) Usual care (6) | Older adults with chronic illness – 3432 Practice staff – NR | Clinical Economic 2 years | Good
Hebert, 2003^13^ | Canada (Quebec) Non U.S. government: Canadian Healthcare System | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (1 region; # of clinics NR) Usual care (1 region; # of clinics NR) | Older adults with chronic illness – 482 Practice staff - NR | Clinical 2 years | Poor; – Possible selection bias; – Possible performance bias; – Possible detection bias
Taplin, 1998^14^ | U.S.A. HMO: Group Health Cooperative of Puget Sound | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Structural changes | Intervention (1) Usual care (27) | Adults – 398,000 Practice staff - NR | Process of care 2 years | Fair; – Possible selection bias; – Possible performance bias
Wise, 2006^15^ | U.S.A. Other insurance organization: Partnership Health in partnership with University of Michigan's Medical Management Center | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive | Intervention (NR) Usual care (NR) | All ages; high utilizers – 54,479 Practice staff - NR | Process of care Clinical Economic 1 year | Fair; – Possible performance bias

a Based on longest followup period among abstracted outcomes.

b The most significant quality limitations are listed for all “Fair” and “Poor” studies.

Abbreviations: CSHCN = children with special health care needs; HMO = health maintenance organization; KQ = key question; NR = not reported; PC = primary care; PCMH = patient-centered medical home

## References

1 Domino ME, Humble C, Lawrence WW Jr., et al. Enhancing the medical homes model for children with asthma. Med Care. 2009;47(11):1113-20. [pmid: 19786921].
2 Martin AB, Crawford S, Probst JC, et al. Medical homes for children with special health care needs: a program evaluation. J Health Care Poor Underserved. 2007;18(4):916-30. [pmid: 17982215].
3 Reid RJ, Fishman PA, Yu O, et al. Patient-centered medical home demonstration: a prospective, quasi-experimental, before and after evaluation. Am J Manag Care. 2009;15(9):e71-87. [pmid: 19728768].
4 Reid RJ, Coleman K, Johnson EA, et al. The group health medical home at year two: cost savings, higher patient satisfaction, and less burnout for providers. Health Aff (Millwood). 2010;29(5):835-43. [pmid: 20439869].
5 Coleman K, Reid RJ, Johnson E, et al. Implications of reassigning patients for the medical home: a case study. Ann Fam Med. 2010;8(6):493-8. [pmid: 21060118].
6 Steele GD, Haynes JA, Davis DE, et al. How Geisinger's advanced medical home model argues the case for rapid-cycle innovation. Health Aff (Millwood). 2010;29(11):2047-53. [pmid: 21041747].
7 Gilfillan RJ, Tomcavage J, Rosenthal MB, et al. Value and the medical home: effects of transformed primary care. Am J Manag Care. 2010;16(8):607-14. [pmid: 20712394].
8 Boyd CM, Boult C, Shadmi E, et al. Guided care for multimorbid older adults. Gerontologist. 2007;47(5):697-704. [pmid: 17989412].
9 Sylvia ML, Griswold M, Dunbar L, et al. Guided care: cost and utilization outcomes in a pilot study. Dis Manag. 2008;11(1):29-36. [pmid: 18279112].
10 Boyd CM, Shadmi E, Conwell LJ, et al. A pilot test of the effect of guided care on the quality of primary care experiences for multimorbid older adults. J Gen Intern Med. 2008;23(5):536-42. [pmid: 18266045].
11 Dorr DA, Wilcox AB, Brunker CP, et al. The effect of technology-supported, multidisease care management on the mortality and hospitalization of seniors. J Am Geriatr Soc. 2008;56(12):2195-202. [pmid: 19093919].
12 Dorr DA, Wilcox A, Burns L, et al. Implementing a multidisease chronic care model in primary care using people and technology. Dis Manag. 2006;9(1):1-15. [pmid: 16466338].
13 Hebert R, Durand PJ, Dubuc N, et al. Frail elderly patients. New model for integrated service delivery. Can Fam Physician. 2003;49:992-7. [pmid: 12943358].
14 Taplin S, Galvin MS, Payne T, et al. Putting population-based care into practice: real option or rhetoric?. J Am Board Fam Pract. 1998;11(2):116-26. [pmid: 9542703].
15 Wise CG, Bahl V, Mitchell R, et al. Population-based medical and disease management: an evaluation of cost and quality. Dis Manag. 2006;9(1):45-55. [pmid: 16466341].