# Characteristics of Included Studies (KQs 1–3, RCTs)

Table G1 Characteristics of included studies (KQ1, RCTs)

Study | Country; Organization | Explicitly PCMH?; Intervention Components | Practices (n) | Subjects | Outcomes Reported; Followup Period^a^ | Study Quality^b^
Farmer, 2011^1^ | U.S.A. Other insurance: Medicaid managed care plan | Yes; 1. Coordinated care; 2. Team; 3. Sustained partnership; 4. Comprehensive; 5. Enhanced access; 6. Structural changes | Intervention (32) Usual care (0) – crossover design | CSHCN – 100 Practice staff - NR | Patient experiences 6 months | Fair; – Randomization process not described; – Blinding of outcomes assessment unclear
Jaen, 2010^2-9^ | U.S.A. Stand-alone primary care provider: Physician and hospital/health system owned | Yes; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (18) Usual care (17) | Adults – 1983 Practice staff – NR | Patient experiences Staff experiences Process of care Clinical 26 months | Fair; – Outcomes assessment not blinded; – Incomplete data not adequately addressed; – Potentially significant conflict of interest
Boult, 2008^10-16^ | U.S.A. HMO: Kaiser-Permanente Mid-Atlantic States; Integrated delivery system: Johns Hopkins Community Physicians; Stand-alone primary care provider: MedStar Physician Partners (multisite group practice) | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (7 PC care teams; 8 practices) Usual care (7 PC care teams; 8 practices) | Older adults with chronic illness – 904 Practice staff - 49 | Patient experiences Staff experiences Economic 26 months | Good
Rubin, 1992^17^ | U.S.A. Other: Parkland Memorial Hospital | No; 1. Coordinated care; 2. Team; 3. Sustained partnership; 4. Comprehensive; 5. Structural changes | Intervention (1) Usual care (NR) | Older adults at high risk for rehospitalization – 200 Practice staff - NR | Economic 26 months | Fair; – Outcomes not assessed using validated procedures/instruments; – Significant differences in baseline characteristics across groups
Schraeder, 2005^18,19^ | U.S.A. Integrated delivery system: Carle Health System in Urbana, IL | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (12) Usual care (0) | Older adults with COPD, CAD, DM, CHF, or Afib – 2657 Practice staff – NR | Process of care Economic 2 years | Fair; – Outcomes assessment not blinded
Sommers, 2000^20^ | U.S.A. Stand-alone primary care provider | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (9) Usual care (9) | Older adults with chronic illness – 543 Practice staff – NR | Clinical Economic 2 years | Good
Toseland, 1997^21,22^ | U.S.A. Federal (U.S.) – Department of Veterans Affairs | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (1) Usual care (1) | Older adults with chronic illness – 160 Practice staff - NR | Patient experiences Process of care Clinical Economic 2 years | Good
Zuckerman, 2004^23-25^ | U.S.A. Other: multiple separate primary care practices across 14 states | No; 1. Quality included; 2. Coordinated care; 3. Team; 4. Sustained partnership; 5. Comprehensive; 6. Enhanced access; 7. Structural changes | Intervention (15) Usual care (15) | Young children – 3737 Practice staff - NR | Patient experiences Process of care 5.5 years | Fair; – Blinding of outcomes assessment unclear; – Unclear whether Incomplete data adequately addressed; – Significant differences in baseline characteristics across groups

a Based on longest followup period among abstracted outcomes.

b The most significant quality limitations are listed for all “Fair” and “Poor” studies.

Abbreviations: Afib = atrial fibrillation; CAD = coronary artery disease; CHF = congestive heart failure; CSHCN = children with special health care needs; COPD = chronic obstructive pulmonary disease; DM = diabetes mellitus; HMO = health maintenance organization; KQ = key question; NR = not reported; PC = primary care; PCMH = patient-centered medical home; RCT = randomized controlled trial

## References

1 Farmer JE, Clark MJ, Drewel EH, et al. Consultative care coordination through the medical home for CSHCN: a randomized controlled trial. Matern Child Health J. Oct. 2011;15(7):1110-18. [pmid: 20721612].
2 Jaen CR, Crabtree BF, Palmer RF, et al. Methods for evaluating practice change toward a patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S9-20. S92. [pmid: 20530398].
3 Crabtree BF, Nutting PA, Miller WL, et al. Summary of the National Demonstration Project and recommendations for the patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S80-90. S92. [pmid: 20530397].
4 Miller WL, Crabtree BF, Nutting PA, et al. Primary care practice development: a relationship-centered approach. Ann Fam Med. Suppl 1. 2010;8:S68-79. S92. [pmid: 20530396].
5 Jaen CR, Ferrer RL, Miller WL, et al. Patient outcomes at 26 months in the patient-centered medical home National Demonstration Project. Ann Fam Med. Suppl 1. 2010;8:S57-67. S92. [pmid: 20530395].
6 Nutting PA, Crabtree BF, Miller WL, et al. Journey to the patient-centered medical home: a qualitative analysis of the experiences of practices in the National Demonstration Project. Ann Fam Med. Suppl 1. 2010;8:S45-56. S92. [pmid: 20530394].
7 Nutting PA, Crabtree BF, Stewart EE, et al. Effect of facilitation on practice outcomes in the National Demonstration Project model of the patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S33-44. S92. [pmid: 20530393].
8 Stewart EE, Nutting PA, Crabtree BF, et al. Implementing the patient-centered medical home: observation and description of the national demonstration project. Ann Fam Med. Suppl 1. 2010;8:S21-32. S92. [pmid: 20530392].
9 Nutting PA, Miller WL, Crabtree BF, et al. Initial lessons from the first national demonstration project on practice transformation to a patient-centered medical home. Ann Fam Med. 2009;7(3):254-60. [pmid: 19433844].
10 Boult C, Reider L, Frey K, et al. Early effects of “Guided Care” on the quality of health care for multimorbid older persons: a cluster-randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2008;63(3):321-7. [pmid: 18375882].
11 Leff B, Reider L, Frick KD, et al. Guided care and the cost of complex healthcare: a preliminary report. Am J Manag Care. 2009;15(8):555-9. [pmid: 19670959].
12 Marsteller JA, Hsu YJ, Reider L, et al. Physician satisfaction with chronic care processes: a cluster-randomized trial of guided care. Ann Fam Med. 2010;8(4):308-15. [pmid: 20644185].
13 Boyd CM, Reider L, Frey K, et al. The effects of guided care on the perceived quality of health care for multi-morbid older persons: 18-month outcomes from a cluster-randomized controlled trial. J Gen Intern Med. 2010;25(3):235-42. [pmid: 20033622].
14 Wolff JL, Giovannetti ER, Boyd CM, et al. Effects of guided care on family caregivers. Gerontologist. 2010;50(4):459-70. [pmid: 19710354].
15 Wolff JL, Rand-Giovannetti E, Palmer S, et al. Caregiving and chronic care: the guided care program for families and friends. J Gerontol A Biol Sci Med Sci. 2009;64(7):785-91. [pmid: 19349586].
16 Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. 2011;171(5):460-6. [pmid: 21403043].
17 Rubin CD, Sizemore MT, Loftis PA, et al. The effect of geriatric evaluation and management on Medicare reimbursement in a large public hospital: a randomized clinical trial. J Am Geriatr Soc. 1992;40(10):989-95. [pmid: 1401688].
18 Schraeder C, Dworak D, Stoll JF, et al. Managing elders with comorbidities. J Ambul Care Manage. 2005;28(3):201-9. [pmid: 15968212].
19 Peikes D, Chen A, Schore J, et al. Effects of care coordination on hospitalization, quality of care, and health care expenditures among Medicare beneficiaries: 15 randomized trials. JAMA. 2009;301(6):603-18. [pmid: 19211468].
20 Sommers LS, Marton KI, Barbaccia JC, et al. Physician, nurse, and social worker collaboration in primary care for chronically ill seniors. Arch Intern Med. 2000;160(12):1825-33. [pmid: 10871977].
21 Toseland RW, O'Donnell JC, Engelhardt JB, et al. Outpatient geriatric evaluation and management: is there an investment effect?. Gerontologist. 1997;37(3):324-32. [pmid: 9203756].
22 Toseland RW, O'Donnell JC, Engelhardt JB, et al. Outpatient geriatric evaluation and management. Results of a randomized trial. Med Care. 1996;34(6):624-40. [pmid: 8656727].
23 Zuckerman B, Parker S, Kaplan-Sanoff M, et al. Healthy Steps: a case study of innovation in pediatric practice. Pediatrics. 2004;114(3):820-6. [pmid: 15342859].
24 Minkovitz CS, Strobino D, Mistry KB, et al. Healthy Steps for Young Children: sustained results at 5.5 years. Pediatrics. 2007;120(3):e658-68. [pmid: 17766506].
25 Minkovitz CS, Hughart N, Strobino D, et al. A practice-based intervention to enhance quality of care in the first 3 years of life: the Healthy Steps for Young Children Program. JAMA. 2003;290(23):3081-91. [pmid: 14679271].