# List of Excluded Studies (KQs 1–3)

All studies listed below were reviewed in their full-text version for possible inclusion for KQs 1–3 and were excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this review and are not intended as criticisms of the articles.

Adam P, Brandenburg DL, Bremer KL, et al. Effects of team care of frequent attenders on patients and physicians. Fam Syst Health. 2010;28(3):247-57. Exclude—does not meet PCMH definition. [pmid: 20939629].
Adams EK, Bronstein JM, Florence CS. The impact of Medicaid primary care case management on office-based physician supply in Alabama and Georgia. Inquiry. 2003;40(3):269-82. Exclude—does not meet PCMH definition. [pmid: 14680259].
Afifi AA, Morisky DE, Kominski GF, et al. Impact of disease management on health care utilization: evidence from the “Florida: A Healthy State (FAHS)” Medicaid Program. Prev Med. 2007;44(6):547-53. Exclude—does not meet PCMH definition. [pmid: 17350086].
Ahmed S, Gogovor A, Kosseim M, et al. Advancing the chronic care road map: a contemporary overview. Healthc Q. 2010;13(3):72-9. Exclude—not original data. [pmid: 20523157].
Aita V, McIlvain H, Backer E, et al. Patient-centered care and communication in primary care practice: what is involved?. Patient Educ Couns. 2005;58(3):296-304. Exclude—does not meet PCMH definition. [pmid: 16122641].
Alkema GE, Shannon GR, Wilber KH. Using interagency collaboration to serve older adults with chronic care needs: the Care Advocate Program. Fam Community Health. 2003;26(3):221-9. Exclude—does not meet PCMH definition. [pmid: 12829944].
Al-Khaldi YM, Al-Sharif AI, Al-Jamal MN, et al. Difficulties faced when conducting primary health care programs in rural areas. Saudi Med J. 2002;23(4):384-7. Exclude—does not meet PCMH definition. [pmid: 11953760].
Allen JK, Scott LB. Alternative models in the delivery of primary and secondary prevention programs. J Cardiovasc Nurs. 2003;18(2):150-156. Exclude—does not meet PCMH definition. [pmid: 12680575].
Alvarado R, Zepeda A, Rivero S, et al. Integrated maternal and infant health care in the postpartum period in a poor neighborhood in Santiago, Chile. Stud Fam Plann. 1999;30(2):133-41. Exclude—does not meet PCMH definition. [pmid: 16617547].
Amorim DG, Adam T, Amaral JJ, et al. Integrated Management of Childhood Illness: efficiency of primary health in Northeast Brazil. Rev Saude Publica. 2008;42(2):183-90. Exclude—does not meet PCMH definition. [pmid: 18372970].
Andersen MD, Smereck GA, Hockman EM, et al. Nurses decrease barriers to health care by “hyperlinking” multiple-diagnosed women living with HIV/AIDS into care. J Assoc Nurses AIDS Care. 1999;10(2):55-65. Exclude—does not meet PCMH definition. [pmid: 10065410].
Anderson LA, Persky NW, Whall AL, et al. Interdisciplinary team training in geriatrics: reaching out to small and medium-size communities. Gerontologist. 1994;34(6):833-8. Exclude—does not meet PCMH definition. [pmid: 7843614].
Anderson RJ, Pickens S, Boumbulian PJ. Toward a new urban health model: moving beyond the safety net to save the safety net—resetting priorities for healthy communities. J Urban Health. 1998;75(2):367-78. Exclude—does not meet PCMH definition. [pmid: 9684248].
Anfinson TJ, Bona JR. A health services perspective on delivery of psychiatric services in primary care including internal medicine. Med Clin North Am. 2001;85(3):597-616. Exclude—does not meet PCMH definition. [pmid: 11349475].
Angstman KB, MacLaughlin KL, Rasmussen NH, et al. Age of depressed patient does not affect clinical outcome in collaborative care management. Postgrad Med. 2011;123(5):122-8. Exclude—does not meet PCMH definition. [pmid: 21904094].
Anker-Unnever L, Netting FE. Coordinated care partnership: case management with physician practices. J Case Manag. 1995;4(1):3-8. Exclude—does not meet PCMH definition. [pmid: 7795541].
Anonymous. Integrated management of the sick child. Bull World Health Organ. 1995;73(6):735-40. Exclude—does not meet PCMH definition. [pmid: 8907767].
Anonymous. Asthma DM effort slashes utilization, produces substantial ROI. Dis Manag Advis. 2001;7(10):145-9. Exclude—does not meet PCMH definition. [pmid: 11697023].
Anonymous. HCFA demo sites offer a smorgasbord of managed care innovation. Dis Manag Advis. 2001;7(4):52-7. 49. Exclude—not original data. [pmid: 11345904].
Anonymous. Role of the pediatrician in family-centered early intervention services. Pediatrics. 2001;107(5):1155-7. Exclude—not original data. [pmid: 11331701].
Anonymous. Medicare demonstration project creeping to the starting line. Capitation Manag Rep. 2004;11(10):109-11. Exclude—does not meet PCMH definition. [pmid: 15566118].
Anonymous. Blue Cross/Blue Shield promotes medical home demonstrations. Dis Manag Advis. suppl 1-4. 2008;14(1):1. Exclude—not original data. [pmid: 18290277].
Anonymous. Medical home payment structure offered. Report issued in preparation of CMS demonstration project. Dis Manag Advis. 2008;14(7):1-2. 6. Exclude—not original data. [pmid: 18683595].
Anonymous. Patient-Centered Medical Homes. Health Aff (Millwood). 2010. Exclude—background (other).
Anonymous. Peds program reduces ED visits by 55%. ED Manag. 2010;22(6):66-7. Exclude—not original data. [pmid: 20535895].
Ansari Z, Barbetti T, Carson NJ, et al. The Victorian ambulatory care sensitive conditions study: rural and urban perspectives. Soz Praventivmed. 2003;48(1):33-43. Exclude—does not meet PCMH definition. [pmid: 12756887].
Antonelli RC, Stille CJ, Antonelli DM. Care coordination for children and youth with special health care needs: a descriptive, multisite study of activities, personnel costs, and outcomes. Pediatrics. 2008;122(1):e209-16. Exclude—does not meet PCMH definition. [pmid: 18595966].
Anumanrajadhon T, Rajchagool S, Nitisiri P, et al. The community care model of the Intercountry Centre for Oral Health at Chiangmai, Thailand. Int Dent J. 1996;46(4):325-33. Exclude—does not meet PCMH definition. [pmid: 9147120].
Appleton PL, Boll V, Everett JM, et al. Beyond child development centres: care coordination for children with disabilities. Child Care Health Dev. 1997;23(1):29-40. Exclude—does not meet PCMH definition. [pmid: 9023029].
Art B, De Roo L, De Maeseneer J. Towards unity for health utilising community-oriented primary care in education and practice. Educ Health (Abingdon). 2007;20(2):74. Exclude—does not meet PCMH definition. [pmid: 18058692].
Artz N, Whelan C, Feehan S. Caring for the adult with sickle cell disease: results of a multidisciplinary pilot program. J Natl Med Assoc. 2010;102(11):1009-1016. Exclude—population and/or setting is not eligible. [pmid: 21141288].
Asch SM, Baker DW, Keesey JW, et al. Does the collaborative model improve care for chronic heart failure?. Med Care. 2005;43(7):667-675. Exclude—population and/or setting is not eligible. [pmid: 15970781].
Bachmann MO, Reading R, Husbands C, et al. What are children's trusts? Early findings from a national survey. Child Care Health Dev. 2006;32(2):137-46. Exclude—does not meet PCMH definition. [pmid: 16441848].
Badger LW, Ackerson B, Buttell F, et al. The case for integration of social work psychosocial services into rural primary care practice. Health Soc Work. 1997;22(1):20-9. Exclude—does not meet PCMH definition. [pmid: 9021415].
Bair-Merritt MH, Crowne SS, Burrell L, et al. Impact of intimate partner violence on children's well-child care and medical home. Pediatrics. 2008;121(3):e473-80. Exclude—does not meet PCMH definition. [pmid: 18310168].
Barnes-Boyd C, Fordham Norr K, Nacion KW. Promoting infant health through home visiting by a nurse-managed community worker team. Public Health Nurs. 2001;18(4):225-35. Exclude—does not meet PCMH definition. [pmid: 11468062].
Barnett S, Niebuhr V, Baldwin C. Principles for developing interdisciplinary school-based primary care centers. J Sch Health. 1998;68(3):99-105. Exclude—does not meet PCMH definition. [pmid: 9608450].
Bao Y, Casalino LP, Ettner SL, et al. Designing payment for Collaborative Care for Depression in primary care. Health Serv Res. 2011;46(5):1436-51. Exclude—does not meet PCMH definition. [pmid: 21609327].
Bartels SJ, Miles KM, Dums AR. Improving the quality of care for older adults with mental disorders: the outcomes-based treatment planning system of the NH-Dartmouth Psychiatric Research Center. Policy Brief (Cent Home Care Policy Res). 2002;(9):1-6. Exclude—does not meet PCMH definition. [pmid: 14997912].
Basilakis J, Lovell NH, Redmond SJ, et al. Design of a decision-support architecture for management of remotely monitored patients. IEEE Trans Inf Technol Biomed. 2010;14(5):1216-26. Exclude—does not meet PCMH definition. [pmid: 20615815].
Battersby M, Harvey P, Mills PD, et al. SA HealthPlus: a controlled trial of a statewide application of a generic model of chronic illness care. Milbank Q. 2007;85(1):37-67. Exclude—does not meet PCMH definition. [pmid: 17319806].
Battersby M, McDonald P, Pearce R, et al. The changing attitudes of health professionals and consumers towards a coordinated care trial—SA HealthPlus. Aust Health Rev. 2001;24(2):172-8. Exclude—does not meet PCMH definition. [pmid: 11496460].
Beland F, Bergman H, Lebel P, et al. Integrated services for frail elders (SIPA): a trial of a model for Canada. Can J Aging. 2006;25(1):5-42. Exclude—does not meet PCMH definition. [pmid: 16770746].
Benfari RC. The multiple risk factor intervention trial (MRFIT). III. The model for intervention. Prev Med. 1981;10(4):426-42. Exclude—does not meet PCMH definition. [pmid: 7027237].
Bennett P, Blackall M, Clapham M, et al. A multi-disciplinary approach to the prevention of coronary heart disease. Health Educ J. 1988;47(4):164-6. Exclude—does not meet PCMH definition. [pmid: 10293251].
Berman S, Armon C, Todd J. Impact of a decline in Colorado Medicaid managed care enrollment on access and quality of preventive primary care services. Pediatrics. 2005;116(6):1474-9. Exclude—does not meet PCMH definition. [pmid: 16322173].
Berman S, Miller AC, Rosen C, et al. Assessment training and team functioning for treating children with disabilities. Arch Phys Med Rehabil. 2000;81(5):628-33. Exclude—does not meet PCMH definition. [pmid: 10807104].
Bernabei R, Landi F, Gambassi G, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. BMJ. 1998;316(7141):1348-51. Exclude—does not meet PCMH definition. [pmid: 9563983].
Bichel A, Erfle S, Wiebe V, et al. Improving patient access to medical services: preventing the patient from being lost in translation. Healthc Q. Spec No. 2009;13:61-8. Exclude—does not meet PCMH definition. [pmid: 20057252].
Bird S, Noronha M, Sinnott H. An integrated care facilitation model improves quality of life and reduces use of hospital resources by patients with chronic obstructive pulmonary disease and chronic heart failure. Australian Journal of Primary Health. 2010;16(4):326-333. Exclude—does not meet PCMH definition. [pmid: 21138701].
Bird SR, Kurowski W, Dickman GK, et al. Integrated care facilitation for older patients with complex health care needs reduces hospital demand. Aust Health Rev. 2007;31(3):451-61. discussion 449-50. Exclude—does not meet PCMH definition. [pmid: 17669069].
Bithoney WG, McJunkin J, Michalek J, et al. The effect of a multidisciplinary team approach on weight gain in nonorganic failure-to-thrive children. J Dev Behav Pediatr. 1991;12(4):254-8. Exclude—does not meet PCMH definition. [pmid: 1939681].
Bitton A, Martin C, Landon BE. A nationwide survey of patient centered medical home demonstration projects. J Gen Intern Med. 2010;25(6):584-92. Exclude—background (other). [pmid: 20467907].
Blomquist KB. Health, education, work, and independence of young adults with disabilities. Orthop Nurs. 2006;25(3):168-187. Exclude—does not meet PCMH definition. [pmid: 16735848].
Bodenheimer T, Wang MC, Rundall TG, et al. What are the facilitators and barriers in physician organizations' use of care management processes?. Jt Comm J Qual Saf. 2004;30(9):505-14. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 15469128].
Bogner HR, de Vries HF. Integration of depression and hypertension treatment: a pilot, randomized controlled trial. Ann Fam Med. 2008;6(4):295-301. Exclude—does not meet PCMH definition. [pmid: 18626028].
Bonomi AE, Wagner EH, Glasgow RE, et al. Assessment of chronic illness care (ACIC): a practical tool to measure quality improvement. Health Serv Res. 2002;37(3):791-820. Exclude—does not meet PCMH definition. [pmid: 12132606].
Boorsma M, van Hout HP, Frijters DH, et al. The cost-effectiveness of a new disease management model for frail elderly living in homes for the elderly, design of a cluster randomized controlled clinical trial. BMC Health Serv Res. 2008;8:143. Exclude—does not meet PCMH definition. [pmid: 18606020].
Bosch M, Dijkstra R, Wensing M, et al. Organizational culture, team climate and diabetes care in small office-based practices. BMC Health Serv Res. 2008;8:180. Exclude—does not meet PCMH definition. [pmid: 18717999].
Boult C, Boult LB, Morishita L, et al. A randomized clinical trial of outpatient geriatric evaluation and management. J Am Geriatr Soc. 2001;49(4):351-9. Exclude—does not meet PCMH definition. [pmid: 11347776].
Boustani MA, Munger S, Gulati R, et al. Selecting a change and evaluating its impact on the performance of a complex adaptive health care delivery system. Clin Interv Aging. 2010;5:141-8. Exclude—not original data. [pmid: 20517483].
Boyer L, Francois P, Fourny M, et al. Managed care's clinical and economic impact on patients with type II diabetes in France: a controlled population-based study. Int J Health Care Qual Assur. 2008;21(3):297-307. Exclude—does not meet PCMH definition. [pmid: 18578214].
Bradley J, Igras S. Improving the quality of child health services: participatory action by providers. Int J Qual Health Care. 2005;17(5):391-9. Exclude—not high income country. [pmid: 15951311].
Branch LG, Coulam RF, Zimmerman YA. The PACE evaluation: initial findings. Gerontologist. 1995;35(3):349-59. Exclude—does not meet PCMH definition. [pmid: 7622088].
Brand CA, Jones CT, Lowe AJ, et al. A transitional care service for elderly chronic disease patients at risk of readmission. Aust Health Rev. 2004;28(3):275-84. Exclude—does not meet PCMH definition. [pmid: 15595909].
Branger PJ, van ‘t Hooft A, van der Wouden JC, et al. Shared care for diabetes: supporting communication between primary and secondary care. Stud Health Technol Inform. 1998;52(Pt 1):412-6. Exclude—does not meet PCMH definition. [pmid: 10384489].
Bray P, Cummings DM, Wolf M, et al. After the collaborative is over: what sustains quality improvement initiatives in primary care practices?. Jt Comm J Qual Patient Saf. 2009;35(10):502-8. Exclude—does not meet PCMH definition. [pmid: 19886089].
Breton M, Denis JL, Lamothe L. Incorporating public health more closely into local governance of health care delivery: lessons from the Quebec experience. Can J Public Health. 2010;101(4):314-7. Exclude—does not meet PCMH definition. [pmid: 21033545].
Briggs CJ, Garner P. Strategies for integrating primary health services in middle- and low-income countries at the point of delivery. Cochrane Database Syst Rev. 2006;(2):CD003318. Exclude—background (SR/MA). [pmid: 16625576].
Brousseau DC, Dansereau LM, Linakis JG, et al. Pediatric emergency department utilization within a statewide medicaid managed care system. Acad Emerg Med. 2002;9(4):296-9. Exclude—does not meet PCMH definition. [pmid: 11927453].
Brown JB, Lewis L, Ellis K, et al. Mechanisms for communicating within primary health care teams. Can Fam Physician. 2009;55(12):1216-22. Exclude—does not meet PCMH definition. [pmid: 20008604].
Bryan AA, Wirth DL. Birth to three early intervention: nursing's role on the interdisciplinary team. J Community Health Nurs. 1995;12(2):73-88. Exclude—does not meet PCMH definition. [pmid: 7602338].
Bryce J, Gouws E, Adam T, et al. Improving quality and efficiency of facility-based child health care through Integrated Management of Childhood Illness in Tanzania. Health Policy Plan. Suppl 1. 2005;20:i69-i76. Exclude—does not meet PCMH definition. [pmid: 16306072].
Bryce J, Victora CG. Ten methodological lessons from the multi-country evaluation of integrated Management of Childhood Illness. Health Policy Plan. Suppl 1. 2005;20:i94-i105. Exclude—does not meet PCMH definition. [pmid: 16306075].
Burke M, Carey P, Haines L, et al. Implementing the information prescription protocol in a family medicine practice: a case study. J Med Libr Assoc. 2010;98(3):228-34. Exclude—does not meet PCMH definition. [pmid: 20648257].
Burl JB, Bonner A, Rao M. Demonstration of the cost-effectiveness of a nurse practitioner/physician team in long-term care facilities. HMO Pract. 1994;8(4):157-61. Exclude—does not meet PCMH definition. [pmid: 10139218].
Burns R, Nichols LO, Martindale-Adams J, et al. Interdisciplinary geriatric primary care evaluation and management: two-year outcomes. J Am Geriatr Soc. 2000;48(1):8-13. Exclude—does not meet PCMH definition. [pmid: 10642014].
Byng R, Jones R. Mental Health Link: the development and formative evaluation of a complex intervention to improve shared care for patients with long-term mental illness. J Eval Clin Pract. 2004;10(1):27-36. Exclude—does not meet PCMH definition. [pmid: 14731149].
Byng R, Jones R, Leese M, et al. Exploratory cluster randomised controlled trial of shared care development for long-term mental illness. Br J Gen Pract. 2004;54(501):259-66. Exclude—does not meet PCMH definition. [pmid: 15113492].
Callahan CM, Boustani MA, Weiner M, et al. Implementing dementia care models in primary care settings: The Aging Brain Care Medical Home. Aging Ment Health. 2011;15(1):5-12. Exclude—does not meet PCMH definition. [pmid: 20945236].
Calman NSP. A Study Of The Patient-Centered Medical Home: Lessons From A New York State Commu. Agency for Health Care Research and Quality (Funding Institution). 2010. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4).
Calnan M, Cant S, Williams S, et al. Involvement of the primary health care team in coronary heart disease prevention. Br J Gen Pract. 1994;44(382):224-8. Exclude—does not meet PCMH definition. [pmid: 8204337].
Calsyn RJ, Winter JP, Morse GA. Do consumers who have a choice of treatment have better outcomes?. Community Ment Health J. 2000;36(2):149-60. Exclude—does not meet PCMH definition. [pmid: 10800864].
Campbell SM, Hann M, Hacker J, et al. Identifying predictors of high quality care in English general practice: observational study. BMJ. 2001;323(7316):784-7. Exclude—does not meet PCMH definition. [pmid: 11588082].
Carbone PS, Behl DD, Azor V, et al. The medical home for children with autism spectrum disorders: parent and pediatrician perspectives. J Autism Dev Disord. 2010;40(3):317-24. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 19768528].
Carlisle JB, Hoffman AH. Children in foster care: effect of a medical home. Sigma Theta Tau International. 2005. 16th International Nursing Research Congress. Exclude—not original data.
Carlisle R, Avery AJ, Marsh P. Primary care teams work harder in deprived areas. J Public Health Med. 2002;24(1):43-8. Exclude—does not meet PCMH definition. [pmid: 11939382].
Carlo ME, Powers JS. Ambulatory care sensitive emergency department use among low-cost medical home patients. Tenn Med. 2010;103(1):31-3. Exclude—does not meet PCMH definition. [pmid: 20108865].
Caruso LB, Clough-Gorr KM, Silliman RA. Improving quality of care for urban older people with diabetes mellitus and cardiovascular disease. J Am Geriatr Soc. 2007;55(10):1656-62. Exclude—does not meet PCMH definition. [pmid: 17714460].
Casey PH, Lyle RE, Bird TM, et al. Effect of hospital-based comprehensive care clinic on health costs for Medicaid-insured medically complex children. Arch Pediatr Adolesc Med. 2011;165(5):392-8. Exclude—population and/or setting is not eligible. [pmid: 21300650].
Cashman S, Reidy P, Cody K, et al. Developing and measuring progress toward collaborative, integrated, interdisciplinary health care teams. J Interprof Care. 2004;18(2):183-96. Exclude—does not meet PCMH definition. [pmid: 15203676].
Cass H, Kugler B. Service evaluation and development: experience of a paediatric disability team. Child Care Health Dev. 1999;25(2):115-27. Exclude—does not meet PCMH definition. [pmid: 10188066].
Cavalieri TA, Chopra A, Gray-Miceli D, et al. Geriatric assessment teams in nursing homes: do they work?. J Am Osteopath Assoc. 1993;93(12):1269-72. Exclude—population and/or setting is not eligible. [pmid: 8307806].
Chan DS, Callahan CW, Moreno C. Multidisciplinary education and management program for children with asthma. Am J Health Syst Pharm. 2001;58(15):1413-7. Exclude—does not meet PCMH definition. [pmid: 11494786].
Charles-Jones H, May C, Latimer J, et al. Telephone triage by nurses in primary care: what is it for and what are the consequences likely to be?. J Health Serv Res Policy. 2003;8(3):154-9. Exclude—does not meet PCMH definition. [pmid: 12869341].
Charney E, Kitzman H. The child-health nurse (pediatric nurse practitioner) in private practice. A controlled trial. N Engl J Med. 1971;285(24):1353-8. Exclude—does not meet PCMH definition. [pmid: 4399266].
Chen H, Coakley EH, Cheal K, et al. Satisfaction with mental health services in older primary care patients. Am J Geriatr Psychiatry. 2006;14(4):371-9. Exclude—does not meet PCMH definition. [pmid: 16582046].
Cherry JC, Dryden K, Kobb R, et al. Opening a window of opportunity through technology and coordination: a multisite case study. Telemed J E Health. 2003;9(3):265-71. Exclude—does not meet PCMH definition. [pmid: 14611694].
Chesluk BJ, Holmboe ES. How teams work—or don't—in primary care: a field study on internal medicine practices. Health Aff (Millwood). 2010;29(5):874-879. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 20439874].
Chin MH, Alexander-Young M, Burnet DL. Health care quality-improvement approaches to reducing child health disparities. Pediatrics. Suppl 3. 2009;124:S224-36. Exclude—background (other). [pmid: 19861474].
Chin MH, Drum ML, Guillen M, et al. Improving and sustaining diabetes care in community health centers with the health disparities collaboratives. Med Care. 2007;45(12):1135-43. Exclude—population and/or setting is not eligible. [pmid: 18007163].
Chiou ST, Lin HD, Yu NC, et al. An initial assessment of the feasibility and effectiveness of implementing diabetes shared care system in Taiwan—some experiences from I-Lan County. Diabetes Res Clin Pract. Suppl 1. 2001;54:S67-73. Exclude—does not meet PCMH definition. [pmid: 11580971].
Christianson JB, Pietz L, Taylor R, et al. Implementing programs for chronic illness management: the case of hypertension services. Jt Comm J Qual Improv. 1997;23(11):593-601. Exclude—does not meet PCMH definition. [pmid: 9407263].
Ciccone MM, Aquilino A, Cortese F, et al. Feasibility and effectiveness of a disease and care management model in the primary health care system for patients with heart failure and diabetes (Project Leonardo). Vasc Health Risk Manag. 2010;6:297-305. Exclude—does not meet PCMH definition. [pmid: 20479952].
Ciechanowski PS, Russo JE, Katon WJ, et al. The association of patient relationship style and outcomes in collaborative care treatment for depression in patients with diabetes. Med Care. 2006;44(3):283-291. Exclude—does not meet PCMH definition. [pmid: 16501401].
Cimpean D, Drake RE. Treating co-morbid chronic medical conditions and anxiety/depression. Epidemiol Psychiatr Sci. 2011;20(2):141-50. Exclude—background (SR/MA). [pmid: 21714361].
Clarke D, Howells J, Wellingham J, et al. Integrating healthcare: the Counties Manukau experience. N Z Med J. 2003;116(1169):U325. Exclude—does not meet PCMH definition. [pmid: 12601402].
Clarkson P, Venables D, Hughes J, et al. Integrated specialist assessment of older people and predictors of care-home admission. Psychol Med. 2006;36(7):1011-21. Exclude—does not meet PCMH definition. [pmid: 16563208].
Clow D, Mustafa A, Szollar J, et al. Reducing waiting times associated with an integrated child health service. J R Soc Promot Health. 2002;122(4):245-50. Exclude—does not meet PCMH definition. [pmid: 12557734].
Coca A, Francis MD. Implementing the chronic care model in an academic setting: a resident's perspective. Hosp Physician. 2007;43(2):49-56. Exclude—does not meet PCMH definition.
Cohen C, Onserud H, Monaco C. Outcomes for the mentally ill in a program for older homeless persons. Hosp Community Psychiatry. 1993;44(7):650-6. Exclude—does not meet PCMH definition. [pmid: 8354503].
Cohen E, Friedman JN, Mahant S, et al. The impact of a complex care clinic in a children's hospital. Child Care Health Dev. 2010;36(4):574-82. Exclude—does not meet PCMH definition. [pmid: 20337643].
Cohen HJ, Feussner JR, Weinberger M, et al. A controlled trial of inpatient and outpatient geriatric evaluation and management. N Engl J Med. 2002;346(12):905-12. Exclude—does not meet PCMH definition. [pmid: 11907291].
Coleman EA, Grothaus LC, Sandhu N, et al. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. 1999;47(7):775-83. Exclude—does not meet PCMH definition. [pmid: 10404919].
Coleman J. Case management imbedded into disease management: the formula for effective disease management in HMOs and IDSs. Case Manager. 2005;16(6):40-2. Exclude—does not meet PCMH definition. [pmid: 16326322].
Comer CM, Redmond AC, Bird HA, et al. Assessment and management of neurogenic claudication associated with lumbar spinal stenosis in a UK primary care musculoskeletal service: a survey of current practice among physiotherapists. BMC Musculoskelet Disord. 2009;10:121. Exclude—does not meet PCMH definition. [pmid: 19796387].
Conrad D, Fishman P, Grembowski D, et al. Access intervention in an integrated, prepaid group practice: effects on primary care physician productivity. Health Serv Res. 2008;43(5 Pt 2):1888-905. Exclude—does not meet PCMH definition. [pmid: 18662171].
Cook G, Gerrish K, Clarke C. Decision-making in teams: issues arising from two UK evaluations. J Interprof Care. 2001;15(2):141-51. Exclude—does not meet PCMH definition. [pmid: 11705010].
Cooley WC. Medical Home Transformation In Pediatric Primary Care—What Drives Change. Agency for Health Care Research and Quality (Funding Institution). 2010. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4).
Cooper LA, Roter DL, Bone LR, et al. A randomized controlled trial of interventions to enhance patient-physician partnership, patient adherence and high blood pressure control among ethnic minorities and poor persons: study protocol NCT00123045. Implementation Science. 2009;4:7-7. Exclude—does not meet PCMH definition. [pmid: 19228414].
Corney RH. A comparative study of referrals to a local authority intake team with a general practice attachment scheme and the resulting social workers' interventions. Soc Sci Med Med Psychol Med Sociol. 1980;14A(6):675-82. Exclude—does not meet PCMH definition. [pmid: 7209641].
Counsell SR, Callahan CM, Buttar AB, et al. Geriatric Resources for Assessment and Care of Elders (GRACE): a new model of primary care for low-income seniors. J Am Geriatr Soc. 2006;54(7):1136-41. Exclude—does not meet PCMH definition. [pmid: 16866688].
Counsell SR, Callahan CM, Clark DO, et al. Geriatric care management for low-income seniors: a randomized controlled trial. JAMA. 2007;298(22):2623-33. Exclude—does not meet PCMH definition. [pmid: 18073358].
Counsell SR, Callahan CM, Tu W, et al. Cost analysis of the Geriatric Resources for Assessment and Care of Elders care management intervention. J Am Geriatr Soc. 2009;57(8):1420-6. Exclude—does not meet PCMH definition. [pmid: 19691149].
Crabtree BF, Chase SM, Wise CG, et al. Evaluation of patient centered medical home practice transformation initiatives. Med Care. 2011;49(1):10-6. Exclude—background (other). [pmid: 21079525].
Crabtree BF, Nutting PA, Miller WL, et al. Primary Care Practice Transformation Is Hard Work: Insights From a 15-Year Developmental Program of Research. Med Care. 2010. Exclude—background (other). [pmid: 20856145].
Craven MA, Bland R. Better practices in collaborative mental health care: an analysis of the evidence base. Can J Psychiatry. 2006;51(6 Suppl 1):7S-72S. Exclude—does not meet PCMH definition. [pmid: 16786824].
Creedy D, Collis D, Ludlow T, et al. Development and evaluation of an intensive intervention program for children with a chronic health condition: a pilot study. Contemp Nurse. 2004;18(1-2):46-56. Exclude—does not meet PCMH definition. [pmid: 15729797].
Cretin S, Shortell SM, Keeler EB. An evaluation of collaborative interventions to improve chronic illness care. Framework and study design. Evaluation Review. 2004;28(1):28-51. Exclude—does not meet PCMH definition. [pmid: 14750290].
Cromwell J, McCall N, Burton J. Evaluation of Medicare Health Support chronic disease pilot program. Health Care Financ Rev. 2008;30(1):47-60. Exclude—does not meet PCMH definition. [pmid: 19040173].
Cuellar AE, Wagner TH, Hu TW, et al. New opportunities for integrated child health systems: results from the multifaceted pre-to-three program. Am J Public Health. 2003;93(11):1889-90. Exclude—does not meet PCMH definition. [pmid: 14600059].
Cullum AS. Changing provider practices to enhance preconceptional wellness. J Obstet Gynecol Neonatal Nurs. 2003;32(4):543-9. Exclude—does not meet PCMH definition. [pmid: 12903705].
Curran V, Sargeant J, Hollett A. Evaluation of an interprofessional continuing professional development initiative in primary health care. J Contin Educ Health Prof. 2007;27(4):241-52. Exclude—does not meet PCMH definition. [pmid: 18085602].
Dall TM, Askarinam Wagner RC, Zhang Y, et al. Outcomes and lessons learned from evaluating TRICARE's disease management programs. Am J Manag Care. 2010;16(6):438-46. Exclude—does not meet PCMH definition. [pmid: 20560687].
Damiano PC, Momany ET, Tyler MC, et al. Cost of outpatient medical care for children and youth with special health care needs: investigating the impact of the medical home. Pediatrics. 2006;118(4):e1187-94. Exclude—does not meet PCMH definition. [pmid: 17015507].
Davey B, Levin E, Iliffe S, et al. Integrating health and social care: implications for joint working and community care outcomes for older people. J Interprof Care. 2005;19(1):22-34. Exclude—does not meet PCMH definition. [pmid: 15842078].
DeBusk RF. MULTIFIT: a new approach to risk factor modification. Cardiol Clin. 1996;14(1):143-57. Exclude—does not meet PCMH definition. [pmid: 9072287].
Dey P, Roaf E, Collins S, et al. Randomized controlled trial to assess the effectiveness of a primary health care liaison worker in promoting shared care for opiate users. J Public Health Med. 2002;24(1):38-42. Exclude—does not meet PCMH definition. [pmid: 11939381].
Diaz-Perez Mde J, Farley T, Cabanis CM. A program to improve access to health care among Mexican immigrants in rural Colorado. J Rural Health. 2004;20(3):258-64. Exclude—does not meet PCMH definition. [pmid: 15298101].
Dihoff RE, Brosvic GM, Kafer LB, et al. Efficacy of part- and full-time early intervention. Percept Mot Skills. 1994;79(2):907-11. Exclude—does not meet PCMH definition. [pmid: 7532855].
Dimmick SL, Burgiss SG, Robbins S, et al. Outcomes of an integrated telehealth network demonstration project. Telemed J E Health. 2003;9(1):13-23. Exclude—does not meet PCMH definition. [pmid: 12699604].
Doherty D, Davies S, Woodcock L. Examining the impact of a specialist care homes support team. Nurs Stand. 2008;23(5):35-41. Exclude—does not meet PCMH definition. [pmid: 18947081].
Domurat ES. Diabetes managed care and clinical outcomes: the Harbor City, California Kaiser Permanente diabetes care system. Am J Manag Care. 1999;5(10):1299-307. Exclude—does not meet PCMH definition. [pmid: 10622995].
Drennan V, Iliffe S, Haworth D, et al. The feasibility and acceptability of a specialist health and social care team for the promotion of health and independence in ‘at risk’ older adults. Health Soc Care Community. 2005;13(2):136-44. Exclude—does not meet PCMH definition. [pmid: 15717915].
Driscoll DL. (PI). Transforming Primary Care Practice. Agency for Health Care Research and Quality (Funding Institution). 2010. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4).
Drummond N, Iliffe S, McGregor S, et al. Can primary care be both patient-centred and community-led?. J Manag Med. 2001;15(4-5):364-75. Exclude—does not meet PCMH definition. [pmid: 11765319].
Druss BG, Rohrbaugh RM, Levinson CM, et al. Integrated medical care for patients with serious psychiatric illness: a randomized trial. Arch Gen Psychiatry. 2001;58(9):861-8. Exclude—does not meet PCMH definition. [pmid: 11545670].
Druss BG, von Esenwein SA, Compton MT, et al. A randomized trial of medical care management for community mental health settings: the Primary Care Access, Referral, and Evaluation (PCARE) study. Am J Psychiatry. 2010;167(2):151-9. Exclude—does not meet PCMH definition. [pmid: 20008945].
DuBard CA. Moving forward with the medical home: evidence, expectations, and insights from CCNC. N C Med J. 2009;70(3):225-30. Exclude—not original data. [pmid: 19658260].
Dudas RA, Lemerman H, Barone M, et al. PHACES (Photographs of Academic Clinicians and Their Educational Status): a tool to improve delivery of family-centered care. Acad Pediatr. 2010;10(2):138-45. Exclude—does not meet PCMH definition. [pmid: 20206913].
Dungy CI, Morgan BC, Adams WH. Pediatrics in the Marshall Islands. Clin Pediatr (Phila). 1984;23(1):29-32. Exclude—does not meet PCMH definition. [pmid: 6418429].
Dunn KDP. A Medical Home Pilot Evaluation: A Model For Comparative Effectiveness Research. National Center for Research Resources (Funding Institution). 2010. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4).
Eaton M, Scherger J. Health team function: testing a method for improvement. J Fam Pract. 1978;6(1):101-7. Exclude—does not meet PCMH definition. [pmid: 621469].
Edelman D, Fredrickson SK, Melnyk SD, et al. Medical clinics versus usual care for patients with both diabetes and hypertension: a randomized trial. Ann Intern Med. 2010;152(11):689-96. Exclude—does not meet PCMH definition. [pmid: 20513826].
Edwards MA, Patel AC. Telemedicine in the state of Maine: a model for growth driven by rural needs. Telemed J E Health. 2003;9(1):25-39. Exclude—does not meet PCMH definition. [pmid: 12699605].
Ee-Ming K, Kidd MR. Primary health care and general practice—a comparison between Australia and Malaysia. Asia Pac J Public Health. 2002;14(2):59-63. Exclude—not original data. [pmid: 12862408].
Eggert GM, Zimmer JG, Hall WJ, et al. Case management: a randomized controlled study comparing a neighborhood team and a centralized individual model. Health Serv Res. 1991;26(4):471-507. Exclude—does not meet PCMH definition. [pmid: 1917502].
Ejlertsson G, Berg S. Continuity of care in health care teams. A comparison of continuity measures and organisational solutions. Scand J Prim Health Care. 1985;3(2):79-85. Exclude—does not meet PCMH definition. [pmid: 4059704].
Ejlertsson G, Jansson AK. The district nurse and the district physician in health care teams. An analysis of the content of primary health care. Scand J Prim Health Care. 1987;5(2):73-8. Exclude—does not meet PCMH definition. [pmid: 3616276].
El Arifeen S, Blum LS, Hoque DM, et al. Integrated Management of Childhood Illness (IMCI) in Bangladesh: early findings from a cluster-randomised study. Lancet. 2004;364(9445):1595-602. Exclude—not high income country. [pmid: 15519629].
Eliasoph H, Monaghan B, Beaudoin R, et al. “We are all in this together”: integrated health service plans in Ontario. Healthc Q. 2007;10(3):82-7. Exclude—background (other). [pmid: 18271108].
Ell K, Katon W, Cabassa LJ, et al. Depression and diabetes among low-income Hispanics: design elements of a socioculturally adapted collaborative care model randomized controlled trial. Int J Psychiatry Med. 2009;39(2):113-32. Exclude—does not meet PCMH definition. [pmid: 19860071].
Emshoff JG, Darnell AJ, Darnell DA, et al. Systems change as an outcome and a process in the work of community collaboratives for health. Am J Community Psychol. 2007;39(3-4):255-67. Exclude—does not meet PCMH definition. [pmid: 17410424].
Engels Y, van den Hombergh P, Mokkink H, et al. The effects of a team-based continuous quality improvement intervention on the management of primary care: a randomised controlled trial. Br J Gen Pract. 2006;56(531):781-7. Exclude—does not meet PCMH definition. [pmid: 17007709].
Espinet LM, Osmick MJ, Ahmed T, et al. A cohort study of the impact of a national disease management program on HEDIS diabetes outcomes. Dis Manag. 2005;8(2):86-92. Exclude—does not meet PCMH definition. [pmid: 15815157].
Evans DJ, Oakey S, Almdahl S, et al. Goal attainment scaling in a geriatric day hospital. Team and program benefits. Can Fam Physician. 1999;45:954-60. Exclude—does not meet PCMH definition. [pmid: 10216794].
Evans LK, Yurkow J, Siegler EL. The CARE Program: a nurse-managed collaborative outpatient program to improve function of frail older people. Collaborative Assessment and Rehabilitation for Elders. J Am Geriatr Soc. 1995;43(10):1155-60. Exclude—does not meet PCMH definition. [pmid: 7560709].
Every B. Better for ourselves and better for our patients: chronic disease management in primary care networks. Healthc Q. 2007;10(3):70-4. Exclude—does not meet PCMH definition. [pmid: 17626549].
Fagan PJ, Schuster AB, Boyd C, et al. Chronic care improvement in primary care: evaluation of an integrated pay-for-performance and practice-based care coordination program among elderly patients with diabetes. Health Serv Res. 2010;45(6 Pt 1):1763-82. Exclude—does not meet PCMH definition. [pmid: 20849553].
Fardy HJ. Moving towards organised care of chronic disease. The 3+ visit plan. Aust Fam Physician. 2001;30(2):121-5. Exclude—not original data. [pmid: 11280110].
Farley DO, Zellman G, Ouslander JG, et al. Use of primary care teams by HMOS for care of long-stay nursing home residents. J Am Geriatr Soc. 1999;47(2):139-44. Exclude—does not meet PCMH definition. [pmid: 9988283].
Farmer J, West C, Whyte B, et al. Primary health-care teams as adaptive organizations: exploring and explaining work variation using case studies in rural and urban Scotland. Health Serv Manage Res. 2005;18(3):151-64. Exclude—does not meet PCMH definition. [pmid: 16102244].
Farrior KC, Engelke MK, Collins CS, et al. A community pediatric prevention partnership: linking schools, providers, and tertiary care services. J Sch Health. 2000;70(3):79-83. Exclude—does not meet PCMH definition. [pmid: 10763474].
Fawcett KJ Jr., Brummel S, Byrnes JJ. Restructuring primary care for performance improvement. J Med Pract Manage. 2009;25(1):49-56. Exclude—does not meet PCMH definition. [pmid: 19743712].
Feifer C, Ornstein SM, Nietert PJ, et al. System supports for chronic illness care and their relationship to clinical outcomes. Top Health Inf Manage. 2001;22(2):65-72. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 11761794].
Fenton JJ, Levine MD, Mahoney LD, et al. Bringing geriatricians to the front lines: evaluation of a quality improvement intervention in primary care. J Am Board Fam Med. 2006;19(4):331-9. Exclude—does not meet PCMH definition. [pmid: 16809646].
Fernandopulle R, Patel N. How the electronic health record did not measure up to the demands of our medical home practice. Health Aff (Millwood). 2010;29(4):622-8. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 20368591].
Ferrante JM, Balasubramanian BA, Hudson SV, et al. Principles of the patient-centered medical home and preventive services delivery. Ann Fam Med. 2010;8(2):108-16. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 20212297].
Ferrante JM, Cohen DJ, Crosson JC. Translating the patient navigator approach to meet the needs of primary care. J Am Board Fam Med. 2010;23(6):736-44. Exclude—does not meet PCMH definition. [pmid: 21057069].
Fischman D. Applying Lean Six Sigma methodologies to improve efficiency, timeliness of care, and quality of care in an internal medicine residency clinic. Qual Manag Health Care. 2010;19(3):201-10. Exclude—does not meet PCMH definition. [pmid: 20588139].
Fisk AA. Comprehensive health care for the elderly. JAMA. 1983;249(2):230-6. Exclude—does not meet PCMH definition. [pmid: 6401335].
Fletcher AE, Jones DA, Bulpitt CJ, et al. The MRC trial of assessment and management of older people in the community: objectives, design and interventions [ISRCTN23494848]. BMC Health Serv Res. 2002;2(1):21. Exclude—does not meet PCMH definition. [pmid: 12398790].
Fletcher AE, Price GM, Ng ES, et al. Population-based multidimensional assessment of older people in UK general practice: a cluster-randomised factorial trial. Lancet. 2004;364(9446):1667-77. Exclude—does not meet PCMH definition. [pmid: 15530627].
Flocke SA, Miller WL, Crabtree BF. Relationships between physician practice style, patient satisfaction, and attributes of primary care. J Fam Pract. 2002;51(10):835-40. Exclude—does not meet PCMH definition. [pmid: 12401151].
Fokkens AS, Wiegersma PA, van der Meer K, et al. Structured diabetes care leads to differences in organization of care in general practices: the healthcare professional and patient perspective. BMC Health Serv Res. 2011;11:113. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 21600064].
Fordyce M, Bardole D, Romer L, et al. Senior Team Assessment and Referral Program—STAR. J Am Board Fam Pract. 1997;10(6):398-406. Exclude—does not meet PCMH definition. [pmid: 9407480].
Forman SA, Kelliher M, Wood G. Clinical improvement with bottom-line impact: custom care planning for patients with acute and chronic illnesses in a managed care setting. Am J Manag Care. 1997;3(7):1039-48. Exclude—does not meet PCMH definition. [pmid: 10173368].
Fortinsky RH. Health care triads and dementia care: integrative framework and future directions. Aging Ment Health. Suppl 1. 2001;5:S35-48. Exclude—does not meet PCMH definition. [pmid: 11513496].
Fortney JC, Maciejewski ML, Tripathi SP, et al. A budget impact analysis of telemedicine-based collaborative care for depression. Med Care. 2011;49(9):872-80. Exclude—does not meet PCMH definition. [pmid: 21623240].
Foster MM, Mitchell G, Haines T, et al. Does Enhanced Primary Care enhance primary care? Policy-induced dilemmas for allied health professionals. Med J Aust. 2008;188(1):29-32. Exclude—does not meet PCMH definition. [pmid: 18205560].
Francis CF, Feyer AM, Smith BJ. Implementing chronic disease self-management in community settings: lessons from Australian demonstration projects. Aust Health Rev. 2007;31(4):499-509. discussion 498. Exclude—does not meet PCMH definition. [pmid: 17973606].
Frazee SG, Kirkpatrick P, Fabius R, et al. Leveraging the trusted clinician: documenting disease management program enrollment. Disease Management. 2007;10(1):16-29. Exclude—does not meet PCMH definition. [pmid: 17309361].
Frazee SG, Sherman B, Fabius R, et al. Leveraging the trusted clinician: increasing retention in disease management through integrated program delivery. Population Health Management. 2008;11(5):247-254. Exclude—does not meet PCMH definition. [pmid: 18942916].
Freund T, Peters-Klimm F, Rochon J, et al. Primary care practice-based care management for chronically ill patients (PraCMan): study protocol for a cluster randomized controlled trial [ISRCTN56104508]. Trials. 2011;12:163. Exclude—background (other). [pmid: 21714883].
Friedman B, Wamsley BR, Liebel DV, et al. Patient satisfaction, empowerment, and health and disability status effects of a disease management-health promotion nurse intervention among Medicare beneficiaries with disabilities. Gerontologist. 2009;49(6):778-92. Exclude—does not meet PCMH definition. [pmid: 19587109].
Fung CH, Woods JN, Asch SM, et al. Variation in implementation and use of computerized clinical reminders in an integrated healthcare system. Am J Manag Care. 2004;10(11 Pt 2):878-85. Exclude—does not meet PCMH definition. [pmid: 15609742].
Gabbay RA. (PI). A Multi-Payer Patient Centered Medical Home Initiative In Pennsylvania. Agency for Health Care Research and Quality (Funding Institution). 2010. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4).
Gabbay RA, Bailit MH, Mauger DT, et al. Multipayer patient-centered medical home implementation guided by the chronic care model. Jt Comm J Qual Patient Saf. 2011;37(6):265-73. Exclude—does not meet PCMH definition. [pmid: 21706986].
Gadomski A, Jenkins P, Nichols M. Impact of a Medicaid primary care provider and preventive care on pediatric hospitalization. Pediatrics. 1998;101(3):E1. Exclude—does not meet PCMH definition. [pmid: 9481020].
Galbreath AD, Krasuski RA, Smith B, et al. Long-term healthcare and cost outcomes of disease management in a large, randomized, community-based population with heart failure. Circulation. 2004;110(23):3518-26. Exclude—does not meet PCMH definition. [pmid: 15531765].
Gallagher SM, Relf M, McKim R. Primary health care. Integrated services in northeast Edmonton. Can Nurse. 2003;99(1):25-9. Exclude—not original data. [pmid: 12630269].
Gallo JJ, Zubritsky C, Maxwell J, et al. Primary care clinicians evaluate integrated and referral models of behavioral health care for older adults: results from a multisite effectiveness trial (PRISM-e). Ann Fam Med. 2004;2(4):305-9. Exclude—does not meet PCMH definition. [pmid: 15335128].
Gariola G. Developing rural interdisciplinary geriatrics teams in a changing health care environment. J Allied Health. 1997;26(1):27-9. Exclude—does not meet PCMH definition. [pmid: 9136059].
Gask L. Waking up to chronic care. Qual Saf Health Care. 2004;13(4):246. Exclude—does not meet PCMH definition. [pmid: 15289622].
Gask L, Ludman E, Schaefer J. Qualitative study of an intervention for depression among patients with diabetes: how can we optimize patient-professional interaction?. Chronic Illness. 2006;2(3):231-242. Exclude—does not meet PCMH definition. [pmid: 17007699].
Geist R. Psychosocial care in the pediatric hospital. The need for scientific validation of clinical and cost effectiveness. Gen Hosp Psychiatry. 1995;17(3):228-34. Exclude—does not meet PCMH definition. [pmid: 7649468].
Geller JS, Orkaby A, Cleghorn GD. Impact of a group medical visit program on Latino health-related quality of life. Explore (NY). 2011;7(2):94-9. Exclude—does not meet PCMH definition. [pmid: 21397870].
Gill JM, Fagan HB, Townsend B, et al. Impact of providing a medical home to the uninsured: evaluation of a statewide program. J Health Care Poor Underserved. 2005;16(3):515-35. Exclude—does not meet PCMH definition. [pmid: 16118840].
Gillies S. The long and winding road: merging two case management programs in a developing healthcare network. Nurs Case Manag. 1998;3(3):104-7. Exclude—not original data. [pmid: 10067546].
Gilmore KA, Hargie O. Quality issues in the treatment of depression in general practice. Int J Health Care Qual Assur Inc Leadersh Health Serv. 2000;13(1):34-41. Exclude—does not meet PCMH definition. [pmid: 11183226].
Glasser M, Holt N, Hall K, et al. Meeting the needs of rural populations through interdisciplinary partnerships. Fam Community Health. 2003;26(3):230-45. Exclude—does not meet PCMH definition. [pmid: 12829945].
Glenn JK, Williamson HA Jr., Hector MG Jr., et al. Communications among nurse practitioners and physicians in team-delivered ambulatory care. Comparison with physician-to-physician interactions. Med Care. 1987;25(6):570-6. Exclude—does not meet PCMH definition. [pmid: 3695662].
Gouws E, Bryce J, Habicht JP, et al. Improving antimicrobial use among health workers in first-level facilities: results from the multi-country evaluation of the Integrated Management of Childhood Illness strategy. Bull World Health Organ. 2004;82(7):509-15. Exclude—does not meet PCMH definition. [pmid: 15508195].
Gozzoli V, Palmer AJ, Brandt A, et al. Economic and clinical impact of alternative disease management strategies for secondary prevention in type 2 diabetes in the Swiss setting. Swiss Med Wkly. 2001;131(21-22):303-10. Exclude—does not meet PCMH definition. [pmid: 11584692].
Grady GF, Castle B, Sibley K. Outcomes management: an interdisciplinary approach to improving patient outcomes. Nephrol News Issues. 1996;10(11):28-9. Exclude—does not meet PCMH definition. [pmid: 9025503].
Grant R, Bowen SK, Neidell M, et al. Health care savings attributable to integrating guidelines-based asthma care in the pediatric medical home. J Health Care Poor Underserved. 2010;21(2 Suppl):82-92. Exclude—population and/or setting is not eligible. [pmid: 20453378].
Gravelle H, Dusheiko M, Sheaff R, et al. Impact of case management (Evercare) on frail elderly patients: controlled before and after analysis of quantitative outcome data. BMJ. 2007;334(7583):31. Exclude—does not meet PCMH definition. [pmid: 17107984].
Graves MT, Slater MA, Maravilla V, et al. Implementing an early intervention case management program in three medical groups. Case Manager. 2003;14(5):48-52. Exclude—does not meet PCMH definition. [pmid: 14593346].
Green BB, Ralston JD, Fishman PA, et al. Electronic communications and home blood pressure monitoring (e-BP) study: design, delivery, and evaluation framework. Contemp Clin Trials. 2008;29(3):376-95. Exclude—does not meet PCMH definition. [pmid: 17974502].
Greene J, Rogers VW, Yedidia MJ. The impact of implementing a chronic care residency training initiative on asthma outcomes. Acad Med. 2007;82(2):161-7. Exclude—does not meet PCMH definition. [pmid: 17264695].
Gross R, Tabenkin H, Porath A, et al. Teamwork in treating diabetes and hypertension in Israeli managed care organizations. Int J Health Care Qual Assur. 2009;22(4):353-65. Exclude—does not meet PCMH definition. [pmid: 19725208].
Gupta R, Sachdev HP, Shah D. Evaluation of the WHO/UNICEF algorithm for integrated management of childhood illness between the ages of one week to two months. Indian Pediatr. 2000;37(4):383-90. Exclude—does not meet PCMH definition. [pmid: 10781231].
Haggerty J, Fortin M, Beaulieu MD, et al. At the interface of community and healthcare systems: a longitudinal cohort study on evolving health and the impact of primary healthcare from the patient's perspective. BMC Health Serv Res. 2010;10:258. Exclude—does not meet PCMH definition. [pmid: 20815880].
Hagglund M, Chen R, Koch S. Modeling shared care plans using CONTsys and openEHR to support shared homecare of the elderly. J Am Med Inform Assoc. 2011;18(1):66-9. Exclude—does not meet PCMH definition. [pmid: 21106993].
Hagland M. Arrested development. Early medical management improves the outcomes of diseases, even chronic ones. Healthc Inform. 2003;20(11):41-4. Exclude—does not meet PCMH definition. [pmid: 14649089].
Haig AJ, Nagy A, LeBreck DB, et al. Outpatient planning for persons with physical disabilities: a randomized prospective trial of physiatrist alone versus a multidisciplinary team. Arch Phys Med Rehabil. 1995;76(4):341-8. Exclude—does not meet PCMH definition. [pmid: 7717834].
Halfon N, Inkelas M, Hochstein M. The health development organization: an organizational approach to achieving child health development. Milbank Q. 2000;78(3):447-97. 341. Exclude—background (other). [pmid: 11028191].
Halstead LS. Team care in chronic illness: a critical review of the literature of the past 25 years. Arch Phys Med Rehabil. 1976;57(11):507-11. Exclude—does not meet PCMH definition. [pmid: 985051].
Hamar B, Wells A, Gandy W, et al. The impact of proactive chronic care management on hospital admissions in a German senior population. Popul Health Manag. Suppl 1. 2011;14:S29-33. Exclude—does not meet PCMH definition. [pmid: 21323617].
Hanson JL, Randall VF. Evaluating and improving the practice of family-centered care. Pediatr Nurs. 1999;25(4):445-9. Exclude—does not meet PCMH definition. [pmid: 12024367].
Harris DE, Record NB, Gipson GW, et al. Lipid lowering in a multidisciplinary clinic compared with primary physician management. Am J Cardiol. 1998;81(7):929-33. Exclude—does not meet PCMH definition. [pmid: 9555787].
Harris MF, Chan BC, Daniel C, et al. Development and early experience from an intervention to facilitate teamwork between general practices and allied health providers: the Team-link study. BMC Health Serv Res. 2010;10:104. Exclude—does not meet PCMH definition. [pmid: 20423471].
Harris MF, Jayasinghe UW, Taggart JR, et al. Multidisciplinary Team Care Arrangements in the management of patients with chronic disease in Australian general practice. Med J Aust. 2011;194(5):236-9. Exclude—does not meet PCMH definition. [pmid: 21381995].
Harris MF, Proudfoot JG, Jayasinghe UW, et al. Job satisfaction of staff and the team environment in Australian general practice. Med J Aust. 2007;186(11):570-3. Exclude—does not meet PCMH definition. [pmid: 17547545].
Harrison MI, Kimani J. Building capacity for a transformation initiative: system redesign at Denver Health. Health Care Manage Rev. 2009;34(1):42-53. Exclude—does not meet PCMH definition. [pmid: 19104263].
Harrison S, Hunter D, Fairfield G, et al. Health Management Guide. Disease management. Health Serv J. Suppl 7. 1996:1-12. Exclude—does not meet PCMH definition. [pmid: 10162374].
Harzheim E, Duncan BB, Stein AT, et al. Quality and effectiveness of different approaches to primary care delivery in Brazil. BMC Health Serv Res. 2006;6:156. Exclude—no relevant outcomes (Pt/Staff Experience; Process of Care; Clinical Outcomes; Economic Outcomes). [pmid: 17147819].
Helene B, Ford P. Mind-body innovations—an integrative care approach. Psychiatric Quarte ly. 2000;71(1):47-58. Exclude—does not meet PCMH definition. [pmid: 10736816].
Hernandez SR. Horizontal and vertical healthcare integration: lessons learned from the United States. Healthc Pap. 2000;1(2):59-66. discussion 104-7. Exclude—does not meet PCMH definition. [pmid: 12811066].
Hess R, Bryce CL, Paone S, et al. Exploring challenges and potentials of personal health records in diabetes self-management: implementation and initial assessment. Telemed J E Health. 2007;13(5):509-17. Exclude—does not meet PCMH definition. [pmid: 17999613].
Heuer LJ, Hess C, Batson A. Cluster clinics for migrant Hispanic farmworkers with diabetes: perceptions, successes, and challenges. Rural Remote Health. 2006;6(1):469. Exclude—does not meet PCMH definition. [pmid: 16573366].
Hickie IB, Davenport TA, Naismith SL, et al. Treatment of common mental disorders in Australian general practice. Med J Aust. 2001;175(Suppl):S25-30. Exclude—does not meet PCMH definition. [pmid: 11556432].
Hicks LS, O'Malley AJ, Lieu TA, et al. Impact of health disparities collaboratives on racial/ethnic and insurance disparities in US community health centers. Arch Intern Med. 2010;170(3):279-86. Exclude—does not meet PCMH definition. [pmid: 20142575].
Hoang T, Goetz MB, Yano EM, et al. The impact of integrated HIV care on patient health outcomes. Med Care. 2009;47(5):560-7. Exclude—does not meet PCMH definition. [pmid: 19318998].
Hobbs C, Hanks HG. A multidisciplinary approach for the treatment of children with failure to thrive. Child Care Health Dev. 1996;22(4):273-84. Exclude—does not meet PCMH definition. [pmid: 8818430].
Hogg W, Lemelin J, Dahrouge S, et al. Randomized controlled trial of anticipatory and preventive multidisciplinary team care: for complex patients in a community-based primary care setting. Can Fam Physician. 2009;55(12):e76-85. Exclude—does not meet PCMH definition. [pmid: 20008582].
Holmes AM, Ackermann RD, Zillich AJ, et al. The net fiscal impact of a chronic disease management program: Indiana Medicaid. Health Aff (Millwood). 2008;27(3):855-64. Exclude—does not meet PCMH definition. [pmid: 18474980].
Horn SD. The clinical practice improvement (CPI) model and how it is used to examine the availability of pharmaceuticals and the utilisation of ambulatory healthcare services in HMOs. Results from the Managed Care Outcomes Project (MCOP). Pharmacoeconomics. Suppl 2. 1996;10:50-5. Exclude—does not meet PCMH definition. [pmid: 10163436].
Hornick TR, Higgins PA, Stollings C, et al. Initial evaluation of a computer-based medication management tool in a geriatric clinic. Am J Geriatr Pharmacother. 2006;4(1):62-9. Exclude—does not meet PCMH definition. [pmid: 16730622].
Horwood C, Voce A, Vermaak K, et al. Experiences of training and implementation of integrated management of childhood illness (IMCI) in South Africa: a qualitative evaluation of the IMCI case management training course. BMC Pediatr. 2009;9:62. Exclude—does not meet PCMH definition. [pmid: 19796377].
Howard M, Brazil K, Akhtar-Danesh N, et al. Self-reported teamwork in family health team practices in Ontario: organizational and cultural predictors of team climate. Can Fam Physician. 2011;57(5):e185-91. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 21571706].
Howie JG, Heaney DJ, Maxwell M. Measuring quality in general practice. Pilot study of a needs, process and outcome measure. Occas Pap R Coll Gen Pract. 1997;(75):i-xii. 1. 32. Exclude—does not meet PCMH definition. [pmid: 9141884].
Hroscikoski MC, Solberg LI, Sperl-Hillen JM, et al. Challenges of change: a qualitative study of chronic care model implementation. Ann Fam Med. 2006;4(4):317-26. Exclude—does not meet PCMH definition. [pmid: 16868235].
Huff C. Patient care. Disease dilemma. Can a case be made for programs that improve health, but may not reduce costs?. Hosp Health Netw. 2005;79(4):24. 26. Exclude—does not meet PCMH definition. [pmid: 15916338].
Hughes DC, Brindis C, Halfon N, et al. Integrating children's health services: evaluation of a national demonstration project. Matern Child Health J. 1997;1(4):243-52. Exclude—no relevant outcomes (Pt/Staff Experience; Process of Care; Clinical Outcomes; Economic Outcomes). [pmid: 10728250].
Hughes SL, Weaver FM, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. 2000;284(22):2877-85. Exclude—does not meet PCMH definition. [pmid: 11147984].
Humbert J, Legault F, Dahrouge S, et al. Integration of nurse practitioners into a family health network. Can Nurse. 2007;103(9):30-4. Exclude—does not meet PCMH definition. [pmid: 18095528].
Inglis SC, Clark RA, McAlister FA, et al. Structured telephone support or telemonitoring programmes for patients with chronic heart failure. Cochrane Database Syst Rev. 2010;(8):CD007228. Exclude—does not meet PCMH definition. [pmid: 20687083].
Jackson CL, de Jong I, Oats J. Clinical pathways involving general practice—a new approach to integrated health care?. Aust Health Rev. 2000;23(2):88-95. Exclude—does not meet PCMH definition. [pmid: 11010582].
Jans MP, Schellevis FG, Le Coq EM, et al. Health outcomes of asthma and COPD patients: the evaluation of a project to implement guidelines in general practice. Int J Qual Health Care. 2001;13(1):17-25. Exclude—does not meet PCMH definition. [pmid: 11330439].
Jansson A, Isacsson A, Lindholm LH. Organization of health care teams and the population's contacts with primary care. Scand J Prim Health Care. 1992;10(4):257-65. Exclude—does not meet PCMH definition. [pmid: 1480864].
Jessop DJ, Stein RE. Providing comprehensive health care to children with chronic illness. Pediatrics. 1994;93(4):602-7. Exclude—no relevant outcomes (Pt/Staff Experience; Process of Care; Clinical Outcomes; Economic Outcomes). [pmid: 8134215].
Jilcott SB, Keyserling TC, Samuel-Hodge CD, et al. Linking clinical care to community resources for cardiovascular disease prevention: the North Carolina Enhanced WISEWOMAN Project. Journal of Women's Health. (15409996). 2006;15(5):569-583. Exclude—does not meet PCMH definition.
Jiwa M, Gerrish K, Gibson A, et al. Preventing avoidable hospital admission of older people. Br J Community Nurs. 2002;7(8):426-31. Exclude—does not meet PCMH definition. [pmid: 12192347].
Johnson AE, Yin M, Berg G. Utilization and financial outcomes of an asthma disease management program delivered to Medicaid members: results of a three-group comparison study. Disease Management & Health Outcomes. 2003;11(7):455-465. Exclude—does not meet PCMH definition.
Johri M, Beland F, Bergman H. International experiments in integrated care for the elderly: a synthesis of the evidence. Int J Geriatr Psychiatry. 2003;18(3):222-35. Exclude—background (SR/MA). [pmid: 12642892].
Jones K. Integrated care pilot programme: ensuring people with dementia receive joined up care. Nurs Times. 2010;106(10):12-4. Exclude—does not meet PCMH definition. [pmid: 20426294].
Joseph A, Boult C. Managed primary care of nursing home residents. J Am Geriatr Soc. 1998;46(9):1152-6. Exclude—does not meet PCMH definition. [pmid: 9736112].
Judd F, Davis J, Hodgins G, et al. Rural Integrated Primary Care Psychiatry Programme: a systems approach to education, training and service integration. Australas Psychiatry. 2004;12(1):42-7. Exclude—does not meet PCMH definition. [pmid: 15715738].
Kane DJ, Kasehagen L, Punyko J, et al. What factors are associated with state performance on provision of transition services to CSHCN?. Pediatrics. Suppl 4. 2009;124:S375-83. Exclude—does not meet PCMH definition. [pmid: 19948602].
Kane RL, Homyak P, Bershadsky B, et al. Variations on a theme called PACE. J Gerontol A Biol Sci Med Sci. 2006;61(7):689-93. Exclude—does not meet PCMH definition. [pmid: 16870630].
Kane RL, Huck S. The implementation of the EverCare demonstration project. J Am Geriatr Soc. 2000;48(2):218-23. Exclude—does not meet PCMH definition. [pmid: 10682954].
Kashner TM, Rush AJ, Crismon ML, et al. An empirical analysis of cost outcomes of the Texas Medication Algorithm Project. Psychiatr Serv. 2006;57(5):648-59. Exclude—does not meet PCMH definition. [pmid: 16675759].
Kathol RG, Butler M, McAlpine DD, et al. Barriers to physical and mental condition integrated service delivery. Psychosom Med. 2010;72(6):511-8. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 20498293].
Katon WJ, Lin EH, Von Korff M, et al. Collaborative care for patients with depression and chronic illnesses. N Engl J Med. 2010;363(27):2611-20. Exclude—does not meet PCMH definition. [pmid: 21190455].
Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Arch Gen Psychiatry. 2004;61(10):1042-9. Exclude—does not meet PCMH definition. [pmid: 15466678].
Katz BP, Holmes AM, Stump TE, et al. The Indiana Chronic Disease Management Program's impact on medicaid claims: a longitudinal, statewide evaluation. Med Care. 2009;47(2):154-60. Exclude—does not meet PCMH definition. [pmid: 19169115].
Keeler EB, Robalino DA, Frank JC, et al. Cost-effectiveness of outpatient geriatric assessment with an intervention to increase adherence. Med Care. 1999;37(12):1199-206. Exclude—does not meet PCMH definition. [pmid: 10599601].
Keijzers G, Crilly J, Walters B, et al. Does a dedicated pediatric team within a busy mixed emergency department make a difference in waiting times, satisfaction, and care transition?. Pediatr Emerg Care. 2010;26(4):274-80. Exclude—does not meet PCMH definition. [pmid: 20401972].
Kempe A, Beaty B, Englund BP, et al. Quality of care and use of the medical home in a state-funded capitated primary care plan for low-income children. Pediatrics. 2000;105(5):1020-8. Exclude—does not meet PCMH definition. [pmid: 10790457].
Kennedy-Symonds H. Managing chronic illnesses. Nurs BC. 2006;38(1):21-3. Exclude—does not meet PCMH definition. [pmid: 16521898].
Kerski D, Drinka T, Carnes M, et al. Post-geriatric evaluation unit follow-up: team versus nonteam. J Gerontol. 1987;42(2):191-5. Exclude—does not meet PCMH definition. [pmid: 3819345].
Ketola E, Makela M, Klockars M. Individualised multifactorial lifestyle intervention trial for high-risk cardiovascular patients in primary care. Br J Gen Pract. 2001;51(465):291-4. Exclude—does not meet PCMH definition. [pmid: 11458482].
Kibbe DC. Physicians, care coordination, and the use of web-based information systems to manage chronic illness across the continuum. Case Manager. 2001;12(5):56-61. Exclude—not original data. [pmid: 11552096].
Kilbourne AM, Biswas K, Pirraglia PA, et al. Is the collaborative chronic care model effective for patients with bipolar disorder and co-occurring conditions?. J Affect Disord. 2009;112(1-3):256-61. Exclude—does not meet PCMH definition. [pmid: 18504059].
Kimura J, DaSilva K, Marshall R. Population management, systems-based practice, and planned chronic illness care: integrating disease management competencies into primary care to improve composite diabetes quality measures. Disease Management. 2008;11(1):13-22. Exclude—population and/or setting is not eligible. [pmid: 18279110].
King EB, Gregory RP, Flannery ME. Today's educator. Feasibility test of a shared care network for children with type 1 diabetes mellitus. Diabetes Educ. 2006;32(5):723-733. Exclude—does not meet PCMH definition. [pmid: 16971706].
Kinmonth AL, Woodcock A, Griffin S, et al. Randomised controlled trial of patient centred care of diabetes in general practice: impact on current wellbeing and future disease risk. The Diabetes Care From Diagnosis Research Team. BMJ. 1998;317(7167):1202-8. Exclude—does not meet PCMH definition. [pmid: 9794859].
Kirsh S, Watts S, Pascuzzi K, et al. Shared medical appointments based on the chronic care model: a quality improvement project to address the challenges of patients with diabetes with high cardiovascular risk. Qual Saf Health Care. 2007;16(5):349-53. Exclude—does not meet PCMH definition. [pmid: 17913775].
Kleinsorge CA, Roberts MC, Roy KM, et al. The program evaluation of services in a primary care clinic: attaining a medical home. Clin Pediatr (Phila). 2010;49(6):548-59. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 20139106].
Klitzner TS, Rabbitt LA, Chang RK. Benefits of care coordination for children with complex disease: a pilot medical home project in a resident teaching clinic. J Pediatr. 2010;156(6):1006-10. Exclude—does not meet PCMH definition. [pmid: 20223482].
Knight AW. Learning from four years of collaborative access work in Australia. Qual Prim Care. 2009;17(1):71-4. Exclude—does not meet PCMH definition. [pmid: 19281677].
Kozma CM. Demonstration projects recognize the value of disease management. Manag Care Interface. 2002;15(11):39-40. Exclude—does not meet PCMH definition. [pmid: 12449901].
Kroner BA, Billups SJ, Garrison KM, et al. Actual versus projected cost avoidance for clinical pharmacy specialist-initiated medication conversions in a primary care setting in an integrated health system. Journal of Managed Care Pharmacy. 2008;14(2):155-163. Exclude—does not meet PCMH definition. [pmid: 18331117].
Kucukarslan SN, Hagan AM, Shimp LA, et al. Integrating medication therapy management in the primary care medical home: A review of randomized controlled trials. Am J Health Syst Pharm. 2011;68(4):335-45. Exclude—background (SR/MA). [pmid: 21289329].
Laaser U, Breckenkamp J. Trends in risk factor control in Germany 1984-1998: high blood pressure and total cholesterol. Eur J Public Health. 2006;16(2):217-22. Exclude—does not meet PCMH definition. [pmid: 16093306].
Laffel LMB, Brackett J, Ho J, et al. Changing the process of diabetes care improves metabolic outcomes and reduces hospitalizations. Qual Manag Health Care. 1999;7(3):53-62. Exclude—does not meet PCMH definition.
LaFramboise LM, Todero CM, Zimmerman L, et al. Comparison of Health Buddy with traditional approaches to heart failure management. Fam Community Health. 2003;26(4):275-88. Exclude—does not meet PCMH definition. [pmid: 14528134].
Lamb GS, Mahn V, Dahl R. Using data to design systems of care adults with chronic illness. Manag Care Q. 1996;4(3):46-53. Exclude—does not meet PCMH definition. [pmid: 10159033].
Lamothe L, Fortin JP, Labbe F, et al. Impacts of telehomecare on patients, providers, and organizations. Telemed J E Health. 2006;12(3):363-9. Exclude—does not meet PCMH definition. [pmid: 16796505].
Lancaster T, Moher M. Review: multidisciplinary CHD management programs improve the process of care and reduce hospitalizations. ACP J Club. 2002;136(2):73-73. Exclude—not original data. [pmid: 11874298].
Landis SE, Gaynes BN, Morrissey JP, et al. Generalist care managers for the treatment of depressed medicaid patients in North Carolina: a pilot study. BMC Fam Pract. 2007;8:7. Exclude—does not meet PCMH definition. [pmid: 17338822].
Landon BE, Hicks LS, O'Malley AJ, et al. Improving the management of chronic disease at community health centers. N Engl J Med. 2007;356(9):921-34. Exclude—does not meet PCMH definition. [pmid: 17329699].
Larivaara P, Taanila A. Towards interprofessional family-oriented teamwork in primary services: the evaluation of an education programme. J Interprof Care. 2004;18(2):153-63. Exclude—does not meet PCMH definition. [pmid: 15203674].
Lawson KA, Bloom SR, Sadof M, et al. Care Coordination for Children with Special Health Care Needs: Evaluation of a State Experiment. Matern Child Health J. 2010. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4. [pmid: 20721611].
Leath C, Thatcher RM. Team-managed care for older adults. A clinical demonstration of a community model. J Gerontol Nurs. 1991;17(7):25-8. Exclude—not original data. [pmid: 2071853].
Ledlow GR, Bradshaw DM, Shockley C. Primary care access improvement: an empowerment-interaction model. Mil Med. 2000;165(5):390-5. Exclude—does not meet PCMH definition. [pmid: 10826388].
Lee K, Palacia C, Alexandraki I, et al. Increasing access to health care providers through medical home model may abolish racial disparity in diabetes care: evidence from a cross-sectional study. J Natl Med Assoc. 2011;103(3):250-6. Exclude – population and/or setting not eligible. [pmid: 21671528].
Lee W, Eng C, Fox N, et al. PACE: a model for integrated care of frail older patients. Program of All-inclusive Care for the Elderly. Geriatrics. 65. 1998;53(6):62-6. 69. 73. quiz 74. Exclude—does not meet PCMH definition. [pmid: 9634107].
Lemmens KM, Rutten-Van Molken MP, Cramm JM, et al. Evaluation of a large scale implementation of disease management programmes in various Dutch regions: a study protocol. BMC Health Serv Res. 2011;11:6. Exclude – not original data. [pmid: 21219620].
Levesque RF. The PACE (Program of All-Inclusive Care for the Elderly) model—success in cooperation. Caring. 1993;12(10):62-6. Exclude—not original data. [pmid: 10129033].
Lewin SA, Skea ZC, Entwistle V, et al. Interventions for providers to promote a patient-centred approach in clinical consultations. Cochrane Database Syst Rev. 2001;(4):CD003267. Exclude—does not meet PCMH definition. [pmid: 11687181].
Lim FS, Toh MP, Emmanuel SC, et al. A preliminary evaluation of a disease management programme for patients with diabetes mellitus and hypertension in a primary healthcare setting. Ann Acad Med Singapore. 2002;31(4):431-9. Exclude—does not meet PCMH definition. [pmid: 12161877].
Lima HA. Disease management in the alternate-site health care setting. Am J Health Syst Pharm. 1998;55(5):471-6. Exclude—not original data. [pmid: 9522932].
Lin BY. Integration in primary community care networks (PCCNs): examination of governance, clinical, marketing, financial, and information infrastructures in a national demonstration project in Taiwan. BMC Health Serv Res. 2007;7:90. Exclude—does not meet PCMH definition. [pmid: 17577422].
Lin BY, Lin CC, Lin YK. Patient satisfaction evaluations in different clinic care models: care stratification under a national demonstration project. Health Place. 2010;16(1):85-92. Exclude—does not meet PCMH definition. [pmid: 19783465].
Lind A, Kaplan L. An evaluation of Washington's Medicaid disease-management program. Manag Care Interface. 2007;20(10):45-50. Exclude—does not meet PCMH definition. [pmid: 18405208].
Linnell K. Chronic disease self-management: one successful program. Nurs Econ. 2005;23(4):189-91. 196. 8. Exclude—does not meet PCMH definition. [pmid: 16189984].
Lipton HL. Home is where the health is: advancing team-based care in chronic disease management. Arch Intern Med. 2009;169(21):1945-1948. Exclude—background (other). [pmid: 19933953].
Litaker D, Mion L, Planavsky L, et al. Physician—nurse practitioner teams in chronic disease management: the impact on costs, clinical effectiveness, and patients' perception of care. J Interprof Care. 2003;17(3):223-37. Exclude—does not meet PCMH definition. [pmid: 12850874].
Little P, Everitt H, Williamson I, et al. Observational study of effect of patient centredness and positive approach on outcomes of general practice consultations. BMJ. 2001;323(7318):908-11. Exclude—does not meet PCMH definition. [pmid: 11668137].
Long AF, Gambling T, Young RJ, et al. Acceptability and satisfaction with a telecarer approach to the management of type 2 diabetes. Diabetes Care. 2005;28(2):283-289. Corporate Author: PACCTS (Pro-Active Call-Center Treatment Support) Team. Exclude—does not meet PCMH definition. [pmid: 15677780].
Lorig K, Ritter PL, Laurent DD, et al. Online diabetes self-management program: a randomized study. Diabetes Care. 2010;33(6):1275-1281. Exclude—does not meet PCMH definition. [pmid: 20299481].
Lorig KR, Ritter P, Stewart AL, et al. Chronic disease self-management program: 2-year health status and health care utilization outcomes. Med Care. 2001;39(11):1217-23. Exclude—does not meet PCMH definition. [pmid: 11606875].
Lorig KR, Sobel DS, Stewart AL, et al. Evidence suggesting that a chronic disease self-management program can improve health status while reducing hospitalization: a randomized trial. Med Care. 1999;37(1):5-14. Exclude—does not meet PCMH definition. [pmid: 10413387].
Low LF, Yap M, Brodaty H. A systematic review of different models of home and community care services for older persons. BMC Health Serv Res. 2011;11:93. Exclude—background (SR/MA). [pmid: 21549010].
Lowe J, Byles J, Dolja-Gore X, et al. Does systematically organized care improve outcomes for women with diabetes?. J Eval Clin Pract. 2010;16(5):887-94. Exclude—does not meet PCMH definition. [pmid: 20663004].
Loxterkamp D, Kazal LA Jr. Changing horses midstream: the promise and prudence of practice redesign. Ann Fam Med. 2008;6(2):167-70. Exclude—background (other). [pmid: 18332412].
Lucena RJ, Lesage A, Elie R, et al. Strategies of collaboration between general practitioners and psychiatrists: a survey of practitioners' opinions and characteristics. Can J Psychiatry. 2002;47(8):750-8. Exclude—does not meet PCMH definition. [pmid: 12420653].
Lutfiyya MN, Scott N, Hurliman B, et al. Determining an association between having a medical home and uncontrolled asthma in US school-aged children: a population-based study using data from the National Survey of Children's Health. Postgrad Med. 2010;122(2):94-101. Exclude—does not meet PCMH definition. [pmid: 20203460].
Macko P, Dunn S, Blech M, et al. The social HMOs. Meeting the challenge of integrated team care coordination. J Case Manag. 1995;4(3):102-6. Exclude—does not meet PCMH definition. [pmid: 7580950].
MacLean CD, Littenberg B, Gagnon M. Diabetes decision support: initial experience with the Vermont diabetes information system. Am J Public Health. 2006;96(4):593-5. Exclude—does not meet PCMH definition. [pmid: 16507723].
Mahmood-Yousuf K, Munday D, King N, et al. Interprofessional relationships and communication in primary palliative care: impact of the Gold Standards Framework. Br J Gen Pract. 2008;58(549):256-63. Exclude—does not meet PCMH definition. [pmid: 18387229].
Makowsky MJ, Schindel TJ, Rosenthal M, et al. Collaboration between pharmacists, physicians and nurse practitioners: a qualitative investigation of working relationships in the inpatient medical setting. J Interprof Care. 2009;23(2):169-84. Exclude—does not meet PCMH definition. [pmid: 19234987].
Malcolm L, Wright L, Carson S. Integrating primary and secondary care: the case of Christchurch South Health Centre. N Z Med J. 2000;113(1123):514-7. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 11198513].
Maljanian R, Grey N, Staff I, et al. Intensive telephone follow-up to a hospital-based disease management model for patients with diabetes mellitus. Disease Management. 2005;8(1):15-25. Exclude—does not meet PCMH definition. [pmid: 15722700].
Malouin RA, Turner J. A review of the evidence for the medical home for children with special health care needs. Pediatrics. 2009;123(2):e369. Exclude—not original data. [pmid: 19171603].
Martin-Misener R, McNab J, Sketris IS, et al. Collaborative practice in health systems change: the Nova Scotia experience with the Strengthening Primary Care Initiative. Nurs Leadersh (Tor Ont). 2004;17(2):33-45. Exclude—does not meet PCMH definition. [pmid: 15239315].
May CR, Finch TL, Cornford J, et al. Integrating telecare for chronic disease management in the community: what needs to be done?. BMC Health Serv Res. 2011;11:131. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 21619596].
Mayer JB, Kapust LR, Mulcahey AL, et al. Empowering families of the chronically ill: a partnership experience in a hospital setting. Soc Work Health Care. 1990;14(4):73-90. Exclude—does not meet PCMH definition. [pmid: 2237715].
McAlister FA, Lawson FM, Teo KK, et al. Randomised trials of secondary prevention programmes in coronary heart disease: systematic review. BMJ. 2001;323(7319):957-62. Exclude—does not meet PCMH definition. [pmid: 11679383].
McAlister FA, Stewart S, Ferrua S, et al. Multidisciplinary strategies for the management of heart failure patients at high risk for admission: a systematic review of randomized trials. Journal of the American College of Cardiology (JACC). 2004;44(4):810-819. Exclude—background (other).
McBurney PG, Simpson KN, Darden PM. Potential cost savings of decreased emergency department visits through increased continuity in a pediatric medical home. Ambulatory Pediatrics. 2004;4(3):204-208. Exclude—background (other). [pmid: 15153047].
McClatchey S. Disease management as a performance improvement strategy. Top Health Inf Manage. 2001;22(2):15-23. Exclude—does not meet PCMH definition. [pmid: 11761788].
McCracken LM, Vowles KE, Eccleston C. Acceptance-based treatment for persons with complex, long standing chronic pain: a preliminary analysis of treatment outcome in comparison to a waiting phase. Behav Res Ther. 2005;43(10):1335-46. Exclude—does not meet PCMH definition. [pmid: 16086984].
McCulloch DK. Impact of endocrine and diabetes team consultation on hospital length of stay for patients with diabetes. commentary on Levetan CS, Salas R, Wiltes IF et al. AM J MED 99:22-8, 1995. Diabetes Spectrum. 1996;9(3):180-181. Exclude—does not meet PCMH definition.
McDermott MT, Haugen BR, Lezotte DC, et al. Management practices among primary care physicians and thyroid specialists in the care of hypothyroid patients. Thyroid. 2001;11(8):757-64. Exclude—does not meet PCMH definition. [pmid: 11525268].
McDermott R, Tulip F, Schmidt B, et al. Sustaining better diabetes care in remote indigenous Australian communities. BMJ: British Medical Journal. 2003;327(7412):428-430. Exclude—does not meet PCMH definition.
McDonald K, Ledwidge M, Cahill J, et al. Elimination of early rehospitalization in a randomized, controlled trial of multidisciplinary care in a high-risk, elderly heart failure population: the potential contributions of specialist care, clinical stability and optimal angiotensin-converting enzyme inhibitor dose at discharge. Eur J Heart Fail. 2001;3(2):209-15. Exclude—does not meet PCMH definition. [pmid: 11246059].
McDonald K, Ledwidge M, Cahill J, et al. Heart failure management: multidisciplinary care has intrinsic benefit above the optimization of medical care. J Card Fail. 2002;8(3):142-8. Exclude—does not meet PCMH definition. [pmid: 12140806].
McGhee G, Murphy E. Research on reducing hospitalizations in patients with chronic heart failure. Home Healthc Nurse. 2010;28(6):335-340. Exclude—not original data.
McGregor M, Lin EH, Katon WJ. TEAMcare: an integrated multicondition collaborative care program for chronic illnesses and depression. J Ambul Care Manage. 2011;34(2):152-62. Exclude – does not meet PCMH definition. [pmid: 21415613].
McGrew JH, Bond GR. The association between program characteristics and service delivery in assertive community treatment. Adm Policy Ment Health. 1997;25(2):175-89. Exclude—does not meet PCMH definition. [pmid: 9727215].
McGuire A, Newman A, McTernan SE. Research briefs. Recent research in pediatrics: implications for home health nursing. Home Healthc Nurse. 2008;26(2):91-95. Exclude—not original data.
McLean DL, McAlister FA, Johnson JA, et al. A randomized trial of the effect of community pharmacist and nurse care on improving blood pressure management in patients with diabetes mellitus: Study of Cardiovascular Risk Intervention by Pharmacists—Hypertension (SCRIP-HTN). Arch Intern Med. 2008;168(21):2355-2361. Corporate Author: SCRIP-HTN (Study of Cardiovascular Risk Intervention by Pharmacists—Hypertension) Investigators. Exclude—does not meet PCMH definition. [pmid: 19029501].
McLean M, Armstrong D. Eliciting patients' concerns: a randomised controlled trial of different approaches by the doctor. Br J Gen Pract. 2004;54(506):663-6. Exclude—does not meet PCMH definition. [pmid: 15353051].
McMahon GT, Katz JT, Thorndike ME, et al. Evaluation of a redesign initiative in an internal-medicine residency. N Engl J Med. 2010;362(14):1304-11. Exclude—does not meet PCMH definition. [pmid: 20375407].
McMenamy JM, Perrin EC. Filling the GAPS: description and evaluation of a primary care intervention for children with chronic health conditions. Ambul Pediatr. 2004;4(3):249-56. Exclude—does not meet PCMH definition. [pmid: 15153046].
McNab L, Smith B, Minardi HA. A new service in the intermediate care of older adults with mental health problems. Nurs Older People. 2006;18(3):22-6. Exclude—does not meet PCMH definition. [pmid: 16634391].
McNair R, Brown R, Stone N, et al. Rural interprofessional education: promoting teamwork in primary health care education and practice. Aust J Rural Health. Suppl 1. 2001;9:S19-26. Exclude—does not meet PCMH definition. [pmid: 11998271].
Mead N, Bower P. Patient-centred consultations and outcomes in primary care: a review of the literature. Patient Educ Couns. 2002;48(1):51-61. Exclude—does not meet PCMH definition. [pmid: 12220750].
Mead N, Bower P, Hann M. The impact of general practitioners' patient-centredness on patients' post-consultation satisfaction and enablement. Soc Sci Med. 2002;55(2):283-99. Exclude—does not meet PCMH definition. [pmid: 12144142].
Mease A, Whitlock WL, Brown A, et al. Telemedicine improved diabetic management. Mil Med. 2000;165(8):579-584. Exclude—does not meet PCMH definition. [pmid: 10957848].
Meenan RT. (PI). Transformation To Patient-Centered Medical Home In Care Oregon Clinics. Agency for Health Care Research and Quality (Funding Institution). 2010. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4).
Mehler PS. Diagnosis and care of patients with anorexia nervosa in primary care settings. Ann Intern Med. 2001;134(11):1048-59. Exclude—does not meet PCMH definition. [pmid: 11388818].
Mejhert M, Kahan T, Persson H, et al. Limited long term effects of a management programme for heart failure. Heart. 2004;90(9):1010-1015. Exclude—does not meet PCMH definition. [pmid: 15310688].
Melancon J, Oomen-Early J, del Rincon LM. Using the PEN-3 model to assess knowledge, attitudes, and beliefs about diabetes type 2 among Mexican American and Mexican Native men and women in North Texas. International Electronic Journal of Health Education. 2009;12:203-221. Exclude—does not meet PCMH definition.
Melin AL, Wieland D, Harker JO, et al. Health outcomes of post-hospital in-home team care: secondary analysis of a Swedish trial. J Am Geriatr Soc. 1995;43(3):301-7. Exclude—does not meet PCMH definition. [pmid: 7884123].
Melis RJ, van Eijken MI, Teerenstra S, et al. A randomized study of a multidisciplinary program to intervene on geriatric syndromes in vulnerable older people who live at home (Dutch EASYcare Study). J Gerontol A Biol Sci Med Sci. 2008;63(3):283-90. Exclude—does not meet PCMH definition. [pmid: 18375877].
Meredith LS, Mendel P, Pearson M, et al. Implementation and maintenance of quality improvement for treating depression in primary care. Psychiatr Serv. 2006;57(1):48-55. Exclude—population and/or setting is not eligible. [pmid: 16399962].
Micevski V. Review: multidisciplinary disease management programmes do not reduce death or recurrent myocardial infarction but reduce admission to hospital. Evidence-Based Nursing. 2002;5(2):54-54. Exclude—does not meet PCMH definition. [pmid: 11995657].
Miller LS, Clark ML, Clark WF. The comparative evaluation of California's multipurpose senior services project. Home Health Care Serv Q. 1985;6(3):49-79. Exclude—does not meet PCMH definition. [pmid: 10300655].
Moczygemba LR, Goode JV, Gatewood SB, et al. Integration of collaborative medication therapy management in a safety net patient-centered medical home. J Am Pharm Assoc (2003). 2011;51(2):167-72. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 21382806].
Mohiddin A, Naithani S, Robotham D, et al. Sharing specialist skills for diabetes in an inner city: a comparison of two primary care organisations over 4 years. J Eval Clin Pract. 2006;12(5):583-590. Exclude—population and/or setting is not eligible. [pmid: 16987121].
Montori VM. Review: interventions focusing on patient behaviors in provider-patient interactions improve diabetes outcomes. ACP J Club. 2004;140(2):51-51. Exclude—does not meet PCMH definition. [pmid: 15122871].
Moore J, West RM, Keen J, et al. Networks and governance: the case of intermediate care. Health Soc Care Community. 2007;15(2):155-64. Exclude—does not meet PCMH definition. [pmid: 17286677].
Moore LG, Wasson JH, Johnson DJ, et al. The emergence of Ideal Micro Practices for patient-centered, collaborative care. J Ambul Care Manage. 2006;29(3):215-21. Exclude—no relevant outcomes (Pt/Staff Experience; Process of Care; Clinical Outcomes; Economic Outcomes). [pmid: 16788354].
Moretti C, Kalucy E, Hordacre A, et al. South Australian Divisions of General Practice supporting diabetes care: insights from reporting data. Australian Journal of Primary Health. 2010;16(1):60-65. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 21133300].
Morishita L, Siu AL, Wang RT, et al. Comprehensive geriatric care in a day hospital: a demonstration of the British model in the United States. Gerontologist. 1989;29(3):336-40. Exclude—does not meet PCMH definition. [pmid: 2759455].
Morisky DE, Kominski GF, Afifi AA, et al. The effects of a disease management program on self-reported health behaviors and health outcomes: evidence from the “Florida: A Healthy State (FAHS)” Medicaid Program. Health Educ Behav. 2009;36(3):505-517. Exclude—does not meet PCMH definition. [pmid: 18292218].
Morrissey J, Calloway M, Johnsen M, et al. Service system performance and integration: a baseline profile of the ACCESS demonstration sites. Access to Community Care and Effective Services and Supports. Psychiatr Serv. 1997;48(3):374-80. Exclude—does not meet PCMH definition. [pmid: 9057241].
Murphy HR, Wadham C, Rayman G, et al. Integrating pediatric diabetes education into routine clinical care: the Families, Adolescents and Children's Teamwork Study (FACTS). Diabetes Care. 2006;29(5):1177-1177. Exclude—does not meet PCMH definition. [pmid: 16644662].
Murray C, Jolley G. Initiatives in primary health care: evaluation of a South Australian program. Aust Health Rev. 1999;22(3):155-61. Exclude—not original data. [pmid: 10662225].
Musich S, Chapman L. Status report on disease management efforts for the health promotion community. Am J Health Promot. 2006;20(3). suppl 1-9. Exclude—does not meet PCMH definition. [pmid: 16422143].
Myers J. Community children's nursing services in the 21st century. Paediatr Nurs. 2005;17(2):31-4. Exclude—does not meet PCMH definition. [pmid: 15793987].
Naar-King S, Ellis DA, Idalski A, et al. Multisystemic therapy decreases parental overestimation of adolescent responsibility for type 1 diabetes management in urban youth. Families, Systems & Health: The Journal of Collaborative Family HealthCare. 2007;25(2):178-189. Exclude—does not meet PCMH definition.
Nagykaldi ZJ, Chou AF, Aspy CB, et al. Engaging patients and clinicians through a wellness portal to improve the health of Oklahomans. J Okla State Med Assoc. 2010;103(10):498-501. Exclude—does not meet PCMH definition. [pmid: 21189828].
Naimoli JF, Rowe AK, Lyaghfouri A, et al. Effect of the Integrated Management of Childhood Illness strategy on health care quality in Morocco. Int J Qual Health Care. 2006;18(2):134-44. Exclude—does not meet PCMH definition. [pmid: 16423842].
Naylor MD, Sochalski JA. Scaling up: bringing the transitional care model into the mainstream. Issue Brief (Commonw Fund). 2010;103:1-12. Exclude—does not meet PCMH definition. [pmid: 21053533].
NCT01275378. Comparative Effectiveness Research for Two Medical Home Models for Attention Deficit Hyperactivity. Exclude—population and/or setting is not eligible.
Netting FE, Williams FG. Expanding the boundaries of primary care for elderly people. Health Soc Work. 2000;25(4):233-42. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 11103696].
Neumann A, Jahn R, Diehm C, et al. Presentation and medical management of peripheral arterial disease in general practice: rationale, aims, design and baseline results of the PACE-PAD Study. Journal of Public Health. (09431853). 2009;17(2):127-135. Corporate Author: Patient Care Evaluation-Peripheral Arterial Disease (PACE-PAD) Study Investigators. Exclude—does not meet PCMH definition.
Newcomer R, Harrington C, Kane R. Implementing the second generation social health maintenance organization. J Am Geriatr Soc. 2000;48(7):829-34. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 10894325].
Nicoll A, Mann N, Mann S, et al. The child health clinic: results of a new strategy of community care in a deprived area. Lancet. 1986;1(8481):606-8. Exclude—does not meet PCMH definition. [pmid: 2869314].
Nicollerat JA. Implications of the United Kingdom Prospective Diabetes Study (UKPDS) results on patient management. Association of American Diabetes Educators' symposium. Orlando, Florida. August 1999. Diabetes Educ. 2000:8-10. Exclude—does not meet PCMH definition.
Nikolaus T, Specht-Leible N, Bach M, et al. Effectiveness of hospital-based geriatric evaluation and management and home intervention team (GEM-HIT). Rationale and design of a 5-year randomized trial. Z Gerontol Geriatr. 1995;28(1):47-53. Exclude—does not meet PCMH definition. [pmid: 7773832].
Nine SL, Lakies CL, Jarrett HK, et al. Community-based chronic disease management program for African Americans. Outcomes Manag. 2003;7(3):106-12. Exclude—does not meet PCMH definition. [pmid: 12881971].
Nunez DE, Armbruster C, Phillips WT, et al. Community-based senior health promotion program using a collaborative practice model: the Escalante Health Partnerships. Public Health Nurs. 2003;20(1):25-32. Exclude—does not meet PCMH definition. [pmid: 12492822].
Oakley C, Moore D, Burford D, et al. The Montana model: integrated primary care and behavioral health in a family practice residency program. J Rural Health. 2005;21(4):351-4. Exclude—does not meet PCMH definition. [pmid: 16294659].
O'Connor ME, Spinks C, Mestas TA, et al. “Dyading” in the pediatric clinic improves access to care. Clin Pediatr (Phila). 2010;49(7):664-70. Exclude—does not meet PCMH definition. [pmid: 20356919].
Oddone EZ, Weinberger M, Giobbie-Hurder A, et al. Enhanced access to primary care for patients with congestive heart failure. Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. Eff Clin Pract. 1999;2(5):201-9. Exclude—does not meet PCMH definition. [pmid: 10623052].
Oelke ND, Cunning L, Andrews K, et al. Organizing care across the continuum: primary care, specialty services, acute and long-term care. Healthc Q. Spec No. 2009;13:75-9. Exclude—does not meet PCMH definition. [pmid: 20057254].
Ofman JJ, Badamgarav E, Henning JM, et al. Does disease management improve clinical and economic outcomes in patients with chronic diseases? A systematic review. Am J Med. 2004;117(3):182-92. Exclude—background (SR/MA). [pmid: 15300966].
Orr P, Hobgood A, Coberley S, et al. Improvement of LDL-C laboratory values achieved by participation in a cardiac or diabetes disease management program. Disease Management. 2006;9(6):360-370. Exclude—does not meet PCMH definition. [pmid: 17115883].
Ortolon K. Raising expectations. Tex Med. 2004;100(4):33-6. Exclude—does not meet PCMH definition. [pmid: 15303486].
Orzano AJ, McInerney CR, McDaniel RR Jr., et al. A medical home: value and implications of knowledge management. Health Care Manage Rev. 2009;34(3):224-33. Exclude—does not meet PCMH definition. [pmid: 19625827].
Osterweis M, Chickadonz G, Huntley RR, et al. HMO development for primary care team teaching of medical and nursing students. J Med Educ. 1980;55(9):743-50. Exclude—does not meet PCMH definition. [pmid: 7441690].
O'Toole TP, Buckel L, Bourgault C, et al. Applying the chronic care model to homeless veterans: effect of a population approach to primary care on utilization and clinical outcomes. Am J Public Health. 2010;100(12):2493-9. Exclude—population and/or setting is not eligible. [pmid: 20966377].
O'Toole TP, Cabral R, Blumen JM, et al. Building high functioning clinical teams through quality improvement initiatives. Qual Prim Care. 2011;19(1):13-22. Exclude—does not meet PCMH definition. [pmid: 21703108].
Ouwens M, Wollersheim H, Hermens R, et al. Integrated care programmes for chronically ill patients: a review of systematic reviews. Int J Qual Health Care. 2005;17(2):141-6. Exclude—not original data. [pmid: 15665066].
Oxman A, Treweek S. Does integration of primary healthcare services improve healthcare delivery and outcomes? A SUPPORT Summary of a systematic review. August. 2008. Available at: http://www.support-collaboration.org/summaries.htm. October 5, 2010. 2008. Exclude—not original data.
Oxman TE. Collaborative care may improve depression management in older adults. Evidence-Based Mental Health. 2003;6(3):86-86. Exclude—not original data. [pmid: 12893797].
Palmieri J, Redline S, Morita R. Goal attainment in patients referred to a telephone-based dyslipidemia program. Am J Health Syst Pharm. 2005;62(15):1586-1591. Exclude—does not meet PCMH definition. [pmid: 16030368].
Paradis PE, Nemis-White J, Meilleur M, et al. Icons. Managing care and costs: the sustained cost impact of reduced hospitalizations in a partnership-measurement model of disease management. Healthcare Quarterly. 2010;13(4):30-39. Corporate Author: Improving Cardiac Outcomes in Nova Scotia (ICONS) Investigators. Exclude—population and/or setting is not eligible. [pmid: 20523149].
Parchman ML, Pugh JA, Wang CP, et al. Glucose control, self-care behaviors, and the presence of the chronic care model in primary care clinics. Diabetes Care. 2007;30(11):2849-54. Exclude—does not meet PCMH definition. [pmid: 17682121].
Parette HP Jr., Bartlett CR, Holder-Brown L. The nurse's role in planning for inclusion of medically fragile and technology-dependent children in public school settings. Issues Compr Pediatr Nurs. 1994;17(2):61-72. Exclude—does not meet PCMH definition. [pmid: 7883603].
Pastel LC, Liu S, Homa K, et al. Bridges to excellence. Improving care for patients with diabetes at a rural primary care clinic by empowering licensed nursing assistants with a flow sheet tool. Clinical Diabetes. 2009;27(3):115-118. Exclude—population and/or setting is not eligible.
Patwari AK, Raina N. Integrated Management of Childhood Illness (IMCI): a robust strategy. Indian J Pediatr. 2002;69(1):41-8. Exclude—not high income country. [pmid: 11876120].
Pearson ML, Wu S, Schaefer J, et al. Assessing the implementation of the chronic care model in quality improvement collaboratives. Health Serv Res. 2005;40(4):978-96. Exclude—does not meet PCMH definition. [pmid: 16033488].
Pearson S, Inglis SC, McLennan SN, et al. Prolonged effects of a home-based intervention in patients with chronic illness. Arch Intern Med. 2006;166(6):645-50. Exclude—does not meet PCMH definition. [pmid: 16567604].
Penn CL. Special needs children need medical homes too. ACH seeing success with hospital-based outpatient medical home. J Ark Med Soc. 2010;106(9):200-3. Exclude—not original data. [pmid: 20337165].
Peters AS, Schnaidt KN, Seward SJ, et al. Teaching care management in a longitudinal primary care clerkship. Teach Learn Med. 2005;17(4):322-7. Exclude—does not meet PCMH definition. [pmid: 16197317].
Peterson ED. Patient-centered cardiac care for the elderly: TIME for reflection. JAMA: Journal of the American Medical Association. 2003;289(9):1157-1158. Exclude—does not meet PCMH definition.
Peterson KA, Radosevich DM, O'Connor PJ, et al. Improving Diabetes Care in Practice: findings from the TRANSLATE trial. Diabetes Care. 2008;31(12):2238-2243. Exclude—population and/or setting is not eligible. [pmid: 18809622].
Phelan EA, Balderson B, Levine M, et al. Delivering effective primary care to older adults: a randomized, controlled trial of the senior resource team at group health cooperative. J Am Geriatr Soc. 2007;55(11):1748-56. Exclude—does not meet PCMH definition. [pmid: 17979898].
Phillips P. Involving patients with type 2 diabetes, hypertension, and hyperlipidemia in disease management improved outcomes. ACP J Club. 2003;138(1):13-13. Exclude—does not meet PCMH definition. [pmid: 12511125].
Piatt GA, Anderson RM, Brooks MM, et al. 3-year follow-up of clinical and behavioral improvements following a multifaceted diabetes care intervention: results of a randomized controlled trial. Diabetes Educ. 2010;36(2):301-9. Exclude—does not meet PCMH definition. [pmid: 20200284].
Piatt GA, Orchard TJ, Emerson S, et al. Translating the chronic care model into the community: results from a randomized controlled trial of a multifaceted diabetes care intervention. Diabetes Care. 2006;29(4):811-7. Exclude—does not meet PCMH definition. [pmid: 16567820].
Piatt GA, Orchard TJ, Emerson S, et al. Translating the chronic care model into the community: results from a randomized controlled trial of a multifaceted diabetes care intervention. Diabetes Care. 2006;29(4):811-817. Exclude—population and/or setting is not eligible. [pmid: 16567820].
Piette JD, McPhee SJ, Weinberger M, et al. Use of automated telephone disease management calls in an ethnically diverse sample of low-income patients with diabetes. Diabetes Care. 1999;22(8):1302-1309. Exclude—does not meet PCMH definition. [pmid: 10480775].
Piette JD, Weinberger M, Kraemer FB, et al. Impact of automated calls with nurse follow-up on diabetes treatment outcomes in a Department of Veterans Affairs health care system: a randomized controlled trial. Diabetes Care. 2001;24(2):202-208. Exclude—does not meet PCMH definition. [pmid: 11213866].
Pimentel ML. Instituting a chronic care model for incarcerated male inmates with asthma. Commun Nurs Res. 2010;43:455-455. Exclude—population and/or setting is not eligible.
Pitty D, Reeves P, Rickards A. Protocol-directed shared care in cardiology. Stud Health Technol Inform. 1995;16:145-56. Exclude—does not meet PCMH definition. [pmid: 10163709].
Poenaru D, Roblin N, Bird M, et al. The Pediatric Bowel Management Clinic: initial results of a multidisciplinary approach to functional constipation in children. J Pediatr Surg. 1997;32(6):843-8. Exclude—does not meet PCMH definition. [pmid: 9200083].
Poon EG, Wald J, Schnipper JL, et al. Empowering patients to improve the quality of their care: design and implementation of a shared health maintenance module in a US integrated healthcare delivery network. Stud Health Technol Inform. 2007;129(Pt 2):1002-6. Exclude—does not meet PCMH definition. [pmid: 17911866].
Pope G, Wall N, Peters CM, et al. Specialist medication review does not benefit short-term outcomes and net costs in continuing-care patients. Age Ageing. 2011;40(3):307-12. Exclude – does not meet PCMH definition. [pmid: 20817937].
Poulton BC, West MA. Effective multidisciplinary teamwork in primary health care. J Adv Nurs. 1993;18(6):918-25. Exclude—does not meet PCMH definition. [pmid: 8320386].
Price CP, St John A. Managing diabetes in the community setting. Point of Care. 2006;5(2):52-57. Exclude—does not meet PCMH definition.
Pridham KA, Krolikowski MM, Limbo RK, et al. Guiding mothers' management of health problems of very low birth-weight infants. Public Health Nurs. 2006;23(3):205-215. Exclude—does not meet PCMH definition. [pmid: 16684198].
Pugh J, Lawrence V. A nurse-facilitator intervention improved the use of ss-blockers in outpatients with stable congestive heart failure. ACP J Club. 2004;140(1):22-22. Exclude—does not meet PCMH definition. [pmid: 14711293].
Pugh LC, Tringali RA, Boehmer J, et al. Partners in care: a model of collaboration. Holist Nurs Pract. 1999;13(2):61-5. Exclude—does not meet PCMH definition. [pmid: 10196904].
Pullen C, Edwards JB, Lenz CL, et al. A comprehensive primary health care delivery model. J Prof Nurs. 1994;10(4):201-8. Exclude—not original data. [pmid: 7930166].
Quinn DC, Graber AL, Elasy TA, et al. Overcoming turf battles: developing a pragmatic, collaborative model to improve glycemic control in patients with diabetes. Jt Comm J Qual Improv. 2001;27(5):255-64. Exclude—does not meet PCMH definition. [pmid: 11367773].
Racine AD, Stein RE, Belamarich PF, et al. Upstairs downstairs: vertical integration of a pediatric service. Pediatrics. 1998;102(1 Pt 1):91-7. Exclude—does not meet PCMH definition. [pmid: 9651419].
Ralston JD, Martin DP, Anderson ML, et al. Group Health Cooperative's transformation toward patient-centered access. Med Care Res Rev. 2009;66(6):703-24. Exclude—does not meet PCMH definition. [pmid: 19549993].
Ramalho de Oliveira D, Brummel AR, Miller DB. Medication therapy management: 10 years of experience in a large integrated health care system. J Manag Care Pharm. 2010;16(3):185-95. Exclude—does not meet PCMH definition. [pmid: 20331323].
Randolph F, Blasinsky M, Leginski W, et al. Creating integrated service systems for homeless persons with mental illness: the ACCESS Program. Access to Community Care and Effective Services and Supports. Psychiatr Serv. 1997;48(3):369-73. Exclude—does not meet PCMH definition. [pmid: 9057240].
Randolph G, Fried B, Loeding L, et al. Organizational characteristics and preventive service delivery in private practices: a peek inside the “black box” of private practices caring for children. Pediatrics. 2005;115(6):1704-1711. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 15930235].
Ratner D, Louria D, Sheffet A, et al. Wealth from Health: an incentive program for disease and population management: a 12-year project. Lippincotts Case Manag. 2001;6(5):184-204. Exclude—does not meet PCMH definition. [pmid: 16398037].
Reilly S, Graham-Jones S, Gaulton E, et al. Can a health advocate for homeless families reduce workload for the primary healthcare team? A controlled trial. Health Soc Care Community. 2004;12(1):63-74. Exclude—does not meet PCMH definition. [pmid: 14675366].
Reiss-Brennan B, Briot P, Cannon W, et al. Mental health integration: rethinking practitioner roles in the treatment of depression: the specialist, primary care physicians, and the practice nurse. Ethn Dis. 2006;16(2 Suppl 3):S3-37-43. Exclude—does not meet PCMH definition. [pmid: 16774022].
Reiss-Brennan B, Briot PC, Savitz LA, et al. Cost and quality impact of Intermountain's mental health integration program. J Healthc Manag. 2010;55(2):97-113. Exclude—population and/or setting is not eligible. [pmid: 20402366].
Renders CM, Valk GD, Griffin SJ, et al. Interventions to improve the management of diabetes mellitus in primary care, outpatient and community settings. Cochrane Database of Systematic Reviews. 2000;(4). Exclude—does not meet PCMH definition.
Retchin SM, Garland SL, Anum EA. The transfer of uninsured patients from academic to community primary care settings. Am J Manag Care. 2009;15(4):245-252. Exclude—does not meet PCMH definition. [pmid: 19355797].
Reuben DB. Organizational interventions to improve health outcomes of older persons. Med Care. 2002;40(5):416-28. Exclude—background (other). [pmid: 11961476].
Reuben DB, Hirsch SH, Chernoff JC, et al. Project Safety Net: a health screening outreach and assessment program. Gerontologist. 1993;33(4):557-60. Exclude—does not meet PCMH definition. [pmid: 8375687].
Reuben DB, Schnelle JF, Buchanan JL, et al. Primary care of long-stay nursing home residents: approaches of three health maintenance organizations. J Am Geriatr Soc. 1999;47(2):131-8. Exclude—does not meet PCMH definition. [pmid: 9988282].
Rich JD, Holmes L, Salas C, et al. Successful linkage of medical care and community services for HIV-positive offenders being released from prison. J Urban Health. 2001;78(2):279-89. Exclude—does not meet PCMH definition. [pmid: 11419581].
Richards DA, Lankshear AJ, Fletcher J, et al. Developing a U.K. protocol for collaborative care: a qualitative study. Gen Hosp Psychiatry. 2006;28(4):296-305. Exclude—does not meet PCMH definition. [pmid: 16814628].
Riegel B, Carlson B, Glaser D, et al. Randomized controlled trial of telephone case management in Hispanics of Mexican origin with heart failure. J Card Fail. 2006;12(3):211-219. Exclude—does not meet PCMH definition. [pmid: 16624687].
Rittenhouse DR. (PI). Transforming Primary Care Practice: Lessons From The New Orleans Safety-Net. Agency for Health Care Research and Quality (Funding Institution). 2010. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4).
Roberts F, Mitchell H. Tennessee Medical Home Project. J Tenn Med Assoc. 1990;83(8):406-7. Exclude—does not meet PCMH definition. [pmid: 2402148].
Roblin DW, Vogt TM, Fireman B. Primary health care teams. Opportunities and challenges in evaluation of service delivery innovations. J Ambul Care Manage. 2003;26(1):22-35. discussion 36-8. Exclude—does not meet PCMH definition. [pmid: 12545513].
Rodriguez E, Marquett R, Hinton L, et al. The impact of education on care practices: an exploratory study of the influence of “action plans” on the behavior of health professionals. Int Psychogeriatr. 2010;22(6):897-908. Exclude—does not meet PCMH definition. [pmid: 20594385].
Rogers A, Sheaff R. Formal and informal systems of primary healthcare in an integrated system: evidence from the United Kingdom. Healthc Pap. 2000;1(2):47-58. discussion 104-7. Exclude—does not meet PCMH definition. [pmid: 12811065].
Rollins G. Newly recognized PACE (Programs of All-Inclusive Care for the Elderly) programs benefit patients, providers, payers. Exec Solut Healthc Manag. 1999;2(6):13-6. Exclude—does not meet PCMH definition. [pmid: 10538254].
Rollins G. Coordinated care reduces functional declines in hospitalized elderly patients. Rep Med Guidel Outcomes Res. 2001;12(2):1-2. 5. Exclude—not original data. [pmid: 11767776].
Rosenman MB, Holmes AM, Ackermann RT, et al. The Indiana Chronic Disease Management Program. Milbank Q. 2006;84(1):135-63. Exclude—background (other). [pmid: 16529571].
Rosenthal J, Rodewald L, McCauley M, et al. Immunization coverage levels among 19- to 35-month-old children in 4 diverse, medically underserved areas of the United States. Pediatrics. 2004;113(4):e296-302. Exclude—does not meet PCMH definition. [pmid: 15060256].
Rossiter LF, Whitehurst-Cook MY, Small RE, et al. The impact of disease management on outcomes and cost of care: a study of low-income asthma patients. Inquiry. 2000;37(2):188-202. Exclude—does not meet PCMH definition. [pmid: 10985112].
Roth LM, Markova T, Monsur JC, et al. Effects of implementation of a team model on physician and staff perceptions of a clinic's organizational and learning environments. Fam Med. 2009;41(6):434-9. Exclude—does not meet PCMH definition. [pmid: 19492191].
Rothman RL, Malone R, Bryant B, et al. A randomized trial of a primary care-based disease management program to improve cardiovascular risk factors and glycated hemoglobin levels in patients with diabetes. Am J Med. 2005;118(3):276-84. Exclude—does not meet PCMH definition. [pmid: 15745726].
Roush K. Controlling hypertension in patients with diabetes. Am J Nurs. 2009;109(11):64-65. Exclude—does not meet PCMH definition.
Rubenfire M. [Commentary on]. The cost-effectiveness of a disease management programme for secondary prevention of coronary heart disease and heart failure in primary care. ACC Cardiosource Review Journal. 2008;17(6):24-24. Exclude—does not meet PCMH definition.
Rubenstein LZ, Abrass IB, Kane RL. Improved care for patients on a new geriatric evaluation unit. J Am Geriatr Soc. 1981;29(11):531-6. Exclude—does not meet PCMH definition. [pmid: 7299012].
Rubenstein LZ, Josephson KR, Wieland GD, et al. Effectiveness of a geriatric evaluation unit. A randomized clinical trial. N Engl J Med. 1984;311(26):1664-70. Exclude—does not meet PCMH definition. [pmid: 6390207].
Ruelas V, Roybal GM, Lu Y, et al. Clinical and behavioral correlates of achieving and maintaining glycemic targets in an underserved population with type 2 diabetes. Diabetes Care. 2009;32(1):54-56. Exclude—does not meet PCMH definition. [pmid: 18931097].
Ruggiero L, Moadsiri A, Butler P, et al. Supporting diabetes self-care in underserved populations: a randomized pilot study using medical assistant coaches. Diabetes Educ. 2010;36(1):127-131. Exclude—does not meet PCMH definition. [pmid: 20185612].
Rundall TG, Shortell SM, Wang MC, et al. As good as it gets? Chronic care management in nine leading US physician organisations. BMJ. 2002;325(7370):958-61. Exclude—does not meet PCMH definition. [pmid: 12399351].
Russell GM, Dahrouge S, Hogg W, et al. Managing chronic disease in ontario primary care: the impact of organizational factors. Ann Fam Med. 2009;7(4):309-18. Exclude—does not meet PCMH definition. [pmid: 19597168].
Ryan JW. An innovative approach to the medical management of the nursing home resident: the EverCare experience. Nurse Pract Forum. 1999;10(1):27-32. Exclude—does not meet PCMH definition. [pmid: 10542578].
San Agustin M, Sidel VW, Drosness DL, et al. A controlled clinical trial of “family care” compared with “child-only care” in the comprehensive primary care of children. Med Care. 1981;19(2):202-22. Exclude—does not meet PCMH definition. [pmid: 7010014].
Sankaran S, Kenealy T, Adair A, et al. A complex intervention to support ‘rest home’ care: a pilot study. N Z Med J. 2010;123(1308):41-53. Exclude—does not meet PCMH definition. [pmid: 20173804].
Sanoski CA. Update on dyslipidemia management: emerging CHD risk factors, new evidence and strategies… part 1 of 2. Formulary. 2001;36(6):438. Exclude—does not meet PCMH definition.
Savage M. Children with special needs—2: The Early Support Pilot Programme. J Fam Health Care. 2004;14(5):129-31. Exclude—does not meet PCMH definition. [pmid: 15598011].
Scanlon DP, Hollenbeak CS, Beich J, et al. Financial and clinical impact of team-based treatment for medicaid enrollees with diabetes in a federally qualified health center. Diabetes Care. 2008;31(11):2160-5. Exclude—population and/or setting is not eligible. [pmid: 18678609].
Schneir A, Kipke MD, Melchior LA, et al. Childrens Hospital Los Angeles: a model of integrated care for HIV-positive and very high-risk youth. J Adolesc Health. 1998;23(2 Suppl):59-70. Exclude—does not meet PCMH definition. [pmid: 9712254].
Schoen C, Osborn R, Huynh PT, et al. On the front lines of care: primary care doctors' office systems, experiences, and views in seven countries. Health Aff (Millwood). 2006;25(6):w555-71. Exclude—does not meet PCMH definition. [pmid: 17102164].
Schraeder C, Fraser C, Clark I, et al. The effect of primary care management on lipids testing and LDL-C control of elderly patients with comorbidities. Prof Case Manag. 2009;14(2):84-95. Exclude—does not meet PCMH definition. [pmid: 19318900].
Schultz PR, McGlone FB. Primary health care provided to the elderly by a nurse practitioner/physician team: analysis of cost effectiveness. J Am Geriatr Soc. 1977;25(10):443-6. Exclude—does not meet PCMH definition. [pmid: 409754].
Schwerner H, Mellody T, Goldstein AB, et al. Evaluating the impact of a disease management program for chronic complex conditions at two large northeast health plans using a control group methodology. Dis Manag. 2006;9(1):34-44. Exclude—does not meet PCMH definition. [pmid: 16466340].
Scisney-Matlock M, Makos G, Saunders T, et al. Comparison of quality-of-hypertension-care indicators for groups treated by physician versus groups treated by physician-nurse team. J Am Acad Nurse Pract. 2004;16(1):17-23. Exclude—does not meet PCMH definition. [pmid: 15008034].
Scott I, Harper C, Clough A, et al. WESTCOP: a disease management approach to coronary artery disease. Aust Health Rev. 2000;23(2):96-112. Exclude—does not meet PCMH definition. [pmid: 11010583].
Scott JC, Conner DA, Venohr I, et al. Effectiveness of a group outpatient visit model for chronically ill older health maintenance organization members: a 2-year randomized trial of the cooperative health care clinic. J Am Geriatr Soc. 2004;52(9):1463-70. Exclude—does not meet PCMH definition. [pmid: 15341547].
Seow H, Phillips CO, Rich MW, et al. Isolation of health services research from practice and policy: the example of chronic heart failure management. J Am Geriatr Soc. 2006;54(3):535-540. Exclude—does not meet PCMH definition. [pmid: 16551325].
Shafer D, Miller M. Research on coordinating care for patients with chronic conditions. Home Healthc Nurse. 2009;27(7):403-409. Journal Subset: Core Nursing. Exclude—not original data.
Shakur H. A COPD self management programme reduced hospital use and improved health status. Evidence-Based Nursing. 2003;6(4):111-111. Exclude—does not meet PCMH definition. [pmid: 14577393].
Shannon E. The devil is in the detail: lessons for multi-disciplinary care teams from a local evaluation of coordinated care. Aust Health Rev. 2002;25(2):87-94. Exclude—does not meet PCMH definition. [pmid: 12046159].
Sharma VK, Wilkinson G, Dowrick C, et al. Developing mental health services in a primary care setting: Liverpool Primary Care Mental Health Project. Int J Soc Psychiatry. 2001;47(4):16-29. Exclude—does not meet PCMH definition. [pmid: 11694055].
Shortell SM, Marsteller JA, Lin M, et al. The role of perceived team effectiveness in improving chronic illness care. Med Care. 2004;42(11):1040-8. Exclude—does not meet PCMH definition. [pmid: 15586830].
Sia CC, Iwaishi L, Taba S, et al. Learning to implement the medical home in communities. Hawaii Med J. 2000;59(1):15-9. Exclude—background (other). [pmid: 10740929].
Sidorov J, Gabbay R, Harris R, et al. Disease management for diabetes mellitus: impact on hemoglobin A1c. Am J Manag Care. 2000;6(11):1217-26. Exclude—does not meet PCMH definition. [pmid: 11185847].
Simeonsson NW, Lorimer MS. Transition planning in early intervention: nurse practitioner implications. J Pediatr Health Care. 1995;9(4):172-7. Exclude—does not meet PCMH definition. [pmid: 7629683].
Simon GE, Katon WJ, VonKorff M, et al. Cost-effectiveness of a collaborative care program for primary care patients with persistent depression. Am J Psychiatry. 2001;158(10):1638-44. Exclude—does not meet PCMH definition. [pmid: 11578996].
Sindhu S, Pholpet C, Puttapitukpol S. Meeting the challenges of chronic illness: a nurse-led collaborative community care program in Thailand. Collegian. 2010;17(2):93-99. Exclude—does not meet PCMH definition. [pmid: 20738062].
Sipila R, Ketola E, Tala T, et al. Facilitating as a guidelines implementation tool to target resources for high risk patients—the Helsinki Prevention Programme (HPP). J Interprof Care. 2008;22(1):31-44. Exclude—does not meet PCMH definition. [pmid: 18202984].
Slimmer L. A collaborative care management programme in a primary care setting was effective for older adults with late life depression. Evidence-Based Nursing. 2003;6(3):91-91. Exclude—does not meet PCMH definition. [pmid: 12882204].
Smith CS. The impact of an ambulatory firm system on quality and continuity of care. Med Care. 1995;33(3):221-6. Exclude—does not meet PCMH definition. [pmid: 7861824].
Smith KE, Levine BA, Clement SC, et al. Impact of MYCARETEAM for poorly controlled diabetes mellitus. Diabetes Technology & Therapeutics. 2004;6(6):828-835. Exclude—does not meet PCMH definition. [pmid: 15684636].
Smith MD, Smith SA. Pharmacist led, primary care based disease management reduced risk factors and improved glycaemic control in diabetes. Evidence-Based Medicine. 2005;10(5):154-154. Exclude—does not meet PCMH definition.
Smith SM, Allwright S, O'Dowd T. Effectiveness of shared care across the interface between primary and specialty care in chronic disease management. Cochrane Database Syst Rev. 2007;(3):CD004910. Exclude—background (SR/MA). [pmid: 17636778].
Sochalski J, Jaarsma T, Krumholz HM, et al. What works in chronic care management: the case of heart failure. Health Aff (Millwood). 2009;28(1):179-189. Exclude—does not meet PCMH definition. [pmid: 19124869].
Solberg LI, Crain AL, Sperl-Hillen JM, et al. Care quality and implementation of the chronic care model: a quantitative study. Ann Fam Med. 2006;4(4):310-6. Exclude—does not meet PCMH definition. [pmid: 16868234].
Sönnichsen AC, Rinnerberger A, Url MG, et al. Effectiveness of the Austrian disease-management-programme for type 2 diabetes: study protocol of a cluster-randomized controlled trial. Trials. 2008;9:38-38. Exclude—does not meet PCMH definition. [pmid: 18565213].
Sookaneknun P, Richards RME, Sanguansermsri J, et al. Pharmacist involvement in primary care improves hypertensive patient clinical outcomes. Ann Pharmacother. 2004;38(12):2023-2028. Exclude—does not meet PCMH definition. [pmid: 15522983].
Soran OZ, Pina IL, Lamas GA, et al. A randomized clinical trial of the clinical effects of enhanced heart failure monitoring using a computer-based telephonic monitoring system in older minorities and women. J Card Fail. 2008;14(9):711-717. Exclude—does not meet PCMH definition. [pmid: 18995174].
Sorrento TA, Casselman MB, Noonan J. A consultant pharmacist's role on a geriatric assessment service. Consult Pharm. 2007;22(11):935-43. Exclude—does not meet PCMH definition. [pmid: 18198980].
Spalek VH, Gong WC. Pharmaceutical care in an integrated health system. J Am Pharm Assoc (Wash). 1999;39(4):553-7. Exclude—does not meet PCMH definition. [pmid: 10467822].
Spar D, Macknin M. Use of letters and phone calls to encourage preparticipation Special Olympics physical examinations to be done in a medical home: a randomized, controlled trial. Clin Pediatr (Phila). 2001;40(12):685-687. Exclude—does not meet PCMH definition. [pmid: 11771924].
Sperl-Hillen J, O'Connor PJ, Carlson RR, et al. Improving diabetes care in a large health care system: an enhanced primary care approach. Jt Comm J Qual Improv. 2000;26(11):615-22. Exclude—does not meet PCMH definition. [pmid: 11098424].
St Clair D. Collaborative disease management: leveraging MCO data to improve patient outcomes. Health Manag Technol. 2005;26(7):28-30. Exclude—does not meet PCMH definition. [pmid: 16075479].
Stange KC, Miller WL, Nutting PA, et al. Context for understanding the National Demonstration Project and the patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S2-8. S92. Exclude—not original data. [pmid: 20530391].
Steed L, Lankester J, Barnard M, et al. Evaluation of the UCL Diabetes Self-Management Programme (UCL-DSMP): a randomized controlled trial. Journal of Health Psychology. 2005;10(2):261-276. Exclude—does not meet PCMH definition. [pmid: 15723895].
Steiner RM, Walsworth DT. Using quality experts from manufacturing to transform primary care. J Contin Educ Health Prof. 2010;30(2):95-105. Exclude—does not meet PCMH definition. [pmid: 20564711].
Steuten LMG, Bruijsten MWA, Vrijhoef HJM. Economic evaluation of a diabetes disease management programme with a central role for the diabetes nurse specialist. European Diabetes Nursing. 2007;4(2):64-71. Exclude—does not meet PCMH definition.
Stewart S. Review: multidisciplinary interventions reduce hospital admission and all cause mortality in heart failure. Evidence-Based Nursing. 2006;9(1):23-23. Exclude—not original data. [pmid: 16437805].
Stewart S, Marley JE, Horowitz JD. Effects of a multidisciplinary, home-based intervention on unplanned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. Lancet. 1999;354(9184):1077-1083. Exclude—does not meet PCMH definition. [pmid: 10509499].
Stille CJ, Frantz J, Vogel LC, et al. Building communication between professionals at children's specialty hospitals and the medical home. Clin Pediatr (Phila). 2009;48(6):661-73. Exclude—does not meet PCMH definition. [pmid: 19286621].
Strickland BB, Jones JR, Ghandour RM, et al. The medical home: health care access and impact for children and youth in the United States. Pediatrics. 2011;127(4):604-11. Exclude—does not meet PCMH definition. [pmid: 21402643].
Strickland PA, Hudson SV, Piasecki A, et al. Features of the Chronic Care Model (CCM) associated with behavioral counseling and diabetes care in community primary care. J Am Board Fam Med. 2010;23(3):295-305. Exclude—does not meet PCMH definition. [pmid: 20453175].
Stroebel RJ, Broers JK, Houle SK, et al. Improving hypertension control: a team approach in a primary care setting. Jt Comm J Qual Improv. 2000;26(11):623-32. Exclude—does not meet PCMH definition. [pmid: 11098425].
Stroebel RJ, Gloor B, Freytag S, et al. Adapting the chronic care model to treat chronic illness at a free medical clinic. J Health Care Poor Underserved. 2005;16(2):286-96. Exclude—population and/or setting is not eligible. [pmid: 15937392].
Strycker LA, Glasgow RE. Assessment and enhancement of social and community resources utilization for disease self-management. Health Promotion Practice. 2002;3(3):374-386. Exclude—does not meet PCMH definition.
Stuart M, Weinrich M. Integrated health system for chronic disease management: lessons learned from France. Chest. 2004;125(2):695-703. Exclude—not original data. [pmid: 14769754].
Styrborn K. Early discharge planning for elderly patients in acute hospitals—an intervention study. Scand J Soc Med. 1995;23(4):273-85. Exclude—does not meet PCMH definition. [pmid: 8919370].
Sunaert P, Bastiaens H, Feyen L, et al. Implementation of a program for type 2 diabetes based on the Chronic Care Model in a hospital-centered health care system: “the Belgian experience”. BMC Health Serv Res. 2009;9:152. Exclude—does not meet PCMH definition. [pmid: 19698185].
Swavely D, Merkle LN, Bub S, et al. A diabetes disease management model in the primary care setting. Journal of Clinical Outcomes Management. 2002;9(12):683-688. Exclude—does not meet PCMH definition.
Sweet MG. A patient-centered approach to chronic disease management. JAAPA. 2004;17(11):25-8. Exclude—not original data. [pmid: 15575520].
Tait AR. Clinical governance in primary care: a literature review. J Clin Nurs. 2004;13(6):723-30. Exclude—background (SR/MA). [pmid: 15317512].
Tallia AF, Stange KC, McDaniel RR Jr., et al. Understanding organizational designs of primary care practices. J Healthc Manag. 2003;48(1):45-59. discussion 60-1. Exclude—does not meet PCMH definition. [pmid: 12592868].
Tanios AT, Lyle RE, Casey PH. CH medical home program for special needs children. A new medical era. J Ark Med Soc. 2009;105(7):163-5. Exclude—does not meet PCMH definition. [pmid: 19170334].
Tataw DB, James F, Bazargan S. The Preventive Health Education and Medical Home Project: a predictive and contextual model for low-income families. Soc Work Public Health. 2009;24(6):491-510. Exclude—no relevant outcomes (Pt/Staff Experience; Process of Care; Clinical Outcomes; Economic Outcomes). [pmid: 19821189].
Tatman MA, Woodroffe C, Kelly PJ, et al. Paediatric home care in Tower Hamlets: a working partnership with parents. Qual Health Care. 1992;1(2):98-103. Exclude—does not meet PCMH definition. [pmid: 10136850].
Taveira TH, Friedmann PD, Cohen LB, et al. Pharmacist-led group medical appointment model in type 2 diabetes. Diabetes Educ. 2010;36(1):109-117. Exclude—does not meet PCMH definition. [pmid: 19966072].
Taylor CR, Hepworth JT, Buerhaus PI, et al. Effect of crew resource management on diabetes care and patient outcomes in an inner-city primary care clinic. Qual Saf Health Care. 2007;16(4):244-7. Exclude—does not meet PCMH definition. [pmid: 17693668].
Taylor J, Blue I, Misan G. Approach to sustainable primary health care service delivery for rural and remote South Australia. Aust J Rural Health. 2001;9(6):304-10. Exclude—does not meet PCMH definition. [pmid: 11998266].
Thomas P, While A. Increasing research capacity and changing the culture of primary care towards reflective inquiring practice: the experience of the West London Research Network (WeLReN). J Interprof Care. 2001;15(2):133-9. Exclude—does not meet PCMH definition. [pmid: 11705009].
Tien KJ, Hung HC, Hsiao JY, et al. Effectiveness of comprehensive diabetes care program in Taiwanese with type 2 diabetes. Diabetes Res Clin Pract. 2008;79(2):276-283. Exclude—population and/or setting is not eligible. [pmid: 17904243].
Tjam EY, Sherifali D, Steinacher N, et al. Physiological outcomes of an Internet disease management program vs. in-person counselling: a randomized, controlled trial. Canadian Journal of Diabetes. 2006;30(4):397-405. Exclude—does not meet PCMH definition.
Tobe SW, Wentworth J, Ironstand L, et al. DreamTel; diabetes risk evaluation and management tele-monitoring study protocol. BMC Endocrine Disorders. 2009;9:11p. Exclude—does not meet PCMH definition. [pmid: 19351411].
Toomey SL, Finkelstein J, Kuhlthau K. Does connection to primary care matter for children with attention-deficit/hyperactivity disorder?. Pediatrics. 2008;122(2):368-74. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 18676555].
Tourigny A, Durand P, Bonin L, et al. Quasi-experimental study of the effectiveness of an integrated service delivery network for the frail elderly. Can J Aging. 2004;23(3):231-46. Exclude—does not meet PCMH definition. [pmid: 15660297].
Trietsch J, Verstappen W, Janknegt R, et al. A cluster randomized controlled trial aimed at implementation of local quality improvement collaboratives to improve prescribing and test ordering performance of general practitioners: Study Protocol. Implementation Science. 2009;4:6-6. Exclude—does not meet PCMH definition. [pmid: 19222840].
Tsai AC, Morton SC, Mangione CM, et al. A meta-analysis of interventions to improve care for chronic illnesses. Am J Manag Care. 2005;11(8):478-88. Exclude—background (SR/MA). [pmid: 16095434].
Turnbull DA, Beilby JJ, Ziaian T, et al. Disease management for hypertension: a pilot cluster randomized trial of 67 Australian general practices. Disease Management & Health Outcomes. 2006;14(1):27-35. Exclude—population and/or setting is not eligible.
Turner JL. The longitudinal patient-centered experience. Acad Med. 2001;76(5):536-7. Exclude—does not meet PCMH definition. [pmid: 11346581].
Tzeng DS, Lian LC, Chang CU, et al. Healthcare in schizophrenia: effectiveness and progress of a redesigned care network. BMC Health Serv Res. 2007;7:129. Exclude—does not meet PCMH definition. [pmid: 17705853].
Unutzer J, Katon W, Williams JW Jr., et al. Improving primary care for depression in late life: the design of a multicenter randomized trial. Med Care. 2001;39(8):785-99. Exclude—does not meet PCMH definition. [pmid: 11468498].
van Uden CJ, Ament AJ, Voss GB, et al. Out-of-hours primary care. Implications of organisation on costs. BMC Fam Pract. 2006;7:29. Exclude—does not meet PCMH definition. [pmid: 16674814].
Venketasubramanian N, Ang YH, Chan BP, et al. Bridging the gap between primary and specialist care—an integrative model for stroke. Ann Acad Med Singapore. 2008;37(2):118-27. Exclude—does not meet PCMH definition. [pmid: 18327347].
Vera M, Perez-Pedrogo C, Huertas SE, et al. Collaborative care for depressed patients with chronic medical conditions: a randomized trial in Puerto Rico. Psychiatr Serv. 2010;61(2):144-50. Exclude—does not meet PCMH definition. [pmid: 20123819].
Versnel N, Welschen LM, Baan CA, et al. The effectiveness of case management for comorbid diabetes type 2 patients; the CasCo study. Design of a randomized controlled trial. BMC Fam Pract. 2011;12:68. Exclude—background (other). [pmid: 21729265].
Vines RF, Richards JC, Thomson DM, et al. Clinical psychology in general practice: a cohort study. Med J Aust. 2004;181(2):74-7. Exclude—does not meet PCMH definition. [pmid: 15257641].
Volkmann K, Castanares T. Clinical community health workers: linchpin of the medical home. J Ambul Care Manage. 2011;34(3):221-33. Exclude—study design (not a longitudinal evaluative study and not relevant to KQ4). [pmid: 21673521].
Von Korff M, Katon W, Unutzer J, et al. Improving depression care: barriers, solutions, and research needs. J Fam Pract. 2001;50(6):E1. Exclude—does not meet PCMH definition. [pmid: 11401751].
von Sternberg T, Hepburn K, Cibuzar P, et al. Post-hospital sub-acute care: an example of a managed care model. J Am Geriatr Soc. 1997;45(1):87-91. Exclude—does not meet PCMH definition. [pmid: 8994495].
Wagner EH, Glasgow RE, Davis C, et al. Quality improvement in chronic illness care: a collaborative approach. Jt Comm J Qual Improv. 2001;27(2):63-80. Exclude—does not meet PCMH definition. [pmid: 11221012].
Walker B, Haslett T. System dynamics and action research in aged care. Aust Health Rev. 2001;24(1):183-91. Exclude—does not meet PCMH definition. [pmid: 11357735].
Walker DR, Landis DL, Stern PM, et al. Disease management positively affects patient quality of life. Manag Care Interface. 2003;16(4):56-60. Exclude—does not meet PCMH definition. [pmid: 12747143].
Walker DR, Stern PM, Landis DL. Examining healthcare disparities in a disease management population. Am J Manag Care. 2004;10(2 Pt 1):81-8. Exclude—does not meet PCMH definition. [pmid: 15011808].
Want J, Kamas G, Nguyen TN. Disease management in the frail and elderly population: integration of physicians in the intervention. Dis Manag. 2008;11(1):23-8. Exclude—does not meet PCMH definition. [pmid: 18279111].
Warner S. The cost-effectiveness of a nursing demonstration project, Part II. Arch Psychiatr Nurs. 1993;7(2):61-7. Exclude—does not meet PCMH definition. [pmid: 8494402].
Warren JR, Beliakov GV, Noone JT, et al. Chronic disease coordinated care planning: flexible, task-centered decision support. Top Health Inf Manage. 1999;20(2):52-68. Exclude—does not meet PCMH definition. [pmid: 10662093].
Wasson JH, Ahles T, Johnson D, et al. Resource planning for patient-centered, collaborative care. J Ambul Care Manage. 2006;29(3):207-14. Exclude—does not meet PCMH definition. [pmid: 16788353].
Watts BV, Shiner B, Pomerantz A, et al. Outcomes of a quality improvement project integrating mental health into primary care. Qual Saf Health Care. 2007;16(5):378-81. Exclude—does not meet PCMH definition. [pmid: 17913780].
Weaver MR, Conover CJ, Proescholdbell RJ, et al. Cost-effectiveness analysis of integrated care for people with HIV, chronic mental illness and substance abuse disorders. J Ment Health Policy Econ. 2009;12(1):33-46. Exclude—does not meet PCMH definition. [pmid: 19346565].
Weinstein JN, Brown PW, Hanscom B, et al. Designing an ambulatory clinical practice for outcomes improvement: from vision to reality—the Spine Center at Dartmouth-Hitchcock, year one. Qual Manag Health Care. 2000;8(2):1-20. Exclude—does not meet PCMH definition. [pmid: 10787504].
Weir RC, Emerson HP, Tseng W, et al. Use of enabling services by Asian American, Native Hawaiian, and other Pacific Islander patients at 4 community health centers. Am J Public Health. 2010;100(11):2199-2205. Exclude—does not meet PCMH definition. [pmid: 20864726].
Weisner C, Mertens J, Parthasarathy S, et al. Integrating primary medical care with addiction treatment: a randomized controlled trial. JAMA. 2001;286(14):1715-23. Exclude—does not meet PCMH definition. [pmid: 11594896].
Wellingham J, Tracey J, Rea H, et al. The development and implementation of the Chronic Care Management Programme in Counties Manukau. N Z Med J. 2003;116(1169):U327. Exclude—does not meet PCMH definition. [pmid: 12601404].
Weng HC, Yuan BC, Su YT, et al. Effectiveness of a nurse-led management programme for paediatric asthma in Taiwan. J Paediatr Child Health. 2007;43(3):134-8. Exclude—does not meet PCMH definition. [pmid: 17316186].
Werry T, Burnett S, Parmar R, et al. The Combined Cardiac-Kidney-Diabetes Care clinic: an innovative approach to health care delivery. Can J Cardiovasc Nurs. 2006;16(2):28-28. Exclude—does not meet PCMH definition. [pmid: 16615262].
White RO, DeWalt DA, Malone RM, et al. Leveling the field: addressing health disparities through diabetes disease management. Am J Manag Care. 2010;16(1):42-48. Exclude—does not meet PCMH definition. [pmid: 20148604].
Wieland D. The effectiveness and costs of comprehensive geriatric evaluation and management. Crit Rev Oncol Hematol. 2003;48(2):227-37. Exclude—background (other). [pmid: 14607385].
Williams BC, Remington T, Foulk M. Teaching interdisciplinary geriatrics team care. Acad Med. 2002;77(9):935. Exclude—does not meet PCMH definition. [pmid: 12228107].
Williams GO. The elderly in family practice: an evaluation of the geriatric visiting nurse. J Fam Pract. 1977;5(3):369-73. Exclude—does not meet PCMH definition. [pmid: 903748].
Williams ME, Rabiner DJ, Hunter RH. The interdisciplinary geriatric team evaluation project. A new approach to the delivery of geriatric medicine in geographically remote locations. N C Med J. 1995;56(10):502-5. Exclude—does not meet PCMH definition. [pmid: 7477455].
Williams ME, Williams TF. Evaluation of older persons in the ambulatory setting. J Am Geriatr Soc. 1986;34(1):37-43. Exclude—does not meet PCMH definition. [pmid: 3941241].
Williams ME, Williams TF, Zimmer JG, et al. How does the team approach to outpatient geriatric evaluation compare with traditional care: a report of a randomized controlled trial. J Am Geriatr Soc. 1987;35(12):1071-8. Exclude—population and/or setting is not eligible. [pmid: 3119693].
Wilson T, Berwick DM, Cleary PD. What do collaborative improvement projects do? Experience from seven countries. Jt Comm J Qual Saf. 2003;29(2):85-93. Exclude—does not meet PCMH definition. [pmid: 12616923].
Windham BG, Bennett RG, Gottlieb S. Care management interventions for older patients with congestive heart failure. Am J Manag Care. 2003;9(6):447-59. quiz 460-1. Exclude—does not meet PCMH definition. [pmid: 12816174].
Wood D, Winterbauer N, Sloyer P, et al. A longitudinal study of a pediatric practice-based versus an agency-based model of care coordination for children and youth with special health care needs. Matern Child Health J. 2009;13(5):667-76. Exclude—does not meet PCMH definition. [pmid: 18766431].
Wood DL, McCaskill QE, Winterbauer N, et al. A multi-method assessment of satisfaction with services in the medical home by parents of children and youth with special health care needs (CYSHCN). Maternal & Child Health Journal. 2009;13(1):5-17. Exclude—background (other). [pmid: 18274884].
Woods ER, Samples CL, Melchiono MW, et al. Boston HAPPENS Program: a model of health care for HIV-positive, homeless, and at-risk youth. Human immunodeficiency virus (HIV) Adolescent Provider and Peer Education Network for Services. J Adolesc Health. 1998;23(2 Suppl):37-48. Exclude—does not meet PCMH definition. [pmid: 9712252].
Wooldridge DB, Parker G, MacKenzie PA. An acute inpatient geriatric assessment and treatment unit. Clin Geriatr Med. 1987;3(1):119-29. Exclude—does not meet PCMH definition. [pmid: 3815238].
Woolf SH, Glasgow RE, Krist A, et al. Putting it together: finding success in behavior change through integration of services. Ann Fam Med. Suppl 2. 2005;3:S20-7. Exclude—does not meet PCMH definition. [pmid: 16049077].
Woolfson LH. Using a model of transactional developmental regulation to evaluate the effectiveness of an early intervention programme for pre-school children with motor impairments. Child Care Health Dev. 1999;25(1):55-79. Exclude—does not meet PCMH definition. [pmid: 9921421].
Worth T. Taking diabetes care to the community. Am J Nurs. 2010;110(2):20-20. Exclude—does not meet PCMH definition.
Wysen KH, Hennessy PM, Lieberman MI, et al. Kids get care: integrating preventive dental and medical care using a public health case management model. J Dent Educ. 2004;68(5):522-30. Exclude—does not meet PCMH definition. [pmid: 15186069].
Yang W, Dall TM, Zhang Y, et al. Disease management 360 degrees: a scorecard approach to evaluating TRICARE's programs for asthma, congestive heart failure, and diabetes. Med Care. 2010;48(8):683-93. Exclude—does not meet PCMH definition. [pmid: 20613658].
Yehle KS. A comparison of standard office visits and shared medical appointments in adults with heart failure. Touro University International. 2007. Exclude—does not meet PCMH definition.
Yeo G, Ingram L, Skurnick J, et al. Effects of a geriatric clinic on functional health and well-being of elders. J Gerontol. 1987;42(3):252-8. Exclude—does not meet PCMH definition. [pmid: 3571860].
Yodfat Y. A new method of teamwork in family medicine in Israel with the participation of nurses as physician's assistants. Am J Public Health. 1972;62(7):953-6. Exclude—does not meet PCMH definition. [pmid: 4402670].
Young KR. An evaluative study of a community health service development. J Adv Nurs. 1994;19(1):58-65. Exclude—does not meet PCMH definition. [pmid: 8138630].
Zanetti ML, Otero LM, Peres DS, et al. Progess [sic] of the patients with diabetes mellitus who were managed with the staged diabetes management framework. Acta Paulista de Enfermagem. 2007;20(3):338-344. Exclude—does not meet PCMH definition.
Zatzick DF, Roy-Byrne P, Russo JE, et al. Collaborative interventions for physically injured trauma survivors: a pilot randomized effectiveness trial. Gen Hosp Psychiatry. 2001;23(3):114-23. Exclude—does not meet PCMH definition. [pmid: 11427243].
Zhang Y, Dai Y, Zhang S. Impact of implementation of Integrated Management of Childhood Illness on improvement of health system in China. J Paediatr Child Health. 2007;43(10):681-5. Exclude—does not meet PCMH definition. [pmid: 17854453].
Zhou YY, Unitan R, Wang JJ, et al. Improving population care with an integrated electronic panel support tool. Popul Health Manag. 2011;14(1):3-9. Exclude – does not meet PCMH definition. [pmid: 20658943].
Zimmer JG, Eggert GM, Chiverton P. Individual versus team case management in optimizing community care for chronically ill patients with dementia. J Aging Health. 1990;2(3):357-72. Exclude—does not meet PCMH definition. [pmid: 10170566].
Zuckerman S, Merrell K, Berenson R, et al. Incremental Cost Estimates for the Patient-Centered Medical Home. October. 2009. The Commonwealth Fund. Available at http://www.commonwealthfund.org/∼/media/Files/Publications/Fund%20Report/2009/Oct/1325_Zuckerman_Incremental_Cost_1019.pdf. September 21, 2010. Exclude—background (other).