# List of Included Studies (KQs 1–3)

The Table below lists all studies included for KQs 1–3, broken down into primary and secondary publications.

Table Included studies (KQs 1–3)

Primary Publication | Secondary Publications
KQs 1–3
Boult, 2008^1^ | Boult, 2011^2^ Boyd, 2010^3^ Leff, 2009^4^ Marsteller, 2010^5^ Wolff, 2009^6^ Wolff, 2010^7^
Boyd, 2007^8^ | Boyd, 2008^9^ Sylvia, 2008^10^
Domino, 2009^11^ | Mercer, 2008^12^ Steiner, 2008^13^
Dorr, 2008^14^ | Dorr, 2006^15^
Farmer, 2011^16^ | None
Hebert, 2003^17^ | None
Jaen, 2010^18^ | Crabtree, 2010^19^ Jaen, 2010^20^ Miller, 2010^21^ Nutting, 2009^22^ Nutting, 2010^23^ Nutting, 2010^24^ Stewart, 2010^25^
Martin, 2007^26^ | None
Reid, 2009^27^ | Coleman, 2010^28^ Reid, 2010^29^
Rubin, 1992^30^ | None
Schraeder, 2005^31^ | Peikes, 2009^32^
Sommers, 2000^33^ | None
Steele, 2010^34^ | Gilfillan, 2010^35^
Taplin, 1998^36^ | None
Toseland, 1997^37^ | Toseland, 1996^38^
Wise, 2006^39^ | None
Zuckerman, 2004^40^ | Minkovitz, 2003^41^ Minkovitz, 2007^42^
KQs 2–3 only
Chandler, 1997^43^ | None
Farmer, 2005^44^ | None
Farris, 2004^45^ | Dieleman, 2004^46^
Palfrey, 2004^47^ | Samuels, 2005^48^
Peleg, 2008^49^ | None
Rankin, 2009^50^ | None
Schifalacqua, 2000^51^ | None
Treadwell, 2009^52^ | None
Vedel, 2009^53^ | None
Waxmonsky, 2011^54^ | None

## References

1 Boult C, Reider L, Frey K, et al. Early effects of “Guided Care” on the quality of health care for multimorbid older persons: a cluster-randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2008;63(3):321-7. [pmid: 18375882].
2 Boult C, Reider L, Leff B, et al. The effect of guided care teams on the use of health services: results from a cluster-randomized controlled trial. Arch Intern Med. 2011;171(5):460-6. [pmid: 21403043].
3 Boyd CM, Reider L, Frey K, et al. The effects of guided care on the perceived quality of health care for multi-morbid older persons: 18-month outcomes from a cluster-randomized controlled trial. J Gen Intern Med. 2010;25(3):235-42. [pmid: 20033622].
4 Leff B, Reider L, Frick KD, et al. Guided care and the cost of complex healthcare: a preliminary report. Am J Manag Care. 2009;15(8):555-9. [pmid: 19670959].
5 Marsteller JA, Hsu YJ, Reider L, et al. Physician satisfaction with chronic care processes: a cluster-randomized trial of guided care. Ann Fam Med. 2010;8(4):308-15. [pmid: 20644185].
6 Wolff JL, Rand-Giovannetti E, Palmer S, et al. Caregiving and chronic care: the guided care program for families and friends. J Gerontol A Biol Sci Med Sci. 2009;64(7):785-91. [pmid: 19349586].
7 Wolff JL, Giovannetti ER, Boyd CM, et al. Effects of guided care on family caregivers. Gerontologist. 2010;50(4):459-70. [pmid: 19710354].
8 Boyd CM, Boult C, Shadmi E, et al. Guided care for multimorbid older adults. Gerontologist. 2007;47(5):697-704. [pmid: 17989412].
9 Boyd CM, Shadmi E, Conwell LJ, et al. A pilot test of the effect of guided care on the quality of primary care experiences for multimorbid older adults. J Gen Intern Med. 2008;23(5):536-42. [pmid: 18266045].
10 Sylvia ML, Griswold M, Dunbar L, et al. Guided care: cost and utilization outcomes in a pilot study. Dis Manag. 2008;11(1):29-36. [pmid: 18279112].
11 Domino ME, Humble C, Lawrence WW Jr., et al. Enhancing the medical homes model for children with asthma. Med Care. 2009;47(11):1113-20. [pmid: 19786921].
12 Mercer. Executive Summary, 2008 Community Care of North Carolina Evaluation. Available at: www.communitycarenc.com/PDFDocs/Mercer%20ABD%20Report%20SFY08.pdf. September 21, 2010.
13 Steiner BD, Denham AC, Ashkin E, et al. Community care of North Carolina: improving care through community health networks. Ann Fam Med. 2008;6(4):361-7. [pmid: 18626037].
14 Dorr DA, Wilcox AB, Brunker CP, et al. The effect of technology-supported, multidisease care management on the mortality and hospitalization of seniors. J Am Geriatr Soc. 2008;56(12):2195-202. [pmid: 19093919].
15 Dorr DA, Wilcox A, Burns L, et al. Implementing a multidisease chronic care model in primary care using people and technology. Dis Manag. 2006;9(1):1-15. [pmid: 16466338].
16 Farmer JE, Clark MJ, Drewel EH, et al. Consultative care coordination through the medical home for CSHCN: a randomized controlled trial. Matern Child Health J. Oct. 2011;15(7):1110-18. [pmid: 20721612].
17 Hebert R, Durand PJ, Dubuc N, et al. Frail elderly patients. New model for integrated service delivery. Can Fam Physician. 2003;49:992-7. [pmid: 12943358].
18 Jaen CR, Crabtree BF, Palmer RF, et al. Methods for evaluating practice change toward a patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S9-20. S92. [pmid: 20530398].
19 Crabtree BF, Nutting PA, Miller WL, et al. Summary of the National Demonstration Project and recommendations for the patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S80-90. S92. [pmid: 20530397].
20 Jaen CR, Ferrer RL, Miller WL, et al. Patient outcomes at 26 months in the patient-centered medical home National Demonstration Project. Ann Fam Med. Suppl 1. 2010;8:S57-67. S92. [pmid: 20530395].
21 Miller WL, Crabtree BF, Nutting PA, et al. Primary care practice development: a relationship-centered approach. Ann Fam Med. Suppl 1. 2010;8:S68-79. S92. [pmid: 20530396].
22 Nutting PA, Miller WL, Crabtree BF, et al. Initial lessons from the first national demonstration project on practice transformation to a patient-centered medical home. Ann Fam Med. 2009;7(3):254-60. [pmid: 19433844].
23 Nutting PA, Crabtree BF, Miller WL, et al. Journey to the patient-centered medical home: a qualitative analysis of the experiences of practices in the National Demonstration Project. Ann Fam Med. Suppl 1. 2010;8:S45-56. S92. [pmid: 20530394].
24 Nutting PA, Crabtree BF, Stewart EE, et al. Effect of facilitation on practice outcomes in the National Demonstration Project model of the patient-centered medical home. Ann Fam Med. Suppl 1. 2010;8:S33-44. S92. [pmid: 20530393].
25 Stewart EE, Nutting PA, Crabtree BF, et al. Implementing the patient-centered medical home: observation and description of the national demonstration project. Ann Fam Med. Suppl 1. 2010;8:S21-32. S92. [pmid: 20530392].
26 Martin AB, Crawford S, Probst JC, et al. Medical homes for children with special health care needs: a program evaluation. J Health Care Poor Underserved. 2007;18(4):916-30. [pmid: 17982215].
27 Reid RJ, Fishman PA, Yu O, et al. Patient-centered medical home demonstration: a prospective, quasi-experimental, before and after evaluation. Am J Manag Care. 2009;15(9):e71-87. [pmid: 19728768].
28 Coleman K, Reid RJ, Johnson E, et al. Implications of reassigning patients for the medical home: a case study. Ann Fam Med. 2010;8(6):493-8. [pmid: 21060118].
29 Reid RJ, Coleman K, Johnson EA, et al. The group health medical home at year two: cost savings, higher patient satisfaction, and less burnout for providers. Health Aff (Millwood). 2010;29(5):835-43. [pmid: 20439869].
30 Rubin CD, Sizemore MT, Loftis PA, et al. The effect of geriatric evaluation and management on Medicare reimbursement in a large public hospital: a randomized clinical trial. J Am Geriatr Soc. 1992;40(10):989-95. [pmid: 1401688].
31 Schraeder C, Dworak D, Stoll JF, et al. Managing elders with comorbidities. J Ambul Care Manage. 2005;28(3):201-9. [pmid: 15968212].
32 Peikes D, Chen A, Schore J, et al. Effects of care coordination on hospitalization, quality of care, and health care expenditures among Medicare beneficiaries: 15 randomized trials. JAMA. 2009;301(6):603-18. [pmid: 19211468].
33 Sommers LS, Marton KI, Barbaccia JC, et al. Physician, nurse, and social worker collaboration in primary care for chronically ill seniors. Arch Intern Med. 2000;160(12):1825-33. [pmid: 10871977].
34 Steele GD, Haynes JA, Davis DE, et al. How Geisinger's advanced medical home model argues the case for rapid-cycle innovation. Health Aff (Millwood). 2010;29(11):2047-53. [pmid: 21041747].
35 Gilfillan RJ, Tomcavage J, Rosenthal MB, et al. Value and the medical home: effects of transformed primary care. Am J Manag Care. 2010;16(8):607-14. [pmid: 20712394].
36 Taplin S, Galvin MS, Payne T, et al. Putting population-based care into practice: real option or rhetoric?. J Am Board Fam Pract. 1998;11(2):116-26. [pmid: 9542703].
37 Toseland RW, O'Donnell JC, Engelhardt JB, et al. Outpatient geriatric evaluation and management: is there an investment effect?. Gerontologist. 1997;37(3):324-32. [pmid: 9203756].
38 Toseland RW, O'Donnell JC, Engelhardt JB, et al. Outpatient geriatric evaluation and management. Results of a randomized trial. Med Care. 1996;34(6):624-40. [pmid: 8656727].
39 Wise CG, Bahl V, Mitchell R, et al. Population-based medical and disease management: an evaluation of cost and quality. Dis Manag. 2006;9(1):45-55. [pmid: 16466341].
40 Zuckerman B, Parker S, Kaplan-Sanoff M, et al. Healthy Steps: a case study of innovation in pediatric practice. Pediatrics. 2004;114(3):820-6. [pmid: 15342859].
41 Minkovitz CS, Hughart N, Strobino D, et al. A practice-based intervention to enhance quality of care in the first 3 years of life: the Healthy Steps for Young Children Program. JAMA. 2003;290(23):3081-91. [pmid: 14679271].
42 Minkovitz CS, Strobino D, Mistry KB, et al. Healthy Steps for Young Children: sustained results at 5.5 years. Pediatrics. 2007;120(3):e658-68. [pmid: 17766506].
43 Chandler C, Barriuso P, Rozenberg-Ben-Dror K, et al. Pharmacists on a primary care team at a Veterans Affairs medical center. Am J Health Syst Pharm. 1997;54(11):1280-7. [pmid: 9179348].
44 Farmer JE, Clark MJ, Sherman A, et al. Comprehensive primary care for children with special health care needs in rural areas. Pediatrics. 2005;116(3):649-56. [pmid: 16140704].
45 Farris KB, Cote I, Feeny D, et al. Enhancing primary care for complex patients. Demonstration project using multidisciplinary teams. Can Fam Physician. 2004;50:998-1003. [pmid: 15317232].
46 Dieleman SL, Farris KB, Feeny D, et al. Primary health care teams: team members' perceptions of the collaborative process. J Interprof Care. 2004;18(1):75-8. [pmid: 14668104].
47 Palfrey JS, Sofis LA, Davidson EJ, et al. The Pediatric Alliance for Coordinated Care: evaluation of a medical home model. Pediatrics. 2004;113(5 Suppl):1507-16. [pmid: 15121919].
48 Samuels RC, Liu J, Sofis LA, et al. Immunizations in children with special health care needs in a medical home model of care. Matern Child Health J. 2008;12(3):357-62. [pmid: 17578657].
49 Peleg R, Press Y, Asher M, et al. An intervention program to reduce the number of hospitalizations of elderly patients in a primary care clinic. BMC Health Serv Res. 2008;8:36. [pmid: 18254972].
50 Rankin KM, Cooper A, Sanabria K, et al. Illinois medical home project: pilot intervention and evaluation. Am J Med Qual. 2009;24(4):302-9. [pmid: 19515943].
51 Schifalacqua M, Hook M, O'Hearn P, et al. Coordinating the care of the chronically ill in a world of managed care. Nurs Adm Q. 2000;24(3):12-20. [pmid: 10986928].
52 Treadwell J, Bean G, Warner W. Supporting disease management through intervention in the medical home. Prof Case Manag. 2009;14(4):192-7. [pmid: 19625938].
53 Vedel I, De Stampa M, Bergman H, et al. A novel model of integrated care for the elderly: COPA Coordination of Professional Care for the Elderly. Aging Clin Exp Res. 2009;21(6):414-23. [pmid: 20154510].
54 Waxmonsky JA, Giese AA, McGinnis GF, et al. Colorado access' enhanced care management for high-cost, high-need Medicaid members: preliminary outcomes and lessons learned. J Ambul Care Manage. 2011;34(2):183-91. [pmid: 21415616].