# Exact Search Strings

The PubMed^®^ search strategies described below (updated search date December 6, 2011) were adapted for use in the Cumulative Index to Nursing & Allied Health Literature database (CINAHL^®^, search date March 30, 2011) and the Cochrane Database of Systematic Reviews (CDSR, search date March 30, 2011). Results from Searches A and B, described below, were combined to form the full citation set.

## PubMed^®^ search strategies

---------------------------------------------------------------------------------------------------------------------

### Search A (December 6, 2011)

1. “medical home” OR “health-care home” OR “advanced primary care” OR “guided care” OR “patient aligned care team” OR “pcmh[tiab]
2. Clinical[tiab] AND trial[tiab]
3. clinical trials[MeSH] OR clinical trial[PT] OR random*[tiab] OR random allocation[MeSH] OR “time points”[tiab]
4. “time series AND interrupt[tiab]
5. pretest[tiab] OR pre-test[tiab] OR posttest[tiab]
6. quasi-experiment*[tiab] OR quasiexperiment*[tiab] OR quasirandom*[tiab] OR quasirandom*[tiab] OR quasi-control*[tiab] OR quasicontrol*[tiab]
7. cluster[tiab] AND trial[tiab]
8. (study[tiab] AND continuing[tiab] OR follow-up[tiab] OR longitudinal[tiab] OR demonstration[tiab] OR intervention[tiab])
9. treatment outcome[MeSH] OR multicenter study[PT] OR comparative study[PT] OR clinical trial OR comparative[tiab] OR comparison[tiab] OR matched[tiab] OR “Evaluation Studies as Topic”[MeSH:noexp] OR ““Program Evaluation”[MeSH] OR “Validation Studies as Topic”[MeSH] OR “Multicenter Studies as Topic”[MeSH] OR “Controlled Clinical Trials as Topic”[MeSH:noexp] OR “evaluation studies”[PT]
10. #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9
11. #1 AND #10

Limits:

Language: English

Not: Editorial, Letter, Practice Guideline

### Search B (December 6, 2011)

1. “Patient-Centered Care”[MeSH] OR “Delivery of Health Care, Integrated”[MeSH] OR “Patient Care Team”[MeSH:noexp] OR “chronic care model” or “system redesign” OR “systems redesign” OR “disease management”[mh] OR “patient care management”[MeSH:noexp] OR collaboratives
2. “Primary Health Care”[Mesh:noexp] OR “family practice”[mesh] OR “internal medicine”[Mesh] OR “physicians, family”[mesh] OR geriatrics[Mesh] OR “primary care”[tiab] OR chronic disease[mh] OR “ambulatory Care”[Mesh] OR “Health Services for the Aged”[MeSH] OR “Community networks”[mesh] OR “pediatrics”[Mesh] OR “Child Health Services”[Mesh] OR “Health Care Coalitions”[Mesh] OR (child*[tiab] AND special[tiab] AND health*[tiab]) OR “diabetes mellitus”[Mesh] OR “diabetes mellitus”[tiab] OR “depressive disorder”[Mesh] OR “major depression”[tiab] OR “heart failure”[Mesh] OR “heart failure”[tiab] OR “coronary disease”[Mesh] OR “angina pectoris”[Mesh:noexp] OR hypertension[Mesh] OR hypertension[tiab] OR hyperlipidemias[Mesh] OR hyperlipidemia[tiab]
3. clinical[tiab] AND trial[tiab]) OR clinical trials[MeSH] OR clinical trial[PT] OR random*[tiab] OR random allocation[MeSH] OR “time points”[tiab] OR (“time series” AND interrupt[tiab]) OR pretest[tiab] OR pre-test[tiab] OR post-test[tiab] OR posttest[tiab]
4. quasi-experiment*[tiab] OR quasiexperiment*[tiab] OR quasirandom*[tiab] OR quasirandom*[tiab] OR quasi-control*[tiab] OR quasicontrol*[tiab]
5. (cluster[tiab] AND trial[tiab]) OR (study[tiab] AND continuing[tiab] OR follow-up[tiab] OR longitudinal[tiab] OR demonstration[tiab] OR intervention[tiab])
6. treatment outcome[Mesh] OR multicenter study[pt] OR comparative study[pt] OR clinical trial OR comparative[tiab] OR comparison[tiab] OR matched[tiab] OR “Evaluation Studies as Topic”[Mesh:noexp] OR “Program Evaluation”[Mesh] OR “Validation Studies as Topic”[Mesh] OR “Multicenter Studies as Topic”[Mesh] OR “Controlled Clinical Trials as Topic”[Mesh:noexp] OR “evaluation studies”[pt]
7. #3 OR #4 OR #5 OR #6
8. #1 AND #2 AND #7

Limits:

Language: English

Not: Editorial, Letter, Practice Guideline

Not: Citations from Search A