# Abbreviations

AAFP NDP: American Academy of Family Physicians National Demonstration Project
ACP: American College of Physicians
AHRQ: Agency for Healthcare Research and Quality
CCM: chronic care model
CDC: Centers for Disease Control and Prevention
CDSR: Cochrane Database of Systematic Reviews
CI: confidence interval
CINAHL: Cumulative Index to Nursing & Allied Health Literature
CMS: Centers for Medicare & Medicaid Services
CRICC: Colorado Regional Integrated Care Collaborative
EHR: electronic health record
EPC: Evidence-based Practice Center
EPOC: Cochrane Effective Practice and Organisation of Care Review Group
HbA1c: glycated hemoglobin
HEDIS: Healthcare Effectiveness Data and Information Set
HMO: health maintenance organization
HRSA: Health Resources and Services Administration
HSR&D: Health Services Research & Development Service
HSRProj: Health Services Research Projects in Progress
IOM: Institute of Medicine
MD: medical doctor
MeSH: medical subject headings
NASHP: National Academy for State Health Policy
NCQA: National Committee for Quality Assurance
NIDDK: National Institute of Diabetes and Digestive and Kidney Diseases
NIH: National Institutes of Health
NIMH: National Institute of Mental Health
NP: nurse practitioner
NR: not reported
OR: odds ratio
P4P: pay for performance
PA: physician's assistant
PACT: Patient Aligned Care Team
PCMH: patient-centered medical home
PCP: primary care provider
PCPCC: Patient-Centered Primary Care Collaborative
PDSA: Plan-Do-Study-Act
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, Settings
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QI: quality improvement
RN: registered nurse
RWJ: Robert Wood Johnson Foundation
SD: standard deviation
SMD: standardized mean difference
SOE: strength of evidence
TCHP: Texas Children's Health Plan
TEP: Technical Expert Panel
USPSTF: U.S. Preventive Services Task Force
VA: United States Department of Veterans Affairs