# Summary and Discussion

We reviewed 58 studies that evaluated the effects of 19 bundled payment programs on spending and quality of care. We also analyzed four reviews of the Medicare Inpatient Prospective Payment System. Despite the fairly broad inclusion criteria used to identify studies for this review, the majority of published studies we retrieved focused on Medicare post-acute care prospective payment systems (40 studies) and various international programs of bundled payment (9 studies). Most of the bundled payment interventions included in these studies applied to single institutional providers such as inpatient hospitals, skilled nursing facilities, and home health care agencies. The bundle definitions and payment methods varied substantially. Despite the heterogeneity of settings, interventions, study designs, and measures used, reviewers noted highly consistent evidence of impacts of bundled payment on spending and utilization relative to usual, predominantly fee-for-service payment (Key Question 1) but inconsistent evidence of impacts on quality measures. No studies explicitly included analyses of differential impacts by key design feature (Key Question 2). Some studies reported on differential impacts by key contextual factors, but this evidence was limited to a small number of key contextual factors (Key Question 3). We did not attempt to address Key Questions 2 and 3 by collating the evidence across studies interventions because these analyses would be limited by the heterogeneity of the interventions and evaluation methods.

In this chapter, we first summarize the evidence for each Key Question across payment systems and assess the strength of the evidence. These summaries are supplemented by a table summarizing the strength of evidence for each Key Question and study outcome (Appendix D) and evidence tables summarizing data abstracted from each study (Appendix A). We then conclude with a discussion of the applicability of the reviewed studies for policymakers, payers, and providers considering implementation of a bundled payment system, recommendations for further research, and key points for policymakers.

## Key Question 1 Impact of Bundled Payment on Health Care Spending and Quality Measures

### Summary of Findings Across Payment Systems

The published evidence suggests that transitioning from cost-based or fee-for-service to bundled payment reimbursement resulted in declines in spending and utilization with small and inconsistently signed changes in individual quality metrics. The transition from a cost-based or fee-for-service reimbursement to bundled payment was generally associated with a decline in spending of 10 percent or less. This result was generally observed for varying interventions and settings. However, the magnitude of the decline was dependent on how payment rates were determined in bundled payment systems. Some programs were designed to be budget neutral. Others, such as the Medicare Participating Heart Bypass Demonstration, were designed to include a discount over previous payment rates.

Across the programs, the published evidence suggests that bundled payment was associated with a decrease in utilization and costs of services included in the bundle, often measured as reductions in length of stay or utilization of specific services (between five percent and 15 percent reductions in many cases). For example, the Medicare IPPS was associated with a 20 to 25 percent decline in length of stay and a similar decline in hospital days per beneficiary in the first few years after its implementation.19 The Department of Veterans Affairs Resource Allocation Methodology was associated with smaller but consistent length of stay reductions across various types of hospital stays (about five percent reductions for medical, surgical, and psychiatric patients).60

Finally, the body of published evidence provides little evidence that bundled payment (and the associated cost reductions) had major effects on quality. Studies found inconsistent effects; the inconsistency in findings on quality measures included both differences in the direction and magnitude of effects on different quality measures within a single study and differences in the direction and magnitude of effects for similar quality measures between studies. For a given bundled payment intervention, either some quality measures improved while others worsened, or studies of the same intervention arrived at different conclusions about the effect of bundled payment on related quality measures. For example, the Medicare IPPS did not have a negative effect on mortality, but was found to adversely affect selected quality measures, such as patient stability at discharge. For Medicare post-acute care in IRFs, functional improvement declined slightly post-PPS in four studies, improved slightly in two studies, and was not found to significantly differ from pre-PPS levels in two studies. Two studies reported very small increases in SNF deficiencies reported to CMS post-PPS. While two Medicare post-acute care studies found that patients were less likely to be discharged to the community post-PPS, three other studies found no significant difference in discharge before and after PPS implementation. The availability of quality measures has increased over the time period of the reviewed studies. However, given the number and variety of quality measures used in reviewed studies, it is unlikely that the overall quality effect is mainly a result of limitations of available measures.

There was limited evidence available on other types of potential negative effects of bundled payment programs such as unbundling and upcoding. There was consistent evidence from multiple studies of different programs that bundled payment programs focusing on single provider types resulted in shifts of services to other provider types (e.g., shift from inpatient to outpatient care following the Medicare IPPS). Some studies reported that measures of patient risk increased following bundled payment, although no studies tested whether this was a result of changes in coding practices (upcoding) or actual changes in patient risk.

### Strength of Evidence

Overall reviewers graded the evidence for this Key Question as “low,” indicating a low level confidence that the evidence reflects the true effect, and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. The ratings and specific criteria that form the basis for this assessment of strength of evidence are shown in Appendix D and discussed below.

All included studies were observational or descriptive. Only two of the 58 reviewed studies were rated as “good” methodologically, and 19 were rated “poor.” We did not exclude any studies based on their quality rating. However, we determined that our conclusions are not sensitive to the inclusion of “poor” studies.

Many studies used a pre-post design and may have been subject to bias from secular trends. Other studies employed small, often non-random samples and may have been subject to selection bias. Residual confounding may have affected the results of most or all of the included studies, but due to the large number of potential confounders, it is impossible to estimate whether confounding would be expected to reduce or increase the magnitude of observed effects. Most reported magnitudes were large enough to be economically or clinically important but small enough to raise the possibility that they were caused by confounders.

The results of included studies were consistent in the direction of the effect for cost and utilization measures, but inconsistent for quality measures. Based on the consistency of findings across heterogeneous interventions and evaluations, it is likely that the direction of the observed effects on cost and utilization measures would not change in future studies, although the magnitude of the effect could change. It is possible that the studied interventions may have been designed cautiously in order to encourage participation and avoid adverse effects.

The directness of the link between the bundled payment interventions and study outcomes was also stronger for spending and utilization measures than for quality measures. Many of the quality measures used were process or intermediate health outcome measures and therefore the effects were indirectly related to health outcomes. The reviewed studies used a limited number of quality measures that in general were selected based on availability rather than because they represented the aspects of quality most likely to be impacted by bundled payment.

## Key Question 2 Differential Effects by Key Design Features

### Summary of Findings Across Payment Systems

No studies explicitly tested the differential effect of key intervention design features on spending or quality measures. We did not perform comparisons of design feature impacts across studies because of the heterogeneity of the bundled payment programs studied and evaluation designs.

### Strength of Evidence

Reviewers graded the evidence for this Key Question as insufficient to permit an estimation of effects due to the lack of evidence.

### Description of Key Design Features

Below, we describe the key design features of the bundled payment programs reviewed and how these design features varied across programs. We provide some discussion of the potential impact of design features on study outcomes, but as previously stated we do not perform direct comparisons across studies.

Reviewed payment systems differed in the degree to which the bundled payment applied to multiple providers and/or providers of different types. In several of the international bundled payment applications this information either was not provided or was implicit as payments to providers (e.g., physicians and hospitals) were integrated prior to bundled payment. In the United States, however, physicians and hospitals are reimbursed separately by Medicare and other payers. Only the two reviewed Medicare demonstrations, the Geisinger ProvenCare(SM) program, and the Michigan Arthroscopic Surgery Bundling pilot integrated physician payments with hospital payments where these payments were previously separate. Studies of these programs found evidence for reduced costs with inconsistent effects on different quality measures. However, there was limited basis for a comparison of the magnitude of these findings to those of studies of bundled payment interventions that apply to a single setting.

The reviewed bundled payment interventions employed a variety of bundle definitions that were tailored to the relevant care setting. Most bundled payment systems defined the services included in bundles as those related to treatment for specific diagnoses (e.g., diagnosis-related groups; see Table 2). The Belgian non-medical inpatient PPS and the Medicare SNF PPS used a per diem unit of payment which may be appropriate when length of stay is highly variable. While this bundle definition does not constrain utilization in terms of length of stay, it does affect incentives to provide services in a given day, and studies on both systems reported either declining or steady length of stay post-PPS.

In the evaluated programs, quality metrics or incentives were rarely integrated into bundled payment systems. Despite the potential for undesired effects of bundled payment on quality of care (as discussed in the introduction), programs generally did not include quality as an intrinsic part of the bundled payment mechanism. Among the programs reviewed, only the Geisinger ProvenCare(SM) program integrated pay-for-performance components into a bundled payment system, and therefore no differential effects across evaluations can be reported for this design feature. It is possible that inclusion of quality-related incentives as a component of future bundled payment programs will change providers' response to the program in a way that impacts quality measures, but the effect is unknown at this time. Other programs used quality measurement in program monitoring and evaluation or as a criterion for program participation but not as a component of the payment method.

Many of the bundled payment programs studied were implemented prior to the recent proliferation of pay-for-performance programs. The science of health care quality measurement and quality incentives has developed since many of the programs were implemented. In some cases, the bundled payment programs reviewed subsequently will be accompanied by a separate pay-for-performance program that addresses the same providers and services. For example, Medicare has a quality pay-for-reporting program, and the Affordable Care Act of 2010 mandates a Medicare hospital value-based purchasing program that will add quality-related incentive payments to the Medicare Inpatient Prospective Payment system, as well as a hospital payment adjustment based on readmission rates. It is unclear how these pay-for-performance programs will interact with the bundled payment programs studied, or the differential impact on quality of including the quality-related incentives as an integrated part of bundled payment or as a standalone program. Among more recent bundled payment programs that have been announced or initiated but not yet evaluated, some use quality measurement in a monitoring and evaluation role (e.g., Medicare Bundled Payments for Care Improvement initiative) while others incorporate pay-for-performance with the bundled payment (e.g., PROMETHEUS Payment).

Some of the reviewed payment systems blended bundled payment and fee-for-service reimbursement. Retaining some facets of fee-for-service may diminish the impact of bundled payment on spending or quality improvement. For example, scaling bundled payment reimbursement rates with utilization presents providers an opportunity to increase revenue by providing additional care. Three of the four Medicare post-acute care prospective payment systems included bundled payment rates which are partially determined by the services provided. The evidence suggests providers increased utilization of services that increase reimbursement rates in blended payment systems while at the same time decreasing utilization of other services and overall length of stay. For example, in the Medicare SNF PPS, the reimbursement rate increased for patients with additional rehabilitation therapy time. Three studies reported the number of rehabilitation therapy minutes increased post-PPS.25,33,36 One study in particular looked at the issue of SNF rehabilitation therapy time in detail and found SNFs not only increased utilization of rehabilitation therapy minutes, but also increased the probability (by 12 percent) of providing a “nodal” amount of rehabilitation therapy which would qualify a patient for higher reimbursement.36 In the Medicare HH PPS, reimbursement was higher when home health agencies provided more therapy visits per episode. While the reviewed studies suggested aggregate home health visits per episode (including aide, therapy, and other visits) declined post-PPS, one study reporting visits by type found an eight percent increase in home health therapy visits per episode post-PPS compared to decreases in the number of aide and nursing visits post-PPS (all p<0.001).58 The Medicare LTACH PPS payment rates also varied with services provided, but the one reviewed study on this payment system did not report utilization outcomes.

The use of risk adjustment and outlier payments to account for patient risk in bundled payment programs differed between the reviewed payment systems. Separate outlier payments were common in bundled payment programs, both for high-cost patients and occasionally for low-cost patients (as in the Medicare post-acute care systems where short-stay patients are reimbursed separately). Risk adjustment approaches were not always well described in international applications of bundled payment. For domestic public applications (namely the Medicare prospective payment systems), the specific approach to risk adjustment was setting-specific. The reviewed studies did not address the effect of outlier or risk adjustment methods on study outcomes.

Reviewed payment systems differed in their approach to establish the initial bundle reimbursement rate. Historical expenditures were typically used to determine the initial bundled payment rates, but programs differed in whether the bundled payment rate was set at an amount estimated to increase, decrease, or maintain historical expenditure levels. The Medicare Inpatient PPS is an example of a program where payment rates were relatively generous in the first years post-implementation. This may have had the effect of mitigating potential adverse impacts on quality in response to the new payment system. At the same time generous initial payments may mitigate the impact of bundled payment on reductions in spending.

The two reviewed Medicare demonstration programs (Participating Heart Bypass and Cataract Alternative Payment demonstrations) are examples of programs where initial bundled payment rates were set at a level lower than historical expenditure. The payment rates were determined by negotiation between Medicare and participating providers, who were selected for participation in the demonstrations based in part on the level of discount over historical expenditure offered to Medicare. In the Medicare Participating Heart Bypass Demonstration, Medicare reduced spending for bundled and non-bundled services from admission through 90 days post-discharge by about ten percent at the seven demonstration sites. Eighty-six percent of this decline was due to the negotiated bundled payment rate between Medicare and the hospital while five percent was from lower post-discharge spending (which was excluded from the bundle) and nine percent was due to shifts in market share towards lower-cost demonstration hospitals. The effect on spending would likely be much lower in a similar bundled payment program with prices set at levels designed to be budget-neutral compared to historical spending. The effect on spending would also likely be lower if hospitals participating in the demonstration were not selected in part on their ability to negotiate low payment rates.

Some bundled payment interventions were implemented in the context of other simultaneous health care spending reduction efforts separate from the bundled payment intervention. The Medicare SNF PPS, for example, was estimated by the Congressional Budget Office to cut SNF spending by almost $10 billion over five years. Reviewed studies provided little evidence on the aggregate impact of the SNF PPS on spending, but one study34 suggested a decline in the use of any SNF services by beneficiaries was responsible for decreased spending per hospital stay. In another post-acute care setting, the Medicare Home Health PPS was preceded by an Interim Payment System which imposed limits on per-visit and per-beneficiary reimbursement and dramatically curtailed Medicare home health expenditures and utilization (total expenditures fell from $16 billion in 1997 to less than $8 billion in 1999 and utilization dropped by about 25 percent over the same period).80 Viewed in this context, the increase in home health spending post-PPS reported in one study57 appears more as a reaction to previous dramatic declines in home health spending rather than an effect attributable to the switch to bundled payment. Other bundled payment interventions were combined with very modest anticipated spending cuts (e.g., a four percent decline in Japan outpatient dialysis spending) or were loosely motivated by health care cost control efforts. No differential effects were observed for these bundled payment interventions.

The design of bundled payment programs affects the costs of payment administration, including costs to both providers and payers. More complex bundled payment designs are likely to incur higher administration costs. The two reviewed Medicare demonstrations, which included bundles applying to multiple providers and provider types, did report some difficulty in administration of the bundled payment programs, in part due to challenges of distributing payment among the multiple providers participating in the bundled payment.75,76 Several other studies reported increases in administrative costs related to bundled payment, but no study reported differential impacts by design feature.40,56,61

Finally, payment systems differed in implementation strategy, with some systems undergoing a lengthy phase-in period and others immediately supplanting the previous payment system. Three of the four Medicare post-acute care prospective payment systems included phase-in periods. Under the IRF PPS, some facilities had the option to blend the previous cost-based and bundled payment rates for one year. Under the SNF PPS, all SNFs blended cost-based and PPS rates for three years. For the LTACH PPS, hospitals chose either a five year phase-in program or switched to PPS immediately. The HH PPS did not have a phase-in period but instead followed an Interim Payment System which imposed additional controls and caps on the previous cost-based payment system. While gradual phase-in introduces challenges for evaluators, they may be warranted given providers' reported difficulty adjusting administrative staffing, finances, and provider relationships to new reimbursement regimes.29,35,40,59,75 Interestingly, there appears that there were some selection effects at work where facilities had an option to phase-in a new payment system. The study of the Medicare LTACH PPS59 reported facilities choosing to immediately adopt the PPS hired additional nursing staff (the opposite effect was hypothesized), perhaps because early adopters outperformed competitors.

Several reviewed studies either directly studied the implementation process of one or more bundled payment systems or included implementation-related anecdotes. Most studies providing survey or anecdotal evidence from providers noted new bundled payment systems faced significant initial resistance from providers/facilities.

## Key Question 3 Differential Effects by Key Contextual Factors

### Summary of Findings Across Payment Systems

Based on the conceptual model presented in Figure 1, we aimed to address differential effects by key contextual factors including predisposing factors (general financial environment, other incentives, charters and missions of participating organizations, market characteristics, etc.) and enabling factors (capabilities and goals of participating organizations, degree of integration of participating organizations, staffing factors, and patient factors). The effects of most of these contextual factors were not addressed by any studies.

Some studies reported outcomes separately for patients and facilities of different characteristics, although results from appropriate statistical tests to compare these results were rarely included. The most striking of these comparisons involved for-profit versus not-for-profit providers. In general, for-profit providers experienced larger declines in utilization under bundled payment than their not-for-profit counterparts (including U.S. and ex-U.S. hospitals, skilled nursing facilities, inpatient rehabilitation facilities, and home health agencies).13,33,34,36,46,49,54,68 For-profit providers may have utilized more or more intense ancillary services than their not-for-profit counterparts prior to transitions from fee-for-service to bundled payment reimbursement. No studies examined differential impacts on quality measures by provider profit status.

The four review articles on the Medicare IPPS noted that studies examined the impact of financial pressure on utilization effects. The studies found that hospitals under greater financial pressure had greater reductions in utilization in response to bundled payment. Afendulis et al. (2011) tested whether the Medicare SNF PPS had a differential impact on hospitalized stroke patients in areas with higher integration between hospitals and SNFs (i.e., in areas with less competition).21 They found the SNF PPS led to larger declines in the use of any SNF services in more integrated areas. They also found spending declined in more integrated areas (by 5.3% from 1997–1999, p<0.05) but not in less integrated areas. There were no differential effects in quality measures across more and less-integrated areas. This result may be due to effective self-referral in integrated hospital-SNFs prior to PPS.

Several studies reported outcomes separately for patients with relatively severe disease or injury and patients with relatively less severe disease or injury.13,26,43,58,68 Others reported outcomes separately for patients with different diagnoses.46,47,57,60 These studies produced inconsistent results on the differential effects of patient characteristics on quality and utilization measures.

One study reported outcomes separately by geographic region.53 This study found considerable geographic variation in baseline cost and utilization and in change in cost and utilization attributed to a single bundled payment intervention, the Medicare HH PPS, although no explanation for this differential impact was provided in the reviewed article. Most individual regional outcomes differed from national outcomes with p<00001.

### Strength of Evidence

For the effect of three specific contextual factors, patient severity, provider for-profit/not-for-profit status, and provider financial pressure, on one outcome, utilization, reviewers graded the strength of evidence as “low.” The ratings and specific criteria that form the basis for this assessment of strength of evidence are shown in Appendix D. Seventeen studies addressed the differential effects of key contextual factors on utilization outcomes. These studies had the same risk of bias and residual confounding as described in the discussion of Key Question 1. In addition, the findings were inconsistent and imprecise. The evidence was rated as insufficient to permit an estimation of effects of other contextual factors on utilization outcomes due to sparse and weak or nonexistent evidence.

For other study outcomes, reviewers graded the evidence for this Key Question as insufficient to permit an estimation of effects for any key contextual factor due to the lack of evidence. There were a small number of studies that reported effects of a single contextual factor on spending or quality outcomes, but this evidence was rated as too weak and sparse to permit any conclusions to be drawn.

### Description of Key Contextual Factors

Below, we describe several other key contextual factors described in the reviewed studies. However, none of the reviewed studies directly addressed the effects of these contextual factors on study outcomes.

Some bundled payment interventions were implemented in the context of simultaneous but independent health care spending reduction efforts, including payment reforms other than bundled payment. For example, the Medicare Resource-Based Relative Value Scale physician fee schedule was implemented in 1992, overlapping with the time periods examined in several of the reviewed studies. Capitation and the spread of health maintenance organizations are two other examples of reforms that occurred during the time period of bundled payment programs in reviewed studied. Due to the study designs used, studies were not able to differentiate the effects of bundled payment programs from related but independent interventions.

None of the reviewed studies provided insight into differential results by the degree of integration between health care delivery organizations and payers or between various health care delivery organizations. As noted above, most reviewed bundled payment interventions applied to a specific outpatient care settings or to inpatient environments where hospital and physician actors are not integrated. None of the reviewed studies reported on payer or provider competitive environments.

## Applicability

The main intended audience for this report is policymakers, payers, and providers in the United States that are considering implementation of a bundled payment program. The findings of this review are likely to be applicable most directly to those considering a bundled payment program targeting single providers. The majority of bundled payment programs in the included studies focused on single institutional providers such as inpatient hospitals, skilled nursing facilities, or inpatient rehabilitation facilities. Many of these interventions included all participating U.S. providers of each type.

Recent interest in bundled payment has focused mostly on programs that bundle payments for multiple providers and/or provider types. The findings of this review are less applicable to these types of programs. There were several reviewed studies of bundled payment across multiple provider types, but these included a small number of participating provider organizations that are not representative of the U.S. delivery system more broadly. More evidence is likely to be available in the future as evaluations of ongoing programs, such as the Medicare Acute Care Episode Demonstration, are published.

The interventions studied were typically specific to a single payer, most often Medicare or various public insurance systems outside the United States. The applicability of findings in studies involving one payer (e.g., Medicare) to other payer contexts is limited due to differences in beneficiary characteristics, provider bargaining power, and competitive pressures.

Interventions implemented in countries other than the United States may have limited applicability to the U.S. context due to differences in health system organization, financing, and delivery. Although non-U.S. studies were screened for comparability to a U.S. delivery setting, in practice this criterion was difficult to apply and no studies were excluded on the basis of nationality.

Most reviewed studies analyzed samples or the universe of national patient and/or provider data (specifically, Medicare data). While this improves generalizability, studies with national scope often focused specifically on a handful of diagnoses or interventions to simplify analyses and conclusions. For example, many of the Medicare post-acute care studies restricted their analyses to patients receiving care due to a hip fracture, stroke, or joint replacement.

All reviewed studies assessed the impact of bundled payment relative to either fee-for-service or cost-based payment. The magnitude and sign of effects relative to fee-for-service or cost-based payment may differ from absolute effects. For example, bundled payment might slow an increase in absolute spending relative to usual payment. Transitions to bundled payment from other payment methods, e.g., salary or capitation, may have other effects.

Some reviewed bundled payment systems, including Geisinger ProvenCare (SM) and several international systems, involved settings where care for most or all patients was reimbursed by a single payer. Many other reviewed payment systems were implemented by a single payer (e.g., the U.S. Medicare program) but applied to providers with diverse patient populations and multiple payers. The reported effects of bundled payment may not be fully realized if interventions affect only a small portion of providers' overall business. Similarly, providers may not significantly alter behavior if bundled payment interventions are perceived as temporary.

Finally, evidence on bundled payment applies specifically to cases where reimbursement based on episodes of care is both reasonable and feasible. Bundled payment may be less feasible or effective when applied to health care related to conditions without clearly defined treatment regimens, conditions with multiple treatment approaches, or rare conditions.

## Recommendations for Further Research

There are several ways that future evaluations could produce a stronger evidence base. Policymakers and evaluation researchers must recognize the tension between producing timely, practical evidence and conducting rigorous evaluations. The most rigorous study designs are usually only feasible when policymakers plan for an evaluation experiment in the course of implementation. We focus our recommendations on improving retrospective quasi-experimental studies which formed the bulk of research reviewed for this report.

Use stronger evaluation study designs. Most reviewed studies used a pre-post design with no comparison group, which creates the possibility that selection and history (i.e., changes in practice over time other than the bundled payment program) bias results. While some reviewed studies rated “fair” and both studies rated “good” controlled for potential confounders including patient characteristics (e.g., age, race/ethnicity, and comorbidities) and facility characteristics (e.g., number of beds, staffing levels, and teaching status), most studies rated “poor” presented results from univariate analyses. The benefits to validity from including a comparison group likely outweigh the associated increase in evaluation time and cost. Comparison groups including non-participating providers similar to participants are likely to be the most promising and feasible option.

Most studies considered a brief time horizon after the implementation of bundled payment systems. For the Medicare post-acute care PPS interventions, most studies used “post” data from less than two years after implementation of the new payment system (11 of 19 skilled nursing facility PPS studies, six of nine inpatient rehabilitation facility PPS studies, and eight of nine home health PPS studies). Given the challenges in implementation and redesign of care processes reported in studies with qualitative components a longer time horizon is likely necessary to observe many important impacts. Studies with follow-up in the range of five years post-implementation might capture longer-term changes in quality effects (particularly health outcomes), evolving practice patterns, new technologies, or supply-side market conditions (i.e., closures, mergers, etc.). However, the benefits of a longer time horizon must be balanced against the need for rapid information on program effects and the risk of attributing changes due to secular variation to the payment intervention. Future evaluations could balance these needs by reporting at several points in time post-intervention.

Practical data, time, and funding constraints often dictate the choice of evaluation study design. The limitations intrinsic to retrospective observational studies prevent the reviewed studies from approaching the “gold standard” equivalent of a randomized controlled trial. However, the two studies rated “good” and several studies rated “fair” outlined natural experiments or quasi-experimental strategies to identify the effect of bundled payment on spending and quality outcomes. While the instrumental variables approach is appealing in this context, valid and strong instruments are elusive. One promising natural experiment approach involved exploiting variation due to the staggered implementation of Medicare post-acute care bundled payment interventions, although this approach introduces its own selection concerns. Future evaluations should consider these and related methods that could improve evaluation validity with little effect on the timeliness of results.

Use standardized measures of impact on spending and quality. The measures used to evaluate each bundled payment intervention varied across studies. While different measures are likely more relevant to different interventions and implementations, increased consistency in the use of measures could increase the comparability of future evaluations of the impact of bundled payment. In particular, the use of quality measures was relatively rare and the measures used were inconsistent across studies. Important potential quality effects were often unmeasured, including measures of underuse of appropriate services within bundles, indications of the appropriateness of bundles, measures of the patient experience of care, measures of coordination of care within and across bundles, and health outcomes of bundles of care.4 Evaluators' collaboratives, such as the Patient-Centered Medical Home Evaluators' Collaborative, are one potential mechanism for identifying priority measurement areas and achieving homogeneity in measures used for a given type of intervention. Evaluation sponsors could also encourage evaluators to use standard measurement approaches or to collaborate with evaluators of similar interventions to harmonize measurement approaches. However, standardization needs to be balanced against the fact that the most relevant and meaningful measures, especially quality measures, may differ across health care settings and diseases/conditions.

Use stratification to understand the impact of bundled payment on specific patient groups. While most reviewed studies reported changes in spending and quality of care on average, few reported changes in outcomes for different patient groups. One study in the latter category found significant differences in the impact of bundled payment systems across patient groups, e.g., women versus men (p<0.0001), and dual-eligibles versus Medicare-only beneficiaries (p<0.0001).54 This is perhaps not surprising if the characteristics of a “marginal” patient or service under the prior fee-for-service or cost-based are different from the characteristics of a “marginal” patient or service under bundled payment. Even if aggregate utilization or spending remains constant, changes in incentives may dramatically alter the characteristics of patients or the services provided.

Future research on the impact of payment system changes should focus on the effect of bundled payment on specific patient populations and types of service. In terms of patient characteristics, differential effects by disease/condition severity and payer seem particularly important. Measuring differential effects by disease/condition severity may be possible where researchers have finer resolution data on patient condition than is captured by case mix systems used to assign patients to bundled payment rates. The question of interest in this case is whether relatively ill patients experience different impacts of bundled payment on utilization or quality measures. The questions of interest in this case are whether payer or providers adjust utilization for certain patient groups, and whether impact in quality measures varies by patient group.

Incorporate quantitative and qualitative measures of program design and contextual factors. Few studies considered how specific design elements or contextual factors affect outcomes. This type of evidence will be critical as Medicare and private payers experiment with various payment and delivery reforms including bundled payment as well as others including global payment or shared savings for accountable care organizations, and seek to identify which aspects of these pilots have the potential to be scaled widely. Important design features to be addressed include the definition of the bundle (how many providers are included, what length of time, which services are included and excluded from the bundle); methods for limiting financial risk and incentives for risk selection, including risk adjustment and outlier payments; use of quality measurement; methods to update payment rates to reflect new technologies; and methods for distributing payment among participating providers. Important contextual factors to be addressed include whether bundled payment is more effective in more highly integrated delivery settings; the role of financial pressure and the general financial environment on responses to bundled payment; and differential effects between subgroups of patients, as discussed above.

Incorporate measurement of ancillary or spillover effects. Only a handful of studies explored broader consequences of bundled payment beyond the setting of care or patient group targeted by the intervention. One study noted that decreases in inpatient length of stay in response to the Swedish inpatient PPS were offset by additional nursing facility care.70 Another study22 specifically focused on utilization changes in each Medicare post-acute care setting in response to the implementation of all three prospective payment systems. In general, the implementation of each payment system had a direct effect on the corresponding post-acute care setting and secondary effects as utilization shifted to or from other Medicare post-acute care settings. This complex substitution pattern has important implications. Other substitution effects between Medicare and Medicaid for some post-acute care services and, in the United States and other settings, between private and public payers may also be important. Some studies examined the impact of bundled payment systems implemented by one payer on patients with other payers, but differences between patient populations complicate these results. For example, several studies compared post-acute care outcomes for Medicare and Medicaid or Medicare and “non-Medicare” patients after the implementation of one or more of the Medicare post-acute care prospective payment systems. The obvious differences between Medicare, Medicaid, and privately insured individuals render these comparisons tenuous even in well-controlled studies. Future research should target more similar patient groups to identify spillover effects to patients with different payers.

Other indirect effects of bundled payment were not evaluated by any reviewed study. For example, the introduction of bundled payment may alter incentives for innovators or the adoption of new technologies by providers. Future evaluations should consider these broader implications of bundled payment interventions.

## Limitations

While reviewers carefully screened and selected studies for inclusion in this review, it is possible relevant studies were not captured in the initial search or were mistakenly excluded in the title or abstract reviews. The search process may not have identified all non-English language studies. Some relevant evaluations may not have been published or are not included in the data sources reviewed, particularly sources in the grey literature which are not included in literature databases. While the search strategy included ad hoc and reference mining searches, including recommendations from a panel of experts, few of the studies from these sources met inclusion criteria. While reviewers aimed to screen non-U.S. studies for comparability to U.S. delivery settings, in practice this criterion was difficult to apply and no studies were excluded based on nationality.

The evidence review is limited by the design and implementation of bundled payment programs that have been evaluated. Most of the bundled payment interventions studied in reviewed articles (16/20) were limited to payments to single institutional providers (e.g., hospitals, skilled nursing facilities) and so have limited generalizability to newer programs including multiple care settings and/or multiple providers. The majority of the reviewed programs were applied simultaneously to all providers by large public payers.

The evidence review is also limited by the strength of the underlying studies. Reviewers identified several main gaps in the evidence reviewed, as described above. A summary of methodological limitations is listed in Appendix A for the studies rated “poor” by reviewers. These and other studies rated “fair” often raised one or more of the following methodological concerns: (1) Limited or no consideration or controls for likely confounders in descriptive or observational studies; (2) small and/or convenience samples of providers; and (3) limited post-intervention data. Small sample size and limited followup time are likely to be particularly important for detecting quality effects which may be relatively rare and develop long post-intervention. As noted above, direct evidence on Key Questions 2 and 3 was extremely limited even though it is crucial to understand the differential effects of bundled payment by design features or contextual factors as various health care payers and systems consider payment reform.

## Conclusion

In summary, the introduction of bundled payment was associated with: (1) reductions in health care spending and utilization; and (2) inconsistent and generally small effects on quality measures. These findings were consistent across different bundled payment programs and settings but the strength of the body of evidence was rated as low due mainly to concerns about bias and residual confounding. For policymakers considering implementation of bundled payment programs, this evidence provides some support that the programs are likely to be an effective strategy for reducing health care spending. While the effects on health care quality are less certain, the available evidence doesn't support the worst concerns about potential adverse effects of bundled payment.

Policymakers considering bundled payment programs should also consider several caveats, however. First, future bundled payment programs are likely to differ in important ways from those reviewed in this study. Most of the programs reviewed were single-setting prospective payment systems that replaced fee-for-service reimbursement systems. In contrast, recent and forthcoming bundled payment programs, such as the Medicare national bundled payment initiative, focus on bundling services provided by different providers over the course of an episode defined by a condition, diagnosis or procedure. The few completed studies of programs involving payment for multiple providers did find evidence for reduced costs and inconsistent impacts on quality, although there were some reports of implementation difficulty. These programs are likely to be more complex than most of the reviewed programs, and therefore may have different effects. Nevertheless, multiple-setting programs present a logical next step building on the largely positive effects of previous single-setting bundled payment programs.

Second, although evidence of effects on quality was inconsistent, bundled payment has the potential to either adversely affect quality or be used as part of a quality improvement strategy. Future bundled payment programs should incorporate a robust quality monitoring and improvement component, potentially as an integrated part of the payment system.

Third, the strength of evidence on bundled payment effects was low, reflecting the difficulty in evaluating large-scale policy interventions that occur in a rapidly changing health care system. Better information from evaluations could improve the impact of bundled payment programs, in particular by illustrating how the programs could be adapted for adoption in the variety of health care delivery contexts found in the United States.