# Results

In this chapter, we first summarize the results of the search and characteristics of studies and bundled payment systems reviewed. We then narratively summarize the evidence from studies on each of the payment systems, which are listed in Table 2 below. We categorize these systems into three groups based on two key dimensions: whether they were implemented domestically or abroad (a key contextual factor), and whether they were implemented in a single setting or include multiple settings of care (a key design factor). The first category is prospective payment systems implemented in the United States including a single care delivery setting. All of these programs except for one were implemented in public insurance systems, the one exception was implemented by a private managed behavioral healthcare organization. The second category is bundled payment systems implemented in international settings and including a single setting. The third category includes bundled payment programs that involve providers across multiple care delivery settings. These programs include two implemented by public payers and two by private payers, all located in the United States. There were no systems in the fourth category (i.e., systems implemented abroad in multiple settings of care).

Table 2 Bundled payment systems in included studies

Payment System | No. of Included Studies | Intervention Date | Payer | Provider Type(s) | Services Included in Bundle
U.S. Public Insurance Prospective Payment Systems
Medicare Inpatient Prospective Payment System | 4^6-9^ (Reviews) | October 1983^a^ | Medicare | Inpatient hospitals | Per-discharge payment for hospital costs associated with each diagnosis-related group, including nursing, accommodation, etc., and outpatient services in three days prior to admission.
Medicare Skilled Nursing Facility Prospective Payment System | 20^10-29^ | July 1998 | Medicare | Skilled nursing facilities | Per diem payment for routine, ancillary, and capital-related skilled nursing services for each of 56 Resource Utilization Groups.
Medicare Inpatient Rehabilitation Facility Prospective Payment System | 11^11,19,30-38^ | January 2002 | Medicare | Inpatient rehabilitation facilities | Per-discharge payment for operating and capital costs for each of 92 Case-Mix Groups.
Medicare Home Health Prospective Payment System | 12^5,11,19,39-47^ | October 2000 | Medicare | Home health agencies | Per 60-day episode payment for all nursing care, therapy, and aide services for each of 153 Home Health Resource Groups.
Medicare Long Term Acute Care Hospital Prospective Payment System | 1^48^ | October 2002 | Medicare | Long term acute care hospitals | Per discharge payment for all operating and capital costs for each of 318 Medicare long-term care diagnosis-related groups.
Department of Veterans Affairs Resource Allocation Methodology | 1^49^ | 1985–1988 | Department of Veterans Affairs | Inpatient hospitals | Per admission payment (diagnosis-related groups) for hospital services.
Maine Medicaid Nursing Home Prospective Payment | 1^50^ | 1982–1985 | Maine Medicaid | Nursing homes | Per diem payment for nursing home services (including patient care, dietary care, lodging, etc.).
New Hampshire Medicaid Hospital Prospective Payment | 1^51^ | January 1989 | New Hampshire Medicaid | Inpatient hospitals | Payment includes per discharge prospective component based on Diagnosis Related Group, as well as an actual costs component.
U.S. Private Sector Single-Setting Bundled Payment Systems
Case Rate for Managed Behavioral Health Care | 2^52,53^ | July 1995 | Single U.S. Managed Behavioral Healthcare Organization | Psychiatrists, psychologists, social workers | All outpatient mental health services for one year following referral.
International Bundled Payment Systems
Belgium Inpatient Prospective Payment System | 1^54^ | 1995 | Belgium public health insurance | Inpatient hospitals | Per-admission payment for non-medical hospital services (e.g., nursing staff, accommodation) for each of 604 case mix groups.
National Health Service (England) Payment by Results | 1^55^ | 2003 | England NHS | Hospitals | Hospital services (more detail not reported).
Italy Inpatient Prospective Payment | 1^56^ | January 1995 | Italian Ministry of Health | Inpatient hospitals | Hospital and physician services (more detail not reported).
Japan Outpatient Hemodialysis Bundled Payment | 1^57^ | April 2006 | Not reported | Dialysis clinics and hospitals | Dialysis drugs (more detail not reported).
Netherlands Inpatient Prospective Payment | 1^58^ | 2005 | Not reported | Inpatient hospitals | Hospital and physician services (more detail not reported).
Sweden Inpatient Prospective Payment System | 1^59^ | 1992 | Stockholm County Council | Inpatient hospitals | Hospital services (more detail not reported).
Taiwan Hospital Case Payment | 3^60-62^ | October 1997 | Taiwan National Health Insurance Bureau | Hospitals | Per episode payment for required medical services, “optional” medical services, pharmaceuticals, and evaluations within a two-week period for surgeries.
Bundled Payment Systems Including Multiple Providers/Sites of Care
Geisinger ProvenCare(SM) | 1^63^ | February 2006 | Geisinger Health Plan, PA | Three demonstration hospitals | Per-discharge payment for evaluation, hospital and professional fees, routine post-discharge care, management of complications.
Medicare Participating Heart Bypass Demonstration | 1^64^ | May 1991–June 1996 | Medicare | Seven demonstration hospitals | Per-discharge payment for all inpatient hospital and physician services, including related readmissions.
Medicare Cataract Surgery Alternative Payment Demonstration | 1^65^ | 1991–April 1996 | Medicare | Four demonstration sites | Pre-operative diagnostics and evaluation, surgical services, post-operative exams to 120-days, management of common complications.
Michigan Arthroscopic Surgery Bundling Pilot with Warranty | 1 66 | April 1987 | Blue Care Network (Blue Cross Blue Shield of MI) | Single surgical practice and hospital | Single payment for all care related to surgery, including repeat surgery, repeat hospitalization, or any other related subsequent services rendered by the providers for 2 years.

Source: Authors' analysis of search results

a Implementation was delayed in four states.

We provide a narrative synthesis of evidence for each bundled payment program in these three categories. For each bundled payment program, we summarize the evidence using the following format:

- Description of the payment system
  ○ Description of the payment system's implementation
  ○ Details of the payment method
- Summary of the findings of reviewed studies of the payment system
  ○ Description of the payment methods used for comparison by reviewed studies
  ○ Overview of the design of reviewed studies relevant to the payment program
  ○ Summary of findings of effects on study outcomes of interest (Key Question 1):
    ■ Health care spending (i.e., payments from payers to providers) or costs (i.e., the costs to providers of providing goods or services)
    ■ Utilization of health care services
    ■ Health care quality
    ■ Other study outcomes of interest
  ○ Summary of findings of differential effects by key design features of the intervention (Key Question 2)
  ○ Summary of differential effects by key contextual factors (Key Question 3).

## Articles Identified

The initial search identified 1,310 articles, including 1,198 identified through the PubMed search, 102 additional articles identified through the first Cochrane Library search, and ten others identified through the second Cochrane search. Of these articles, 74 were included following title and abstract review. Twenty-three were eliminated during full text review, and seven were added from other sources including ad hoc searches, reference mining and expert recommendations. This resulted in a total of 58 articles included for review, including peer-reviewed journal articles as well as evaluation reports identified in the grey literature (Figure 2). This total excluded studies of the Medicare IPPS, for which we searched for review articles separately. The initial search for these review articles identified 160 articles, including 150 identified through the PubMed search, and 10 additional articles identified through the Cochrane Library search. Eleven of these review articles were retained following title and abstract review (Figure 3). A list of studies excluded after full-text review, with reasons for exclusion, is included in Appendix C. Three articles remained following the full-text screen, and an additional article was identified by an ad hoc search, resulting in the inclusion of four review articles on the Medicare IPPS.

Figure 2 Search tree for primary sources

This figure depicts the main literature search results through each step of the search process. The initial search yielded 1310 titles. Based on a title review, the literature was narrowed to 113 articles. After reviewing the abstracts of these articles, the pool was further narrowed to 74 titles. The review of the full text of these articles reduced the field to 51 articles. An additional 7 titles were identified through ad hoc searches and reference mining, resulting in a total of 58 included studies. Among the 22 articles excluded at full-text review, 12 did not report an outcome of interest, 5 did not address a bundled payment intervention, and 6 were disqualified for other reasons.

Figure 3 Search tree for Medicare Inpatient Prospective Payment System reviews

This figure depicts the literature search for review articles pertaining to the Medicare Inpatient Prospective Payment System. References regarding this program were specifically excluded from the main literature search. The initial search yielded 160 titles, which the title review narrowed to 30 articles. After reviewing the abstracts of these titles, 11 review articles remained. Full-text review reduced the pool of titles to 3, and 1 additional review article was added based on ad hoc searches, resulting in the inclusion of 4 review articles. Among the 8 articles excluded at full-text review, 6 were not review articles, and 2 were disqualified for other reasons.

The included articles examined 20 different bundled payment interventions (Table 2). Most articles examined U.S. public insurance prospective payment systems or international prospective payment systems. Among the 58 reviewed studies, 48 employed observational designs, while 9 were descriptive. There was only one study randomized at the provider level,13 and we identified no studies of bundled payment programs randomized at the patient level. All but four of the 20 bundled payment interventions involved bundling of services during a period of time by a single provider such as a hospital, skilled nursing facility, or home health provider. Two studies jointly examined multiple Prospective Payment Systems implemented in Medicare through the Balanced Budget Refinement Act of 1999, including systems for skilled nursing facilities, inpatient rehabilitation facilities, and home health care. All but three of the bundled payment interventions in the included sources included public payers only.

Our search identified other bundled payment programs in progress, including the Medicare Acute Care Episode demonstration, PROMETHEUS Payment, and others. However, we did not identify published evaluations of these programs that met our inclusion criteria. Compared with the majority of the bundled payment interventions in reviewed studies, the programs in progress use bundles with greater aggregation of services over time and across provider types and/or providers. Below, we briefly describe selected ongoing programs.

Medicare Acute Care Episode (ACE) Demonstration.14 Medicare is conducting a demonstration that provides bundled payments for acute care episodes for orthopedic and cardiovascular inpatient procedures. The bundles include both Medicare Part A and Part B services, including physician services, provided during a hospital stay. Prices for the bundled payment were established through competitive bidding. Five organizations—entities including an affiliation between at least one physician group and at least one hospital—initiated the demonstration in 2009-2010. CMS is conducting an evaluation, but it has not yet been completed and published.

Medicare Bundled Payments for Care Improvement.15 Medicare is currently accepting applications for a national initiative that will make bundled payments for episodes of care. The initiative includes four “models,” or bundled payment methods. Model 1 is a retrospective payment for hospital and physician services provided during a hospital stay; Model 4 is a prospective payment for these services. Model 2 is similar to Model 1 but also includes 30-90 days of post-discharge care. Model 3 is a retrospective payment for post-discharge services only. Prices for the bundled payment will be negotiated between providers in CMS during the application, with reference to historical utilization and payment amounts for services included in the bundle.

Integrated Healthcare Association (IHA) Bundled Episode Payment and Gainsharing Demonstration. This demonstration is testing bundled payment for episodes related to inpatient surgical procedures in California. The demonstration is funded by AHRQ. IHA serves as a convener of participating hospitals, physician groups, and health plans. The bundles include hospital and physician services during the hospitalization as well as selected services provided during a 90-day post-discharge period (routine followup care, treatment of complications, related readmissions, and optionally therapy). The prices for bundles are negotiated between each participating provider organization and health plan. An evaluation is being conducted by RAND and researchers from the University of California at Berkeley and San Francisco but is not yet complete.

PROMETHEUS Payment. PROMETHEUS is a bundled payment model managed and implemented by the Health Care Incentives Improvement Institute. It is being implemented in several sites where provider organizations and commercial payers have volunteered to participate. The bundles include episodes of care related to chronic conditions, inpatient acute conditions, and inpatient surgical procedures. An evaluation of the implementation of three sites showed that the pilots have faced sizable implementation challenges, with none of the three pilot sites having executed contracts or made bundled payments three years after the pilot initiation.16 Therefore, no information is currently available on the impact of the bundled payment intervention on spending, quality, or other study outcomes of interest for this report.

## U.S. Public Insurance Prospective Payment Systems

We identified studies of eight U.S. public insurance prospective payments systems. We first summarize findings of studies on five Medicare programs, then one Department of Veterans Affairs program and two state Medicaid programs.

### Medicare Inpatient Prospective Payment System

#### Description of the Payment Model

##### Implementation

Prior to 1983, hospitals were reimbursed retrospectively based on costs incurred. In October 1983, Medicare implemented the Medicare IPPS for payments to participating hospitals (implementation was delayed in four states). Payment rates were transitioned over a four-year period, moving from a blend of hospital-specific and regional average payment rates to a relatively generous (4 percent higher) national payment rate.19 Similar payment policies were adopted by other payers. Medicare IPPS was applied to all short-term community hospitals, but excluded sole community hospitals.

The implementation of Medicare IPPS occurred at a time when a number of other trends were shaping hospital costs and utilization. These include technological advances that shifted care from inpatient to outpatient settings; changes in private insurance payment, notably the rapid adoption of managed care; and shifts towards more favorable reimbursement for care nursing home, home health and hospice benefits under Medicare.18

##### Payment Method

Under Medicare IPPS, a single prospective per-discharge payment was made for hospital operating costs associated with a hospital admission, including room and board, nursing, and costs associated with specialized care and ancillary services. The bundle did not include physician professional services provided during the hospital admission. Payments were made to the hospital, which employed staff whose services were included in the payment (nurses, technicians, etc.). Related outpatient department services provided in the three days prior to admission were also included.

Payments were adjusted for the patient's diagnosis, through the classification of discharges into Diagnosis-Related Groups (DRGs). Payment adjustments were also made based on each hospital's local market characteristics and teaching status. Outlier payments were added for the most-costly cases. There was no explicit role of performance measurement built into the payment methodology.

#### Summary of Findings

##### Comparison Payment Methods

The effects of the Medicare IPPS were generally assessed through comparisons with the retrospective reasonable cost-based system of reimbursement that preceded it in the Medicare program.

##### Overview of Design of Relevant Studies

###### Reviews

As noted above, we searched for review articles summarizing prior research on the Medicare IPPS. We identified four articles that reviewed studies of the impact of the Medicare IPPS and were relevant to the Key Questions of this review.17-20 The reviews were published in 1989-1991 and therefore do not include more recent studies. However, the intervention studied was implemented in 1983 and therefore we expect that most relevant studies were published prior to 1991.

None of the four reviews reported detailed information on methods for study selection, data abstraction, and data synthesis, precluding assessment of the quality of the individual reviews against AMSTAR criteria. The reviews did not include lists of included studies, which precluded assessment of the degree of consistency in study inclusion. The findings of the four reviews on the Key Questions were compared and had a high degree of consistency between reviews. Data abstraction and synthesis accuracy were assessed through review of a small sample (4-6 primary source articles per review) of primary source studies; this review confirmed a high degree of accuracy.

Based on these assessments of the quality of the review articles, we concluded that although the lack of transparency in methods indicates that each individual review is at risk of bias, the consistency in findings and the checks against primary source articles indicate a lower risk of bias for the body of evidence from the four reviews considered together.

###### Primary Source Studies

The majority of studies reviewed in the four included review articles relied on a small number of common national data sources and used observational pre/post designs. A handful of studies referenced in the reviews leveraged a delay in implementation of the Medicare IPPS in four states initially exempted from the program under a waiver, allowing contemporaneous comparison between the new system and cost-based reimbursement.

The focus of the analyses was driven largely by the available data, with the primary emphasis on care utilization and Medicare program costs, which could be extracted from available administrative data. There was a secondary focus on the impact of the Medicare IPPS on hospital finances. Analysis of quality and outcomes was largely focused mortality rates, with the acknowledgement that this measure is unlikely to be highly sensitive to Medicare IPPS implementation.

All four reviews noted the inherent difficulty in analyzing the effects of the Medicare IPPS or drawing meaningful conclusions, given the myriad external trends and related policy developments during the years before and after Medicare IPPS implementation. Feinglass in particular noted that rapid increases in the prevalence of outpatient surgery and utilization of home health services, as well as increasing severity of inpatient cases, were influenced by numerous external factors in addition to Medicare IPPS implementation.19 However, given these limitations, there was notable consistency among the included studies and the reported findings across the four reviews.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

The Medicare IPPS was found to substantially reduce the rate of increase in Medicare inpatient hospital expenditures. Medicare payments per discharge increased post-implementation, driven largely by increases in reported case-mix and relatively generous per-discharge payment rates in the early implementation period. However, discharge volumes decreased, leading to an overall decrease in Medicare inpatient spending growth.17 The reductions in growth of total hospital expenditures attenuated following the first two years of the Medicare IPPS, returning to double-digit annual growth in the fourth year of the program.18

Based on comparisons of inflation-adjusted Medicare expenditure growth before and after Medicare IPPS implementation, the reduced rate of spending growth translated into a reduction of $17 billion to $18 billion in Medicare spending on inpatient care in the payment system's first five years.17 These decreases in inpatient spending were offset to some degree by increases in spending for care in other settings.20 Medicare payments for physician services (including inpatient and ambulatory) grew at a slower rate under the Medicare IPPS, while outpatient hospital and post-acute care payments grew slightly faster under the new system. The real rate of growth of total Medicare spending decreased following the Medicare IPPS, from roughly seven percent annually in the four years prior to implementation to roughly four percent annually in the subsequent three years.18,20 These findings suggest that the Medicare IPPS resulted in care shifting from inpatient to outpatient settings, and had a modest impact on overall Medicare spending.17

###### Effect on Health Care Utilization

The reviews found that the Medicare IPPS resulted in a decrease in hospital utilization, particularly in the early years of the program. Feinglass noted that the average length of stay for Medicare patients was 25 percent lower in 1985 than in 1980, while it was five percent lower over that interval for non-Medicare patient under 65. Total hospital days per 1,000 Medicare enrollees per year decreased by 21.8 percent over the initial two years of the Medicare IPPS.19 Chulis reported similar findings, including reductions in length of stay that were large in the initial years of the Medicare IPPS (as high as 1.6 fewer days per stay in the first year), but stabilized thereafter. Due to data limitations, however, this effect may have been overstated, specifically in light of questions about the inclusion or exclusion of long-stay hospitalizations that continued to be reimbursed on a reasonable cost-basis following the Medicare IPPS.17 Limited evidence suggests that the Medicare IPPS resulted in a reduction in the intensity of care (i.e. the volume of tests, procedures and services utilized per patient).

There was strong evidence linking the Medicare IPPS to significant shifts in the delivery of services from inpatient to outpatient settings. The reviews suggested that there was a shift in treatment from hospitals to other post-acute settings, although the results are somewhat mixed.18 Lave reported an increase in Medicare discharges to skilled nursing facilities, and an increase in home health services for discharges to home in the initial years of the Medicare IPPS, but noted that these shifts do not necessarily reflect inappropriate changes in treatment setting.20

Contrary to conventional wisdom at the time of implementation that hospital admissions rates might increase in response to the new payment system, hospital admission rates actually fell during the first several years of the Medicare IPPS, with the decline estimated to be as much as 10 percent in the first year when adjusted for other factors.18 Chulis reported similar decreases in admission rates, totaling 14 percent over the first five years of the Medicare IPPS.17 However, the causes of this reduction in admissions have not been definitively explained. A number of potential causes external to the Medicare IPPS have been theorized, and the four reviews included significant speculation about other factors that contributed to this outcome. In particular, other factors at the time may have encouraged shifting certain types of care from inpatient to outpatient settings, such as surgical procedures that could be performed in an ambulatory setting.17-20

###### Effect on Health Care Quality

There is no evidence of systematic deterioration in quality of care under the Medicare IPPS, as had been predicted by some observers before implementation. On the contrary, the evidence shows that most quality measures improved post-implementation, although the changes can't be attributed to the Medicare IPPS. However, researchers cautioned the length of follow-up might have been insufficient to detect long-term effects on outcomes.18,20

The reviews reported that studies demonstrated either no change or a decline in mortality rates following the Medicare IPPS. This result was consistent across in-hospital mortality rates and long-term mortality rates (up to one year post-discharge). During this time period, the overall population mortality rate among Medicare beneficiaries also decreased.17

There was less evidence available on non-mortality health outcomes or other quality measures. Some studies examined potential adverse quality effects of incentives to discharge patients quickly. The available evidence did not suggest that the Medicare IPPS led to increases in hospital readmissions. Inter-hospital transfer rates did not appear to change in the first two years of the Medicare IPPS. There was insufficient evidence to assess the long-term effect on transfers or any impact on emergency room admissions.18 Lave noted one study that found a higher proportion of previously hospitalized patients residing in nursing homes at six months post-discharge after the implementation of the Medicare IPPS.20 One study also found an increase in the level of instability of patients at the time of discharge after the Medicare IPPS.18

###### Other Effects

The case-mix index of patients treated increased under the Medicare IPPS, with the largest increase in the first year, but it is unclear to what degree this resulted from changes in the actual condition of patients treated, as opposed to changes in coding and DRG assignment.17,18,20

The literature indicated that the Medicare IPPS did not drive hospital closure, but did impact hospital financial performance. The Medicare IPPS led to a sharp short-term increase in hospital margins, followed by reductions over the subsequent years; however, this effect varied across hospitals based on market conditions. The initial payment rates under the Medicare IPPS, particularly in the first year, were widely recognized as overly generous. While these rates were later adjusted, they may have distorted the intended effects in the initial years of the Medicare IPPS, both by dampening the cost-containment incentive in the first year, and by providing revenue to hospitals that could be used to compensate for the changes in later years.18

Some evidence suggested that productivity increased in hospitals under the Medicare IPPS, in terms of the amount of care provided relative to the resource used.18 Chulis reported government estimates of hospital profits exceeding 14 percent on Medicare IPPS business in each of the first two years of the program, decreasing to 2.6 percent by 1988. The impact among hospitals differed substantially, with urban hospitals performing much better than rural hospitals in terms of profitability under the Medicare IPPS, and teaching hospitals performing the best. These differences were mitigated by targeted changes in differential payments among hospital types in the years following the initial implementation of the Medicare IPPS.17

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

When measures of financial pressure on hospitals were applied to the data, the impacts of the Medicare IPPS appear much larger among hospitals identified as experiencing significant pressure. Feinglass defined financial pressure as a measure of the “gap between (hospitals') actual costs and their anticipated or actual PPS revenues.”19 Reductions in utilization were more pronounced among hospitals under a high degree of financial pressure, while reductions are muted among hospitals under lower or negligible pressure. This suggests that local market conditions played a significant mediating role in hospital response to the Medicare IPPS.17-19

### Medicare Skilled Nursing Facility Prospective Payment System

#### Description of the Payment Model

##### Implementation

The Medicare Skilled Nursing Facility (SNF) Prospective Payment System (PPS) replaced a retrospective cost-based payment system on July 1, 1998. The SNF PPS was one of several new Medicare post-acute care payment systems introduced in the 1997 Balanced Budget Act. Unlike the other new payment systems in the Balanced Budget Act which were for the most part budget neutral, the SNF PPS was predicted to reduce Medicare SNF spending by $9.5 billion from 1998-2003.^78^ After implementation, aggregate Medicare SNF spending declined 15 percent from $11.3 billion in 1998 to $9.5 billion in 1999, roughly in line with CBO projections.78,79

The SNF PPS applied to both freestanding and hospital-based SNFs. A three-year mandatory phase-in period blended facility-specific payment rates based on historical allowable costs with the new prospective rates. Several changes were made to the PPS payment rates after implementation. The 1999 Balanced Budget Act included a 20 percent increase for 15 “complex care” case mix groups and a four percent increase for all other case mix groups. The 2000 Benefits Improvement and Protection Act included an additional 6.7 percent increase for all case mix groups and a 16.6 percent increase in each rate's nursing component.

##### Payment Method

The SNF PPS bundled routine, ancillary, and capital-related services provided under Medicare Part A into one per diem payment for each of 56 Resource Utilization Group III (RUG) case-mix groups.^a^ Services provided at SNFs included nursing care, rehabilitation therapy, laboratory services, and drugs. Payment rates were updated each federal fiscal year by CMS using an SNF market basket index. Rates were also adjusted for geographic variation in wages using the hospital wage index.

The RUG system tied the per diem payment amounts to patient clinical and functional characteristics as well as to services provided. Specifically, assignment to one of the 56 RUGs was determined by the amount of rehabilitation therapy provided (in minutes per week), the need for extensive or skilled services, and patient condition.

#### Summary of Findings

##### Comparison Payment Methods

All reviewed studies (n=18) compared the SNF PPS to the previous retrospective cost-based reimbursement system. One study also analyzed the impact of Medicaid SNF case mix reimbursement, and one study assessed the impact of each Balanced Budget Act PPS intervention, including the SNF PPS, on utilization of SNF and other types of post-acute care. Five studies utilized data on non-Medicare patients in a differencing strategy or to report separate pre/post results for Medicare and non-Medicare beneficiaries.

##### Overview of Design of Relevant Studies

Most studies specifically assessing the Medicare SNF PPS (n=14) reported changes in patient outcomes (eight studies), SNF utilization (nine studies), and/or Medicare SNF spending (three studies) attributed to SNF PPS implementation. Five additional studies assessed SNF-level effects associated with the SNF PPS, including staffing levels,29,35,40 efficiency,23,39 and regulatory deficiencies.29 Of the 14 studies focusing on patient-level effects, one considered total knee replacement patients only,24 three considered rehabilitation services only,34,36,38 one considered Medicare patients hospitalized for stroke only,21 one considered long-stay patients only,27 one considered the pharmacologic treatment of depression only, and one considered pharmacologic second ischemic stroke prevention only.32

One study considered a range of utilization, reimbursement category and level, and length of stay measures and was rated “good” by reviewers.25 This study included a SNF profit maximization model supported by a supply response theoretical framework and employed difference-in-differences and difference-in-difference-in-differences identification strategies to estimate the impact of the SNF PPS. Of the remaining 16 studies, 12 were rated “fair” and four were rated “poor”. The poor studies reported only univariate analyses without considering potential confounders (three of the four), and/or lacked generalizability due to the small number of SNFs studied (the remaining one of the four). Reviewed studies provided limited information on the long-term impact of the SNF PPS: Eleven of the seventeen studies used “post” data from 2001 or earlier (compared to the PPS implementation date of July 1998).

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

Few of the reviewed studies provided direct estimates of the impact of the SNF PPS on Medicare SNF spending. The study which most directly addressed this question (rated fair) modeled the change in SNF spending from 1997 to 1999 for elderly patients hospitalized with stroke controlling for a range of individual and hospital-level covariates and the degree of integration between hospitals and SNFs.21 The authors found a statistically insignificant 8.2 percent decline in spending. Another study (rated poor) focused on SNF rehabilitation services and found that average SNF rehabilitation charges per Medicare hospital stay decreased from $421 in 1997 to $233 in 2000 (a 44.6 percent decline) with the largest decreases for for-profit, freestanding SNFs.34 The author suggested that lower rehabilitation charges per SNF day (rather than lower length of stay or probability of discharge to a SNF) were responsible for this decline.

Three studies assessed changes in SNF use of nursing labor in response to the SNF PPS. Changes in nurse staffing are related SNF facility costs. Collectively, these studies suggested SNF staffing decreased post-PPS except for an increase in administrative nurse hours. The first study (rated fair) found SNFs with the average Medicare patient fraction had 13 fewer minutes of nurse staffing per day post-PPS (p<0.001), with a smaller effect for non-profit SNFs.35 The second (rated fair) found a 17 to 33 percent reduction in professional staffing in hours per patient day post-PPS after controlling for time trends, facility characteristics, and demographic factors.29 Finally, a fair study assessing nurse administrative activities found administrative nurse hours per patient day increased by four percent on average post-PPS (p<0.01) but could not identify a dose-response relationship, i.e., a further increase in administrative nursing hours for SNFs with larger Medicare patient populations.40

One fair study directly assessed changes in SNF efficiency over the SNF PPS implementation period using a data envelopment analysis approach. This study found the average SNF efficiency score (measured as the output of resident days divided by operation expense inputs, after controlling for quality and case mix) gradually declined after the 1998 implementation of the PPS, from a mean of 0.198 in 1997 to 0.131 in 2003. However, SNFs with larger proportions of Medicare beneficiaries faced smaller declines in efficiency than those with smaller proportions of Medicare beneficiaries (p<0.0001).39

###### Effect on Health Care Utilization

Reviewed studies considered a wide range of SNF utilization outcomes. In general, studies including robust controls for potential confounders and sophisticated approaches to control for time trends found the SNF PPS had at most a modest impact on utilization. Still, taken as a whole, the evidence suggests the SNF PPS catalyzed small decreases in average length of stay, rehabilitation utilization during SNF stays, and SNF admissions.

One good study assessed whether the SNF PPS affected Medicare enrollment (i.e., the number of Medicare patients at an SNF) and Medicare share (i.e., the proportion of Medicare patients in a total SNF population).25 The SNF PPS was associated with a decrease of one to two Medicare patients per SNF and a decline of the proportion of patients covered by Medicare of about 10 percent to 22 percent (results presented from two models with different approaches to controlling for underlying secular trends).

Three studies assessed changes in SNF average length of stay. One good study found no significant effect on average length of stay within 20 or 90 days post-PPS.25 Two other studies found decreases in average length of stay, with one poor study reporting large but statistically insignificant decrease (from 17.4 to 8.6 days) without controlling for potential confounders,24 and a fair study reporting a decrease from 23.8 days in 1997 to 22.9 days in 2000 without controlling for covariates.35

Several studies measured rehabilitation therapy time during SNF stays. One previously mentioned good study reported PPS implementation was associated with an 8.7 percent increase in therapy minutes per stay (p<0.01).25 A fair study found the number of rehabilitation therapy hours per week decreased from 7.1 to 6.2 post-PPS after controlling for a range of demographic, insurance, and patient-level factors (p<0.001).33 A third study (rated fair) found the number of rehabilitation therapy minutes decreased from 552 pre-PPS to 379 post-PPS (31 percent decline) after controlling for resident and facility observable factors, and reported a larger decline for Medicare beneficiaries than for those with private health insurance (21 percent decline) or Medicaid (2 percent decline).36

Other studies measured rehabilitation utilization during SNF stays using visit counts. One poor study found physical therapy visits per stay decreased from 10.43 pre-PPS to 7.23 post-PPS without controlling for potential confounders (p=0.041).24 In a sample of three SNFs, another poor study reported post-PPS patients had five fewer physical therapy days than pre-PPS patients (down from 18.5 to 13.1 days), and that post-PPS patients received 47 percent and 54 percent of physical and occupational therapy, respectively, than pre-PPS patients.38 A third study (rated fair) found the number of physical and occupational visits per stay for the highest-functioning patients increased at SNFs participating in the SNF PPS demonstration program (19.3 to 26.5 visits per stay) but not in nonparticipating SNFs (decrease from 23.3 to 18.2 days, not statistically significant).26 Overall, there was mixed evidence on the direction of the PPS's impact on rehabilitation therapy utilization, although more studies reported a decrease than an increase.

Four studies reported increases in the patient-level probability of using any SNF or specifically rehabilitation services at all post-PPS. The first (rated fair) predicted a large increase in the probability of SNF resident use of rehabilitation services from 68 percent to 90 percent based on a model including a range of demographic, insurance, and patient-level factors and calibrated with pre-PPS data (p<0.001).33 The second (rated fair) reported an observed but smaller increase in the use of any rehabilitation services amongst SNF residents from 89 percent pre-PPS to 91 percent post-PPS controlling for resident and facility observables.36 The third study (rated poor) reported a decrease in the probability of hospital discharge to a SNF (from 16.3 percent pre-PPS to 14.7 percent post-PPS) without controlling for covariates.34 The fourth study reported a 4.2% decline from 1997 to 1999 (p<0.01) in the use of any SNF services by elderly stroke patients.21

Finally, one fair study assessed the impact of the SNF PPS on utilization of SNF, Inpatient Rehabilitation Facility (IRF), home health, or no Medicare post-acute care after controlling for patient and SNF characteristics.22 Substitution between sources of care in response to payment system change introduces important implications for payers (in this case Medicare) in terms of total expenditure and possibly quality outcomes. This study found the SNF PPS decreased the probability of SNF utilization for hip fracture patients by 0.6 percent (p<0.05) and for joint replacement patients by one percent while utilization for stroke patients was unchanged. The study also attributed the SNF PPS with a small decline in the probability of receiving any Medicare post-acute care and a small increase in the probability of receiving home health services for hip fracture and joint replacement patients (all p<0.05).

###### Effect on Health Care Quality

While several studies considered quality using metrics such as SNF deficiencies reported to CMS and the proportion of patients discharged to the community, very few reported consistent effects of the SNF PPS across multiple quality metrics. On the whole it appears the SNF PPS did not consistently affect quality. One study assessed the change in all-cause mortality and rehospitalizations due to a variety of causes from 1997 to 1999.^21^ All-cause mortality increased by a marginally statistically significant 1.6% (p<0.1) while differences in readmission rates were not statistically significant.

Four fair studies measured changes in care “deficiencies” reported on regulatory forms, e.g., pressure sores or use of restraints. One study reported a significant increase in SNF-level deficiencies of about 12 percent over the pre-PPS mean of 5.4 deficiencies per report, although this study did not find a significant dose-response relationship between a SNF's Medicare beneficiary share and deficiencies.29 Three other studies found a nil35 or very small effect of PPS on deficiencies reported (less than 0.25 percent greater risk of urinary tract infection or pressure sores post-PPS).27,28

Two fair studies measured changes in discharge patterns. The first did not find a change in discharge to community for the highest-functioning patients, or in residence in community at 30, 60 or 90 days post discharge attributed to participation in the SNF PPS demonstration.26 The second reported the relative risk of discharge to home increased post-PPS (p<0.01) but noted that the increase was smaller for Medicare beneficiaries than for non-Medicare beneficiaries (p<0.001).37 The same study reported Medicare beneficiaries faced lower relative risk of death in a SNF post-PPS (p<0.01) but noted this effect was greater for Medicare beneficiaries than for non-Medicare beneficiaries (p<0.001).37 The authors conclude the SNF PPS was “associated with neither uniformly declining standards of care nor a large improvement in effectiveness”.37

Other studies focusing on specific patient groups considered various clinically-based quality metrics. A poor study of orthopedic patients found one health outcome improved (ambulation distance feet increased by 40 percent post-PPS, p=0.003), one health outcome declined (extension range of motion decreased by 40 percent post-PPS, p=0.035), and one remained the same (knee flexion range of motion) post-PPS, all without controlling for potential confounders.24 A poor study of stroke patients found antiplatelet use was between 21 percent and 37 percent higher post-PPS, and found no change in anticoagulant use post-PPS (odds ratio 95% confidence interval (0.88, 10.8).32 Finally, a fair study of depressed patients found no change in the likelihood of antidepressant medication use pre/post-PPS (odds ratio 95% confidence interval (0.93, 1.18).31

###### Other Effects

Patient condition and categorization. Several studies suggested patient condition, disease severity, and comorbidities on admission worsened over time. This may have been a secular trend, in which case unobserved or otherwise omitted variables may mistakenly attribute declines in health status or outcomes to the SNF PPS. It is also conceivable that incentives in the SNF PPS induced SNFs to admit sicker patients (e.g., high rehabilitation RUGs may provide a greater margin than non-rehabilitation RUGs) or to more thoroughly document diagnoses to qualify for higher payments. In one fair study, patients had lower cognitive and motor scores, probability of planned home discharge, probability of family/friend contact, vision abilities, and ability to make needs understood post-PPS compared to pre-PPS. In the same study, post-PPS patients experienced higher rates of depression, psychiatric medication, diabetes, congestive heart failure, pulmonary disease, and other comorbidities compared to pre-PPS patients (all reported with p<0.001).33 In a poor study (with patients from only three SNFs), post-PPS patients had significantly lower admission physical functioning scores (down from 20.10 to 10.52) and physical summary scores.38 A good study analyzed shifts in RUG classification utilization pre/post-PPS and found a 6.4 percent increase in the assignment of patients to rehabilitation RUGs (from 75 percent to 79 percent; p<0.05) and a 30 percent increase in assignment to “high rehabilitation” RUGs (from 13 percent to 17 percent; p<0.01).25

One fair study analyzed the response of SNFs to a design feature of the SNF PPS, namely defining rehabilitation therapy RUGs on specific cutoffs in the number of minutes of therapy provided.36 This study found the distribution of therapy minutes transitioned from a relatively even distribution pre-PPS to a distribution with some clustering at “nodal points” defining the boundaries of rehabilitation therapy RUG classifications (45, 150, 325, 500, and 720 minutes of therapy). Overall, there was a 12 percent increase in the probability of receiving rehabilitation therapy at a nodal point post-PPS.36

##### Differential Effects by Key Design Feature

As described above, one fair study focused on a specific design feature of the SNF PPS, the definition of rehabilitation therapy RUGs on the basis of therapy minutes provided. However, this study did not report on the effects of this design feature on health spending or quality. No other studies reported differential effects by key design feature.

##### Differential Effects by Key Contextual Factor

Facility ownership status and hospital affiliation. One poor study decomposed rehabilitation spending changes by SNF ownership status and found that a significant decline in rehabilitation charges per stay for for-profit, freestanding SNFs was offset by smaller decline for not-for-profit SNFs and a small increase in charges for hospital-based SNFs.34 The same study found that for-profit, freestanding SNFs decreased the proportion of patients with greater than $200 in charges from 19 percent in 1997 to just 1.6 percent in 2000.^34^

Zinn et al. tested several hypotheses linking the administrative burden of the SNF PPS (as proxied by administrative nurse staffing) to for-profit status, chain affiliation, and size.40 The study (rated fair) reported that “medium” SNFs (between 100 and 199 beds) and “large” SNFs (200 or more beds) had about 5 percent higher administrative nurse staffing post-PPS compared to “small” SNFs with fewer than 100 beds (p<0.01). The study reported no differences in administrative nursing levels between chain and non-chain SNFs and for-profit vs. not-for-profit SNFs.

Konetzka examined differential effects on staffing and regulatory deficiencies among different types of facilities and found no strong pattern of differential effects between for-profits and nonprofits or between chain and independent facilities (study rated fair). While the authors stressed that the results were not conclusive, they noted somewhat stronger evidence that hospital-based facilities responded to PPS (and subsequent rate adjustments) more strongly than freestanding facilities.29 Similarly, the same researchers examined differences in incidence of urinary tract infections and pressure sores by facility type (for-profit/non-profit) and market characteristics (high-occupancy area/low-occupancy area). The study (rated fair) reported no consistent, statistically significant differences in overall effect based on these variables.27

Patient characteristics. One fair study reported differential utilization outcomes for relatively high-functioning and low-functioning patients.26 This study found that use of physical therapy and occupational therapy increased for the highest functioning patients in PPS facilities, while there was no significant difference among patients at lower functional levels at admission. The same study reported that despite increased therapy provision, community residence 60 days after admission did not change for the highest functioning patients.26

SNF characteristics. Afendulis et al. (2011) tested whether the Medicare SNF PPS had a differential impact on hospitalized stroke patients in areas with higher integration between hospitals and SNFs (i.e., in areas with less competition).21 They found the SNF PPS led to larger declines in the use of any SNF services in more integrated areas. They also found spending declined in more integrated areas (by 5.3% from 1997-1999, p<0.05) but not in less integrated areas. There were no differential effects in quality measures across more and less-integrated areas. This result may be due to effective self-referral in integrated hospital-SNFs prior to PPS.

### Medicare Inpatient Rehabilitation Facility Prospective Payment System

#### Description of the Payment Model

##### Implementation

The Medicare Inpatient Rehabilitation Facility Prospective Payment System (IRF PPS) replaced a retrospective, average cost per discharge payment system with facility-level annual total reimbursement caps on January 1, 2002. The IRF PPS was one of several new Medicare post-acute care payment systems introduced in the 1997 Balanced Budget Act. IRFs were defined by CMS as inpatient facilities which admit more than 60 percent of cases from a list of 13 qualifying medical conditions.

IRFs with fiscal years starting between 1/1/2002 and 9/30/2002 could choose to blend the previous payment system (one-third) with the new PPS (two-thirds) for that year only. IRF PPS reimbursement rates were usually increased annually to reflect changes in a market basket index, but the Medicare, Medicaid, and SCHIP Extension Act of 2007 held payments constant for the second half of 2008 and all of 2009 (following increases of about 3 percent in 2006 and 2007).

##### Payment Method

The IRF PPS bundled all operating and capital costs into one per-discharge payment for each of 92 Case Mix Groups (CMGs). The CMG system tied payment amount to patient diagnosis, functional status, cognitive status, age, and comorbidities using 92 separate codes. The IRF PPS included separate payment for short-stay outliers, for patients who die prior to discharge, for patients transferred out of the IRF setting, and for high-cost outliers.

Payment rates were updated each federal fiscal year by CMS using an IRF market basket index (including capital). Rates were also adjusted for geographic variation in wages using the hospital wage index, for facility-level proportion of low-income patients, and for teaching status.

The IRF PPS included some patient cost sharing. Beneficiaries admitted from the community (rather than an acute care hospital) pay a deductible (about $1,000) at admission and a copayment (about $250) per day for the 61^st^ through 90^th^ days. Total IRF days are subject to beneficiary-specific caps (90 days for all hospital care per illness).

#### Summary of Findings

##### Comparison Payment Methods

All reviewed studies (n=10) compared the IRF PPS to the previous Tax Equity and Fiscal Responsibility Act (TEFRA) retrospective cost-based system. Four studies reported differential pre/post results for Medicare and non-Medicare beneficiaries. One study assessed the impact of each Balanced Budget Act PPS intervention, including the IRF PPS, on utilization of IRF care and of other types of post-acute care.

##### Overview of Design of Relevant Studies

Most studies (n=8) specifically studying the Medicare IRF PPS assessed changes in patient outcomes (all eight studies), IRF utilization (all eight studies), or Medicare IRF spending or costs (three studies) before and after IRF PPS implementation. One additional study compared IRF financial outcomes before and after the PPS.45 Of the eight studies focusing on patient-level effects, two considered stroke patients only,43,44 one considered spinal injury patients only,47 and one specifically analyzed the impact of IRF PPS on speech and language services.42 One study considering a range of cost, length of stay, and clinical quality measures was rated “good” by reviewers.49 This study included a hospital-level choice model and employed a sophisticated (instrumental variables) identification strategy to measure the impact of the IRF PPS free from the effect of any confounders. Of the other eight studies, five were rated “fair” and three were rated “poor” by reviewers. The poor studies generally reported only univariate analyses without considering potential confounders (all three), and/or lacked generalizability due to the small number of IRFs studied (two of the three). Reviewed studies provided limited information on the long-term impact of the IRF PPS: Six studies used “post” data from 2003 or earlier, one used 2004 data, and two used 2006 data (compared to the PPS implementation date of January 2002).

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

Three studies assessed the impact of the IRF PPS on Medicare spending or resource use by IRFs. Overall, these studies suggested the IRF PPS slowed but did not reverse Medicare IRF spending growth. One good study concluded that the elimination of marginal reimbursement (i.e., payment for additional ancillary or other services) under PPS led to a 7-11 percent reduction in provider costs per IRF patient (p<0.01).49 This reduction was offset by an increase in average reimbursement per IRF patient over the PPS implementation period: The net change was a 5-7 percent increase in provider costs per IRF patient. The key insight from this study is that provider costs did not increase proportionally with increases in reimbursement. Instead, the study found each one percent increase in reimbursement resulted in a 0.3 percent increase in provider expenditure on patients, implying IRF patients received proportionally less care per reimbursement dollar paid to IRFs.49 A second study (rated fair) found a larger than expected decline in patients assigned to “high resource use” cases after controlling for CMG groups and other observables suggesting IRFs admitted fewer relatively high cost patients within CMG groups post-PPS.46 Finally, a poor study found Medicare spending per discharge increased post-PPS but at a slower rate for IRFs transitioning to PPS in 2002 (2.6 percent) compared to IRFs with blended PPS/TEFRA reimbursement in 2002 (12.8 percent) without controlling for observable differences between IRFs, suggesting PPS slowed the rate of IRF spending growth (difference p<0.01).45 The same study reported that the operating costs per discharge declined for IRFs transitioning to PPS in 2002 (-5.8%) compared to IRFs with blended PPS/TERFA reimbursement in 2002 (0.4% increase; difference p<0.01).

###### Effect on Health Care Utilization

Many studies assessed the impact of the IRF PPS on average length of stay. These studies consistently attributed a decrease in average length of stay to the IRF PPS. Five studies (one poor, three fair, one good) reported reduced length of stay with effects ranging from three to 11 percent after adjusting for covariates.41,44,46,47,49 Another study, rated poor, found that the post-PPS decrease in average length of stay was smaller for IRFs transitioning to PPS (an eight percent decrease from 16.7 to 15.4 days) compared to IRFs with blended PPS/TEFRA reimbursement in 2002 (a 14 percent decrease from 16.2 to 13.9 days) without controlling for observable differences between IRFs.45 A fair study focused on language-related services and reported a 25 percent reduction (from 23 days pre-PPS to 17 days post-PPS) in language-related length of stay post-PPS without controlling for potential confounders. This dramatic reduction in length of stay was offset by an increase in sessions per week: For example, the proportion of language rehabilitation patients receiving five or more sessions per week increased from 11 percent pre-PPS to 77 percent post-PPS (difference p<0.001).42 One fair study of three IRFs found no aggregate change in length of stay post-PPS, without adjusting for covariates.43

A previously mentioned fair study assessed the impact of each PPS introduced in the 1997 Balanced Budget Act on substitution between IRF, SNF, home health, or no Medicare post-acute care after controlling for patient and facility characteristics.22 Substitution between provider types is an important outcome as it affects Medicare's overall expenditure on post-acute care. This study found the IRF PPS was not immediately associated with an increase in the probability of IRF utilization for hip fracture, stroke, or joint replacement patients, but was associated with a decrease in the probability of receiving no Medicare post-acute care for all three patient groups, a decrease in the probability of receiving home health care, and an increase in the probability of receiving SNF care (all p<0.05). The IRF PPS was also, over time, associated with a higher probability of IRF use and a lower probability of SNF use for hip fracture patients (both p<0.05).22

###### Effect on Health Care Quality

Several studies measured changes in functional improvement (using the FIM, or Functional Independence Measure) and other clinical quality measures. These studies found that the effects of the IRF PPS on quality were generally small in magnitude and mixed, with some measures improving post-PPS and some declining post-PPS.

The difference in FIM scores between IRF admission and discharge (“FIM score improvement”) was the most commonly used quality measure in studies of the IRF PPS. Two studies (one fair, one good) reported no or minimal change in FIM scores post-PPS.47,49 Four studies reported a decrease in FIM score improvement post-PPS. The magnitude of the effect ranged from a 15 percent decline in FIM improvement for severe CMGs (p=0.049) and a 10 percent decline in FIM improvement for all CMGs (p=0.034),43 eight percent (p<0.05) in a fair study of motor FIM at three IRFs, 48 and 21 percent (p<0.001) in an unadjusted estimate in a single IRF in a study rated poor.44 In contrast, FIM improvement increased by 35 percent (unadjusted) post-PPS in a study of mild CMGs in three IRFs, and by 51 percent in a poor-rated study of cognitive FIM only in four IRFs.48

One additional fair study used the condition-specific Spoken Language Comprehension functional communication measures and found that, while more patients improved on this utility post-PPS (unadjusted estimate of 80 percent versus 67 percent, p=0.004), fewer patients achieved multiple levels of functional improvement post-PPS (p<0.001).42 Treatment-related progress in communication and swallowing did not differ pre/post-PPS.

Two studies assessed discharge outcomes. The first (rated poor) found discharge to the community was less likely post-PPS at a single IRF (p<0.001).44 The second (rated fair) reported no significant change in discharge to the community post-PPS.43

Two studies assessed mortality outcomes, with the first (rated good) reporting no significant impact of PPS on 60-day mortality among patients discharged to the community post-PPS49 and the second (rated fair) reporting a slight (0.5 percent) decrease in predicted 150-day mortality post-PPS (p<0.001).46

Finally, one poor study assessed patient satisfaction and found patient-reported satisfaction increased slightly (from 60.3 percent to 63.4 percent, p<0.01) post-PPS at four affiliated IRFs.48

###### Other Effects

Patient health status. One fair study noted the shifting of patients from more severe CMGs to less severe CMGs, at least for occupational and physical therapy services. This study reported a 20 percent decrease in patients in severe CMGs and a 20 percent increase in patients in moderate CMGs without controlling for potential covariates.43

IRF operations. One poor study specifically evaluated the effect of the IRF PPS on IRFs rather than patients. This study found that IRFs transitioning to PPS in 2002 experienced larger increases in operating margin and total profit margin (12.3 percent and 12.6 percent, respectively) compared to IRFs with blended PPS/TEFRA reimbursement in 2002 (6.5 percent and 4.7 percent, respectively) without controlling for observable differences between IRFs.45

Spillover effects for non-Medicare beneficiaries. Several studies compared the impact of the IRF PPS on Medicare beneficiaries and patients with other payers, e.g., Medicaid or simply all non-Medicare patients aggregated together. In general, differences between these patient populations make comparisons across payers untenable. The addition of Medicare per-beneficiary, per-admission hospital care caps introduces an additional complication. Still, some studies reported interesting “spillover” outcomes of the IRF PPS on non-Medicare patients. One fair study found length of stay for non-Medicare patients decreased by an additional 1.3 days a year post-PPS (p=0.031) after controlling for an existing downward trend in length of stay.47

Dobrez et al. also report differential results for Medicare and non-Medicare beneficiaries (study rated fair). These authors found the decline in average length of stay post-PPS was similar for Medicare and non-Medicare patients, although Medicare patients had lower discharge motor function and cognitive FIM scores (p<0.05) and were less likely to be discharged to the community post-PPS (p<0.01) compared to no significant change for non-Medicare patients on both of these outcomes.41 These differential results are taken from separate regressions on the Medicare and non-Medicare populations with dissimilar sample sizes and underlying characteristics.

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

Patient characteristics. Several studies reported differential effects of bundled payment by patient characteristics. The reviewed studies often presented separate subgroup analyses without testing for statistically significant differences in outcomes across groups.

In one fair study comparing predicted to observed post-PPS average length of stay and spending per case between patients with different health conditions, post-PPS average length of stay was lower for hip fracture patients (12 percent below predicted average length of stay) than for lower extremity joint replacement or stroke patients (about 11 percent and 9.5 percent below predicted average length of stay, respectively).46 A post-PPS reduction in spending per case was larger for hip fracture patients (about 6 percent below predicted spending) than for joint replacement or stroke patients (about 4 percent and 5.5 percent below predicted spending, respectively). While individual results were significant with p<0.01 except for the joint replacement spending result, the study does not report whether the comparisons across groups are statistically significant.

Another fair study reported differential outcomes for patient condition-payer categories and found the IRF PPS was associated with significantly longer length of stay for only Medicare incomplete tetraplegia patients (p<0.05), and not for incomplete paraplegia, complete paraplegia, or incomplete tetraplegia.47

In another fair study limited to three IRFs, FIM score improvement declined 15 percent post-PPS for severe CMGs (from 33.3 to 28.2, p=0.049) but dramatically increased for mild CMGs (41 percent, from 14.0 to 19.8, p=0.015).43

### Medicare Home Health Prospective Payment System

#### Description of the Payment Model

##### Implementation

The Medicare Home Health (HH) Prospective Payment System (PPS) replaced a cost-based payment system on October 1, 2000. The HH PPS was one of several new Medicare post-acute care payment systems introduced in the 1997 Balanced Budget Act. Between the 1997 announcement and 2000 implementation of the HH PPS, the Balanced Budget Act outlined an Interim Payment System which began in October 1997 and imposed additional controls on the previous cost-based reimbursement system, including controls on per-visit costs and per-patient caps. A revised Interim Payment System began in October 1998 and relaxed but did not eliminate per-visit and per-patient caps. Medicare home health spending declined from $18.3 billion in 1997 to $9.5 billion in 1999 before the HH PPS began in October 2000.

##### Payment Method

The HH PPS bundled all skilled nursing care, physical, occupational, and speech therapy, medical social work, and home health aide services received at home during a 60-day episode into a single payment for each of 153 Home Health Resource Groups (HHRGs). No beneficiary cost sharing was required. HH PPS rates were updated annually based on a home health market basket index. Rates were also adjusted for geographic variation in labor and non-labor input prices. The HH PPS did not impose a cap on the number of 60-day episodes a single beneficiary can use.

The HHRG system tied payment amount to patient clinical characteristics, functional score, and service utilization using 153 separate codes. The HH PPS excluded patients with fewer than five stays in a 60-day episode (these visits are reimbursed at a per-visit rate) and included a high-cost outlier payment. Home Health Agencies (HHAs) received half of the reimbursement rate when the Medicare fiscal intermediary received the initial claim, and the balance at the end of the 60-day episode.

#### Summary of Findings

##### Comparison Payment Methods

All reviewed studies (n=9) compared the HH PPS to previous retrospective cost-based systems (including the Interim Payment System and revised Interim Payment System). One study assessed the impact of each Balanced Budget Act PPS intervention, including the HH PPS, on utilization of home health care and other types of post-acute care.

##### Overview of Design of Relevant Studies

Most reviewed studies (n=6) were retrospective observational studies tracking pre and post patient cohorts. Three additional studies were retrospective observational studies tracking home health agencies pre/post PPS implementation. Only one study considered a robust set of controls for potential confounders (FitzGerald et al 2006). The same study also focused specifically on Interim Payment System/PPS differences. Other papers examined changes attributed to both the Interim Payment System and PPS (and sometimes the revised Interim Payment System) over the initial cost-based system. Reviewed studies provided limited information on the long-term impact of the HH PPS: Five studies used “post” data from 2001, three from 2002, and only one from 2003 (compared to the PPS implementation date of October 2000). Reviewers ranked three of the six patient-level studies as “poor,” primarily because they were descriptive, pre/post studies with little or no mention or assessment of potential confounders. Two of the three home health agency-level studies were ranked “poor” for essentially the same reasons.

One additional study rated fair evaluated the Medicare National Home Health Prospective Payment Demonstration.13 The demonstration enrolled 48 treatment HHAs and 43 control HHAs in five states (CA, FL, IL, MA, and TX). All Medicare patients at treatment HHAs were transitioned to a 120-day home health episode-based prospective payment system. The bundled payment included aide services, skilled nursing services, physical and occupational therapy, medical social services, and speech therapy. Reimbursement rates were case-mix adjusted for each HHA based on patient preadmission characteristics and the hospital care history. The demonstration included outlier payments and special treatment of “phase-in” and “phase-out” visits at the beginning and end of the demonstration. The demonstration included significant loss-sharing between HCFA and participating HHAs (between 97 and 99 percent of losses covered by HCFA). Control HHAs were reimbursed actual costs up to 112 percent of the average case-mix adjusted costs across all agencies in the same geographic area.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

One poor study evaluated the effect of the HH PPS on Medicare spending and suggested home health spending increased at the same time the HH PPS was implemented. The study found Medicare mean annual payments per home health user increased in aggregate 11 percent post-PPS with wide variation across patient diagnoses, from a 41 percent increase in mean payments per users with orthopedic diagnoses to an 18 percent decrease for those with diabetes diagnoses (test statistics or p-values not reported for pre/post comparisons).57 The same study reported spending per home health visit (rather than per episode) increased by 38 percent in the first year of PPS after adjusting for inflation and home health discipline. Beneficiaries received fewer total visits (25 percent) but more skilled (10 percent) visits post-PPS, suggesting growth in per visit spending is driven by patients shifted to HHRGs with higher reimbursement rates. No studies evaluated the impact of the HH PPS on the cost of providing an episode of home health care.

The National Home Health Prospective Payment Demonstration evaluation found the average Medicare spending on participating HHAs was 20 percent less than the average Medicare spending on control HHAs.13 The reduction in Medicare spending was primarily due to lower spending after the 120-day episode cutoff. Participating HHAs earned larger profits over time, from no profit in year one to 2.6 percent of Medicare revenues in year two to 7.8 percent in year three. Reductions in HHA costs per episode were larger (approximately 14 percent, p<0.01) but were offset by higher costs per visit (approximately 14 and 10 percent increases in costs per skilled nursing visit and per home health aide visit, respectively (both p<0.01). While profits as a percent of Medicare revenues increased over time, total HHA Medicare revenues declined by 20 percent on average (from $4.4 million, p<0.01).

###### Effect on Health Care Utilization

Studies assessing the impact of the HH PPS on utilization generally found a negative and significant effect of PPS on the number of visits per episode. Four studies (three fair, one poor) reported reductions of between 10 and 25 percent in aggregate visits per episode depending on patient diagnosis.53,54,57,58 A fifth study (rated poor) decomposed the aggregate reduction in visits by visit type and reported a larger decline in aide visits per user (rather than per episode; 34 percent) than for nurse visits per user (23 percent; test statistic or p-value not reported).51 One fair study reported an 8 percent increase in therapy visits per episode contrary to the overall consensus on a decline in all-type visits, perhaps because the number of therapy visits is one criterion used to assign patients to HHRGs.58 Studies (two fair, one poor) assessing the probability of any home health utilization found no54 or small55,57 declines over the HH PPS implementation period.

A previously mentioned study assessed the impact of each PPS introduced in the 1997 Balanced Budget Act on substitution between IRF, SNF, home health, or no Medicare post-acute care after controlling for patient and facility characteristics.22 Substitution between provider types is an important outcome as it affects Medicare's overall expenditure on post-acute care. This study found the HH PPS was immediately associated with a decrease in the probability of receiving home health care for hip fracture, stroke, and joint replacement patients (between 0.5 percent and 1.5 percent, all p<0.05), an increase in the probability of receiving no Medicare post-acute care for all three patient groups (between 0.2 percent and 0.8 percent, all p<0.05), and an increase in the probability of receiving SNF care for stroke and joint replacement patients (1.0 percent and 1.1 percent, respectively, both p<0.05).

The National Home Health Prospective Payment Demonstration evaluation found participating HHAs provided 17 percent fewer visits than control HHAs (37 versus 45 visits on average).13 Participating HHAs provided 33 percent fewer visits in the eight months after an episode (20 versus 30 visits) and 24 percent fewer visits over a one-year period starting at the beginning of an episode (57 versus 75 episodes). Participating HHAs had significantly shorter episode length.

###### Effect on Health Care Quality

Only two studies (rated fair) examined the impact of the HH PPS on quality. Effects on quality measures were generally small and inconsistent, with some improving post-PPS and some declining post-PPS. One study noted most stabilization measures (i.e., outcome measures capturing the fraction of patients whose conditions do not decline while receiving home health services) improved.58 Another study based on responses to a small (n=68) survey suggested the HH PPS contributed to an increase in hospital readmissions.56

The National Home Health Prospective Payment Demonstration evaluation found quality measures differed slightly between participating and control HHAs, with about as many measures improving in participating HHAs as in control HHAs.13 Twelve improvement in clinical symptom measures, three emergency care measures, two improvements in activities of daily living measures, and two other measures were significantly higher for participating HHAs, and three stabilization in activities of daily living measures, two improvement in instrumental activities of daily living measures, three stabilization in instrumental activities of daily living measures, three patient satisfaction measures, and two other measures were significantly higher for control HHAs.

###### Other Effects

Patient health status. One study noted a shift towards higher-reimbursement HHRGs post-PPS. It is unclear if this was caused by changes in patient characteristics or upcoding by providers.58

Implementation challenges. Two studies based on survey data collected from administrators in rural home health agencies provided insight into HH PPS implementation challenges. These studies suggested the PPS led to increased staffing, changes in staffing activities, demands on existing staff, and job-related stress driven by the administrative burden imposed by PPS (study rated poor),56 and that 40 percent of home health agencies reported financial vulnerability and 24 percent reported financial uncertainties post-PPS, but more home health agencies reported their financial situation improved rather than worsened from Interim Payment System to PPS (64 percent versus 22 percent, test statistic or p-value not reported; study rated fair).55

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

Provider profit status. One fair study reporting reductions in visits per episode54 found larger (approximately two times as large, p<0.0001) declines for for-profit home health agencies (for hip fracture and elective joint replacement patients).

Patient characteristics. The same study found larger declines in visits per episode for dual eligibles (for elective joint replacement patients only) and for women (for elective joint replacement patients only). This study and another fair study by the same lead author53 found slight differences in the impact of bundled payment across various patient diagnoses. Briefly, hip fracture patients experienced a slightly larger post-PPS decline in the probability of receiving home health care (five percent) than elective joint replacement patients (two percent) after adjusting for patient, institutional, and regional covariates. However, hip fracture home health users experienced a larger 16 percent decline in mean home health visits during a 120-day episode compared to a 10 percent decline for elective joint replacement surgery patients (statistical significance not reported for pre/post differences). These authors do not report the net implications on overall Medicare home health spending.53,54

The impact of bundled payment on probability of home health use and the number of visits also varied by CMS regional office geography (study rated fair).53 The pre-PPS probability of using home health ranged from 31 percent for hip fracture patients in the Kansas City region to 70 percent for elective joint replacement patients in the Boston region. The impact of bundled payment on the probability of utilization ranged from zero (Kansas City and Chicago joint replacement patients and Boston hip fracture patients) to 11 percent for Denver hip fracture patients. Similarly, the pre-PPS number of visits per 120-day episode ranged from 10.1 for Seattle region elective joint replacement patients to 44.4 for Dallas region hip fracture patients, and impact of bundled payment on the mean number of visits ranged from a decline of 0.5 percent for hip fracture patients in the Seattle region to a decline of 24 percent for hip fracture patients in the Atlanta region.53 The authors do not posit explanations for these differences. Most individual regional outcomes differed from national outcomes with p<0.0001.

One fair study reported the impact of the HH PPS on individual quality measures for different levels of patient baseline severity (specific measures include improvement in transferring, stabilization in transferring, stabilization in housekeeping, improvement in dyspnea, improvement in urinary incontinence, and improvement in confusion frequency).58 While results in the stratified analyses were generally similar to the pooled analysis noted above, there were some differential effects, e.g., the measure “stabilization in transferring” was likely to worsen post-PPS for the least dependent patients (odds ratio 0.883, p=0.002) while more dependent patients were more likely to improve post-PPS (odds ratio = 1.631, p<0.001). The result for more dependent patients drove the pooled result of an improvement on this measure post-PPS (odds ratio 1.134, p<0.001). For improvement in dyspnea, the least severe patients were likely to worsen post-PPS (odds ratio =1.100, p=.001) while the expected impact of PPS on more severe patients was not statistically significant. The authors do not suggest a rationale for these results. Differential effects of bundled payment interventions on quality measures may suggest health care providers (in this case home health agencies) alter services provided or standards of care for some patient subgroups as a response to bundled payment which leads to differential change in quality measures.

One poor study reported the mean number of home health visits and mean payments by patient diagnosis in 2000 and 2001 (the PPS began in October 2000, test statistics or p-values not reported for pre/post comparisons). 57 Decreases in visits were similar across diagnoses ranging from a 19 percent decrease in orthopedic diagnoses to a 26 percent decrease for diabetes diagnoses. Payments increased in real terms for some diagnosis categories (by 41 percent for orthopedic diagnoses and 21 percent for neurological diagnoses) and decreased for others (by 18 percent for diabetes diagnoses and 7 percent for burn or trauma diagnoses). These analyses did not control for potential covariates over time or across patients.

### Medicare Long-Term Acute-Care Hospital Prospective Payment System

#### Description of the Payment Model

##### Implementation

The Medicare Long-term Acute Care Hospital (LTACH) Prospective Payment System (PPS) replaced the TEFRA cost-based payment system in October 2002. CMS defined LTACHs as acute care hospitals with average lengths of stay greater than 25 days. Medicare coverage of hospital stays (including post-acute care hospital stays in LTACHs and IRFs) was limited to 90 days per illness. The LTACH PPS was one of several new Medicare post-acute care payment systems introduced in the 1997 Balanced Budget Act and was designed to be budget neutral.

Individual LTACHs could choose to shift to the new PPS in fiscal year 2003 or to adopt a five-year phase-in program blending TEFRA cost-based reimbursement with the new PPS rates. Several restrictions on self-referral/transfer were implemented after the initial implementation of the LTACH PPS. The “25 percent rule” was phased in between 2006 and 2008 and limited the transfer of patients from an acute care hospital to an LTACH located in the same hospital. The 2007 Medicare, Medicaid, and SCHIP Extension Act of 2007 introduced a three-year moratorium or new or expanded LTACHs.

##### Payment Method

The LTACH PPS bundled the cost of care received in the LTACH setting, including operating and capital costs, into a single payment for each of 318 “Medicare severity long-term care DRGs.” While payment rates were not systematically updated, CMS has made changes over time, and the labor component of each DRG payment (76 percent of the total DRG rate) is adjusted for market area wages and cost of living adjustment for Hawaii and Alaska. Medicare beneficiaries admitted to LTACHs are subject to cost sharing unless they are transferred from an acute care hospital.

The Medicare severity long-term care DRG system tied payment amount to age, sex, discharge status (from acute care hospital), principal and secondary diagnoses, and procedures performed. The LTACH PPS included separate payments for high-cost outliers, short-stay outliers, and “interrupted-stay” patients transferred to another acute-care setting or readmitted to an inpatient hospital.

#### Summary of Findings

##### Comparison Payment Methods

The one reviewed study in this category compared LTACH staffing post-PPS to staffing under the pre-PPS cost-based payment system.59

##### Overview of Design of Relevant Studies

The one reviewed study in this category assessed the impact of Medicare's LTACH PPS on facility-level staffing intensity.59 This study included all LTACHs operating continuously from 2001 to 2004 (n=212). Reviewers rated this study as “fair.”

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

The one reviewed study in this category reported LTACHs increased staffing under PPS (by about one FTE per 1,000 inpatient days, or about a 12.5 percent increase from 2001 to 2004) compared to staffing under the previous cost-based payment system (test statistic or p-value not reported for pre/post comparison). While this result is contrary to the author's hypotheses, it might be explained by the self-selection of LTACHs into 100 percent PPS reimbursement or the five year PPS phase-in program in FY 2003. It may also be explained by the need for additional administrative staffing post-PPS.

###### Effect on Health Care Utilization

None reported.

###### Effect on Health Care Quality

None reported.

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

None reported.

### Department of Veterans Affairs Resource Allocation Methodology

#### Description of the Payment Model

##### Implementation

The Resource Allocation Methodology (RAM) was implemented by the United States Department of Veterans Affairs (VA) in 1985 as the system for financing hospital care within the VA health system. RAM replaced a system of global budgeting at the hospital level that was based on historical utilization and costs. The RAM was utilized for three years, and then replaced in 1988 by a system of case-mix-adjusted capitation.

RAM differed from other prospective payment systems in several ways. First, the VA operated under global budgeting at the system level, and increases in workload did not necessarily result in an increase in total VA funding. An increase in the total number of cases treated resulted in a decline in the payment per case with RAM. Second, the VA's budgetary process imposed a 2-year delay between changes in a hospital's volume and case-mix and the resulting changes in funding. This lag reduced the tie between efficiency and financial rewards. Third, to prevent unreasonable shifts in funds among hospitals and regions of the country, the VA capped the annual change in a hospital's budget. No hospital could gain or lose more than three percent of its previous year's budget.60

##### Payment Method

Under RAM, the unit of payment was the hospital admission. Institutions were paid a single prospective bundled payment, the level of which was based on the VA system-wide global budget and the total number of cases treated. Patients were assigned to diagnostic groups based on clinical characteristics that determined the actual level of payment. There was little additional information provided in the reviewed study about how payments were distributed, or whether quality measurement was incorporated into the RAM payment system.60

#### Summary of Findings

##### Comparison Payment Methods

The RAM was introduced by the VA to replace a global budgeting system in 1985. RAM was replaced by case-mix adjusted capitation in 1998. A single retrospective, observational study compared RAM to both of these alternate payment systems.60

##### Overview of Design of Relevant Studies

The reviewed study utilized data from all 172 VA hospitals, during a period spanning federal fiscal year 1982 through 1990. A multivariate analysis was performed using data for all discharges over that period among 22 medical and surgical diagnostic groups. These were selected based on volume, collective representation of conditions, inclusion of both discretionary and non-discretionary admissions, and diagnostic groups unaffected by technologic innovations.60 Reviewers rated the quality of this study as fair.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

None reported.

###### Effect on Health Care Utilization

While length of stay generally declined over the entire study period, these declines were steepest during the RAM years for 17 of 22 diagnostic groups. Relative to the preceding and subsequent time periods, annual declines in length of stay associated with RAM were less than five percentage points greater for medical diagnosis groups (treatment of chronic disease such as diabetes), four to 6.5 percentage point greater decline for surgical diagnosis groups, and larger for psychiatric patients (nine percent per year according to descriptive analyses). Similar effects were found on inpatient days per patient. The study found negligible associations between RAM and the number of discharges per patient, with slight increases in the growth rate in discharges under RAM for most diagnosis groups.60

###### Effect on Health Care Quality

None reported.

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

Reductions in length of stay and total inpatient days varied based on patient diagnosis. As noted above, RAM reduced length of stay relative to comparison payment methods for 17 of 22 diagnoses examined, and the most significant changes were seen among psychiatric diagnoses.

### Maine Medicaid Nursing Home Prospective Payment

#### Description of the Payment Model

##### Implementation

The Maine Medicaid Agency implemented a PPS for nursing home care in July, 1982. The Medicaid Agency accounted for 80 percent of nursing home payment days and nursing home revenue in Maine. The nursing home market in Maine was characterized by a high number of intermediate care beds, relatively high nursing home bed supply, and high baseline reimbursement rates for nursing home care.61

##### Payment Method

Under PPS, each facility in the state was assigned a prospectively determined per diem rate for nursing home care based on its historical costs. The nursing home PPS replaced cost-based reimbursement in the Maine Medicaid program. The single reviewed study did not provide additional details about the payment methodology.61

#### Summary of Findings

##### Comparison Payment Methods

The nursing home prospective per diem payment replaced cost-based reimbursement in the Maine Medicaid program.

##### Overview of Design of Relevant Studies

A single retrospective observational study examined admissions in all Maine nursing home between July, 1979 and June, 1985, bracketing the implementation of nursing home PPS in July, 1982.^61^ Reviewers rated the quality of this study as fair.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

Multivariate analysis indicated that total variable provider costs decreased over the three years following PPS implementation, by between $3.31 to $3.69 per patient day, off of a base of $33.17 in the final year before PPS. Patient care costs decreased in the range of $1.60 to $1.94 per patient day by the end of the study (off of a base of $17.61), and room and board costs decreased between $2.41 and $2.55 per patient day over in the initial three years after PPS (off of a base of $12.21). Results indicated a slight decrease in administrative costs after three years, although these costs initially appeared to increase (p-values on the prospective payment indicator variable positive and significant at p<0.01 for all results described above).61

###### Effect on Health Care Utilization

The analysis indicated no significant trend over the six-year period in the distribution of costs among patient care, room and board, and administrative costs as a percentage of total variable costs resulting from the change in payment system.61

###### Effect on Health Care Quality

None reported.

###### Other Effects

Results weakly indicated a relationship between PPS implementation and a decreasing Medicaid market share for nursing home care.61

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

None reported.

### New Hampshire Medicaid Inpatient Prospective Payment

#### Description of the Payment Model

##### Implementation

The New Hampshire Medicaid Agency replaced cost-based reimbursement with a PPS for inpatient care in January, 1989.

##### Payment Method

The New Hampshire payment system that was examined in this study was actually a mixed system that paid hospitals partially prospectively, and partially retrospectively based on costs. For psychiatric DRGs in particular, the Medicaid agency distinguished between three types of hospitals, and based reimbursement rates in part on hospital type. The three hospital types were known as Designated Receiving Facilities (DRFs), Distinct Part Unit hospitals (DPUs) and “scatterbed” hospitals. There were a total of 28 hospitals in New Hampshire at the time of the study: 3 DRFs, 8 DPUs, and 17 scatterbed facilities. New Hampshire also operated a state hospital, financed outside of the Medicaid reimbursement system, which accounted for a large share of psychiatric discharges prior to the payment change. The payment rates under PPS were based on historical costs, and were initially intended to be budget neutral.62

#### Summary of Findings

##### Comparison Payment Methods

PPS was compared with the previous system of cost-based reimbursement.62

##### Overview of Design of Relevant Studies

A single retrospective, observational study examined all psychiatric admissions to New Hampshire hospitals between July 1, 1987 and June 30, 1992. Patients over 65 years of age or under 21 years of age were excluded from the analysis. A number of control variables were included for multivariate analyses: gender, age group (four categories), race (white/nonwhite), a community proxy for the patient's average income, provider variables, and time dependent variables. Reviewers rated the quality of this study as fair.62

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

None reported.

###### Effect on Health Care Utilization

Multivariate analysis indicated that overall, a 14 percent reduction in length of stay (4.5 days per episode) among the study population could be attributable to payment system reform. The analysis utilized a complex theoretical model to separate this result into component effects, and determined that 1.8 days of the reduction resulted from “moral hazard effects,” 3.0 days were attributable to “practice style effects,” and “selection effects” added 0.3 days back to the total length of stay.62

###### Effect on Health Care Quality

None reported.

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

Changes in length of stay, and the portions of those changes that can be attributed to different effects (moral hazard, selection, and practice style) all varied according to hospital type. In addition, length of stay increased for short-stay patients, and decreased for long-stay patients. Virtually all of the total change in average length of stay was accounted for by changes in treatment for the longest stay patients.62

## U.S. Private Sector Single-Setting Bundled Payment Systems

We identified two studies of one bundled payment system implemented in a single private-sector health care setting in the United States.

### Case Rate for Managed Behavioral Health Care

#### Description of the Payment Model

##### Implementation

A single Managed Behavioral Healthcare Organization (MBHO) implemented a “case rate,” or bundled payment, for mental health services provided by 26 independent practice associations (IPAs) and group practice behavioral health providers. The payment system was phased in among participating providers between July, 1995 and January 1996, and was accompanied by assistance from the MBHO to providers with developing utilization and quality management capabilities.63,64

##### Payment Method

The MBHO case rate involved a single payment to providers for all outpatient mental health services over a period of one year, beginning with referral of the patient for treatment by the MBHO. The case rate payment included services provided by psychiatrists, psychologists and social workers, but excluded substance abuse treatment and inpatient services, which were paid separately. The payment rate was set based on historical utilization by all enrollees of the MBHO, and was not adjusted based on any individual patient characteristics.63,64

#### Summary of Findings

##### Comparison Payment Methods

In both studies, the case-rate system was compared to fee-for-service payment, which was still used by the MBHO to reimburse solo practitioners and small group practices.63,64

##### Overview of Design of Relevant Studies

The case rate for managed behavioral health care was examined in two observational retrospective studies of the same program by a single author. The studies tracked mental health providers over a period of 28 months (updated to 30 months in the second study) following the implementation of the case rate payment. The studies examined the impact of the new payment method on utilization of services, measured as the average number of encounters per episode of care. For the purposes of the studies, an episode of care was defined as a series of outpatient mental health visits with no more than eight weeks between any two of them. It is important to note that while this definition of episode was used for the analysis, it was not used within the payment system, where the episode (or “case”) was defined as a one-year period following initial referral for treatment by the MBHO.63,64 The first study reported that data was analyzed for a total of 21,673 individuals, including 10,488 who received care from case rate providers.63 The second study reported that it was based on analysis of data from 49,463 episodes of care.64 Both studies employed multivariate analyses to estimate the impact of case rate payment, and controlled for patient and provider characteristics. Reviewers rated the quality of both studies as fair.63,64

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

One of the two studies reported that patients under case rate payment were more likely to receive medication, be referred for self-help, or be referred to a community mental health center. This finding indicated that other treatment modalities were being substituted for therapy, which may or may not be appropriate, depending on the circumstances.63

###### Effect on Health Care Utilization

Both studies examined the impact of case rate payment on the number of mental health visits per episode, and found reductions of 20 to 25 percent (p<.05) depending on the model specifications.63,64

###### Effect on Health Care Quality

One study examined the probability that an individual treatment episode would consist of a single visit. The author hypothesized that a high proportion of single visit episodes would offer evidence of patient selection by providers, as they may attempt to divert high-cost patients after the first visit. However, the study found no difference in the proportion of single-visit episodes between the two payment groups.63

The same study examined MBHO quality assurance data to determine if there were differences between the two groups in the reported change in patients' Global Assessment of Functioning scores. No differences were detected, however the author points out that these data are reported by providers, so they may be biased.63

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

Provider characteristics. The studies noted that some case rate providers employed more intensive utilization review procedures. Among these providers, there was an additional reduction in visits of 22.3 percent (p<.01). Case rate providers also generally received some of their revenue through other contracts that continued to pay on a FFS basis during the study. The studies found that the effect on visits under the case rate was mediated by the percentage of total revenue to a provider that was paid by FFS. A case rate provider that received 50 percent of total revenue through FFS contracts was found to provide 34 percent more visits than a case rate provider who received no FFS revenue (p<.05). The author interpreted this as an indication that providers tend to respond to their dominant financial incentives in their treatment of all patients, and do not necessarily respond to payment changes for patients on an individual basis.63,64

## International Bundled Payment Systems

We identified studies of seven international bundled payment systems. All of the reviewed payment systems were implemented in the predominant public insurance program in each country. Six were inpatient prospective payment systems, and the seventh was a bundled payment system for outpatient hemodialysis. We discuss the payment systems in alphabetical order by country.

### Belgium Inpatient Prospective Payment System

#### Description of the Payment Model

##### Implementation

The public health insurance system in Belgium implemented an inpatient hospital PPS in 1995, replacing cost-based per diem payment. The primary source of revenue for Belgian hospitals was public insurance.65

##### Payment Method

The Belgian PPS covered hospital costs associated with an inpatient stay such as accommodation and nursing care, but excluding physician services. Hospitals received a single prospective bundled payment for each hospital admission. The payment was based on the assignment of the patient at admission to one of 604 condition groups. The single reviewed study provided little additional information about the payment methodology, including whether quality measurement is explicitly incorporated into the system.65

#### Summary of Findings

##### Comparison Payment Methods

The inpatient PPS was compared to the cost-based per diem payment system that preceded it in Belgium.

##### Overview of Design of Relevant Studies

The Belgian inpatient PPS was examined in one observational retrospective study. The study tracked hospitals over a period of eight years, spanning roughly equal periods before and after implementation, and included all inpatient stays in Belgium over that period.65 Reviewers rated the quality of this study as fair.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

The study found increases in spending on physician services (0.8 percent for surgical services and 0.5 percent for other medical services) after the implementation of the PPS (both p<0.05).65 The authors suggested this is due to negotiations between physicians and hospitals to distribute fees paid by the government to physicians for procedures performed in hospitals. The authors hypothesized the PPS induced hospitals to demand a larger share of these fees, which in turn induced physicians to increase the number of procedures performed to reach a target income.65 This phenomenon highlights the importance of considering indirect or downstream effects of bundled payment on the spending or utilization of services outside the scope of the bundled payment intervention.

###### Effect on Health Care Utilization

The study found a decrease of 1.49 percent in hospital length of stay attributable to the intervention (after controlling for cost sharing, death and transfer outcomes, and facility fixed effects, p<0.05).65

###### Effect on Health Care Quality

None reported.

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

Patient socioeconomic status. The study notes hospitals serving relatively few or many patients with low socioeconomic status (SES) responded to the IPPS differently in the year of the reform and afterwards. Specifically, in the year of the reform average length of stay decreased in high-SES hospitals and increased in low-SES hospitals. In later years, average length of stay decreased in low-SES hospitals and did not change in high-SES hospitals. The underlying secular decrease in average length of stay was similar in both groups. While the authors do not conjecture on the source of this difference, it is possible that high-SES hospitals responded to the bundled payment system by “cream skimming” relatively healthy patients or by shifting relatively sick patients to low-SES hospitals in the year of implementation.65

### National Health Service (England) Payment by Results

#### Description of the Payment Model

##### Implementation

England's National Health Service (NHS) instituted “Payment by Results” (PBR) in 2003 to pay hospitals for inpatient services. The NHS is the predominant payer for hospital services in England. The Payment-by-Results (PBR) system was phased in between 2003 and 2006 as part of a larger strategy to increase NHS efficiency.66

##### Payment Method

The PBR system implemented inpatient hospital payment, but the single study reviewed provided few details about how the payment system works and does not define the specific services included in the payment bundles. The study refers to PBR as a “case-mix-based, fixed-tariff” payment system, and it appears to have operated much like other inpatient prospective payment systems. Payment rates were adjusted for individual patient clinical characteristics, through the assignment of patients to Healthcare Resource Groups (HRGs).66

#### Summary of Findings

##### Comparison Payment Methods

The NHS PBR system was compared to a suite of payment arrangements that preceded it, known as block contracts, sophisticated block contracts, cost and volume contracts, and cost per case contracts.

##### Overview of Design of Relevant Studies

The NHS PBR was examined in one observational retrospective study.66 The study tracked hospitals over a period of four years, using statistics from the year spanning 2002-2003 through the year spanning 2005-2006. The study included 258 hospitals in England that were tracked before and after case-payment implementation, and 49 Scottish hospitals that were never subjected to case payment as additional controls. The English hospitals included two different types, known as foundation and non-foundation trusts. Foundation trusts were created in order to give high performing trusts more autonomy from central government control. They have more independence, and implemented the program more quickly, than non-foundation trusts. Foundation trusts implemented PBR for all elective and non-elective admissions in 2004/5, and non-foundation trusts implemented PBR for all elective admissions in 2005/6. The study included four separate difference-in-difference analyses based on pre-post and treatment-control comparisons:66

- Analysis 1: Changes in foundation trusts (treatment) were compared to non-foundation trusts (control) over the period from 2003/4 to 2004/5
- Analysis 2: Changes in foundation trusts (treatment) were compared to Scotland (control) over the period from 2003/4 to 2004/5.
- Analysis 3: Changes in non-foundation trusts (treatment) were compared to Scotland (control) over the period from 2004/5 to 2005/6.
- Analysis 4: Changes in foundation trusts (treatment) were compared to Scotland (control) over the period from 2003/4 to 2005/6, the only comparison that included two years of treatment data.

Reviewers rated the quality of this study as fair.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

None reported.

###### Effect on Health Care Utilization

In three of the four analyses (see above), length of stay fell more quickly where PBR was implemented, resulting in eight days (analysis 2), three days (analysis 3), and 18 days (analysis 4) saved per 100 admissions; in the remaining analysis (analysis 1), PBR resulted in two additional inpatient days per 100 admissions. All four comparisons showed that the proportion of elective care provided through day treatment increased more quickly where PBR was implemented, by (in order of analysis) 0.4, 0.4, 0.8 and 1.5 percentage points. Both foundation trusts and non-foundation trusts experienced a growth in volume associated with payment by results.66

###### Effect on Health Care Quality

The study examined several outcome variables, including in-hospital mortality, 30-day postsurgical mortality, and emergency readmission after treatment for hip fracture. Little evidence was found demonstrating an association between the introduction of payment by results and clinical outcomes. However, the fourth comparison did show a statistically significant reduction in in-hospital mortality over the first two years of PBR.66

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

While the reviewed study presented separate analyses for different types of hospitals, the authors did not directly compare or test for differential effects in outcomes across hospital types.

### Italy Inpatient Prospective Payment

#### Description of the Payment Model

##### Implementation

The Italian Ministry of Health implemented an inpatient prospective payment system on January 1, 1995. The Ministry of Health was the dominant payer for hospital services in Italy.67

##### Payment Method

Under the PPS, the Ministry of Health paid for all hospital costs associated with an admission, including physician costs, as a single prospective bundled payment. Payments were adjusted based on individual clinical characteristics, and varied by geographic region. The single reviewed study provided few additional details about the payment methodology.67

#### Summary of Findings

##### Comparison Payment Methods

The inpatient prospective payment system replaced cost-based reimbursement of hospitals in Italy.

##### Overview of Design of Relevant Studies

One descriptive study was reviewed which examined the impact of the inpatient PPS in Italy. It examined all cases of congestive heart failure in four hospitals selected because of perceived highly reliable diagnosis coding procedures, in the Marche region of Italy.67 Reviewers rated the quality of this study as poor, due to the small number of sites and a lack of control for confounding variables.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending/Costs

The average cost per discharge declined by 14 percent following the introduction of the PPS (p<.05).67

###### Effect on Health Care Utilization

Average length of stay decreased from 13.6 days to 11.7 days per case, for a reduction of 13.9 percent (p<.05). Total discharges increased by 10.3 percent, while congestive heart failure discharges increased by 13.4 percent and grew as a proportion of all discharges by 2.8 percent. There were no significant changes in the rate of hospital readmissions after three months.67

###### Effect on Health Care Quality

None reported.

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

Patient age. While reductions in length of stay and cost per case were relatively consistent across age groups, there was an increase in readmissions detected among patient 70 years of age and older of approximately 17 percent (p<.05). Statistically significant effects on readmissions were not detected in younger patients or in the study population as a whole.67

### Japan Outpatient Hemodialysis Bundled Payment

#### Description of the Payment Model

##### Implementation

Japan implemented a bundled payment for outpatient dialysis services on April 1, 2006. The Japanese government plays a central role in health care cost control through fee schedules and regulation. The outpatient dialysis services bundled payment system was designed to reduce spending on these services by four percent.68

##### Payment Method

The bundled payment included outpatient hemodialysis services (including for example, recombinant human erythropoetin [rHuEPO] and intravenous iron [iron]) provided at hospitals and clinics offering outpatient dialysis services. Little other information on risk-adjustment, distribution, or quality measurement was reported in the one reviewed study on this payment system.68

#### Summary of Findings

##### Comparison Payment Methods

One study examined the impact of replacing fee-for-service reimbursement with a bundled payment system for outpatient hemodialysis in Japan.

##### Overview of Design of Relevant Studies

One descriptive study examined this intervention, comparing prescription and dosing of rHuEPO and iron in a sample of 3,206 patients from 53 geographically representative outpatient dialysis sites. The study included a pre/post comparison of patients seen in a narrow, one-year period which spanned the bundled payment implementation date.68 Reviewers rated the quality of this study as fair.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

None reported.

###### Effect on Health Care Utilization

The study examined the number of patients receiving rHuEPO and iron, as well as the average dosages. While the study reported no significant change in the proportion of patients that received rHuEPO, it did report an 11.8 percent decrease in average rHuEPO dosage, suggesting that providers became more judicious in their use of this drug as a result of the policy. The prescription of intravenous iron was more likely after implementation of bundling, undergoing a 9.6 percent increase (p<0.001), while average dosage was not affected (p=0.15).68 Given that iron was relatively inexpensive compared to rHuEPO and similar drugs, providers may have been substituting iron among some patients as they reduced dosages of more expensive treatments.

###### Effect on Health Care Quality

No change in hemoglobin levels among dialysis patients was detected as a result of payment bundling,68 indicating that patients' conditions did not deteriorate due to the intervention.

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

Provider characteristics. The study identified differential effects by ownership and facility type, e.g., private hospitals were more likely to prescribe rHuEPO after bundled payment (by 5.2 percent, p<0.01, compared to no change in the aggregate sample and a negative but insignificant change in private clinics and public hospitals). Private clinics and hospitals showed a larger decline in rHuEPO dosage (12.1 percent and 13.7 percent, respectively) than public hospitals (8.8 percent), but this difference was not statistically significant. The net effect including changes in the probability of prescription and dosage was difficult to compare across provider types.68

Patient severity. The study also identified differential effects of bundled payment on relatively sicker patients (i.e., patients with lower hemoglobin levels). The authors found rHuEPO dosage decreased by 13.9 percent for relatively sicker patients (p<0.001) but only by 7.4 percent for relatively healthier patients (p=0.01). The percent of relatively sicker and relatively healthier patients receiving iron increased by 6.5 percent and 11.3 percent, respectively. The authors did not report a statistic testing whether differences for either outcome were significant. While relatively sicker patients experienced a larger decline in rHuEPO dosage and a smaller increase in intravenous iron use, it is unclear whether these patients were receiving appropriate prescriptions prior to the bundled payment intervention.68

### Netherlands Inpatient Prospective Payment

#### Description of the Payment Model

##### Implementation

An inpatient PPS was introduced in the Netherlands in 2005, and gradually replaced fee-for-service reimbursement of hospital care.69

##### Payment Method

Under the Netherlands inpatient PPS, hospital budgets were determined based on the number of Diagnosis Treatment Combinations (DTCs) they deliver. A single DTC consisted of all diagnosis and treatment related costs incurred by hospitals and clinicians over the course of an episode, from the initial consultation to the final follow-up visit. Unlike other similar systems in the United States and elsewhere, hospital budgets under PPS in the Netherlands were not open-ended. Hospitals negotiated with health insurers to determine the number of DTCs they may deliver each year. The single reviewed article that examined the Netherlands system did not provide any additional details regarding the PPS.69

#### Summary of Findings

##### Comparison Payment Methods

The inpatient PPS in the Netherlands was compared with the pre-existing fee-for-service reimbursement of hospital care.

##### Overview of Design of Relevant Studies

The Netherlands PPS was the subject of a single study employing a retrospective, observational design. The study was based on a survey of hospital Chief Executive Officers which was sent to all 96 hospitals in the Netherlands. The survey was intended to assess whether hospitals were more likely to establish care programs for patients as a step towards becoming more “process-oriented” under the PPS. The statistical analysis was oriented towards demonstrating relationships between management processes linked to payment incentives in a logic model, rather than showing an explicit link between payment bundling and the outcomes of interest.69 The reviewers classified the study as poor, as it relied on cross-sectional, self-reported survey data, with no adjustment for confounding variables.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

None reported.

###### Effect on Health Care Utilization

None reported.

###### Effect on Health Care Quality

None reported.

###### Other Effects

At the time of the survey, two years after the introduction of the PPS, 81 percent of hospitals reported that they undertook projects to establish care programs; 33 percent of care delivery was organized in care programs; 75.4 percent of hospitals appointed process owners for care processes; 93.5 percent of hospitals reported having clinical protocols for specific diseases; and 75 percent maintained organizational protocols for routing patients.69

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

None reported.

### Sweden Inpatient Prospective Payment System

#### Description of the Payment Model

##### Implementation and Payment Method

The Stockholm County Council implemented a PPS in 1992 to pay hospitals for inpatient admissions. Implementation coincided with a change in the authority in charge of nursing homes and long-term care. Local municipal welfare authorities took over the responsibility for about 80 percent of geriatric beds, which were previously administered by hospitals. The single reviewed study of the Swedish PPS included very few details about the methodology or parameters of the bundled payments.70

#### Summary of Findings

##### Comparison Payment Methods

The inpatient prospective payment system replaced fee-for-service reimbursement in Sweden.

##### Overview of Design of Relevant Studies

A single descriptive study examined the inpatient PPS in Sweden. The study examined patients in five Stockholm hospitals admitted for hip fracture before and after the implementation of PPS. The sample included 2,331 consecutive patients in the five hospitals, with 1,271 admitted after the initiation of the new payment method. Reviewers rated the quality of this study as poor due to its pre-post design and lack of control for confounding variables.70

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

Total costs per discharge increased by 12 percent, despite a decrease in orthopedic department costs (including surgery costs). The overall cost increase was due to an increase in post-acute care utilization. Home help costs did not change.70

###### Effect on Health Care Utilization

Average orthopedic department length of stay decreased by 42 percent after implementation of PPS (p<0.05), from 20 to 12 days. Total inpatient hospital days post-fracture decreased but were replaced by nursing home days. Total combined hospital and nursing home days increased by eight percent (p<.05), from 73 to 79 days.70

###### Effect on Health Care Quality

The percentage of patients discharged from the hospital to home decreased from 56 to 43 percent following PPS implementation with a corresponding increase in the percentage discharged to an institutional setting from 36 to 54 percent. At one year post-fracture, residence at home was 68 percent before PPS and 64 percent after PPS and residence in an institution increased from 11 percent to 14 percent; these changes were not statistically significant. Mortality at one year post-fracture remained constant at 21 percent. 70

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

As noted above, total costs per discharge increased by 12 percent for all Stockholm hospitals, however a single hospital operating a dedicated hip fracture unit actually decreased total costs by 12 percent under PPS. Taking into account only hospitalizations directly related to hip fractures, bed-days and total costs increased by 18 percent and 15 percent respectively for Stockholm hospitals in general, but decreased by 23 percent and 15 percent in the hospital with a dedicated hip fracture unit.70

### Taiwan Hospital Case Payment

#### Description of the Payment Model

##### Implementation

The Taiwan National Health Insurance Bureau implemented a PPS, referred to as “case payment,” for reimbursing hospital care on October 1, 1997. The PPS was implemented two and a half years after the introduction of National Health Insurance in Taiwan, which paid for about 95 percent of hospital services. Physicians and hospitals were generally highly integrated in Taiwan, and hospitals typically employed physicians.

##### Payment Method

Under the PPS, hospitals received a single prospective bundled payment for most costs related to an episode of care. The inpatient case payment included pre-defined “basic” and “optional” care elements, including tests, examinations, and medical treatments. Surgery-related examinations within a 2-week interval around a patient hospital episode were included as well. All other related outpatient care was excluded, as well as outlier costs above condition-specific thresholds. Cases were assigned to tiers based on individual patient factors, with higher rates for more complicated cases.

#### Summary of Findings

##### Comparison Payment Methods

The PPS was compared with pre-existing fee-for-service reimbursement for inpatient hospital services in Taiwan.

##### Overview of Design of Relevant Studies

Three studies examined the impact of the introduction of the PPS in Taiwan, including two retrospective observational studies72,73 and one descriptive study.71 One study examined all cases of five surgical procedures (n = 22,327) at three related teaching hospitals for one year before the change to the PPS and nearly two years following the change.73 A second study examined all hemorrhoidectomies performed in Taiwan (n = 23,638) for a period of nine months prior to implementation and nine months following the change in payment.72 The descriptive study looked at 199 appendectomies performed at a single hospital, half performed in the six months prior to the PPS, and the other half performed in the six months following the shift.71 Subjects in the two large studies averaged 45 to 47 years of age, and 35 to 40 percent were women.72,73 Subjects in the descriptive study were slightly younger, averaging 31 years of age.71 All three studies excluded patients with high costs that were classified as outliers.71-73 The reviewers rated the two observational studies as fair, and the descriptive study as poor due to its small sample size and inadequately controlled pre-post design.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

One fair study showed that inpatient claims were two percent lower in the first year and six percent lower in the second year of the PPS, compared to the final year of fee-for-service. Claims associated with x-ray imaging decreased by seven percent in the first year, and were 15 percent lower in the second year. Laboratory test claims increased by four percent in the first year of the PPS, but were four percent lower in the second year under the PPS compared to the final year under fee-for-service.73

The poor study found that total hospital costs were lower by 19 percent under the PPS compared to fee-for-service, including component decreases associated with room costs (35.1 percent), treatment costs (33.5 percent), pharmacy utilization (34.3 percent), examinations (25.3 percent) and anesthesia (9.2 percent) (all p < 0.01, except for anesthesia p < 0.05).71

###### Effect on Health Care Utilization

The two fair studies both found a decrease in length of stay post-PPS, with a decrease of 0.6 days per case in the first year of PPS and an additional 0.26 day decrease in the second year in one study,73 and a decrease of 0.6 days during the nine month follow-up period in the second study.72

Both fair studies also found that the PPS reduced some other types of utilization but also observed increased utilization of certain types of services. Wen found a decrease of 0.15 outpatient visits per case after two years of the PPS. Pre-surgery outpatient claims were 79 percent higher after 2 years of case payment, post-surgery outpatient claims were eight percent higher after one year but 117 percent lower two years after the change from fee-for-service, and overall outpatient claims were six percent higher after the first year of case payment but 61 percent lower after two years under the new system.73

The second fair study found that the number of minimally required services that were delivered increased (between 2.19 and 4.24 more items, p < 0.0001), the number of optional service items provided was lower (by 0.32 items, p < 0.0001), and medication prescriptions decreased slightly (between fewer 0.58 and 0.99 items, p < 0.0001) per hospitalization. Descriptive statistics showed a 24 percent increase in the number of surgeries performed under the PPS.72

In the poor study, the PPS did not have an effect on length of stay, and mean operating time and use of general anesthesia decreased (p<.01).71

###### Effect on Health Care Quality

The poor study found no significant differences in frequencies of painful incision sites, clear incision wounds on the day of discharge, and the removal of stitches at the hospital (p > 0.05 for all comparisons).71 The two fair studies did not examine quality outcomes.

###### Other Effects

One fair study showed that the number of comorbidities per case at intake increased, indicating more unhealthy patients were receiving surgery (p<.01).73

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

One fair study reported average length of stay reductions by type of facility.72 Average length of stay decreased by 0.59 days, 0.67 days, and 0.83 days at medical centers, district hospitals, and regional hospitals, respectively. The authors did not report baseline average length of stay, did not report tests for significant differences between these changes, and did not discuss the implications of these differences.

## Bundled Payment Systems Including Multiple Providers/Sites of Care

The reviewed studies included three bundled payment systems that included multiple providers and sites of care in the bundle, all implemented in the United States. We first discuss two Medicare demonstrations, then one private-sector program implemented by Geisinger Health System.

### Medicare Participating Heart Bypass Demonstration

#### Description of the Payment Model

##### Implementation

The Medicare Participating Heart Bypass Demonstration was intended to evaluate the feasibility and impact on spending and outcomes of a negotiated bundled payment system for coronary artery bypass graft surgery. Participating hospitals aimed to increase their market share by advertising themselves as Medicare Participating Heart Bypass Centers.

The Health Care Financing Administration (HCFA; now CMS) selected hospitals to participate in the demonstration program based on breadth of service coverage, performance on quality measures, financial incentives for patients and physicians, health information systems quality, heart bypass service volume, geographic diversity, and discount offered to Medicare for providing heart bypass services. Over 200 of the 734 hospitals invited to participate in the demonstration submitted initial applications. Of these, HCFA invited 42 to submit more extensive applications and to propose a bundled payment rate for two DRG codes (106 and 107, bypass with or without catheterization). Ten of the 27 responding hospitals were selected by HCFA as finalists, and of these four were selected to participate in the demonstration which began in 1991 (St. Joseph's Hospital in Atlanta, St. Joseph Mercy Hospital in Ann Arbor, The Ohio State Univ. Hospitals in Columbus, and University Hospital in Boston). Three additional hospitals were added to the demonstration in 1993 (St. Luke's Episcopal Hospital in Houston, Texas, St. Vincent's Hospital in Portland, Oregon, and Methodist Hospital in Indianapolis, Indiana). All but one of the demonstration hospitals were major teaching hospitals, all but one were not-for-profit (the remaining hospital was public), and the demonstration hospitals' beds accounted for seven to 28 percent of their respective markets.

While the demonstration was initially scheduled to end in June 1994, this date was pushed back to the second quarter of 1996 at the same time the three expansion hospitals joined. Participating hospitals were specifically excluded from changes to Medicare physician fee schedule rules which occurred during the demonstration. National cardiac bypass surgery trends changed dramatically during the evaluation period with a 40 percent growth in volume, 175 percent increase in post-acute care costs, and 33 percent decrease in length of stay. To control for these secular trends the demonstration hospitals were compared to nonparticipating hospitals in each market.

##### Payment Method

The bundle included all inpatient hospital and physician services for DRGs 106 and 107 and readmissions, including pro-rated pass-throughs for capital and medical education. Physician services before admission and after discharge were not included beyond those included in the surgical global period.

Participating hospitals were reimbursed a single per-discharge rate negotiated between HCFA and providers for DRGs 106 and 107 (when DRG 108 was reclassified into 106 and 107 in 1992, these patients joined the demonstration). These rates were updated annually based on Medicare IPPS and physician fee schedule rules in place at the start of the demonstration. There were no separate payments for high cost or low cost outliers, although negotiation did allow for an expected outlier payment included in the global rate based on each hospital's prior experience.

Hospital discharge abstract and physician bills were submitted by the hospital to Medicare for payment. The claims for physician services that were included in the bundle were not paid by Medicare but were tracked for evaluation purposes. Patients were subject to the usual Part B deductibles plus 20 percent coinsurance which, as the negotiated rate included all bundled services, resulted in a single coinsurance amount for each hospital/DRG.

HCFA did not specify how payments should be divided between the hospitals that received the payments and the participating physicians. All demonstration hospitals provided a capitated amount to specialists (i.e., the surgeon, anesthesiologist, cardiologist, and radiologist) while reserving some funds to compensate consulting physicians on an ad hoc basis.

Quality measurement was not intrinsic to the payment method. However, quality was assessed at participating hospitals as part of the demonstration evaluation. While demonstration hospitals provided clinical data on each patient as part of the demonstration, researchers used surveys to collect analogous data from patients at comparison hospitals. Panels of clinical experts reviewed the appropriateness of bypass surgery at demonstration hospitals.

#### Summary of Findings

##### Comparison Payment Methods

For some analyses, the evaluation report for this demonstration compared participating hospitals to control hospitals over time. Control hospitals were from the same markets as the participating hospitals and were reimbursed on a per-case basis for Coronary Artery Bypass Grafts (CABGs) while physicians at control hospitals were reimbursed fee-for-service. For other analyses, demonstration hospitals alone were tracked over time.

##### Overview of Design of Relevant Studies

The one reviewed report in this category is the Final Report submitted to HCFA (now CMS) by Health Economics Research, Inc. in July 1998.^75^ In addition to the direct evaluation of the bundled payment on spending, utilization, and quality, the demonstration included provisions for HCFA review of promotional materials and case study-based analysis of changes to the organization and practice of care. Reviewers rated the report as “fair” due to the small number of participating hospitals and the risk of bias from self-selected participants.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

Medicare spending on demonstration bypass patients (including spending on bundled and non-bundled services within 90 days post-discharge) decreased by 10 percent in aggregate between May 1991 and June 1996, with 86 percent of this decrease due to savings from negotiated bundled payment rates, five percent from decreases in post-discharge care expense (which were excluded from the bundled), and nine percent from net shifts in market share towards lower-cost hospitals.75 The hospitals' cost per bundle decreased between 18 percent and 40 percent in real terms for both DRGs at three of the original four demonstration hospitals. The fourth hospital (Ohio State University Hospital) experienced cost increases of 10 percent and 24 percent for the two DRGs (in nominal terms; cost increases were not reported in real terms).

###### Effect on Health Care Utilization

Length of stay declined between 0.5 and one day per year in all seven demonstration hospitals, but these changes differed between demonstration and comparison hospitals in only one hospital.75

###### Effect on Health Care Quality

The inpatient mortality rate declined at all demonstration hospitals, although this decline was significantly different than trends at comparison hospitals in only one case. Complication rates increased slightly at demonstration hospitals. Self-reported outcomes were not systematically different between patients at demonstration and comparison hospitals. Patients at demonstration hospitals reported higher levels of satisfaction with the overall skill of nurses, length of stay, and billing than patients at comparison hospitals.75

###### Other Effects

Two of the originally participating hospitals realized statistically significant gains in Medicare bypass market share while a third realized a statistically significant decline in share. All three hospitals added later in the demonstration realized statistically significant declines in Medicare bypass market share. Two of the four original demonstration hospitals realized significantly increased margins while the other two faced declines in margins (although margins remained positive for all demonstration hospitals). Feedback from demonstration hospitals suggests the administrative burden of implementing the bundled payment system was considerable and greater than anticipated. One particular challenge involved coordination and revenue sharing between hospitals and physicians.75

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

None reported.

### Medicare Cataract Surgery Alternative Payment Demonstration

#### Description of the Payment Model

##### Implementation

The Medicare Cataract Surgery Alternative Payment Demonstration was implemented from April, 1993 through April, 1996. The demonstration was carried out in four practice sites in three metropolitan areas (Dallas/Ft. Worth, Phoenix, and Cleveland), which were selected based on geographic, demographic and market characteristics. Selection criteria for the individual sites included the proposed bundle price, commitments for high participation among surgeons and ophthalmologists, demonstrated access to quality care for beneficiaries, historical practice patterns and utilization rates, and the presence of quality safeguards. Among the demonstration sites, participants included hospitals, hospital units, physician groups, and ambulatory surgical centers.76

Cataract surgery was selected as the focus of the demonstration following a 1988 report to Congress from the Physician Payment Review Commission. The report identified cataract surgery as the surgical procedure most frequently performed on Medicare beneficiaries and the single most costly procedure in the Part B program. In the years that followed, several regulations reduced the amount that Medicare reimbursed for outpatient cataract procedures. As a result, average allowed Medicare charges for surgeons performing cataract surgery dropped by 25 percent from 1986 to 1991. The demonstration also followed the introduction of the Resource-Based Relative Value Scale introduced in 1992, which set payment rates based on the relative value of medical services, fundamentally changing how Medicare physician payment rates were determined.76

The evaluation report noted several challenges in recruiting demonstration sites. Among the three geographic areas chosen for the demonstration, one had to be replaced due to insufficient response to the request for applications, and demonstration participation overall was low. In addition, a lawsuit brought by the American Academy of Ophthalmology sought to cease the demonstration before the sites could be recruited. The Academy criticized the demonstration design on the grounds that it lacked patient protections, violated federal and state anti-trust laws and several state medical practice laws, and did not substantially increase the amount of bundling relative to status quo Medicare payments for cataract surgery. The government ultimately prevailed in court and the demonstration went forward.76

##### Payment Method

Under the demonstration, participating provider sites received a single prospective bundled payment for providing cataract surgery. The provider sites negotiated the payment rates as part of their recruitment into the demonstration, and the rates were not risk adjusted once they were set. The bundle of care was defined as surgery for cataract removal and the insertion of an interocular lens (IOL) implant. In addition to facility costs, specific services that made up the bundle included pre-operative diagnostic tests (e.g. A-scan ultrasound, specular microscopy, flourescien angiogram), the pre-operative surgical evaluation (including keratometry), all surgical services (including pathology of the extracted lens, in applicable), all post-operative exams up to 120 days after surgery and final refraction, and treatment of all common complications. All professional services were part of the bundle, including those provided by surgeons, anesthesiologists, certified registered nurse anesthetists, surgical nurses, technicians, allied professionals, and clinical administrative personnel such as those involved in quality assurance, utilization review, discharge planning, project direction. Services provided prior to the ophthalmological tests and exams required for surgery were excluded, such as ophthalmological exams that determine the presence of cataracts and establish the need for surgery, and the general physical exam and medical release required for surgery. All services provided after 120 days from date of surgery were also excluded, as well as eyeglasses and drugs prescribed at discharge for self-administration.76

#### Summary of Findings

##### Comparison Payment Methods

Bundled payment for cataract surgery was compared with pre-existing Medicare fee-for-service reimbursement at the demonstration sites.

##### Overview of Design of Relevant Studies

A single prospective, observational study evaluated the Medicare cataract demonstration. This study compared all patients that received cataract surgery under the demonstration (n=4,565) with a randomly selected set of patients that received the surgery prior to the demonstration (n=5,343) in 1991 and 1992. The study excluded inpatient surgeries, surgeries that did not involve the insertion of an IOL implant, surgeries that qualified for an assistant surgeon, or surgeries that were aborted without the removal or the cataract.76 Reviewers rated this study as poor, due to the small number of non-representative, self-selected intervention sites, the contrived comparison group, and overall weak control for confounding variables.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

Medicare negotiated modest discounts of two to five percent relative to prior fee-for-service rates with the demonstration providers. Three of the four sites reported anecdotally that their costs had been reduced during the demonstration.76

###### Effect on Health Care Utilization

The evaluation found that no provider curtailed the use of specific services in the bundle such diagnostic tests, post-operative visits, total visits, or neodymium-doped yttrium aluminium garnet (nd:YAG) capsulotomy. Providers did not experience an increase in surgical volume that could be attributed to the intervention. All providers decreased the rate of nd:YAG capsulotomies delivered within 120 days of surgery, but this finding may have been caused by delaying this procedure in order to receive additional reimbursement.76

###### Effect on Health Care Quality

No change in clinical outcomes could be attributed to the intervention. The outcomes examined included visual acuity, complication rates, and changes in Snellan lines.76

###### Other Effects

One provider's patients exhibited more favorable pre-operative characteristics during the demonstration, but this could not be attributed to the intervention. The remaining sites exhibited roughly the same pre-operative patient characteristics.76

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

The report noted that a number of previous policies had reduced the price that Medicare paid for cataract surgery prior to the initiation of the demonstration project. Significant price reductions had already been achieved in the facility fee paid to the hospital or ambulatory surgery center for the procedure; in the charge for the IOL implant; and in the physician fee. Despite these recent price reductions, the authors noted that there was still potential to realize significant additional savings, however the demonstration did not impose sufficient price competition to do so.76

### Geisinger “Proven Care(SM)”

#### Description of the Payment Model

##### Implementation

Geisinger Health Plan (“Geisinger”) implemented the ProvenCare(SM) program on February 2, 2006. Geisinger was a large, non-profit integrated delivery system in central and northeast Pennsylvania, with approximately 210,000 members and a total service area population of roughly 2.6 million at the time of ProvenCare(SM) implementation. ProvenCare(SM) was initially implemented in three practice locations for elective CABG surgeries only. The bundled payment system was introduced together with an effort to re-engineer care processes, which included the introduction of 40 specific elements of care based on 20 clinical practice guidelines to be implemented and documented in each CABG episode.74

##### Payment Method

The ProvenCare(SM) CABG bundle was all-inclusive, spanning the preoperative evaluation and work-up; all hospital and professional fees; all routine post-discharge care, such as smoking cessation counseling and cardiac rehabilitation; and management of all related complications. Hospitals received a single prospective bundled payment with pay-for-performance incentives for delivering all 40 care elements, and provided a warranty for preventable follow-up care. The one reviewed study did not provide additional details regarding the payment methodology, and did not describe the payment system that preceded prospective bundled payment under ProvenCare(SM).74

#### Summary of Findings

##### Comparison Payment Methods

Not reported.

##### Overview of Design of Relevant Studies

A single observational retrospective study of ProvenCare(SM) was reviewed.74 The study included all 254 elective CABG cases performed at three Geisinger hospitals over approximately two years, with 137 in the year before the implementation of ProvenCare(SM) and 117 in the year after its introduction. Patients on average were 66 years of age, about three quarters were men, and nearly all were white.74 Reviewers rated the quality of this study as fair.

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

The study reported a reduction in hospital charges of five percent for ProvenCare(SM) patients compared to patients under previous payment methods.

###### Effect on Health Care Utilization

The study found no change in post-operative length of stay, a 16 percent reduction in total length of stay (from 6.3 to 5.3 days), and a 15.5 percent reduction in the rate of hospital readmissions at 30 days (from 7.1 percent to 6 percent).74

###### Effect on Health Care Quality

ProvenCare(SM) resulted in an increase from 59 percent to 100 percent in adherence to the full set of 40 care elements. There was no statistically significant change apparent across 19 health outcome measures including complications, operative mortality, and readmissions following the implementation of the program; the sample size (n=117 bundled payment patients and n=137 comparison patients) may have been too small to provide adequate statistical power for analyses of these health outcomes.74

###### Other Effects

The percentage of patients discharged to their home increased from 81.0 percent to 90.6 percent (p<0.05).74

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

The authors noted the organizational culture present within the Geisinger environment was essential to successfully implementing the intervention. They cautioned that applying the ProvenCare(SM) model outside of an electronic health record-enabled integrated delivery system may not achieve the same success.74

### Michigan Arthroscopic Surgery Bundling Pilot

#### Description of the Payment Model

##### Implementation

In 1987, a surgeon in Michigan partnered with a hospital to function as a single provider, and developed a bundled payment program for a set of well-defined surgical services for shoulder and knee problems. This episode based payment included a two-year warranty, meaning that in addition to the surgery and related services, the surgeon and hospital agreed to provide all associated follow-up care for two years after the surgery, including re-operation, if necessary. They contracted with an HMO to accept referrals of patients with shoulder or knee problems that HMO staff physicians determined to be surgical candidates. At the time, the providers believed that less invasive arthroscopic surgery technology that was not widely used yet in Michigan offered a potential profit opportunity, by minimizing the hospitalization expense for treatment of these conditions. The providers offered the bundled payment package between April 1, 1987 and December 31, 1989. 77

##### Payment Method

Under the bundled payment contract, the surgeon and hospital charged the HMO a single flat fee for all referred patients who went on to receive surgery. The surgeon and hospital calculated the fee based on their knowledge of typical costs and charges for the included procedures. The flat fee was split evenly between the surgeon and hospital. The surgeon took responsibility for office visits, radiographs, surgery, additional consultations for complications, follow-up care with video documentation, utilization review (through the electronic medical record), and program administration. The surgeon also agreed to perform any necessary repeat surgery under the single bundled payment. The hospital was responsible for expenses associated with hospitalization, laboratory tests, radiographs performed in the hospital, preoperative electrocardiograms (EKGs), consultation with a cardiologist (if necessary), anesthesiologist, physical therapy and occupational therapy on the day of operation, and any necessary repeat hospitalization. The warranty covered all subsequent related services provided by the surgeon and hospital for two years. The providers paid only for defined services under their control.77

#### Summary of Findings

##### Comparison Payment Methods

The bundled payment price was compared to expected fee-for-service charges for the same patients receiving the same care.77

##### Overview of Design of Relevant Studies

A single descriptive study of the Michigan arthroscopic surgery pilot was studied. The study included 111 patients referred by the participating HMO for surgical consultations. Of these, 49 patients ultimately received surgery under the bundled payment option. The patients averaged 40 years of age, ranging from 8 years to 84 years, and 26 percent were female. The study tracked these patients beginning with their referral through the end of the two-year warranty, for those who received surgery. Reviewers rated the study as poor, as it was descriptive in nature, with a small, selected sample of patients and providers, and had no external comparison group.77

##### Effects on Health Care Spending and Quality

###### Effect on Health Care Spending and Provider Costs

The study reported that health plan spending was reduced by 39 percent, based on the difference between the actual bundled payments made and the authors' calculations of the expected payments under fee-for-service. This calculation did not include reductions in spending associated with the 63 patients who did not receive surgery.

Using similar calculations, the authors reported that hospital revenue was increased by 14 percent for the patients participating in the pilot. The participating surgeon's revenue was 82 percent higher during the pilot than it would have been under standard fee-for-service contracts.77

###### Effect on Health Care Utilization

None reported.

###### Effect on Health Care Quality

None reported.

###### Other Effects

None reported.

##### Differential Effects by Key Design Feature

None reported.

##### Differential Effects by Key Contextual Factor

None reported.

a See Federal Register (2005), “FY 2006 SNF PPS Final Rule,” 70(149): 45025-45127.