# Methods

The methods for this comparative effectiveness review follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm). Below, we describe methods used for topic selection, input from stakeholders, inclusion and exclusion criteria, literature search strategies, data abstraction and management, assessment of methodological quality of individual studies, data synthesis, grading the evidence for each Key Question, and rating applicability of reviewed studies.

## Topic Selection

Topics for the Closing the Quality Gap: Revisiting the State of the Science series were solicited from the portfolio leads at AHRQ. The nominations included a brief background and context; the importance and/or rationale for the topic; the focus or population of interest; relevant outcomes; and references to recent or ongoing work. Among the topics that were nominated, the following considerations were made in selection for inclusion in the series: the ability to focus and clarify the topic area appropriately; relevance to quality improvement and a systems approach; applicability to the EPC program/amenable to systematic review; the potential for duplication and/or overlap with other known or ongoing work; relevance and potential impact in improving care; and fit of the topics as a whole in reflecting the AHRQ portfolios.

## Input From Stakeholders

A Technical Expert Panel (named in the front matter of this report) reviewed and provided input on topic definition, Key Questions, the search strategy, and preliminary search results. The review protocol was then posted on the Effective Health Care program page of the AHRQ Web site for transparency. Eleven experts in health care payment policy and individuals representing stakeholder and user communities provided external peer review of this report. AHRQ staff and an associate editor also provided comments. A draft report was posted on the AHRQ Web site for four weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented revisions in a disposition of comments report that was made available three months after the final report was posted on the AHRQ website.

## Criteria for Inclusion/Exclusion of Studies in This Review

Studies were included that address the Key Questions described above. All study designs were included, including experimental, observational, and descriptive studies. Relevant grey literature, including government and third-party evaluation reports, were included as well. These were identified through ad hoc searches of research sponsors' Web sites, reference mining, and recommendations from the Technical Expert Panel, as these are generally not included in literature databases. Publication date was limited to January 1, 1985 because health care financing has changed over time, potentially limiting the generalizability of earlier findings to the current health care system. The review includes studies published through January 17, 2012.

The following studies were excluded: (1) studies that did not report any of the outcomes of interest; (2) studies that did not report on a bundled payment intervention as defined above; (3) background articles or articles strictly limited to describing theoretical models.

Studies of interventions implemented in countries other than the United States were included only if they met broad criteria for generalizability to the United States. These criteria included:

- The country's delivery system provides similar types of services to the U.S. system (i.e., not low-income countries that provide a much different mix of services);
- The comparison payment method is predominantly fee-for-service as in the United States;
- The delivery context in which the intervention was implemented is similar to one that exists somewhere in the United States;
- The bundled payment intervention meets other inclusion criteria and the study addresses the key study outcomes of interest.

The search strategy did not use language restrictions, however no studies were identified that fit all other inclusion criteria and were not published in English.

## Searching for the Evidence: Literature Search Strategies for Identification of Relevant Studies To Answer the Key Questions

The objective of the search strategy was to identify all published bundled payment evaluations. A Technical Expert Panel reviewed and provided input on the search strategy and preliminary search results.

A librarian performed the initial literature search. One trained reviewer (CS), with input from a second trained reviewer (PH) on questionable titles, scanned the titles/abstracts of the list run by the librarian and selected studies for full-text screening. For each of the selected studies, reviewers performed further reference mining by scanning titles listed in the reference section to identify additional articles to be included. Reviewers reconciled their selections and made joint decisions, following all the inclusion/exclusion criteria listed in previous sections.

The initial search consisted of three separate queries, including one using PubMed and two using the Cochrane Library. The search terms utilized for these searches are provided below.

PubMed Search Terms:

(bundl*[tiab] OR episode[tiab] OR “prospective payment”[tiab] OR warranty[tiab] OR warranti*[tiab] OR global[tiab]) AND (payment[tiab] OR finance*[tiab] OR reimburse*[tiab] OR incentive*[tiab] OR fees[tiab]) AND (trial[tiab] OR compare*[tiab] OR effect*[tiab] OR impact[tiab] OR outcome*[tiab] OR result*[tiab])

First Cochrane Library Search Terms:

(bundl*:ti,ab OR episode:ti,ab OR “prospective payment”:ti,ab OR warranty:ti,ab OR warranti*:ti,ab OR global:ti,ab) AND (payment*:ti,ab OR finance*:ti,ab OR reimburse*:ti,ab OR incentive*:ti,ab OR fees:ti,ab) AND (trial:ti,ab OR compare*:ti,ab OR effect*:ti,ab OR impact:ti,ab OR outcome*:ti,ab OR result*:ti,ab)

Second Cochrane Library Search Terms:

(bundl*:ti OR episode:ti OR prospective:ti OR warranty:ti OR warranti*:ti OR global:ti) AND (payment*:ti OR finance*:ti OR reimburse*:ti OR incentive*:ti OR fees:ti) AND (trial:ti OR compare*:ti OR effect*:ti OR impact:ti OR outcome*:ti OR result*:ti)

### Systematic Reviews for the Medicare Inpatient Prospective Payment System

The Medicare Inpatient Prospective Payment System was implemented in 1983, and represented the first nationwide implementation of bundled payment in the United States. This program was studied heavily in the years after implementation, and these studies have been the subject of previous reviews. Given the large and relatively older body of research on this program and the availability of several published reviews, the researchers, in consultation with the Technical Expert Panel and following AHRQ guidance for using previously published reviews in systematic reviews, chose to consider a review of the review articles for the assessment this program, rather than reviewing individual studies.

The search and review process used for the identifying review articles was the same as those described above, with the exception of the search parameters. The terms utilized for this search are described below.

PubMed Search Terms:

(“prospective payment system” OR (PPS AND Medicare)) AND (Review) AND (impact* OR implicat* OR effect)

Cochrane Library Search Terms:

(“prospective payment system” OR (PPS AND Medicare)) AND (Review) AND (impact* OR implicat* OR effect)

## Data Abstraction and Data Management

Data were independently abstracted by two reviewers per study. The reviewers included three researchers (AM, CS, and PH) trained in the critical assessment of evidence. The following data were abstracted from included studies:

- Trial name;
- Setting and context (including but not limited to number of payers involved, market share, payer relationship with participating providers);
- Provider population characteristics (including but not limited to provider organization type(s), provider organization staffing, profit status);
- Patient population characteristics (including but not limited to sex, age, ethnicity, diagnosis and/or disease severity, baseline health care utilization);
- Eligibility and exclusion criteria;
- Interventions (including “anchor” procedure or diagnosis, services included in the bundle, payment methodology used, risk-adjustment methods, use of quality measurement);
- Any co-interventions;
- Comparisons;
- Results for each outcome;
- Funding source.

We abstracted all information relevant to the above points from reviewed studies. Many individual studies included incomplete descriptions of intervention design and context. The aggregate detail abstracted on some interventions, especially those described in one or a handful of studies, was often incomplete. The accuracy and completeness of descriptions of interventions in the Results section are limited by the availability of information in source studies.

We also abstracted the statistical significance of outcomes when directly reported in the reviewed studies. Studies did not always report test statistics or p-values for individual results or for pair-wise differences or comparisons across groups. We note p-values for individual outcomes when this information was available in the source study.

## Assessment of Methodological Quality of Individual Studies

We assessed the methodological quality of individual studies following methodology outlined in the EPC Methods Guide.11 Each individual study was given a summary rating of good (low risk of bias), fair, or poor (high risk of bias). Studies rated “poor” or “good” were also given a brief explanation of the basis for the rating. The focus of the rating system is to gauge absolute rather than relative strength of evidence presented in each study. Limitations imposed by the design or implementation of the intervention may limit the feasibility of some methodological approaches to evaluation. The rating for each study therefore reflects both study design and intervention characteristics. For example, a study utilizing the most appropriate methodology in a given intervention context may still be rated “fair” or “poor” due to limitations imposed by the intervention. The rating was based on the following list of specific criteria:

Several core elements apply to trials as well as observational studies:

- Similarity of groups at baseline in terms of baseline characteristics and prognostic factors,
- Extent to which valid primary outcomes were described,
- Blinding of subjects and providers,
- Blinded assessment of the outcome,
- Intention-to-treat analysis,
- Differential loss to follow-up between the compared groups or overall high loss to follow-up, and
- Conflict of interest.

For trials two additional elements are important:

- Methods used for randomization,
- Allocation concealment.

For observational studies, yet other additional elements were considered:

- Sample size;
- Methods for selecting participants (inception cohort, methods to avoid selection bias);
- Methods for measuring exposure variables;
- Methods to deal with any design-specific issues such as recall bias, interviewer bias, etc.; and
- Analytical methods to control confounding.

The quality of systematic reviews of the Medicare IPPS were assessed following methodology outlined in the EPC Methods Guide.11 Two independent reviewers (CS and PH) assessed relevant systematic reviews for quality with differences resolved by consensus. The quality of individual reviews was assessed using the Assessment of Multiple Systematic Reviews (AMSTAR) tool, which examines factors including the methods used to identify and select studies, data extraction, and data synthesis. The quality of data abstraction and synthesis was further assessed through review of a sample of primary source studies. The included reviews were checked for consistency in the studies included and the conclusions drawn regarding the Key Questions of this review.

## Data Synthesis

We summarized the evidence for the effects of bundled payment in comparison with usual payment methods. We did not conduct any quantitative synthesis of results because we found there was relatively low similarity between studies along key dimensions such as study outcomes. We synthesized the results by bundled payment program, and then summarized these findings by Key Question. The results are presented below in narrative form, with summary tables provided as Appendix A.

## Grading the Evidence for Each Key Question

We assessed the overall strength of evidence for intervention effectiveness using guidance outlined in the EPC Methods Guide.11 This method was developed for use in a variety of comparative effectiveness reports, many of which study clinical interventions with evidence from randomized trials, as opposed to the health services delivery intervention reviewed here. The rating method is based loosely on one developed by the GRADE Working Group, and classifies the grade of evidence according to the following criteria:

High = High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence on the estimate of effect.

Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.

Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.

Insufficient = Evidence is either unavailable or does not permit estimation of an effect.

The evidence grade is based on four primary domains (required) and three optional domains. The required domains are risk of bias, consistency, directness, and precision; the additional domains are coherence, residual confounding, and strength of association. One other optional domain, dose-response association, was not used in this review. Publication bias was also considered; while not considered a separate domain of strength of evidence, it is related to strength of evidence, particularly consistency and precision. We used both an explicit scoring scheme, completed by three reviewers independently with differences resolved by consensus, and a global implicit judgment about “confidence” in the result. If the explicit scoring and global judgment disagreed, we used the lower classification.

## Applicability

We assessed the overall applicability of the studies reviewed for U.S. policymakers, payers, and providers considering implementation of bundled payment programs. These decisions will be made in widely varying contexts reflecting the diversity of health care markets and delivery settings across the United States. The assessment method was based on the AHRQ Methods Guide for Comparative Effectiveness Reviews.12 We provide a summary of the most important characteristics of the body of reviewed studies that affect applicability and a description of their expected effects on applicability. We considered interventions that have consistent findings in multiple environments as having greater likelihood of greater generalizability.