# Introduction

## Background and Objectives for This Systematic Review

This review is part of the Closing the Quality Gap: Revisiting the State of the Science series, which aims to provide critical analysis of the existing literature on quality improvement strategies for a selection of diseases and healthcare practices. The review focuses on “bundled payment,” a strategy for health care quality improvement and cost containment. Other reviews in the series will address a range of quality improvement topics arising from AHRQ portfolios.

Policymakers, payers, and providers are considering the effects of switching from currently used provider payment methods, which are predominantly fee-for-service, to bundled payment. This strategy has been the subject of increasing interest, with the Centers for Medicare and Medicaid Services announcing a large national bundled payment initiative in August 2011. The hope is that bundled payment would give providers incentives and flexibility to choose those inputs that can most efficiently achieve good health care outcomes. Specifically, bundled payment is hoped to lead to more efficient resource use than fee-for-service payment, in which each additional billable service generates revenue. Thus, part of this review will assess the evidence on whether bundled payments have resulted in lower health care spending or use of services. If one assumes, however, that under fee-for-service payment providers use all the services that could benefit the patient, then a reduction in the use of services could result in a reduction in quality. On the other hand, if fee-for-service leads to excessive use of services, or the failure to compensate for the time for appropriately coordinating care, or the failure to offer effective services that are not billable, then bundling might improve the quality of care. Thus, this review will also assess the evidence on the impact of bundled payment on health care quality.

We define “bundled payment” as a payment method in which payments to health care providers are related to the predetermined expected costs of a grouping, or “bundle,” of related health care services. For the purpose of this review, the definition of “bundled payment” includes several related approaches that have been referred to as “bundling,” “packaging,” “episode-based payment,” and “warranties.” Distinctions are sometimes made between “packaging” of services provided during a single patient encounter and “bundling” of services during multiple visits. Each of these approaches establishes a method to aggregate services into a single unit of care for which a payment will be made. We distinguish the following general aggregation approaches and acknowledge specific payment models may include some or all of these approaches:

- Aggregation of services longitudinally in time for an episode of care. The episode is defined to encompass services related to a health care treatment or condition taking place within a defined time window. For example, a single payment could include a surgical procedure and follow-up care.
- Aggregation of services across providers who may be practicing in different care settings. For example, a single payment could be made for inpatient hospital facility services and physician professional services during an inpatient stay.
- Warranties refer to payment arrangements where payment for complications is aggregated into the unit of payment. Providers assume financial risk for the cost of care defects above a predetermined amount.

Increasingly, policymakers have been interested in bundled payment programs with greater aggregation of services longitudinally in time and across providers and including warranties. For example, the Medicare Inpatient Prospective Payment System, implemented in 1983, involved bundling during a relatively short period of time (a hospital stay) and included only hospital facility services, excluding physician professional services. In contrast, the recently initiated Medicare Bundled Payments for Care Improvement initiative will include bundles of services including the hospital stay and up to a 90-day post-discharge period, including hospital facility, physician professional, and post-acute facility services.

Bundled payment differs from other reimbursement mechanisms. Table 1 lists features of common alternatives to bundled payment. Most health care payers use mixed reimbursement systems which blend these individual mechanisms and integrate separate incentives for cost-control, quality of care, or both.1 The distinction between bundled payment and fee-for-service reimbursement is that fee-for-service reimbursement requires separate payment for each service provided while bundled payment aggregates payment for individual services as described above. We differentiate between bundled payment and payment methods such as global payment or capitation where payment is made for management of a defined patient population. Under bundled payment, payers assume the insurance risk - that is, the financial risk related to incidence of bundles.2 Under global payment and capitation, providers assume this risk. The incentives for quality management and quality improvement activities may also differ under these two models. Global payment and capitation create an incentive to reduce the need for services (bundled or not). Bundled payment creates an incentive to improve the services that are part of the bundle.

Table 1 Features of common comparison reimbursement methods

[underlined: Payment Method] | [underlined: Features]
Cost-based | - Aggregated payments (over patients and related services) reimburse providers for care provided over a fixed period of time.; - Payment amount determined by costs incurred.
Fee-for-service | - Each service reimbursed separately.; - Payment rate determined by a fee schedule negotiated between payers and providers.
Capitation | - Multiple services over a fixed period of time are reimbursed by a single, prospective, per capita payment.; - Provider, not payer, bears insurance risk for the incidence of episodes within the time period.
Salary | - Providers are not reimbursed for specific services provided.

Note: Definitions adapted from CBO (2008) and Gosden, et al. (2006).1,3

While all bundled payment programs share the common element of payment related to the expected cost of a bundle of services, specific payment mechanisms vary. One mechanism is to make a single, prospective payment for the bundle. Other mechanisms include a blend of payment methods. A “shared savings” approach may blend retrospective fee-for-service reimbursement with periodic bonus payments equal to a share of difference between actual and expected payments for episodes if actual costs are lower than a threshold level set below expected costs. Bundled payment programs can explicitly incorporate quality measurement in several ways, including using quality measures as a pay-for-performance payment adjustment; to set eligibility thresholds for provider participation in bundled payment programs; to assess potential negative consequences of bundled payment; and to inform provider performance improvement activities.4 Bundled payments could also be used in conjunction with (or in addition to) other new payment and delivery models such as shared savings for accountable care organizations or medical homes.4 The review is not limited by the types of payment methods employed; all of the above methods are included.

Bundled payment interventions that vary in aggregation of services into the bundle and payment method could differ substantially, including interventions as diverse as prospective payment systems for a single setting of care to retrospective payment adjustments for broad episodes of care. The design of bundled payment interventions may differ in other key ways including the type of conditions or procedures used as the basis for the bundle, risk adjustment, methods used to establish and update payment rates, etc.

In addition, bundled payment may be affected by the context of its implementation, such as the degree of integration of the providers delivering services included in the bundle, disease or condition severity, provider not-for-profit or for-profit status, and the presence of broader policy objectives which affect bundled payment implementation. These design and contextual factors could have important effects on the impact of bundled payment.

The intent of bundled payment systems is to decrease health care spending (i.e., spending by payers) while improving or maintaining the quality of care, relative to usual, e.g., fee-for-service, payment.5 Bundled payment should create a financial incentive for providers to reduce the number and cost of services contained in the bundle, thereby reducing costs to providers.6 Providers are typically given discretion under bundled payment as to the allocation of the services used to treat the patient's episode most effectively. In particular, it has been postulated that the financial risk associated with a bundled payment could motivate and enable providers to eliminate services that are low value (from the perspective of health outcomes), duplicative, or unnecessary.2 This flexibility may encourage providers to use resources to coordinate care; often, these services are not reimbursed under fee-for-service payment. If the bundle includes services delivered by multiple providers in multiple settings, providers have to create a mechanism for managing the shared payment for a given treatment or condition, which could also foster coordination.6

Several types of undesired effects of bundled payment have also been postulated. To offset the financial risk associated with individual bundles, providers might increase the number of bundles provided (an incentive to increase service volume also exists under fee-for-service payment, but not other alternatives such as capitation).2 For example, providers receiving a bundled payment for a surgical procedure may seek to increase volume by encouraging surgery for patients ambivalent between medical management and surgical treatment options. Instead of eliminating low-value services, bundled payment could lead to underuse of appropriate services, with potential adverse effects on patient outcomes.6 In the absence of robust risk adjustment of bundled payments, providers may select low-risk patients and avoid those with higher risks (and costs).6 Providers may “game” the system by changing coding practices to maximize reimbursement for the bundle (“upcoding”) or by moving services in time or location to qualify for separate reimbursement (“unbundling”). Concerns have also been raised about the administrative feasibility of bundled payment programs, particularly in establishing accountability and a mechanism for distributing payment among otherwise independent providers who participate in providing services that are part of a bundle.7,8

This review was designed to address the uncertainties about the effects of bundled payment on health care delivery. This review should help readers to (1) understand what the evidence shows on the effects of bundled payment on health care spending and quality of care relative to usual, e.g., fee-for-service, payment, and (2) understand key design and contextual features of bundled payment programs and their association with bundled payment effects.

## Key Questions

The review addressed three Key Questions:

1. What does the evidence show on the effects of bundled payment versus usual (predominantly fee-for-service) payment on health care spending and quality measures?
2. Does the evidence show differences in the effects of bundled payment systems by key design features?
3. Does the evidence show differences in the effects of bundled payment systems by key contextual factors?

We use the conceptual model in Figure 1 to understand these key questions. This model is based on one developed by Dudley, et al.9 to describe organizations' response to payment incentives in general. The Dudley et al. model draws from the health services research literature and incorporates more general economic concepts, such as opportunity costs, that often are not addressed in research about specific incentives. It is also grounded in Andersen's Behavioral Model of Health Services Use.10 The Andersen model was modified to apply to organizations rather than individuals seeking access to care.

Figure 1 Conceptual model for review of the effects of bundled payment strategies on health care spending and quality of care

Source: Authors' modification of conceptual models by Dudley et al.9 and Andersen10

Note: KQ = Key Question

This figure depicts the provisional analytic framework for evaluating the effectiveness and safety of bundled payment as an alternative approach to provider reimbursement for the treatment of discreet clinical episodes. The figure depicts a set of key design features that will define a particular set of incentives (and disincentives) associated with any specific bundled payment strategy. These key design figures include bundle components, payment methodology, the level of payment, the method for determining payment, risk-sharing properties, risk-adjustment methods, the use of quality measurement, and the distribution of payment among participating providers. The impacts of these design features in defining the incentive structure of the bundled payment strategy are addressed by Key Question 2. The financial and nonfinancial characteristics of these incentives are primary determinants of an organizations “need” to change practice in response to the modified payment policy. This response, however, may be mediated by key contextual factors, including both predisposing and enabling factors. Predisposing factors include the general financial environment, other incentives outside of the bundled payment program, market variables, and characteristics of participating provider organizations such as charter and mission. Enabling factors include the capabilities and goals of participating organizations and the degree to which these organizations are integrated, as well staff and patient level characteristics. The impacts of these contextual factors on organizations' decisions to respond to the strategy, and the nature of their responses, are addressed by Key Question 3. The center of the model reflects how organizations respond to the incentives created by bundled payment through changes in care structures and/or processes. They may also respond through undesirable actions such as selection of low-risk patients or manipulative practices including up-coding or unbundling. Key Question 1 addresses how different potential responses influence study outcomes including health care spending per episode, utilization rates for specific services, the cost to providers to deliver episodes, quality of care, and the average case severity of patients treated (in order to assess adverse risk selection by providers).

In Figure 1, several key design features define a particular set of incentives (and disincentives) associated with any specific bundled payment strategy. The impacts of these design features are addressed by Key Question 2. The financial and nonfinancial characteristics of these incentives are primary determinants of an organization's “need” to change practice in response to the modified payment policy. This response, however, may be mediated by key contextual factors, including both predisposing and enabling factors. Predisposing factors include the general financial environment (including baseline levels of financial performance and efficiency), other incentives outside of the bundled payment program, market variables, and characteristics of participating provider organizations such as charter and mission. Enabling factors include the capabilities and goals of participating organizations and the degree to which these organizations are integrated, as well staff and patient characteristics. The impacts of these contextual factors are addressed by Key Question 3. The center of the model reflects how organizations respond to the incentives created by bundled payment through care redesign. Key Question 1 addresses how different potential responses affect study outcomes including health care spending, health care quality measures, and others.

We distinguish between the impact of bundled payment on spending by payers and cost to providers. By spending we refer to the amount paid to providers in exchange for health care services, i.e., payments to providers. By costs we refer to the value of resources used to provide health care services by providers, e.g., hospitals. The difference between payments (spending) and costs is the provider's margin. The hope is that bundled payment will decrease spending by payers and costs to providers relative to usual, typically fee-for-service, reimbursement. Under this scenario, provider profits may either increase or decrease depending on the relative magnitude of changes in spending and costs. We also note the distinction between aggregate spending and costs and per-episode spending and costs. If the introduction of bundled payment increases the number of episodes provided, aggregate spending may increase even if per-episode spending decreases. In this review, we consider a wide range of related study outcomes including spending, costs, margins, and others.