# Peer Reviewers

Michael Chernew

Harvard Medical School

Boston, MA

Jonathan Christianson

University of Minnesota

Minneapolis, MN

R. Adams Dudley

University of California, San Francisco

San Francisco, CA

Robert Greene

United HealthCare

Edina, MN

Stuart Guterman

The Commonwealth Fund

New York, NY

Harold Luft

Palo Alto Research Institute

Palo Alto, CA

Harold Miller

Network for Regional Health Improvement

Pittsburgh, PA

Gregory Pope

Research Triangle Institute International

Waltham, MA

Meredith Rosenthal

Harvard School of Public Health

Boston, MA

Dennis Scanlon

Pennsylvania State University

State College, PA

Melony Sorbero

RAND Corporation

Pittsburgh, PA