# Technical Expert Panel

Robert Berenson

Urban Institute

Washington, DC

R. Adams Dudley

University of California, San Francisco

San Francisco, CA

Robert Greene

United HealthCare

Edina, MN

Keith Michl

Internist, Private Practice

Manchester Center, VT

Harold Miller

Network for Regional Health Improvement

Pittsburgh, PA

Gregory Pope

Research Triangle Institute International

Waltham, MA

Meredith Rosenthal

Harvard School of Public Health

Boston, MA

Dana Safran

Blue Cross Blue Shield of Massachusetts

Boston, MA

Barbara Wynn

RAND Corporation

Arlington, VA