# Appendix D Strength of Evidence

Table D1 below summarizes the reviewers grading of evidence for each of the outcomes examined in Key Question 1. Tables D2 and D3 address each outcome for Key Questions 2 and 3, respectively.

Table D1 Strength of evidence for Key Question 1

Key Question 1: impact of bundled payment on health care spending and quality measures | | | | | | Overall Strength of Evidence: Low
[underlined: Outcome:] Costs, Spending | [underlined: Finding:] Decline in spending of 10 percent or less. | [underlined: Programs:] 13 | [underlined: Studies, Poor:] 11 | [underlined: Studies, Fair:] 10 | [underlined: Studies, Good:] 2 | [underlined: Outcome SOE:] Low | [underlined: Risk of Bias:] High | [underlined: Consistency:] Consistent | [underlined: Directness:] Direct | [underlined: Precision:] Precise | [underlined: Residual Confounding:] Likely, but cannot assess direction | [underlined: Strength of Association:] Weak
[underlined: Outcome:] Utilization | [underlined: Finding:] Decrease in utilization and costs of services included in the bundle, often measured reductions in length of stay or utilization of specific services (between 5 percent and 15 percent reductions in many cases). | [underlined: Programs:] 17 | [underlined: Studies, Poor:] 15 | [underlined: Studies, Fair:] 27 | [underlined: Studies, Good:] 1 | [underlined: Outcome SOE:] Low | [underlined: Risk of Bias:] High | [underlined: Consistency:] Consistent | [underlined: Directness:] Direct | [underlined: Precision:] Precise | [underlined: Residual Confounding:] Likely, but cannot assess direction | [underlined: Strength of Association:] Weak
[underlined: Outcome:] Quality measures | [underlined: Finding:] Inconsistent and generally small effects on quality; for a given bundled payment intervention, either some quality measures improved while others worsened, or studies of the same intervention arrived at different conclusions about the effect of bundled payment on related quality measures. | [underlined: Programs:] 13 | [underlined: Studies, Poor:] 14 | [underlined: Studies, Fair:] 23 | [underlined: Studies, Good:] 2 | [underlined: Outcome SOE:] Low | [underlined: Risk of Bias:] High | [underlined: Consistency:] Inconsistent | [underlined: Directness:] Direct and indirect (process and intermediate outcomes) evidence available | [underlined: Precision:] Imprecise | [underlined: Residual Confounding:] Likely, but cannot assess direction | [underlined: Strength of Association:] Weak

Table D2 Strength of evidence for Key Question 2

Key Question 2: differential impacts by design feature | | | | | | Overall Strength of Evidence: Insufficient
[underlined: Outcome:] Costs, Spending | [underlined: Finding:] Insufficient evidence to report findings; no studies directly address key question. | [underlined: Programs:] 0 | [underlined: Studies, Poor:] 0 | [underlined: Studies, Fair:] 0 | [underlined: Studies, Good:] 0 | [underlined: Outcome SOE:] N/A | [underlined: Risk of Bias:] N/A | [underlined: Consistency:] N/A | [underlined: Directness:] N/A | [underlined: Precision:] N/A | [underlined: Residual Confounding:] N/A | [underlined: Strength of Association:] N/A
[underlined: Outcome:] Utilization | [underlined: Finding:] Insufficient evidence to report findings; no studies directly address key question. | [underlined: Programs:] 0 | [underlined: Studies, Poor:] 0 | [underlined: Studies, Fair:] 0 | [underlined: Studies, Good:] 0 | [underlined: Outcome SOE:] N/A | [underlined: Risk of Bias:] N/A | [underlined: Consistency:] N/A | [underlined: Directness:] N/A | [underlined: Precision:] N/A | [underlined: Residual Confounding:] N/A | [underlined: Strength of Association:] N/A
[underlined: Outcome:] Quality measures | [underlined: Finding:] Insufficient evidence to report findings; no studies directly address key question. | [underlined: Programs:] 0 | [underlined: Studies, Poor:] 0 | [underlined: Studies, Fair:] 0 | [underlined: Studies, Good:] 0 | [underlined: Outcome SOE:] N/A | [underlined: Risk of Bias:] N/A | [underlined: Consistency:] N/A | [underlined: Directness:] N/A | [underlined: Precision:] N/A | [underlined: Residual Confounding:] N/A | [underlined: Strength of Association:] N/A

Table D3 Strength of evidence for Key Question 3

Key Question 3: differential impacts by contextual factor | | | | | | Overall Strength of Evidence: Insufficient
[underlined: Outcome:] Costs, Spending | [underlined: Finding:] Four studies report few, program-specific results for provider characteristics including ownership, size, chain affiliation, and use of a dedicated hip fracture unit and for patient health condition. Evidence for this outcome is too weak and sparse to permit any conclusion to be drawn. | [underlined: Programs:] 4 | [underlined: Studies, Poor:] 3 | [underlined: Studies, Fair:] 2 | [underlined: Studies, Good:] 0 | [underlined: Outcome SOE:] Insufficient | [underlined: Risk of Bias:] High | [underlined: Consistency:] Unknown (no overlap among studies) | [underlined: Directness:] Indirect (indirect comparisons) | [underlined: Precision:] Imprecise | [underlined: Residual Confounding:] Likely, but cannot assess direction | [underlined: Strength of Association:] Weak
[underlined: Outcome:] Utilization | [underlined: Finding:] Context-specific evidence on two contextual factors, patient disease/condition severity and provider profit status, was presented by several studies. In general, for-profit providers experienced greater declines in utilization than their not-for-profit counterparts. Disease/condition severity was not consistently related to differential utilization outcomes. Four review articles concluded that hospitals under greater financial pressure had greater reductions in utilization under the Medicare Inpatient Prospective Payment System. No evidence on other contextual factors. | [underlined: Programs:] 11 | [underlined: Studies, Poor:] 3 | [underlined: Studies, Fair:] 15 | [underlined: Studies, Good:] 1 | [underlined: Outcome SOE:] Low (provider profit status, provider financial pressure, patient severity); Insufficient (all others) | [underlined: Risk of Bias:] High | [underlined: Consistency:] Inconsistent | [underlined: Directness:] Indirect (indirect comparisons) | [underlined: Precision:] Imprecise | [underlined: Residual Confounding:] Likely, but cannot assess direction | [underlined: Strength of Association:] Weak
[underlined: Outcome:] Quality measures | [underlined: Finding:] Three studies report few, program-specific results for provider ownership and profit status and patient severity. Evidence for this outcome is too weak and sparse to permit any conclusion to be drawn. | [underlined: Programs:] 3 | [underlined: Studies, Poor:] 0 | [underlined: Studies, Fair:] 5 | [underlined: Studies, Good:] 0 | [underlined: Outcome SOE:] Insufficient | [underlined: Risk of Bias:] High | [underlined: Consistency:] Unknown (no overlap among studies) | [underlined: Directness:] Indirect (indirect comparisons) | [underlined: Precision:] Imprecise | [underlined: Residual Confounding:] Likely, but cannot assess direction | [underlined: Strength of Association:] Weak

Source: Authors' analysis of reviewed studies

Note: SOE is Strength of Evidence

For a complete explanation of the criteria for grading the strength of evidence, please refer to the EPC Methods Guide: Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions. In: Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews [posted July 2009]. Rockville, MD. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318.

Reviewers considered the optional coherence domain, however none of the results described were deemed implausible, so this domain was omitted from the table below.