# Appendix B Included Studies

## Primary Studies Included in the Review

1 Abt Associates. (1997). Medicare Cataract Surgery Alternate Payment Demonstration: Final Evaluation Report.
2 Afendulis CC, Kessler DP. (2011). Vertical integration and optimal reimbursement policy. Int J Health Care Finance Econ.
3 Anderson MA, et al. (2005). Hospital readmission from home health care before and after prospective payment. J Nurs Scholarsh.
4 Brizioli E, et al. (1996). Hospital payment system based on diagnosis related groups in Italy: Early effects on elderly patients with heart failure. Archives of Gerontology & Geriatrics.
5 Buntin MB, Colla CH, Escarce JJ. (2009). Effects of payment changes on trends in post-acute care. Health Serv Res.
6 Casale A, et al. (2007). “ProvenCareSM”: A Provider-Driven Pay-for-Performance Program for Acute Episodic Cardiac Surgical Care. Annals of Surgery.
7 Cheh V. (2001). The Final Evaluation Report on the National Home Health Prospective Payment Demonstration: Agencies Reduce Visits While Preserving Quality.
8 Chen BH, et al. (2000). Comparison of appendectomy medical expense and clinical outcome between fee for service and prospective payment system. Kaohsiung J Med Sci.
9 Chen LW, Shea DG. (2002). Does prospective payment really contain nursing home costs?. Health Serv Res.
10 Coburn AF, et al. (1993). Effect of prospective reimbursement on nursing home costs. Health Services Research.
11 Collins T, et al. (2007). Medicare prospective payment before and after implementation: a review of visits and physical performance among Medicare home health patients after total knee replacements. Home Healthc Nurse.
12 Cromwell J, et al. (1998). Medicare Participating Heart Bypass Center Demonstration: Final Report.
13 Davitt JK, Choi S. (2008). The impact of policy on nursing and allied health services. Lessons from the Medicare Home Health Benefit. Res Gerontol Nurs.
14 DeJong G, et al. (2005). The early impact of the inpatient rehabilitation facility prospective payment system on stroke rehabilitation case mix, practice patterns, and outcomes. Arch Phys Med Rehabil.
15 Dobrez D, et al. (2010). Impact of Medicare's prospective payment system for inpatient rehabilitation facilities on stroke patient outcomes. Am J Phys Med Rehabil.
16 Eaton MK. (2005). The influence of a change in medicare reimbursement on the effectiveness of stage III or greater decubitus ulcer home health nursing care. Policy Polit Nurs Pract.
17 Ellis R, McGuire T. (1996). Hospital response to prospective payment: Moral hazard, selection, and practice-style effects. Journal of Health Economics.
18 Farrar S, et al. (2009). Has payment by results affected the way that English hospitals provide care? Difference-in-differences analysis. BMJ.
19 FitzGerald JD, et al. (2006). Impact of changes in Medicare Home Health care reimbursement on month-to-month Home Health utilization between 1996 and 2001 for a national sample of patients undergoing orthopedic procedures. Medical Care.
20 FitzGerald JD, Boscardin WJ, Ettner SL. (2009). Changes in regional variation of Medicare home health care utilization and service mix for patients undergoing major orthopedic procedures in response to changes in reimbursement policy. Health Serv Res.
21 Frymark TB, Mullen RC. (2005). Influence of the prospective payment system on speech-language pathology services. Am J Phys Med Rehabil.
22 Gillen R, Tennen H, McKee T. (2007). The impact of the inpatient rehabilitation facility prospective payment system on stroke program outcomes. Am J Phys Med Rehabil.
23 Grabowski DC, Afendulis CC, McGuire TG. (2011). Medicare prospective payment and the volume and intensity of skilled nursing facility services. J Health Econ.
24 Hasegawa T, et al. (2011). Changes in anemia management and hemoglobin levels following revision of a bundling policy to incorporate recombinant human erythropoietin. Kidney Int.
25 Hutt E, et al. (2001). Prospective payment for nursing homes increased therapy provision without improving community discharge rates. Journal of the American Geriatrics Society.
26 Johnson LL, Becker RL. (1994). An Alternative Health-Care Reimbursement System—Application of Arthroscopy and Financial Warranty: Results of a 2-Year Pilot Study. Arthroscopy: The Journal of Arthroscopic and Related Surgery.
27 Konetzka R, et al. (2004). Effects of Medicare Payment Changes on Nursing Home Staffing and Deficiencies. Health Services Research.
28 Konetzka R, et al. (2006). Medicare Prospective Payment and Quality of Care for Long-Stay Nursing Facility Residents. Medical Care.
29 Konetzka R, Norton E, Stearns S. (2006). Medicare payment changes and nursing home quality: effects on long-stay residents. Int J Health Care Finance Econ.
30 Kulesher RR, Wilder MG. (2006). Prospective payment and the provision of post-acute care: how the provisions of the Balanced Budget Act of 1997 altered utilization patterns for Medicare providers. J Health Care Finance.
31 Lapane KL, Hughes CM. (2004). An evaluation of the impact of the prospective payment system on antidepressant use in nursing home residents. Med Care.
32 Lapane KL, Hughes CM. (2006). Did the introduction of a prospective payment system for nursing home stays reduce the likelihood of pharmacological management of secondary ischaemic stroke?. Drugs Aging.
33 Lin CJ, Meit M. (2005). Changes in Medicare home health care use and practices in rural communities: 1997 to 2001. J Aging Health.
34 Lin CJ, et al. (2005). The financial impact of interim and prospective payment systems on home health providers in rural communities. J Health Care Poor Underserved.
35 McCue MJ, Thompson JM. (2006). Early effects of the prospective payment system on inpatient rehabilitation hospital performance. Arch Phys Med Rehabil.
36 Menke TJ, et al. (1998). Impact of an all-inclusive diagnosis-related group payment system on inpatient utilization. Med Care.
37 Murray PK, et al. (2005). Rehabilitation services after the implementation of the nursing home prospective payment system: differences related to patient and nursing home characteristics. Med Care.
38 Murtaugh CM, et al. (2003). Trends in Medicare home health care use: 1997-2001. Health Aff (Millwood).
39 Nayar P. (2008). The impact of Medicare's Prospective Payment System on staffing of long-term acute care hospitals: the early evidence. Health Care Manage Rev.
40 Paddock SM, et al. (2007). Did the Medicare inpatient rehabilitation facility prospective payment system result in changes in relative patient severity and relative resource use?. Med Care.
41 Perelman J, Closon MC. (2007). Hospital response to prospective financing of in-patient days: the Belgian case. Health Policy.
42 Qu H, et al. (2011). Impact of Medicare prospective payment system on acute rehabilitation outcomes of patients with spinal cord injury. Arch Phys Med Rehabil.
43 Rosenthal MB. (1999). Risk sharing in managed behavioral health care. Health Aff.
44 Rosenthal MB. (2000). Risk sharing and the supply of mental health services. Journal of Health Economics.
45 Schlenker RE, Powell MC, Goodrich GK. (2005). Initial home health outcomes under prospective payment. Health Serv Res.
46 Shah P, Heinemann A, Manheim L. (2007). The Effect of Medicare's Prospective Payment System on Patient Satisfaction: An Illustration with Four Rehabilitation Hospitals. Am. J. Phys. Med. Rehabil.
47 Sood N, Buntin MB, Escarce JJ. (2008). Does how much and how you pay matter? Evidence from the inpatient rehabilitation care prospective payment system. J Health Econ.
48 Stromberg L, Ohlen G, Svensson O. (1997). Prospective payment systems and hip fracture treatment costs. Acta Orthop Scand.
49 Tsai YW, et al. (2005). The effect of changing reimbursement policies on quality of in-patient care, from fee-for-service to prospective payment. Int J Qual Health Care.
50 Vos L, et al. (2010). Does case-mix based reimbursement stimulate the development of process-oriented care delivery?. Health Policy.
51 Wen YP, Wen SY. (2008). Do closed-system hospitals shift care under case payment? Early experiences comparing five surgeries in Taiwan. Chang Gung Med J.
52 White C. (2003). Rehabilitation therapy in skilled nursing facilities: effects of Medicare's new prospective payment system. Health Aff (Millwood).
53 White C. (2005). Medicare's prospective payment system for skilled nursing facilities: effects on staffing and quality of care. Inquiry.
54 Wodchis WP, Fries BE, Hirth RA. (2004). The effect of Medicare's prospective payment system on discharge outcomes of skilled nursing facility residents. Inquiry.
55 Wodchis WP. (2004). Physical rehabilitation following medicare prospective payment for skilled nursing facilities. Health Serv Res.
56 Yip JY, Wilber KH, Myrtle RC. (2002). The impact of the 1997 Balanced Budget Amendment's prospective payment system on patient case mix and rehabilitation utilization in skilled nursing. Gerontologist.
57 Zhang NJ, Unruh L, Wan TT. (2008). Has the Medicare prospective payment system led to increased nursing home efficiency?. Health Serv Res.
58 Zinn J, et al. (2008). Restructuring in response to case mix reimbursement in nursing homes: a contingency approach. Health Care Manage Rev.

## Review Articles Included in the Review of the Medicare Inpatient Prospective Payment System

1 Chulis GS. (1991). Assessing Medicare's prospective payment system for hospitals. Med Care Rev.
2 Coulam R, Gaumer G. (1991). Medicare's Prospective Payment System: A Critical Appraisal. Health Care Financing Review Annual Supplement.
3 Feinglass J, Holloway JJ. (1991). The initial impact of the Medicare prospective payment system on U.S. health care: a review of the literature. Med Care Rev.
4 Lave JR. (1989). The effect of the Medicare prospective payment system. Annu Rev Public Health.